# Methods

This chapter documents procedures that the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop this report on screening for dementia. We first discuss the analytic framework and key questions developed at the beginning of the review. We then describe the inclusion and exclusion criteria for admissible evidence; our strategy for literature search, data extraction, and synthesis; and our approach to developing the final summary of the evidence.

## Analytic Framework and Key Questions

The analytic framework (Figure 1) describes the relationship between screening and treating patients in a clinical setting and reduced suffering from dementia for either patients or caregivers. The arrows in the analytic framework represent steps in the chain of logic connecting screening with 6 defined sets of outcomes: patient function, use of health care, patient behavior, caregiver stress, accidents, and health-related quality of life (HRQOL). The superscripts refer to 9 key questions that guided our literature searches and synthesis of the evidence.

Figure 1. Screening for Dementia: Analytic Framework

We examined 1 overarching question (Key Question No. 1, linking screening and the 6 categories of outcomes) and 8 additional questions pertaining to specific links in the analytic framework, including the prevalence of undiagnosed dementia, the accuracy of screening tests, the availability of effective treatment strategies, and the harms and costs of screening and early treatment.

Key Question No. 1: Does screening for dementia in older adults (>60 years) do any of the following:

- improve or worsen patients' cognitive, social, or physical function?
- increase or decrease hospitalizations, institutionalizations, or health care visits?
- prevent or precipitate behavioral problems?
- alleviate or worsen caregivers' stress and coping?
- prevent or precipitate accidents, such as accidental falls or automobile crashes?
- improve or worsen patients' health-related quality of life?

Key Question No. 2: What is the prevalence of undiagnosed dementia in primary care patients? What are the common causes of dementia in primary care patients?

Key Question No. 3: Is there a reliable and valid screening test to detect dementia in primary care populations?

Key Question No. 4: Do pharmacologic interventions of potentially reversible or irreversible dementia improve any of the 6 outcomes noted in Key Question No. 1? Such treatments include antiplatelet therapy for vascular dementia, cholinesterase inhibitors for Alzheimer's disease, thyroid treatment for hypothyroidism, and vitamin B_12_ for vitamin B_12_ deficiency.

Key Question No. 5: Do nonpharmacologic interventions, such as sensory, environmental, behavioral, or activity-directed programs, improve any of the 6 outcomes noted in Key Question No. 1?

Key Question No. 6: Do caregiver interventions improve any of the 6 outcomes noted in Key Question No. 1?

Key Question No. 7: What are the adverse effects of screening for dementia?

Key Question No. 8: What are the costs and cost-effectiveness of screening for dementia?

Key Question No. 9: What are the adverse effects of dementia therapy?

## Inclusion/Exclusion Criteria for Admissible Evidence

The authors and Task Force liaisons developed inclusion and exclusion criteria for selecting evidence relevant to the key questions. Details can be found in Table 1. We first searched for evidence from randomized controlled trials (RCTs) for the efficacy of screening (Key Question No. 1). As we found no well-conducted RCT of screening, we then examined the evidence for Key Questions No. 2 through 9.

Table 1. Inclusion Criteria, Search Strategy, and Results of Searches

Key Question/Issue | Inclusion Criteria* | Number of Systematic Reviews Found | Number of Full Articles Reviewed | Number of Systematic Reviews and Articles that Met Criteria
1 | Study designs: | 0 | 0 | 0
Direct Effect of Screening on Outcome | RCTs
| Participants: Age 60 or older
| Dementia diagnosed by DSM or ICD
| Any of 6 outcomes from the analytic framework
2 | Study designs: | 0 | MEDLINE - 6 | Studies - 4
Prevalence of Undiagnosed Dementia | Systematic reviews | | PsycINFO - 1
| Cross-sectional prevalence | | Total: - 7
| Participants:
| Age 60 or older in community or primary care setting
| Reference standard for all subjects
| Blinded, independent evaluation for dementia diagnosed by DSM or ICD
| Exclusion of patients with prior diagnosis of dementia
| Data provided for true positives
3 | Study designs: | Cochrane - 1 | MEDLINE - 44 | Reviews - 1
Effectiveness of Screening Tools | Systematic reviews | PsycINFO - 1 | PsycINFO - 21 | Studies - 9
| RCTs | Additional search - 1 | Additional search - 10 | Total - 10
| Prospective cohort | Total - 3 | Total - 75
| Cross-sectional prevalence
| Participants:
| Age 60 or older in community or primary care setting
| Reference standard for all subjects
| Blinded, independent evaluation for dementia diagnosed by DSM or ICD
| Data provided for true positives/negatives and false positives/negatives
4 | Study designs: | Cochrane - 0 | Cochrane - 0 | Systematic reviews - 0
Primary Treatment of Potentially Reversible Dementia | Systematic reviews | MEDLINE - 2 | MEDLINE - 19 | RCT studies - 0
| Longitudinal studies | Total - 2 | Total - 19 | Longitudinal studies - 7
| RCTs | | | Total - 7
| Study participants:
| Age 60 or older in community or outpatient clinics
| Mild to moderate dementia diagnosed by DSM or ICD
| Intervention:
| Treatment of potentially reversible conditions
| Outcomes:
| Any of the 6 outcomes from the analytic framework
Primary Treatment of Irreversible Dementia | Study design: | Cochrane - 12 | MEDLINE - 147 | Systematic reviews - 7
| Systematic reviews | MEDLINE - 5 | PsycINFO - 5 | RCT studies - 16
| RCTs | EMBASE - 2 | EMBASE - 14 | Total - 23
| Participants: | Total - 19 | Other - 4
| Age 60 or older. | | Total - 170
| Dementia diagnosed by DSM or ICD
| Intervention:
| Pharmacologic treatment targeting the primary pathophysiology of the disease
| Outcomes:
| Any of the 6 outcomes from the analytic framework
5 | Study design: | MEDLINE - 2 | MEDLINE - 21 | Systematic reviews - 3
Secondary Treatment for Dementia (pharmacologic interventions) | Systematic reviews | | PsycINFO - 2 | Studies - 3
| RCTs | | EMBASE - 6 | Total - 6
| Participants: | | Total - 29
| Age 60 or older
| Dementia diagnosed by DSM or ICD
| Patients with overt behavioral problems
| Intervention:
| Pharmacologic treatment targeting behavioral problems related to dementia
| Outcomes:
| Any of 6 outcomes from the analytic framework
Secondary Treatment for Dementia (non-pharmacologic interventions) | Study design: | Cochrane: 3 | MEDLINE: 45 | Systematic reviews - 6
| RCTs | MEDLINE: 4 | PsycINFO: 0 | RCTs - 0
| Systematic reviews | EMBASE: 1 | EMBASE: 7 | Total: 6
| Participants: | Total: 8 | Total: 52
| Age 60 and older
| Dementia diagnosed by DSM or ICD
| Intervention:
| Nonpharmacologic, targeting and symptomology
| Outcomes:
| Any of the 6 outcomes from the analytic framework
6 | Study design: | Cochrane - 1 | 29 | Systematic review - 1
Interventions for Caregivers of Patients with Dementia | RCTs | MEDLINE - 8 | | Studies - 5
| Systematic reviews | Total - 9 | | Total - 6
| Participants:
| Caregivers of patients with dementia
| Dementia diagnosed by DSM or ICD
| Intervention:
| Nonpharmacologic interventions targeting the caregivers of patients with dementia
| Outcomes:
| Any of 6 outcomes from the analytic framework
7 | Study design: | 0 | 0 | 0
Adverse Effects of Dementia Screening | Systematic reviews
| Prospective cohort
| Cross-sectional prevalence
| Participants:
| Age 60 or older
| Reference standard for all subjects
| Intervention:
| Any treatment method
| Outcomes:
| Any possible adverse effects of screening
8 | Study design: | 0 | MEDLINE - 41 | MEDLINE - 0
Cost of Dementia Screening | Systematic reviews
| Prospective cohort
| RCTs
| Participants:
| Age 60 or older
| Dementia diagnosed by DSM or ICD
| Community-dwelling
| Intervention:
| Any treatment method
| Outcomes:
| Any possible adverse effects of screening
9 | Study design: Systematic reviews | Cochrane - 12 | Cochrane - 0 | Systematic reviews - 9
Adverse Effects of Dementia Treatment | RCTs | MEDLINE - 9 | MEDLINE - 187 | Studies - 10
| Participants: | EMBASE - 2 | PsycINFO - 7 | Total - 19
| Age 60 or older | Total - 23 | EMBASE - 20
| Dementia diagnosed by DSM or ICD | | Other - 2
| Intervention: | | Total - 216
| Any effective treatment method
| Outcomes:
| Any possible side effects that affect mortality or morbidity of the patient or caregiver

* RCTs, randomized controlled trials; DSM, Diagnostic and Statistical Manual; ICD, International Classification of Diseases

For Key Questions No. 2 and 3, we used systematic reviews, RCTs (Key Question No. 3 only), we accepted cross-sectional prevalence or prospective cohort studies that used an acceptable reference standard in a primary care population comparable to those typical in the United States. Key Questions No. 4 through 6 concerned the efficacy of various treatments (pharmacologic, nonpharmacologic, and caregiver, respectively). We included systematic reviews and required RCTs that included participants with mild to moderate dementia verified by an acceptable diagnostic test and that provided information on at least 1 of the 6 outcomes of interest; for studies of reversible dementia, we also included longitudinal studies.

Pharmacologic searches used specific drug names, restricting the pharmacotherapies to those that the Food and Drug Administration has approved, are available in the US market for off-label use, and are not investigational drugs.

For Key Questions No. 7 and 9, involving harms of screening and treatment, we again used systematic reviews. For screening, we also allowed prospective cohorts and cross-sectional prevalence studies; for therapy, we included RCTs and prospective cohort studies.

For Key Question 8, regarding the costs and cost-effectiveness of screening and early treatment, we searched for systematic reviews or studies of any research design (preferably RCTs and prospective cohort) that provided information about costs and for cost-effectiveness, cost-utility, and cost-benefit studies of screening.

## Literature Search Strategy, Data Extraction, and Synthesis

We used our inclusion and exclusion criteria (Table 1) to develop search terms. In each case, we first searched for well-conducted systematic reviews, including any in the Cochrane Collaboration Database, relevant to the key question. When we found such reviews, we searched the MEDLINE, PsycINFO, and EMBASE databases for studies published since the date of the review. If we found no systematic review, we searched these databases for studies from January 1994 through January 2001. We accepted only studies in the English language concerning humans ages 60 years or older. All searches began with exploding the terms “dementia” and “Alzheimer's disease,” then adding other terms as appropriate.

At least 2 authors independently reviewed the titles and abstracts of the articles identified in the searches and excluded those that did not meet eligibility criteria. If the reviewers disagreed, we carried the article in question forward to the next stage, in which we reviewed the full article, and made a final decision about inclusion or exclusion. All senior authors reviewed articles of special interest. The second and third columns of Table 1 present the number of systematic reviews and articles we identified and examined; the final column presents the number of publications that met our inclusion criteria and were fully reviewed.

Several authors then abstracted data from included articles into predesigned evidence tables (see Appendix B). We also graded the articles using criteria developed by the USPSTF Methods Work Group. ^65^

## Development of the Final Systematic Evidence Review

During preparation of the evidence report, EPC staff collaborated through conference calls with 2 members of the US Preventive Service Task Force (USPSTF) who served as liaisons.

The authors presented an initial work plan including a provisional analytic framework and key questions to the Task Force in December 2000; we also presented interim reports on results of the literature search and early results of the synthesis of information in March 2001 and June 2001. Upon completion of the draft SER incorporating the review at the June 2001 USPSTF meeting, we conducted a broad-based external review of the draft. We took into account the comments of these reviewers in developing the final version of this SER, which was presented to the USPSTF in January 2002.