# Appendix C. Detailed Description of Standard Scales Used

## Alzheimer's Disease Functional Assessment of Change Scale (ADFACS)

The ADFACS is a 16-item functional assessment instrument based on both basic ADLs and IADLs. A trained clinician or research assistant obtains information directly from both the patient and the caregiver. Each of the basic ADL items is scored on a scale of 0 (no impairment) to 4 (severe impairment) and each IADL item is scored on a scale ranging from 0 (no impairment) to 3 (severe impairment). The total score for the 16-item scale ranges from 0 to 54. Table 11 shows the specific items that are included in this scale.

## Clinical Dementia Rating Scale (CDR)

The CDR a global measure of 6 domains, including memory, orientation, judgment and problem solving, community affairs, home and hobbies, and personal care. Its total score ranges from 0 (no impairment) to 3 (severe impairment). ^188^

## Gottfries-Brane-Steen Scale (GBS)

The Gottfries-Brane-Steen (GBS) scale is a 27-item global scale for rating dementia symptoms based on a semi-structured interview by the clinician, with both the patient and the caregiver. ^189^ ^190^ The GBS assesses 4 domains: intellectual impairment (orientation, memory, concentration [12 items]), self-care motor function (6 items), emotional reaction (3 items), and behavioral symptoms (6 items). A 7-point scoring system from 0 to 6 is used for each of the 27 items of this scale, giving a total score range of 0 to 162 points, with an increase in score representing clinical deterioration.

## Interview for Deterioration in Daily living in Dementia Scale (IDDD)

This scale assesses functional disability in basic ADLs (16 items) and IADLs (17 items) of patients living in the community. The caregiver assesses patients' severity of impairment in each item on a 7-point scale, where 1 to 2 points denotes no or slight impairment, 3 to 4 points denotes mild impairment, 5 to 6 points denotes moderate impairment, and 7 points denotes severe impairment. The total score range is 33 to 231 points.

## Neuropsychiatry Inventory Scale (NPI)

The NPI evaluates the frequency and severity of 10 neuropsychiatric disturbances that occur frequently in dementia: agitation, irritability, anxiety, dysphoria, hallucinations, delusions, apathy, euphoria, disinhibition, and aberrant motor behavior. Each item on the NPI is scored on a 1- to 4-point frequency scale and a 1- to 3-point severity scale. The severity score is then multiplied by the frequency score, resulting in a total score ranging from 10 to 120 points. ^191^

## Progressive Deterioration Scale (PDS)

The PDS is a self-administered scale for caregivers that examines the ability of patients to accomplish basic ADLs and IADLs in 11 areas. ^192^ Each item is scored using a 100 mm bipolar visual analogue scale, then a total score range from 0 to100 is derived from the average across the items. ^126^

## Resource Utilization in Dementia Questionnaire Scale (RUD)

The RUD scale is completed by caregivers and compiles data on the use of social services, frequency and duration of hospitalizations, unscheduled contacts with health care professionals, use of concomitant medications by both the caregiver and the patient, amount of time the caregiver spends caring for the patient and missing work, and patients' use of study medication. ^123^