# Appendix B. Evidence Tables

Glossary of Tests and Terms

3MS | Modified Mini-Mental Status Exam
ABID | Antibody Identification
ADAS-Cog | Alzheimer's Disease Assessment Scale-Cognitive
ADAS-Noncog | Alzheimer's Disease Assessment Scale-Noncognitive
ADCS/ADL | Alzheimer's Disease Cooperative Study/Activities of Daily Living
ADFAC | Alzheimer's Disease Functional and Assessment of Change Scale
ADKT | Alzheimer's Disease Knowledge Test
ADL(s) | Activities of Daily Living
AE | Adverse Events
AMT | Abbreviated Mental Test
AR | Attrition Rate
BDI | Beck Depression Inventory
BDRS | Blessed Dementia Rating Scale
BDS | Blessed Dementia Scale
BEHAVE-AD | Behavioral Pathology in Alzheimer's Disease Rating Scale
BFAS | Blessed Functional Activities Scale
BI | Burden Interview
BIMC | Blessed Information Memory Concentration
BMT | Behavior Management Techniques
BOMC | Blessed Orientation Memory Concentration Test
BPRD | Behavioral Problem-Related Dementia
BPRS | Behavioral Psychiatry Rating Scale
BRSD | Behavioral Rating Scale for Dementia
BSI | Brief Symptoms Inventory
BSRS | Behavioral Psychiatry Rating Scale
BSRS-P | Behavioral Psychiatry Rating Scale—Psychosis
BSSD-A | Behavioral Syndromes Scale for Dementia - Agitation
CAMDEX | Cambridge Examination for Mental Disorders of the Elderly
CAPE | Clifton Assessment Procedures for the Elderly
CCAT-SS | Cognitive Concentration Assessment Tool - Speed Second
CCSE | Cognitive Capacity Screening Examination
CDDS | Cornell Depression in Dementia Scale
CDR | Clinical Dementia Rating
CDR-SB | Clinical Dementia Rating-Sum of Boxes
CDT | Clock-Drawing Test
CES-D | Center of Epidemiology Studies of Depression
CG | Centigrams
CGE | Clinical Global Evaluation
CGIC | Clinical Global Impression of Change
CI | Confidence Interval
CIBIC-Plus | Clinician's Interview Based Impression of Change Plus Caregiver Input Scale
CIND | Center for Inherited Neurovascular Disease
CMAI | Cohen Mansfield Agitation Inventory
Cog Imp | Cognitive Impairment
CSI | Caregiver Stress Inventory
CSDD | Cornell Scale for Depression in Dementia
d | Day
D+ | Diagnosed with Dementia
D- | Not Diagnosed with Dementia
D/O | Drop-out
DAD | Disability Assessment for Dementia
DART | Dutch Version of the National Adult Reading Test
DDD | Daily Dose Dependent
DMAS | Dementia Mood Assessment Scale
DS | Dependency Scale
DSM-III | Diagnostic and Statistical Manual of Mental Disorders, Third Edition
DSM-IIIR | Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised
DSST | Digit Symbol Substitution Test
DT | Dementia type
EGB | Gingko Biloba Special Extract
EPS | Extrapyramidal Signs
F | Fluoxetine
F/U | Follow-up
FAQ | Functional Activities Questionnaire
FIM | Functional Independence Measure
FIQCODE | Functional Informant Questionnaire on Cognitive Decline in Elderly
FN | False Negative
FP | False Positive
FOM | Fuld-Object Memory
GB | Gingko Biloba
GBS | Gottfries-Brane-Steen Scale
GDS | Global Deterioration Scale
GERRI | Geriatric Evaluation Relative Rating Instrument
GHQ | General Health Questionnaire
GIC | Global Impression of Change
H | Haloperidol
Ham-D | Hamilton Depression
HCUP | Healthcare Cost and Utilization Project
HD | High Dose
HDS | Hierarchical Dementia Scale
IADL | Instrumental Activities of Daily Living
ICD-10 | International Classification of Disease-10^th^ Revision
IDDD | Interview for Deterioration in Daily Living in Dementia
ITT | Intention-to-Treat
LBD | Lewy body dementia
LD | Low Dose
MD | Moderate Dose
mHARS | Modified Hamilton Anxiety Rating Scale
MMSE | Mini-Mental State Examination
MOSES | Multi Observational Scale for Elderly Subjects
MOUSEPAD | Manchester and Oxford Universities Scales for the Psychopathological Assessment of Dementia
MSBS | Minimal Social Behavioral Scale
MSQ | Mental Status Questionnaire
N | Number
NA | Not applicable
NAI | Nuremberg Age Inventory
NNH | Number Needed to Harm
NPI | Neuropsychiatric Inventory
NR | Not Reported
NS | Not Significant
OR | Odds Ratio
P | Probability
PDRS | Progressive Deterioration Rating Scale
PDS | Progressive Deterioration Scale
PGCMS | Philadelphia Geriatric Center Morale Scale
PSMS | Physical Self Maintenance Scale
PSQI | Pittsburg Sleep Quality Index
PT | Physical Therapy
QOL | Quality of Life
RCT | Randomized Controlled Trials
RDS | Rapid Disability Scale
RMBPC | Revised Memory Behavior Problem Checklist
RMBPC(F) | Revised Memory Behavior Problem Checklist - Frequency
ROC | Receiver-Operator Curve
RUD | Resource Utilization in Dementia Questionnaire
SADS | Schedule for Affective Disorders and Schizophrenia
SCB | Screen of Caregiver Burden
SCB-O | Screen of Caregiver Burden—Objective
SCB-S | Screen of Caregiver Burden—Subjective
SD | Standard Dose
SER | Systematic Evidence Review
SKT | Syndrome Kurtz Test
SMAF | Functional Autonomy Measures
SMD | Standard Mean Difference
STMS | Short Test of Mental Status
TRAZ | Trazadone
WF | Word Fluency
WK | Week
WMD | Weight Mean Difference
ZVT-G | Zahlen-Verbindungs-Test-G

Evidence Table 1. Prevalence of Undiagnosed Dementia

Citation | Design | Population | Measures | Results | Quality and Comments
Eefsting et al., 1996 ^66^ | Community survey and general practitioner study of dementia prevalence | Rural area of Holland in 1991, all patients ≥ 65 years of age registered for care with general practitioner. Community survey included all former patients institutionalized. (n = 2,108 for analysis) | Survey screen: Dutch MMSE | General practitioners: | Fair
| | | Clinical evaluation: all MMSE <17; Sample >17 and <27; None >27 | Sensitivity/Specificity for dementia: 39% (28/71), 99.3% (275/277) | Non-US population; did not evaluate for false negatives; also evaluated contact rate effects on sensitivity and specificity
| | | Survey and general practitioners: Dementia diagnosed with DSM-IIIR criteria based on CAMDEX, follow-up performed at 1 year to confirm diagnosis | General practitioners:
| | | | Sensitivity/specificity including Cog Imp as case vs. gold standard dementia:
| | | | 69% (50/71), 94% (260/277)
Olafsdottir et al., 2000 ^12^ | Cross-sectional prevalence | Random sample of patients >70 years of age in primary care center from community and institutional care in Sweden 1994-1996 (n=350) | DSM-IIIR criteria by neuropsychiatric evaluation and close informant interview for all | Undiagnosed dementia prevalence: | Good
| | | Detected cases: cognitive disturbance noted on medical record | 42/350 (12 %) | Additional 11 patients with questionable dementia, detection status not noted
| | | | Undiagnosed cases/total cases:
| | | | 16/21 mild
| | | | 22/26 moderate
| | | | 4/10 severe
Sternberg et al., 2000 ^13^ | Cross-sectional prevalence | Community dwelling patients ≥ 65 years in Canada | Screening: modified MMSE | 1.8% of patients have undetected dementia (161/9,008 pts) | Fair
| | | Gold standard: DSM-IIIR | | Undetected cases, not diagnosed based on questionnaire to caregiver
| | | Physician recognition: questionnaire for caregiver regarding being seen by a physician or having memory problems
Valcour et al., 2000 ^14^ | Cross-sectional prevalence | Patients ≥ 65 years of age in general internal medicine clinic in Asian American community in Honolulu, HI, Aug-Sept 1998 (n=297) | Screening: CASI | 5.7% of patients with undiagnosed dementia (17/297 patients) | Fair
| | | Reference: Cummings' criteria | 66.7% of cases unrecognized at time of visit; 65.4% of cases undocumented | Questionable screening method; reference standard without masking; no evaluation for false negatives; limited further evaluation of dementia (32.6% of patients)
| | | Physician recognition: questionnaire regarding diagnoses of dementia for each patient seen, chart review

Evidence Table 2a. Effectiveness of Screening Tools: Systematic Review

Reference | Outcome of interest | Search Strategy | Inclusion/Exclusion Criteria | Quality Appraisal | Findings
Costa et al., 1996 ^75^ | Meta-analysis of empirical studies of assessment of mental status instruments for differentiating between persons with and without dementia | No search terms given | [underlined: Included]: | Five-phase evaluation scale: | Instrument with >1 Phase IV studies-
| | | Human studies, Adult/elderly subjects, English | I-Narrow spectrum of disease | Mean Effect Score (studies evaluated)
| | | Assessment of memory complaints, Screening studies, Editorials or commentaries, Meta-analyses | II-Narrow-typical cases vs. healthy controls | [z-value compared to MMSE]
| | | Evaluations of instrument effectiveness or discriminability | III-Expanded spectrum of cases vs. healthy controls | MMSE-1.78 (12)
| | | [underlined: Excluded]: | IV-Inclusion of appropriate comorbidity for cases and controls | BIMC-2.49 (2)
| | | Animal studies, children, non-English, etiology or pathology, biological markers, individual case studies, biochemistry, drug models, clinical trials, drug therapy, dexamethasone suppression, toxic encephalopathy, AIDS, syphilis, neurosyphilis, multiple sclerosis, lumbar punctures, cerebrospinal fluid analysis, treatment, management, detection by neuroimaging, pathophysiology, physiological changes, and normal aging changes | V-Full spectrum of diseased and non-diseased individuals | [z=1.36, NS]
| | | | | BOMC-1.63 (2)
| | | | | [z=0.60, NS]
| | | | | STMS-2.01 (2)
| | | | | [z=0.39, NS]
| | | | | FAQ-2.46 (2)
| | | | | [z=2.81, P <0.05]
| | | | | Conclusions/ Recommendations
| | | | | -MMSE, BIMC, BOMC, and STMS largely equivalent
| | | | | -FAQ is particularly useful for initial assessment of functional impairment

Evidence Table 2b. Effectiveness of Screening Tools: Individual Studies

Source | Country | Setting | Study Design | Number of Subjects | Subject Demographics | Gold Standard | Screening Test(s) | Cutoff Value(s) | TP | TN | FP | FN | Quality and Comments
| | | | | | | | | D+ | D-
Braekhus et al., 1995 ^79^ | Norway | Community-based random sample of subjects age 75 and older | 3-year and 6-year incidence study of dementia | Initial: n=285 | 81% Female | DSM-III-R | MMSE | 3-year: 30 | 1 | 41 | | | Fair
| | | | 3-year: n=215 | Education (years): | | | 29 | 1 | 54 | | | Exclusion of all initial dementia (DSM-III)
| | | | 6-year: n=129 | 0–7: 54% | | | 28 | 3 | 33
| | | | | 8+: 46% | | | 27 | 3 | 26
| | | | | | | | 26 | 4 | 22
| | | | | | | | 25 | 8 | 11
| | | | | | | | 24 | 3 | 5
| | | | | | | | 6-year: 30 | 6 | 27
| | | | | | | | 29 | 10 | 27
| | | | | | | | 28 | 4 | 19
| | | | | | | | 27 | 3 | 15
| | | | | | | | 26 | 2 | 7
| | | | | | | | 25 | 2 | 3
| | | | | | | | 24 | 2 | 2
Law and Wolfson, 1995 ^84^ | Canada | Community-based from prevalence study | Cross-sectional prevalence | 237 | 64.5% female | DSM-III-R | FIQCODE | 3.6 | 37 | 180 | 8 | 12 | Good
| | | | | Mean age (range): | | MMSE (French) | 23 | 35 | 155 | 33 | 14 | In systematic review by Jorm et al.
| | | | | 81 (67–97)
| | | | | Informants:
| | | | | 74% female
| | | | | Mean age (range):
| | | | | 57 (27–86)
| | | | | 57.3% children
| | | | | 20.2% spouse
| | | | | 6.3% sibling
Wilder et al., 1995 ^80^ | United States (New York City) | Community-based pilot study for reporting registry | Extended prevalence study | Pilot study: 162 | Latino: 45% | DSM-III-R | MMSE | ≤24 | 34 | 240 | 10 | 3 | Fair
| | | | | African-American: 38% | | | | | | | | Trained medical student interviewers; diagnosis independent of scores but from initial interview; no discussion of mild dementia or indeterminate results; high dropout rate
| | | | | Non-Latino white: 17%
| | | | | Age:
| | | | | 65–74: 31%
| | | | | 75–84: 39%
| | | | | 85+: 30%
| | | | | Education (years):
| | | | | <5: 32.6%
| | | | | 5–11: 46.3%
| | | | | 12+: 21.1%
Jitapunkul et al., 1996 ^78^ | Thailand | Survey of “old-person home” for self-caring patients | Cross-sectional prevalence | 212 | 87% female | DSM-III-R | CMT | 15 | 17 | 176 | 19 | 0 | Good
| | | | | 24% illiterate | | MMSE | 16 (18) | 13 | 180 | 15 | 4 | Data difficult to calculate—estimated sensitivity/ specificity rates from references, ROC curve, and prevalence
| | | | | Resident of home: mean 8.4 years, Standard deviation 6.6 | | AMT | 5 (6) | 13 | 180 | 15 | 4
| | | | | | | | (literate, illiterate)
Lindeboom et al., 1996 ^77^ | Holland | Community-based sample; full evaluation for all screening positives and sample of others, confirmed with 1 year follow-up | Cross-sectional prevalence | 337 | Nondemented: | NINCDS-ADRDA | 7 Minute Screen (Temporal Orientation Test, Cued Recall, Clock Drawing Test, and Verbal Fluency Test) | Probability of dementia > 0.7 (based on logistic regression predictive model) | 11 | 124 | 2 | 0 | Good
| | | | | 56% female | | | | | | | | [underlined: Actual results]:
| | | | | Education level: | | | | | | | | Positive screens: 10 probable Alzheimer's disease
| | | | | < Primary: 58% | | | | | | | | Mixed dementia: 1
| | | | | < Secondary: 40% | | | | | | | | Refused follow-up: 2
| | | | | > University: 1% | | | | | | | | Negative screen:
| | | | | Mean age: 73.7 | | | | | | | | Sample: 25
| | | | | Demented: | | | | | | | | Normal: 1 (CIND)
| | | | | 78% female
| | | | | Education level
| | | | | < Primary: 75%
| | | | | < Secondary: 25%
| | | | | > University:0%
| | | | | Mean age: 79.5
McDowell et al., 1997 ^76^ | Canada (English and French speaking) | Multi-center community based sample | Cross-sectional prevalence | 1,600 | 59% female | DSM-III-R and ICD-10 Revised | MMSE | 25/26 | 316 | 949 | 283 | 52 | Good
| | | | | Mean age (range): | | 3MS | 77/78 | 316 | 1,072 | 160 | 52 | Also analyzed multiple cutpoints; some analysis of English vs. French; indeterminate results with CIND
| | | | | 80 (65–99)
| | | | | Mean years of education (range):
| | | | | 8.6 (0–28)
Heun et al., 1998 ^81^ | Germany | Stratified community-based sample including institutionalized Individuals | Cross-sectional prevalence | 291 | [underlined: Nondemented]: | DSM-III-R | Dutch MMSE (adjusted for DART and unadjusted) | 22/23 | 24 | 271 | 30 | 12 | Fair
| | | | | Female: 55% | | | | 26 | 280 | 21 | 10 | No discussion of reliability; independent evaluation masked
| | | | | Mean age: 75 | | | 24/25 | 30 | 241 | 60 | 6
| | | | | Education: 9.6 years | | | | 31 | 244 | 57 | 5
| | | | | [underlined: Demented]: | | | 26/27 (Unadjusted Adjusted) | 36 | 123 | 178 | 0
| | | | | Mean age: 89 | | | | 36 | 147 | 154 | 0
| | | | | 92% female
| | | | | Education: 9.0 years
Barberger-Gateau et al., 1999 ^83^ | France | Community survey of 37 parishes | 3-year and 5-year incidence study of dementia | Initial: n=2,780 | Not discussed | DSM-III by psychologist, confirmed by neurologist | IADL | 3 yr: 0 | 19 | 1,195 | | | Fair
| | | | 3 year: n=1,582 | Dartigues et al.^187^ report for same population: | | | 1 | 19 | 209 | | | Exclusion of all prevalent and 1-year incident cases
| | | | 5 year: n=1,283 | 59.8% female | | | 2 | 12 | 72
| | | | | Mean age: 74.8 yrs | | | 3 | 8 | 23
| | | | | Education: | | | 4 | 5 | 20
| | | | | No schooling: 4% | | | 5 yr: 0 | 17 | 1,015
| | | | | Grade school: 61% | | | 1 | 10 | 155
| | | | | High School: 29% | | | 2 | 4 | 52
| | | | | University: 6% | | | 3 | 1 | 16
| | | | | | | | 4 | 1 | 12
Solomon et al., 2000 ^82^ | United States | Primary care practice | Cross-sectional prevalence | 137 | Female: 67% | DSM-III-R | MMSE | ≤24 | 34 | 240 | 10 | 3 | Fair
| | | | | Mean age (range): | | | | | | | | Trained medical student interviewers; diagnosis independent of scores but from initial interview; no discussion of mild dementia or indeterminate results; high dropout rate
| | | | | 77 years (61–88)
| | | | | Education:
| | | | | Mean (range):
| | | | | 11.8 yrs (6–23)

* TP D+, true positive, diagnosis of dementia.

† TP D-, true negative, no diagnosis of dementia.

Evidence Table 3. Longitudinal Studies of the Treatment of Potentially Reversible Dementia

Study | N | Follow-up | Settings | Percentage/Number | Percentage/Number | Percentage/Number | Comment
| | | | Potentially Reversible | Partially Reversible | Fully Reversible
Larson et al., 1984 ^92^ | 100 | 6 months | Geriatric clinic | 15% | 11% | 3% | Fair
| | | | 15 | 11 | 3 | Lost to follow-up: 28%
Larson et al., 1985 ^74^ | 182 | 1 year | Geriatric clinic | 14.3% | 11.5% | 1% | Good
| | | | 26 | 21 | 2 | Lost to follow-up: 0% Living in institutional setting: 7.5%
Cunha et al., 1990 ^57^ | 110 | 2 year | Geriatric clinic | 23.6% | 2.7% | 1.8% | Fair
| | | | 26 | 3 | 2 | Lost to follow-up: 40% (10/26 with potentially reversible lost to follow-up)
Ames et al., 1992 ^58^ | 79 | 6 months | Geriatric clinic | 5.1% | 0% | 0% | Fair
| | | | 4 | 0 | 0 | Lost to follow-up: 2%
Massoud et al., 2000 ^59^ | 56 | N/R | Tertiary care center | 12.5% | N/R | 0% | Fair
| | | | 7 | | 0 | Lost to follow-up: 8.2%
Walstra et al., 1997 ^60^ | 170 | 6 months | Memory clinic | 18% | 0.6% | 0% | Good
| | | | 31 | 1 | 0 | Lost to follow-up: 6.5%
Freter et al., 1998 ^61^ | 196 | 16 months | Memory clinic | 23% | 2% | 1.5% | Fair
| | | | 45 | 4 | 3 | Lost to follow-up: 22.5% (4/7 patients with partially or fully reversible dementia had suspected dementia at baseline)

Evidence Table 4a. Efficacy of Cholinesterase Inhibitors in Treatment of Alzheimer's Disease—Systematic Reviews

Author | N RCT | Intervention | | | Outcomes | Result | | | Quality and comments
| Patients | Drug | Dose | Period (in months) | | Scale | Treatment Dose | P value
Birks et al., 2000 ^115^ | 7 RCTs | Rivastigmine | Low: 1–4 mg/day | 13–16 weeks | Global (CIBIC-plus, GDS) | CIBIC-plus (OR) | Low: 1.4 | (95% CI, 1.1 to 1.9) NS | Good
| 3,370 pts | | High: 6–12 mg/day | | Cognitive (ADAS-Cog, MMSE) | | High: 1.2 | (95% CI, 0.9 to 1.6 ) NS | Information on 1,403 patients not fully available for meta-analysis; authors conclude that high dose rivastigmine had a modest benefit on cognition & ADLs but not on clinical global impression
| | | | | Physical function (PDS) | GDS (WMD) | Low: -0.1 | (95% CI, -0.2 to -0.0)
| | | | | | | High: -0.1 | (95% CI, -0.2 to -0.1)
| | | | | | ADAS-Co (WMD) | Low: -0.9 | (95% CI, -1.6 to -0.2) NS
| | | | | | | High: -2.4 | (95% CI, -3.1 to -1.7)
| | | | | | MMSE (WMD) | Low: -0.3 | (95% CI, -0.8 to +0.2) NS
| | | | | | | High: -0.5 | (95% CI, -1.0 to -0.1)
| | | | | | PDS (WMD) | Low: +0.4 | (95% CI, -0.9 to +1.8)
| | | | | | | High: -2.4 | (95% CI, -3.6 to -1.1)
Birks et al., 2000 ^119^ | 4 RCTs | Donepezil | Low: 5 mg/day | 12–24 weeks | Global | CIBIC-plus (OR) | Low: 2.33 | (95% CI, 3.45 to 1.61) | Good
| 1,102 pts | | High: 10 mg/day | | Cognitive | | High: 2.63 | (95% CI, 3.85 to 1.79) | Authors conclude that donepezil produced modest improvements on cognition & clinical global impression with no improvement in pt self-rated quality of life
| | | | | Physical function | ADAS-Cog (WMD) | Low: -2.61 | (95% CI, -3.45 to -1.78)
| | | | | Quality of life | | High: -3.01 | (95% CI, -3.92 to -2.09)
| | | | | | CDR-SB (WMD) | Low: -0.21 | (95% CI, -0.46 to +0.03) NS
| | | | | | | High: -0.34 | (95% CI, -0.59 to -0.1)
| | | | | | QOL (WMD) | Low: 7.1 | (95% CI, -4.5 to +18.7)
| | | | | | | High: 0.04 | (95% CI, -17.0 to +17.1)
Qizilbash et al., 1998 ^121^ | 12 RCTs | Tacrine | 39–135 mg/day | 12 weeks | Global | CGIC (OR improvement) | 1.58 | (95% CI, 1.18, 2.11) | Good
| 1,984 pts | | | | Cognitive | ADAS-Cog (Mean Difference) | 2.07 | (95% CI, 1.36, 2.78)
| | | | | Physical function | MMSE (MD) | 0.62 | (95% CI, 0.23, 1.00) P =.002
| | | | | Behavioral | PDS (MD) at 6 wks | 0.75 | (95% CI, -0.43, +1.93) NS
| | | | | | ADAS-Noncog (MD) | 0.58 | (95% CI, 0.17, 1.00) P =.006
Qizilbash et al., 2000 ^120^ | 5 RCTs | Tacrine | 40–120 mg/day | 2–6 weeks | Global | CGIC (OR improvement or no change) | 1.15 | (95% CI, 1.64, 0.81) NS | Good (these 5 trials were included in the previous SER)
| 1,434 pts | | | 1–30 weeks | Cognitive | ADAS-Cog (Mean Difference) | -0.22 | (95% CI, -0.32, -0.12) | Authors conclude that there is no evidence of clinical effectiveness of tacrine in treating Alzheimer's disease
| | | | 1–12 weeks | Behavioral | MMSE (MD) | 0.14 | (95% CI, -0.02, +0.3) NS
| | | | 1–4 weeks | | ADAS-Noncog (MD) | -0.1 | (95% CI, -1.23, +1.024) NS

Evidence Table 4b. Efficacy of Cholinesterase Inhibitors in Treatment of Alzheimer's Disease -- Studies

Author | N | Intervention | | | Outcomes | Result | | | | | Quality and comments
| | Drug | Dose | Period (in months) | | Scale | Treatment | Placebo | P value | NNT
Winblad et al., 2001 ^93^ | 286 | Donepezil | 10 mg/day | 12 | Global | GBS (mean change) | +8 | +12 | P = 0.054 | | Good (all outcomes were considered)
| | | | | Cognitive | MMSE (mean change) | -0.3 | -2.2 | P <0.001 | | Dementia type: Alzheimer's disease
| | | | | Physical function | PDS (mean change) | 11.5 | 15 | P = 0.011
| | | | | Behavior | NPI (mean change) | - | - | NS
| | | | | Caregiver time spent assisting patient | Percent of caregivers spending ≥ 16hr /day caring for patient
| | | | | Health care utilization | at 6 months | 0% | 3% | P <0.05
| | | | | | at 9 months | 0% | 5% | P <0.05
| | | | | | at 12 months | 2% | 6% | P <0.1
| | | | | | RUD (mean annual cost per patient in US dollars) | $25,000 | $26,100 | N/A
| | | | | | RUD (days spent in hospital) | 8 | 16 | N/A
| | | | | | RUD (caregiver contact with health care professional) | 613 | 811 | N/A
Mohs et al., 2001 ^95^ | 431 | Donepezil | 10 mg/day | 12 | Time to functional decline | Median time to functional decline (D) | 357 | 208 | P = 0.0051 | | Fair (not all outcomes were considered)
| | | | | Cognitive | MMSE (mean change) | +0.5 | -0.5 | P <0.001 | | Dementia type: Alzheimer's disease
| | | | | Physical function | ADFAC (mean change) | +2.4 | +4.0 | P <0.001
Wilkinson and Murray, 2001 ^112^ | 285 | Galantamine | Low: 18 mg/day | 3 | Cognitive (ADAS-Cog) | ADAS-Cog (mean change) | Low: -0.1 | 1.6 | NS | | Fair (not all outcomes considered)
| | | Mod: 24 mg/day | | Global (CGIC) | | Mod: -1.4 | | P <0.001 | | Attrition rate varies among groups
| | | High: 36 mg/day | | Functional (PDS) | | High: -0.7 | | P = 0.08
| | | | | | CGIC (% improved or no change) | Low: 83% | 70% | NS
| | | | | | | Mod: 80% | | NS
| | | | | | | High: 80% | | P = <0.05
| | | | | | PDS (% improved or no change) | Low: 82% | 75% | NS
| | | | | | | Mod: 89% | | NS
| | | | | | | High: 78% | | NS
Wilcock et al., 2000 ^96^ | 653 | Galantamine | Low: 24 mg/day | 6 | Global | CIBIC-plus (percent stable or improve) | Low: 62% | 50% | P <0.05 | 8 | Fair (not all outcomes were considered)
| | | High: 32 mg/day | | Cognitive | | High: 66% | | P <0.001 | 6 | Dementia type: Alzheimer's disease
| | | | | Physical function | ADAS-Cog (mean change) | Low: -0.5 | +2.4 | P <0.001
| | | | | | | High: -0.8 | | P <0.001
| | | | | | DAD (difference in mean change treatment vs. placebo) | Low: 2.8 | N/A | NS
| | | | | | | High: 3.4 | N/A | P <0.05
Raskind et al., 2000 ^97^ | 636 | Galantamine | Low: 24 mg/day | 6 | Global | CIBIC-plus (percent stable or improve) | Low: 70% | 55% | P <0.05 | 7 | Fair (not all outcomes were considered & some difference in F/U among groups)
| | | High: 32 mg/day | | Cognitive | | High: 68% | | P <0.05 | 8 | Dementia type: Alzheimer's disease
| | | | | Physical function | ADAS-Cog (mean change) | Low: -2.2 | +2.0 | P <0.001
| | | | | | | High: -1.4 | | P <0.001
| | | | | | DAD (difference in mean change treatment vs. placebo) | N/A | N/A | NS
Tariot et al., 2000 ^98^ | 4 | Galantamine | Low: 8 mg/day | 5 | Global | CIBIC-plus (percent stable or improved) | Low: 53% | 49% | NS | 6 | Fair (not all outcomes were considered)
| | | Mod: 16 mg/day | | Cognitive | | Mod: 66% | | P <0.001 | | Dementia type: Alzheimer's disease
| | | High: 24 mg/day | | Physical function | | High: 64% | | P <0.001
| | | | | Behavior | ADAS-Cog (mean change) | Low: +0.4 | +1.7 | NS | 7
| | | | | | | Mod: -1.4 | | P <0.001
| | | | | | | High: -1.4 | | P <0.001
| | | | | | ADCS/ADL (mean change) | Low: -3.2 | -3.8 | NS
| | | | | | | Mod: -0.7 | | P <0.001
| | | | | | | High: -1.5 | | P <0.01
| | | | | | NPI (mean change) | Low: +2.3 | +2.0 | NS
| | | | | | | Mod: -0.1 | | P <0.05
| | | | | | | High: 0 | | P <0.05
Burns et al., 1999 ^99^ | 818 | Donepezil | Low: 5 mg/day | 6 | Global | CIBIC-plus\| (percent improved) | Low: 21% | 14% | N/A | 14 | Fair (not all outcomes were considered)
| | | High: 10 mg/day | | Cognitive | | High: 25% | | N/A | | Dementia type: Alzheimer's disease
| | | | | Physical function (CDR-SB and IDDD) | ADAS-Cog (mean change) | Low: +0.1 | +1.6 | P = 0.002 | 9
| | | | | Quality of life | | High: -1.3 | | P <0.0001
| | | | | | CDR-SB (difference) | Low: 0.3 | | P = 0.002
| | | | | | | High: 0.4 | | P = 0.0387
| | | | | | IDDD (mean) | Low: 70.5 | 71 | NS
| | | | | | | High: 69.5 | | P = 0.007
Greenberg et al., 2000 ^100^ | 60 | Donepezil | 5 mg/day | 3 | Global | Caregiver GIC (percent improved) | 24% | 23% | NS | | Fair: crossover design (analysis done only on the completion of both phases.)
| | | | | Cognition | ADAS-Cog (mean change) | -1.50 | +0.62 | P <0.05 | | Dementia type: Alzheimer's disease
Rosler et al., 1999 ^101^ | 725 | Rivastigmine | Low: 1–4 mg/day | 6.5 | Global | CIBIC-plus (percent improved) | Low: 32% | 22% | P <0.01 | 10 | Fair (not all outcomes were considered)
| | | High: 6–12 mg/day | | Cognitive | | High: 40% | | P <0.001 | | Dementia type: Alzheimer's disease
| | | | | Physical function (PDS;GDS) | ADAS-Cog (mean change) | Low: -1.24 | -1.45 | NS | 6
| | | | | | | High: +0.83 | | P <0.001
| | | | | | PDS (percent of patients with ≥ 10% improvement) | Low: 20% | 20% | NS
| | | | | | | High: 33% | | P <0.01
| | | | | | GDS (mean change) | Low: -0.2 | -0.24 | NS
| | | | | | | High: -.03 | | P <0.05

Evidence Table 5. Studies of the Efficacy of Gingko Biloba in Treatment of Alzheimer's Disease

Author | N RCTs | Intervention | | | Outcomes | Result | | | | Quality & Comments
| Patients | Drug | Dose | Period | | Scale | Trx | Placebo | P value/ NNT
Oken et al, 1998 ^118^ | 5 RCTs | EGB-761 | 120–240 mg/day | 2–12 weeks | Cognitive | Cognitive function over all effect size | 0.413 | | (95% CI, 0.22, 0.61) | Good
(Systematic review) | 424 pts | | | 2–24 weeks | | Translate on ADAS-Cog | 2.1 | | (95% CI, 1.12, 3.01) | Authors conclude that there is a small but significant effect of 3–6 months treatment with 120–240 mg of EGB-761 on objective measures of cognitive in Alzheimer's disease
| | | | 1–26 weeks
Le Bars et al., 1997 ^106^ | 309 pts | EGB-761 | 120 mg/day | 6.5 months | Global | CGIC over all ITT (mean) | 4.2 | 4.2 | P = 0.77 | Fair (not all outcomes were considered)
| | | | 13 months | Cognitive | ADAS-Cog over all ITT (mean change) | +0.1 | +1.5 | P = 0.04 | AR at 6.5 months = 25%
| | | | | Physical function | ADAS-Cog 6.5 months (mean change) | -0.5 | +2.1 | P = 0.04 | AR at 13 months = 58%
| | | | | | ADAS-Cog 13 months (mean change) | -0.3 | +1.5 | P = 0.005 | GERRI is not an established instrument.
| | | | | | GERRI over all ITT (mean change) | -0.06 | +0.08 | P = 0.004 | Dementia type: Alzheimer's disease
| | | | | | GERRI 6.5 months (mean change) | -0.07 | +0.07 | P = 0.04
| | | | | | GERRI 13 months (mean change) | -0.09 | +0.10 | P = 0.002

Evidence Table 6. Efficacy of Anti-Oxidants and Estrogen in Treatment of Alzheimer's Disease

Author | N | Intervention | | | Outcomes | Result | | | | Quality & Comments
| | Drug | Dose | Period | | Scale | Trx | Placebo | P value/ NNT
Birks and Flicker, 2000 ^116^ | 15 | Selegiline | 10 mg/day | 10 days to | Global | Combined global tests (SMD) | -0.11 | | (95% CI, -0.49, +0.27) NS | Good
(Cochrane review) | | | | 3 years | Cognitive | Combined cognitive tests (SMD) | -0.38 | | (95% CI, -0.60, -0.15) | Authors conclude that there is some evidence that selegeline improve the mental function of Alzheimer's disease patients & their behavior and mood, with no effect on clinical global impression
| | | | | Behavioral | BPRS (WMD) 2 RCTs | -2.4 | | (95% CI, -4.11, -0.68)
| | | | | | DMAS (WMD) | -9.6 | | (95% CI, -16.6, -2.6)
| | | | | | Cornell depression scale (WMD) | -0.62 | | 95% CI, -2.28, +1.04 NS
Sano et al., 1997 ^103^ | 341 | Selegiline | 10 mg/day | 2 years | Time to functional loss | Median time to functional loss (D) | Sel: 655 d | 440 d | P = 0.012 | Fair (not all outcome were considered and randomization did not work but the analysis was adjusted for covariate)
| | Vitamin E | 2000 IU/day | | Cognitive (ADAS-Cog, MMSE) | | Vit. E: 670 d | 440 d | P = 0.001
| | Both drugs | Both doses | | Functional (BDS, DS) | | Vit. B: 585 d | 440 d | P = 0.049
| | | | | Behavior (BRSD) | ADAS-Cog (mean change) | Sel: 8.3 | 6.7 | NS
| | | | | | | Vit. E: 8.3
| | | | | | | Vit. B: 6.5
| | | | | | MMSE | ---- | ---- | NS
| | | | | | BDS (mean change) | Sel: 4.2 | 5.4 | P = 0.004
| | | | | | | Vit. E: 4.0
| | | | | | | Vit. B: 4.2
| | | | | | DS (% pt receiving high score) | Sel: 80% | 86% | NS
| | | | | | | Vit. E: 76% | 86% | P = 0.039
| | | | | | | Vit. B: 76% | 86% | P = 0.039
| | | | | | | Sel: +5.4 | +8.9 | P = 0.02
| | | | | | BRSD (mean change) | Vit. E: +4.4
| | | | | | | Vit. B: -1.1
Mulnard et al., 2000 ^105^ | 120 | Estrogen | Low: 0.625 mg/day | 12 months | Global | CGIC over all ITT (mean) | 4.2 | 4.2 | P =0.77 | Fair (not all outcomes considered)
| | | High: 1.25 mg/day | | Cognitive (MMSE, ADAS-Cog) | ADAS-Cog over all ITT (mean change) | +0.1 | +1.5 | P =0.04 | AR at 6.5 months = 25%
| | | | | Physical function (CDR, BDRS, DS) | ADAS-Cog 6.5 months (mean change) | -0.5 | +2.1 | P =0.04 | AR at 13 months = 58%
| | | | | Behavior (mood) | ADAS-Cog 13 months (mean change) | -0.3 | +1.5 | P =0.005 | GERRI is not an established instrument.
| | | | | | GERRI over all ITT (mean change) | -0.06 | +0.08 | P =0.004 | Dementia type: Alzheimer's disease
| | | | | | GERRI 6.5 months (mean change) | -0.07 | +0.07 | P = 0.04
| | | | | | GERRI 13 months (mean change) | -0.09 | +0.10 | P = 0.002
Asthana et al., 2001 ^114^ | 20 | Estrogen patch | 0.1 mg/day | 8 weeks | Cognitive (global and neuropsychological testing) | Attention domain (seconds) | 88 | 108 | P = -.02 | Fair (not all outcomes considered)
| | | | | Functional (IADL, PSMS) | Word recall | 8 | 7 | P = 0.049
| | | | | Behavioral (BPRS) | Immediate recall | 25 | 20 | P = 0.03
| | | | | | Paired association test | ---- | ---- | P = 0.08
| | | | | | Naming | ---- | ---- | P = 0.05
| | | | | | MMSE | ---- | ---- | NS
| | | | | | IADL-PSMS | ---- | ---- | NS

Evidence Table 7. Efficacy of Anti-Inflammatory Medications in Treatment of Alzheimer's Disease

Author | N | Intervention | | | Outcomes | Results | | | | Quality and Comments
| | Drug | Dose | Period | | Scale | Treatment | Placebo | P value/ NNT
Aisen et al., 2000 ^108^ | 138 | Prednisone | 10 mg/day maintenance | 12 months | Global (CDR-SB, BDRS) | CDR-SB (mean change) | 2.9 | 2.2 | 0.07 | Fair (not all outcomes were considered)
| | | | | Cognitive | BDRS (mean change) | 1.7 | 1.7 | 0.60 | Dementia type: Alzheimer's disease
| | | | | Physical function (none) | ADAS-Cog (mean change) | 8.2 | 6.3 | 0.16
| | | | | Behavior (Ham-D, BPRS) | Ham-D (mean change) | 1.7 | 0.7 | 0.25
| | | | | | BPRS (mean change) | 5.4 | 2.0 | 0.003 (placebo favor)
Scharf et al., 1999 ^109^ | 41 | Diclofenac plus | 50 mg/day | 6 months | Global (CGIC, caregiver GIC, GDS) | CGIC (mean change) | 4.29 | 4.57 | NS | Fair (not all outcomes were considered)
| | Misoprostol | 200 mg/day | | Cognitive (ADAS-Co, MMSE) | Caregiver-CGI (mean change) | 4.47 | 4.79 | NS | Significant difference in AR among groups
| | | | | Physical function (IADL, PSMS) | GDS (mean change) | +0.35 | +0.57 | NS
| | | | | Behavior | ADAS-Co (mean change) | +0.25 | +1.93 | NS
| | | | | | MMSE (mean change) | +0.41 | -0.86 | NS all P > 0.125
| | | | | | IADL (mean change) | 0.06 | 1.86 | NS
| | | | | | PSMS (mean change) | 0.53 | 0.21 | NS
| | | | | | ADAS-Noncog (mean change) | -0.59 | +1.36 | NS

Evidence Table 8. Studies of the Treatment of Vascular Dementia

Author | N | Intervention | | | Outcomes | Results | | | | Quality and Comments
| | Drug | Dose | Period | | Scale | Treatment | Placebo | P value/ NNT
Williams et al., 2000 ^117^ | 70 | Aspirin | 325 mg/day | 1 year | Cognitive | CCSE (WMD) | -4.1 | | (95% CI, -9.51 to +1.307) | Good
(Systematic review) | | | | | | | | | | Authors conclude that the evidence to support the use of aspirin in vascular dementia is weak
Pantoni et al., 2000 ^104^ | 251 | Nimodipine | 90 mg/day | 6 months | Global | CGC | ---- | ---- | NS | Fair (not all outcomes were considered & unclear outcome measures)
| | | | | Cognitive (ZVT-G\|, FOM, WF, DS, MMSE) | ZVT-G (time in second) | 3.02 | 13.67 | P = 0.09 | Dementia type: Vascular dementia
| | | | | Physical function (ADL, IADL, RDS, GBS, CDR) | Multiple cognitive tests | ---- | ---- | NS (P range .14–.95)
| | | | | | Multiple physical function tests | ---- | ---- | NS (P range .14–.95)

Evidence Table 9a. Efficacy of Pharmacologic Interventions for Behavioral Problems Related to Dementia: Systematic Reviews

Author | RCT/N | Intervention | | | Outcomes | Result | | | | Quality and Comments
| | Drug | Dose | Period (in weeks) | | Scale | Trx | Placebo | P value NNH
Lanctot et al., 1998 ^122^ | 13 / 295 | Typical neuroleptic | .05–1.2 DDD | At least 4 | Behavioral improvement | Percentage with clinically significant improvement in CGI | 61% | 38% | P = <.0001 4(3, 7) | Good
| | | | | | Treatment vs. placebo difference | 26% | | | Diagnosis of primary dementia in only 70% of RCTs; all patients had BPRD at baseline; patients not exclusively living at home nor had mild to moderate dementia
Davidson et al., 2000 ^124^ | 3 / 911 | Atypical neuroleptic | -- | 6–12 | Behavioral (NPI/BEHAVE-AD) | Efficacy (clinically significant improvement) | OR: 0.59 (95% CI, 044 to 0.78) | | 8 (5, 18) | Good
| | Respiredone/ olanzepine | | | | | | | | All patients had BPRD at baseline; mean MMSE <10 (7.3); clinical setting was NHs
Kirchner et al., 2000 ^125^ | 2 / 670 | Thioridazine | -- | 4, 8, 32 | Behavior (modified Hamilton Anxiety Rating Scale (mHARS)) | mHARS (anxious mood/ tension/fear/insomnia) | OR: 4.9 (95% CI, 3.2 to 7.5) | | | Good
| | | | | Global (CGE clinical global evaluation impression of change) | mHARS (intellect/agitation /depressed mood) | OR: 3.6 (95% CI, 2.4 to 5.5) | | | One RCT with 610 patients was conducted at NH; dementia severity not specified
| | | | | | CGE | ---- | ---- | NS

Evidence Table 9b. Efficacy of Pharmacologic Intervention for Behavioral Problems Related to Dementia: Randomized Controlled Trials

Author | N | Intervention | | | Outcomes | Result | | | | Quality and Comments
| | Drug | Dose | Period | | Scale | Treatment | Placebo | P value/ NNT
Teri et al., 2000 ^113^ | 148 | Haldol | 0.5–3 mg/day | 16 weeks | Behavioral (BRSD, RMBPC, CMAI, ABID, CGIC) | CGIC (% improved) | Hal: 32% | 31% | P > 0.5 | Fair (not all outcomes considered)
| | Trazedone | 50–300 mg/day | | Caregiver burden (SCB) | | Traz: 41% | | | Attrition rate 38%
| | BMT | 8 weekly + 3 biweekly sessions | | Cognitive (MMSE) | | BMT: 32% | | | Significant difference between groups at baseline in caregiver gender; analysis adjusted for this
| | Placebo | | | Functional (ADL) | ABID (mean change) | NS for all | | NS
| | | | | | CMAI (mean change) | NS for all | | NS
| | | | | | RMBPC (mean change) | NS for all | | NS
| | | | | | BRSD (mean change) | NS for all | | NS
| | | | | | MMSE (mean change) | Hal: -0.6 | -0.28 | P < 0.05
| | | | | | | Traz: -1.97
| | | | | | | BMT: -0.05
| | | | | | Basic ADL (mean change) | Hal: 2.5 | 1.3 | P <0.05
| | | | | | | Traz: 1.6
| | | | | | | BMT: -0.3
| | | | | | Instrumental ADL (mean change) | Hal: 1.8 | 0.9 | P < 0.05
| | | | | | | Traz: 1.8
| | | | | | | BMT: 0.2
| | | | | | SCB-Subjective (mean change) | Hal: -1.9 | -2.6 | NS
| | | | | | | Traz: -1.97
| | | | | | | BMT: -2.95
Devanand et al., 1998 ^94^ | 66 | Haldol (standard dose) | 2–3 mg/day | 6 weeks | Behavioral (BSRS-P, BSSD-A, SADS) | BPRS-Psychosis (% clinically responsive patient) | SD: 60% | 30% | P < 06 3 | Fair (not all outcomes considered)
| | Haldol (low dose) | 0.5–.75 mg/day | | Cognitive (MMSE) | | Low: 30%
| | | | | Functional (BFAS) | BSSD-agitation (% clinically responsive patient) | SD: 55% | 30% | P = .11
| | | | | | | Low: 25%
| | | | | | SADS (% clinically responsive patient) | SD: 55% | 25% | P <.06 3
| | | | | | | Low: 35%
| | | | | | MMSE | ---- | ---- | NS
| | | | | | BFAS | ---- | ---- | NS
Auchus et al., 1997 ^110^ | 15 | Haldol | 3 mg/day | 6 weeks | Behavior (CMAI, BEHAVE-AD) | CMAI mean change | H: -2.4 | -1.4 | P =.82 NS | Fair (not all outcomes considered)
| | Fluoxetine | 20 mg/day | | Caregiver burden (CSI) | | F: +1.4
| | | | | | BEHAVE-AD | H: -2.6 | +1.0 | P =.35 NS
| | | | | | | F: +1.8
| | | | | | CSI | H: +14 | +18.6 | P =.67 NS
| | | | | | | F: -16.8
Petracca et al., 1996 ^111^ | 21 | Clomipramine | 25–100 mg/day | 2–6 weeks | Depression (Ham-D) | Ham-D (% pt entered remission at 6 weeks) | 82% lower than placebo | 30% higher | P =.02 2 | Possibly poor (questionable use of ITT)
| | | | crossover design | Cognitive (MMSE) | MMSE mean score | -- | -- | P <.01
| | | | | Functional (FIM) | FIM | | | favors placebo NS
Lyketsos et al., 2000 ^4^ | 22 | Sertraline | 25–150 mg/day | 13 weeks | Depressive (CDDS, HDS, psychiatrist impression) | Psychiatrist impression, % | 75% | 20% | P < 0.05 | Fair (not all outcomes considered)
| | Placebo | | | Functional (ADL, PDRS) | full or partial responders
| | | | | Cognitive (MMSE) | CDDS (mean change) | -10.7% | -2.1% | P = 0.03
| | | | | | HDS (mean change) | -11.1% | -3.5% | P = 0.2
| | | | | | MMSE (mean change) | ---- | ---- | NS
| | | | | | ADL /PDRS | ---- | ---- | NS

Evidence Table 10. Efficacy of Nonpharmacologic Intervention for Behavioral Problems Related to Dementia: Systematic Reviews

Author | N RCT | Intervention | Outcomes | Results | | | Quality and Comments
| Patients
Forbes 1998 ^151^ | 1 RCT + 2 randomized trials | Music, skills training, visual barriers, exercise, light therapy, pet therapy, sensory integration, reality orientation, hand massage, therapeutic touch, life review, white noise | Social interaction; agitation; wandering; physical aggression; day/night disturbance; self-care; eating problems | None of the included studies met our inclusion criteria. | | | Good
| 132 pts | | | 1 strong trial (planned walking + conversation) | Improved communicative function | P = .007 | All strong and moderate studies conducted in long term care facilities; we included only trial with moderate or strong validity and random allocation with control group
| | | | 1 mod trial (attention focused group) | Improve activities participation | P ≤.001
| | | | 1 mod trial (functional skills training) | Improved self-care ability | P = .04
Opie et al., 1999 ^155^ | 4 RCTs | Sensory integration (1 RCT) | General agitation (4 RCTs) | Activities program plus caregiver education | Improve physical aggression | P = significant | Good
| 215 pts | Activities (1 RCT) | Physical aggression (1 RCT) | Activities program | No effect on general agitation | P = NS | Only 1 RCT used multi-disciplinary team met our inclusion criteria with no fatal methodology flaw
| | Caregiver education (2 RCTs) | | Multidisplinary team | Improved general agitation | P = significant
| | Multidisciplinary team (1 RCT) | | Caregiver education | No effect on general agitation | P = NS
Koger and Brotons, 2000 ^160^ | 0 RCTs | Music therapy | ---- | No RCT was found | | | Good
Neal and Briggs, 2000 ^161^ | 2 RCTs | Validation therapy 2–4 times wk for 36–52 wks | Cognitive (MSQ, PGCMS) | MSQ | WMD:-1.8 (99% CI, -9.7 to +6.1) | NS | Good
| 102 | | Functional: MOSES | PGCMS | WMD: 1.1 (95% CI, -7.5 to +5.3) | NS | Both studies conducted in long term care facility; dementia was moderate to severe in 1 RCT and at least moderate in the second
| | | Behavioral: CMAI, MOSES, MSBS | Self-care MOSES | WMD: -1.1 (99% CI, -4.9 to +2.7) | NS
| | | | Verbal agitation CMAI | WMD: 3.9 (99% CI, -4.1 to +11.9) | NS
| | | | Withdrawal MOSES | WMD: 1.6 (99% CI, -6.0 to +2.8) | NS
| | | | Confusion MOSES | WMD: 3.0 (99% CI, -2.8 to +8.8) | NS
| | | | Social behavior MSBS | WMD: 1.1 (99% CI, -10.3 to +8.1) | NS
Spector et al., 2000 ^162^ | 2 RCTs | Reminiscence therapy 30 min 2–5 times weekly for 4–5 weeks | Cognitive CAPE, MMSE, | Information/orientation CAPE | WMD: 0.05 (95% CI, -4.37 to +4.77) | NS | Good
| 15 | | Behavior CAPE BDI | Behavioral CAPE | WMD: -3.3 (95% CI, -14.2 to +7.60) | NS | Clinical setting and dementia severity not specified; in 1 RCT, patients had moderate to severe dementia
Spector et al., 2000 ^163^ | 6 RCTs | Reality orientation 30–60 minutes 2–5 times weekly for 4–21 weeks | Cognitive multiple scales | Cognitive | SMD: -0.59 (95% CI, -0.95 to -0.22) | Significant | Good
| 125 | | Behavior multiple scales | Behavior | SMD: -0.64 (95% CI, -1.20 to -0.08) | Significant | Clinical setting and dementia severity not specified; patients in 1 RCT had severe cognitive impairment, other trial had mild dementia. Patients in 1 RCT were institutionalized

Evidence Table 11a. Efficacy of Caregiver Interventions: Systematic Review

Author | Number of Studies | Interventions | Outcomes | Results | Comments
Thompson and Briggs, 1998 ^172^ | 6 RCTs | (1) Individualized service assessment and planning vs conventional care or support | (1) Caregiver burden, strain, support, quality of life | No significant differences between experimental and control groups for any of these outcomes | Good
| N (33–102) | (2) Technology-based interventions vs conventional care or support | (2) Caregiver mental health: depression, anxiety | | Limited to 1998 and to caregiver outcomes only
| | (3) Career education/ training vs conventional care/support | (3) Service utilization and cost
| | (4) Multi-faceted/ dimensional strategies vs conventional care/support | (4) Others: knowledge of Alzheimer's disease, asking for help, decision-making confidence

Evidence Table 11b. Efficacy of Caregiver Interventions: Studies

Author | N | Intervention | | | | Outcomes Measured | Results | | | | Quality and Comments
| | Support Group | Skills Training | Counseling | Educational | | Scale | Treatment Arm | Control Arm | P Value
Hebert et al., 1994 ^177^ and 1995 ^178^ | 45 | + | + | + | + | [underlined: Caregiver]: | BI | 34.90 | 36.06 | NS | Good
| | | | | | -Burden: BI | BSI | 33.57 | 30.20 | NS | Difficult to implement
| | | | | | -Depression: BSI | RMBPC(R) | 1.39 | 1.73 | NS
| | | | | | -Reaction to pt's BPRD RMBPC | ADKT | 9.52 | 6.53 | P = 0.004
| | | | | | -ADKT | HCUQ | ---- | ---- | NS
| | | | | | -Health care utilization HCUQ | P (nursing home placement) | 0.33 | 0.45 | P = 0.31
| | | | | | [underlined: Patient]: | 3MS | 40.63 | 36.53 | NS
| | | | | | -Nursing home placement | SMAF | 35.67 | 36.73 | NS
| | | | | | -Cognition: 3MS | RMBPC (F) | 1.58 | 1.63 | NS
| | | | | | -Functional: SMAF
| | | | | | -BPRD: RMBPC (F)
Mittelman et al., 1996 ^173^ | 206 | + | + | + | + | [underlined: Patient]: | Days to nursing home placement | 1,03 | 874 | P = 0.02 | Fair (not all outcomes considered)
| | | | | | Median time to nursing home placement | | | | | Difficult to implement
Brodaty et al., 1997 ^176^ | 96 | + | + | + | + | [underlined: Patient]: | Time to nursing home placement (in months) | 47.5 | 27.6 | P < 0.05 | Fair
| | | | | | Time to nursing home placement | Time to death (in months) | 65 | 53 | P = 0.08 | Difficult to implement in-patient setting
| | | | | | Time to death
McCurry et al., 1998 ^175^ | 36 | -- | + | + | + | [underlined: Caregiver]: | SCB | ---- | ---- | NS | Fair
| | | | | | -Burden: SCB | CES-D | ---- | ---- | NS | Difficult to implement; attrition rate varied between the 2 groups at follow-up, but not at immediate post treatment; (included only the results of post treatment); caregivers had sleep problems before entry
| | | | | | -Depression: CES-D | PSQI | 7.8 | 10.6 | P < 0.05
| | | | | | -Sleep problems: PSQI | RMBPC | ---- | ---- | NS
| | | | | | -Reaction to patients' BPRD: RMBPC
Marriott et al., 2000 ^174^ | 42 | -- | + | + | + | [underlined: Caregiver]: | GHQ @ 9 ms | 6.0 | 12.7 | P = 0.001 | Good
| | | | | | -Burden: GHQ | GHQ @ 12 ms | 3.9 | 10.8 | P = 0.001 | Difficult to implement; caregiver had significant psychological morbidity at entry to the trial.
| | | | | | -Depression: BDI | BDI @ 9 ms | 6.9 | 11.8 | P < 0.01
| | | | | | [underlined: Patient]: | BDI @12ms | 6.1 | 11.8 | P = 0.001
| | | | | | -Cognition: MMSE | MMSE | ---- | ---- | NS
| | | | | | -Depression: CSDD | CSDD | ---- | ---- | NS
| | | | | | -BPRD: MOUSEPAD | MOUSEPAD @ 9 ms | 4.9 | 5.6 | P = 0.01
| | | | | | -Functional status: CDR | MOUSEPAD @12ms | 5.3 | 5.2 | NS
| | | | | | | CDR(ADL) @9ms | 5.4 | 5.1 | NS
| | | | | | | CDR(ADL) @ 12ms | 5.5 | 6.4 | P = 0.043

Evidence Table 12a. Adverse Effects of Dementia Therapy: Cholinesterase Inhibitors—Systematic Reviews

Author | Intervention | Result | | | | | Comments
| | Effect | Treatment | Placebo | P | NNH
Birks et al., 2000 ^115^ | Rivastigmine | D/O to AE | OR: 2.6 (95%CI, 2.0 to 3.2) | | | 5 | Good
| 6–12 mg/day
Birks et al., 2000 ^119^ | Donepezil | D/O to AE | Low: OR: 0.8 (95%CI, 0.5 to 1.2) | | NS | --- | Good
| Low dose: 5 mg/day | | High: OR: 1.8 (95%CI, 1.2 to 2.7) | | Significant | ---
| High dose: 10 mg/day
Qizilbash et al., 1998 ^121^ | Tacrine | D/O | OR: 3.6 (95%CI, 2.8 to 4.7) | | | 4 | Good
Qizilbash et al., 2000 ^120^ | Tacrine | D/O to AE | OR: 5.7 (95%CI, 4.1 to 7.9) | | NR | --- | Good

Evidence Table 12b. Adverse Effects of Dementia Therapy: Cholinesterase Inhibitors -- Studies

Author | Intervention | Result | | | | | Comments
| | Effect | Treatment | Placebo | P | NNH
Burns et al.,1999 ^99^ | Donepezil | D/O to AE | Low: 9% | 10% | NR | --- | Fair
| Low dose: 5 mg/day | | High: 18%
| High dose: 10 mg/day
Greenberg et al., 2000 ^100^ | Donepezil 5 mg/day | D/O to AE # pt | 3 patients | 1 pt | | --- | Fair
Mohs et al., 2001 ^95^ | Donepezil 10 mg/day | D/O AE % | 11% | 7% | NR | --- | Fair
Winblad et al, 2001 ^93^ | Donepezil 10 mg/day | D/O to AE % | 7% | 6.3% | NR | --- | Good
Raskind et al., 2000 ^97^ | Galantamine | D/O to AE% | Low: 23% | 8% | NR | --- | Fair
| Low dose: 24 mg/day | | High: 32%
| High dose: 32 mg/day
Tariot et al., 2000 ^98^ | Galantamine | D/O to AE % | Low: 7% | 7% | NR | --- | Fair
| Low dose: 16 mg/day | | High: 10%
| High dose: 24 mg/day
Wilcock et al., 2000 ^96^ | Galantamine | D/O to AE% | Low: 14% | 9% | NR | --- | Fair
| Low dose: 24 mg/day | | High: 22%
| High dose: 32 mg/day
Rosler et al., 1999 ^101^ | Rivastigmine 6–12 mg/day | D/O 2 AE % | 27% | 7% | NR | --- | Fair
McKeith et al., 2000 ^102^ | Rivastigmine 6–12 mg/day | D/O 2 AE % | 12% | 11% | NR | --- | Fair

Evidence Table 12c. Adverse Effects of Dementia Therapy: Typical and Atypical Neuroleptics

Author | Intervention | Result | | | | | Comments
| | Effect | Treatment | Placebo | P | NNH
Lanctot et al., 1998 ^122^ | Neuroleptic | D/O % | 20% | 16% | P = .5 NS | -- | Good
| | Any AE% | 51% | 25% | P <.001 | 4 (3, 8)
Davidson et al., 2000 ^124^ | Atypical neuroleptic | D/O | OR: 1.31 (95% CI, 1 to 1.7) | | | | Good
| | EPS | OR: 2.04 (95%CI, 1.24 to 3.33) | | | --- | 13 (8, 40)
| | Sedation | OR: 1.74 (95%CI, 1.18 to 2.57) | | --- | 10 (7, 22)
Kirchner et al., 2000 ^125^ | Thioridazine | AE | OR: .41 (95%CI, .09 to 1.86) NS | | --- | | Good
Devanand et al., 1998 ^94^ | Haloperidole | D/O % | 5% | 17% | NR | --- | Fair
| (2–3mg/day) | EPS % (mod-severe) | 20% | 0% | P =.08
| | Any AE% | 100% | 70% | NR

Evidence Table 12d. Adverse Effects of Dementia Therapy: Other

Author | Intervention | Result | | | | | Comments
| | Effect | Treatment | Placebo | P | NNH
Petracca et al., 1996 ^111^ | Clomipramine | D/O % | 9% | 20% | NR | --- | Fair (not clear if intention-to-treat analysis)
LeBars et al., 1997 ^106^ | Gingko biloba 120 mg/day | D/O to AE | 6% | 3% | NR | --- | Fair
| | D/O to CG request | 15% | 18% | NR | ---
| | Any AE | 30% | 31% | NR | ---
Oken et al., 1998 ^118^ | Gingko biloba 120–240 mg/day | No difference between groups; average D/O 16% | | | | | Good
Sano et al, 1997 ^103^ | Selegiline 10 mg/day | Drop-off to AE O% in all groups except | | | | | Fair
| Vit E 2000 IU daily | Lost to F/U % Sel: 5% placebo: 7%
| Both | Vit E: 9%
| | Both: 6%
Birks and Flicker, 2000 ^116^ | Selegiline 10 mg/day | No difference between groups; average D/O 20% | | | | | Good