# Appendix A. Acknowledgments

This study was developed by the RTI-UNC Evidence-based Practice Center under contract to the Agency for Healthcare Research and Quality (Contract No. 290-97-0011), Rockville, MD. We acknowledge the ongoing guidance and assistance of David Atkins, M.D., M.P.H., Director of the Preventive Services Program at AHRQ, Jean Slutsky, P.A., M.S.P.H, AHRQ Task Order Officer, and the assistance of Jacqueline Besteman, J.D., M.A., Director of the AHRQ Evidence-based Practice Program.

The investigators deeply appreciate the superior secretarial assistance of Loraine Monroe of RTI International.

Additionally, we would like to thank internal peer reviewers from the USPSTF for their insight and efforts at crucial stages in the development of the systematic evidence review: Steven Woolf, M.D., M.P.H., Medical College of Virginia, Richmond, Virginia, and Albert Siu, M.D., M.S.P.H., Mount Sinai Medical Center, New York, New York. We also thank our external peer reviewers: E. Rodney Hornbake, M.D., F.A.C.P., American College of Physicians, American Society of Internal Medicine, Cold Springs Harbor, New York; Christopher J.S. Patterson, M.D., Hamilton Health Sciences Corporation, Hamilton, Canada; William Reichman, M.D., New Jersey Medical School, Newark, New Jersey; Allan Ronald, M.D., F.A.C.P., Boniface General Hospital, Winnipeg, Canada; Lon S. Schneider, M.D., Alzheimer's Disease Research Center of California, Los Angeles, California; Jane Thibault, M.D., University of Louisville, Louisville, Kentucky; and, Robert Wallace, M.D., University of Iowa, Iowa City, Iowa.