# References

1 Landis SH, Murray T, Bolden S, Wingo PA. Cancer Statistics, 1999. CA Cancer Jr Clin. 1999;49.
2 Cress RD, Holly EA. Incidence of cutaneous melanoma among non-Hispanic whites, Hispanics, Asians, and blacks: an analysis of California cancer registry data, 1988-93. Cancer Causes & Control. 1997;8:246-252. [pmid: 9134249].
3 Ries LAG, Kosary CL, Hankey BF, Miller BA, Edwards BK. SEER Cancer Statistics Review, 1973-95. Bethesda (MD): National Cancer Institute; 1998.
4 Jelfs P, Coates M, Giles G. Cancer in Australia 1989-1990 (with projections to 1995). Canberra: Australian Institute of Health and Welfare; 1996.
5 Kelly J. Melanoma in the elderly—a neglected public health challenge. Med J Aust. 1998;169:403-404. [pmid: 9830382].
6 Dennis LK. Analysis of the melanoma epidemic, both apparent and real: data from the 1973 through 1994 surveillance, epidemiology, and end results program registry. Arch Dermatol. 1999;135:275-280. [pmid: 10086448].
7 Berwick M, Halpern A. Melanoma epidemiology. Curr Opin Oncol. 1997;9:178-182. [pmid: 9161798].
8 Swerlick RA, Chen S. The melanoma epidemic: more apparent than real?. Mayo Clin Proc. 1997;72:559-564. [pmid: 9179141].
9 Burton R, Armstrong B. Recent incidence trends imply a nonmetastasizing form of invasive melanoma. Melanoma Res. 1994;4:107-113. [pmid: 8069096].
10 Burton R. An analysis of a melanoma epidemic. Int J Cancer. 1995;55:765-770. [pmid: 8244573].
11 Swerlick RA, Chen S. The melanoma epidemic. Is increased surveillance the solution or the problem?. Arch Dermatol. 1996;132:881-4. [pmid: 8712837].
12 Gallagher RP, Hill GB, Bajdik CD, et al. Sunlight exposure, pigmentation factors, and risk of nonmelanocytic skin cancer. II. Squamous cell carcinoma. Arch Dermatol. 1995;131:164-169. [pmid: 7857112].
13 Chuang TY, Popescu NA, Su WP, Chute CG. Squamous cell carcinoma. A population-based incidence study in Rochester, Minnesota. Arch Dermatol. 1990;126:185-188. [pmid: 2301956].
14 Chuang TY, Popescu A, Su WP, Chute CG. Basal cell carcinoma. A population-based incidence study in Rochester, Minnesota. J Am Acad Dermatol. 1990;22:413-417. [pmid: 2312827].
15 Karagas MR, Greenberg ER, Spencer SK, Stukel TA, Mott LA. Increase in incidence rates of basal cell and squamous cell skin cancer in New Hampshire, USA. New Hampshire Skin Cancer Study Group. Int J Cancer. 1999;81:555-559. [pmid: 10225444].
16 McGovern V, Cochran A, Van der Esch E. The classification of malignant melanoma, its histological reporting and registration: revision of the 1972 Syndey classification. Pathology. 1986;18:12-21. [pmid: 3725419].
17 Hersey P, Sillar RW, Howe CG, et al. Factors related to the presentation of patients with thick primary melanomas. Med J Aust. 1991;154:583-587. [pmid: 2056943].
18 Heenan PJ, Yu L, English DR. Melanoma in the elderly--a neglected public health challenge [letter]. Med J Aust. 1999;170:394-395. [pmid: 10327959].
19 Whited JD, Grichnik JM. Does this patient have a mole or a melanoma?. JAMA. 1998;279:696-701. [pmid: 9496989].
20 Corona R, Mele A, Amini M, et al. Interobserver variability on the histopathologic diagnosis of cutaneous melanoma and other pigmented skin lesions. J Clin Oncol. 1996;14:1218-1223. [pmid: 8648377].
21 Farmer ER, Gonin R, Hanna MP. Discordance in the histopathologic diagnosis of melanoma and melanocytic nevi between expert pathologists. Hum Pathol. 1996;27:528-531. [pmid: 8666360].
22 Gershenwald JE, Buzaid AC, Ross MI. Classification and staging of melanoma. [Review] [114 refs]. Hematol Oncol Clin North Am. 1998;12:737-765. [pmid: 9759577].
23 Breslow A. Thickness, cross-sectional areas and depth of invasion in the prognosis of cutaneous melanoma. Ann of Surg. 1970;172:902-908. [pmid: 5477666].
24 Weinstock MA. Death from skin cancer among the elderly: epidemiological patterns. Arch Dermatol. 1997;133:1207-1209. [pmid: 9382558].
25 Preston DS, Stern RS. Nonmelanoma cancers of the skin. N Engl J Med. 1992;327:1649-1662. [pmid: 1435901].
26 Stern RS, Liebman EJ, Vakeva L. Oral psoralen and ultraviolet-A light (PUVA) treatment of psoriasis and persistent risk of nonmelanoma skin cancer. PUVA Follow-up Study. J Natl Cancer Inst. 1998;90:1278-1284. [pmid: 9731734].
27 US. Preventive Services Task Force. Screening for Skin Cancer (Including Counseling to Prevent Skin Cancer). In: DiGuiseppi C, Atkins D, Woolf SH, Kamerow DB, eds. Guide to Clinical Preventive Services, 2nd edition. Washington, DC: Office of Disease Prevention and Health Promotion, U. S. Government Printing Office. 1996:141-152.
28 Rigel DS, Friedman RJ, Kopf AW, et al. Importance of complete cutaneous examination for the detection of malignant melanoma. J Am Acad Dermatol. 1986;14:857-860. [pmid: 3711396].
29 Sackett DL, Haynes RB, Guyatte GH, Tugwell P. Clinical Epidemiology, A Basic Science for Clinical Medicine, 2nd Edition. Boston: Little, Brown and Company; 1991.
30 Sox HC, Blatt MA, Higgins MC, Marton KI. Medical Decision Making. Boston: Butterworth-Heinemann; 1988.
31 Limpert GH. Skin-cancer screening: a three-year experience that paid for itself. J Fam Pract. 1995;40:471-475. [pmid: 7730771].
32 de Rooij MJ, Rampen FH, Schouten LJ, Neumann HA. Volunteer melanoma screenings. Follow-up, compliance, and outcome. Dermatol Surg. 1997;23:197-201. [pmid: 9145963].
33 de Rooij MJ, Rampen FH, Schouten LJ, Neumann HA. Skin cancer screening focusing on melanoma yields more selective attendance. Arch Dermatol. 1995;131:422-425. [pmid: 7726583].
34 Jonna BP, Delfino RJ, Newman WG, Tope WD. Positive predictive value for presumptive diagnoses of skin cancer and compliance with follow-up among patients attending a community screening program. Prev Med. 1998;27:611-616. [pmid: 9672956].
35 Rampen RH. Point-counterpoint. Mass population skin cancer screening is not worthwhile. J Cutan Med Surg. 1998;2:128-129. [pmid: 9556369].
36 Koh HK, Norton LA, Geller AC, et al. Evaluation of the American Academy of Dermatology's National Skin Cancer Early Detection and Screening Program. J Am Acad Dermatol. 1996;34:971-978. [pmid: 8647990].
37 Rampen FH, Casparie-van Velsen JI, van Huystee BE, Kiemeney LA, Schouten LJ. False-negative findings in skin cancer and melanoma screening. J Am Acad Dermatol. 1995;33:59-63. [pmid: 7601947].
38 de Rooij MJ, Rampen FH, Schouten LJ, Neumann HA. Factors influencing participation among melanoma screening attenders. Acta Derm Venereol. 1997;77:467-470. [pmid: 9394985].
39 Federman DG, Concato J, Kirsner RS. Comparison of dermatologic diagnoses by primary care practitioners and dermatologists. A review of the literature. Arch Fam Med. 1999;8:170-172. [pmid: 10101989].
40 Burton RC, Howe C, Adamson L, et al. General practitioner screening for melanoma: sensitivity, specificity, and effect of training. J Med Screen. 1998;5:156-161. [pmid: 9795877].
41 Gallagher RP, Ma B, McLean DI, et al. Trends in basal cell carcinoma, squamous cell carcinoma, and melanoma of the skin from 1973 through 1987. J Am Acad Dermatol. 1990;23:413-421. [pmid: 2212139].
42 Gamble JF, Lerman SE, Holder WR, Nicolich MJ, Yarborough CM. Physician-based case-control study of non-melanoma skin cancer in Baytown, Texas. Occup Med. 1996;46:186-196. [pmid: 8695770].
43 Grodstein F, Speizer FE, Hunter DJ. A prospective study of incident squamous cell carcinoma of the skin in the nurses' health study. J Natl Cancer Inst. 1995;87:1061-1066. [pmid: 7616597].
44 Kaldor J, Shugg D, Young B, Dwyer T, Wang YG. Non-melanoma skin cancer: ten years of cancer-registry-based surveillance. Int J Cancer. 1993;53:886-891. [pmid: 8473047].
45 Bataille V, Bishop JA, Sasieni P, et al. Risk of cutaneous melanoma in relation to the numbers, types and sites of naevi: a case-control study. Br J Cancer. 1996;73:1605-1611. [pmid: 8664138].
46 Berwick M, Begg CB, Fine JA, Roush GC, Barnhill RL. Screening for cutaneous melanoma by skin self-examination. J Natl Cancer Inst. 1996;88:17-23. [pmid: 8847720].
47 Garbe C, Buttner P, Weiss J, et al. Risk factors for developing cutaneous melanoma and criteria for identifying persons at risk: multicenter case-control study of the Central Malignant Melanoma Registry of the German Dermatological Society. J Invest Derm. 1994;102:695-699. [pmid: 8176250].
48 Tucker MA, Halpern A, Holly EA, et al. Clinically recognized dysplastic nevi. A central risk factor for cutaneous melanoma. JAMA. 1997;277:1439-1444. [pmid: 9145715].
49 English DR, Armstrong BK. Identifying people at high risk of cutaneous malignant melanoma: results from a case-control study in Western Australia. BMJ (Clin Res Ed). 1988;296:1285-1288. [pmid: 3133052].
50 Marrett LD, King WD, Walter SD, From L. Use of host factors to identify people at high risk for cutaneous malignant melanoma. Can Med Assoc J. 1992;147:445-453. [pmid: 1498755].
51 Bliss JM, Ford D, Swerdlow AJ, et al. Risk of cutaneous melanoma associated with pigmentation characteristics and freckling: systematic overview of 10 case-control studies. The International Melanoma Analysis Group (IMAGE). Int J Cancer. 1995;62:367-376. [pmid: 7635560].
52 Elwood JM, Jopson J. Melanoma and sun exposure: an overview of published studies. Int J Cancer. 1997;73:198-203. [pmid: 9335442].
53 Elwood JM, Gallagher RP. Body site distribution of cutaneous malignant melanoma in relationship to patterns of sun exposure. Int J Cancer. 1998;78:276-280. [pmid: 9766557].
54 Walter SD, King WD, Marrett LD. Association of cutaneous malignant melanoma with intermittent exposure to ultraviolet radiation: results of a case-control study in Ontario, Canada. Int J Epidemiol. 1999;28:418-427. [pmid: 10405843].
55 Byles JE, Hennrikus D, Sanson-Fisher R, Hersey P. Reliability of naevus counts in identifying individuals at high risk of malignant melanoma. Br J Dermatol. 1994;130:51-56. [pmid: 8305317].
56 Westerdahl J, Anderson H, Olsson H, Ingvar C. Reproducibility of a self-administered questionnaire for assessment of melanoma risk. Int J Epidemiol. 1996;25:245-251. [pmid: 9119548].
57 Little P, Keefe M, White J. Self screening for risk of melanoma: validity of self mole counting by patients in a single general practice. BMJ. 1995;310:912-916. [pmid: 7719184].
58 Lawson DD, Moore DH, 2nd, Schneider JS, Sagebiel RW. Nevus counting as a risk factor for melanoma: comparison of self-count with count by physician. J Am Acad Dermatol. 1994;31:438-444. [pmid: 8077469].
59 Titus-Ernstoff L, Thorn M, Tosteson TD, et al. The accuracy of skin self-examination for atypical nevi. Epidemiology. 1996;7:619-623. [pmid: 8899388].
60 Jackson A, Wilkinson C, Ranger M, Pill R, August P. Can primary prevention or selective screening for melanoma be more precisely targeted through general practice? A prospective study to validate a self administered risk score. BMJ. 1998;316:34-38. discussion 38-39. [pmid: 9451264].
61 Schneider JS, Moore DH, 2nd, Sagebiel RW. Risk factors for melanoma incidence in prospective follow-up. The importance of atypical (dysplastic) nevi. Arch Dermatol. 1994;130:1002-1007. [pmid: 8053695].
62 Kelly JW, Crutcher WA, Sagebiel RW. Clinical diagnosis of dysplastic melanocytic nevi. A clinicopathologic correlation. J Am Acad Dermatol. 1986;14:1044-1052. [pmid: 3722481].
63 Jackson A, Wilkinson C, Pill R. Moles and melanomas--who's at risk, who knows, and who cares? A strategy to inform those at high risk. Br J Gen Pract. 1999;49:199-203. [pmid: 10343423].
64 MacKie RM, Freudenberger T, Aitchison TC. Personal risk-factor chart for cutaneous melanoma. Lancet. 1989;2:487-490. [pmid: 2570195].
65 Engelberg D, Gallagher RP, Rivers JK. Follow-up and evaluation of skin cancer screening in British Columbia. J Am Acad Dermatol. 1999;41:37-42. [pmid: 10411408].
66 McGee R, Elwood M, Williams S, Lowry F. Who comes to skin checks?. NZ Med J. 1994;107:58-60.
67 Hourani LL, LaFleur B. Predictors of gender differences in sunscreen use and screening outcome among skin cancer screening participants. J Behav Med. 1995;18:461-477. [pmid: 8847715].
68 Katris P, Crock JG, Gray BN. Research note: the Lions Cancer Institute and the Western Australian Society of Plastic Surgeons skin cancer screening programme. Aust NZ J Surg. 1996;66:101-104.
69 Katris P, Donovan RJ, Gray BN. Nurses screening for skin cancer: an observation study. Aust N Z J Public Health. 1998;22:381-383. [pmid: 9629826].
70 Rivers JK, Gallagher RP. Public education projects in skin cancer. Experience of the Canadian Dermatology Association. Cancer. 1995;75:661-666. [pmid: 7804992].
71 Dozier S, Wagner RF, Jr., Black SA, Terracina J. Beachfront screening for skin cancer in Texas Gulf coast surfers. South Med J. 1997;90:55-58. [pmid: 9003825].
72 Harvey I, Frankel S, Marks R, Shalom D, Nolan-Farrell M. Non-melanoma skin cancer and solar keratoses. I. Methods and descriptive results of the South Wales Skin Cancer Study. Br J Cancer. 1996;74:1302-1307. [pmid: 8883422].
73 Harvey I, Frankel S, Marks R, Shalom D, Nolan-Farrell M. Non-melanoma skin cancer and solar keratoses II analytical results of the South Wales Skin Cancer Study. Br J Cancer. 1996;74:1308-1312. [pmid: 8883423].
74 Ichihashi M, Naruse K, Harada S, et al. Trends in nonmelanoma skin cancer in Japan. Recent Results Cancer Res. 1995;139:263-273. [pmid: 7597297].
75 Tornberg S, Mansson-Brahme E, Linden D, et al. Screening for cutaneous malignant melanoma: a feasibility study. J Med Screen. 1996;3:211-215. [pmid: 9041488].
76 Bergenmar M, Tornberg S, Brandberg Y. Factors related to non-attendance in a population based melanoma screening program. Psychooncology. 1997;6:218-226. [pmid: 9313288].
77 Ruskiewicz J. Skin cancer and actinic keratoses. J Am Optom Assoc. 1998;69:229-235. [pmid: 9585662].
78 Whited JD, Hall RP, Simel DL, Horner RD. Primary care clinicians' performance for detecting actinic keratoses and skin cancer. Arch Int Med. 1997;157:985-990. [pmid: 9140269].
79 Friedman LC, Webb JA, Bruce S, Weinberg AD, Cooper HP. Skin cancer prevention and early detection intentions and behavior. Am J Prev Med. 1995;11:59-65. [pmid: 7748588].
80 Herd RM, Cooper EJ, Hunter JA, et al. Cutaneous malignant melanoma. Publicity, screening clinics and survival--the Edinburgh experience 1982-90. Br J Dermatol. 1995;132:563-570. [pmid: 7748747].
81 Marghoob AA, Slade J, Salopek TG, Kopf AW, Bart RS, Rigel DS. Basal cell and squamous cell carcinomas are important risk factors for cutaneous malignant melanoma. Screening implications. Cancer. 1995;75:707-714. [pmid: 7804999].
82 van der Spek-Keijser LM, van der Rhee HJ, Toth G, Van Westering R, Bruijn JA, Coebergh JW. Site, histological type, and thickness of primary cutaneous malignant melanoma in western Netherlands since 1980. Br J Dermatol. 1997;136:565-571. [pmid: 9155959].
83 Veierod MB, Thelle DS, Laake P. Diet and risk of cutaneous malignant melanoma: a prospective study of 50,757 Norwegian men and women. Int J Cancer. 1997;71:600-604. [pmid: 9178814].
84 De Rooij MJ, Rampen FH, Schouten LJ, Neumann HA. Total skin examination during screening for malignant melanoma does not increase the detection rate. Br J Dermatol. 1996;135:42-45. [pmid: 8776357].
85 Dhir A, Orengo I, Bruce S, Kolbusz RV, Alford E, Goldberg L. Basal cell carcinoma on the scalp of an Indian patient. Dermatol Surg. 1995;21:247-250. [pmid: 7712098].
86 Geller AC, Halpern AC, Sun T, et al. Participant satisfaction and value in American Academy of Dermatology and American Cancer Society skin cancer screening programs in Massachusetts. J Am Acad Dermatol. 1999;40:563-566. [pmid: 10188674].
87 Stern RS, Boudreaux C, Arndt KA. Diagnostic accuracy and appropriateness of care for seborrheic keratoses. A pilot study of an approach to quality assurance for cutaneous surgery. JAMA. 1991;265:74-77. [pmid: 1824572].
88 MacKie RM, Hole D. Audit of public education campaign to encourage earlier detection of malignant melanoma. BMJ. 1992;304:1012-1015. [pmid: 1586781].
89 Koh HK, Geller AC. Public health interventions for melanoma. Prevention, early detection, and education. Hematol Oncol Clin North Am. 1998;12:903-298. [pmid: 9759586].
90 Elwood JM. Screening for melanoma and options for its evaluation?. J Med Screen. 1994;1:22-38. [pmid: 8790483].
91 Hanrahan PF, Hersey P, D'Este CA. Factors involved in presentation of older people with thick melanoma. Med J Aust. 1998;169:410-414. [pmid: 9830387].
92 Giles GG, Armstrong BK, Burton RC, Staples MP, Thursfield VJ. Has mortality from melanoma stopped rising in Australia? Analysis of trends between 1931 and 1994. BMJ. 1996;312:1121-1125. [pmid: 8620126].
93 Melia J, Cooper EJ, Frost T, et al. Cancer Research Campaign health education programme to promote the early detection of cutaneous malignant melanoma. II. Characteristics and incidence of melanoma. Br J Dermatol. 1995;132:414-421. [pmid: 7718458].
94 Melia J. Early detection of cutaneous malignant melanoma in Britain. Int J Epidemiol. 1995;24:S39-S44. [pmid: 7558550].
95 Metzger S, Ellwanger U, Stroebel W, Schiebel U, Rassner G, Fierlbeck G. Extent and consequences of physician delay in the diagnosis of acral melanoma. Melanoma Res. 1998;8:181-186. [pmid: 9610874].
96 Warso M, Gray T, Gonzalez M. Melanoma of the hand. J Hand Surg. 1997;22:354-360.
97 Larsson K, Shaw H, Thompson J, Harman R, McCarthy W. Primary mucosal and glans penis melanomas: the Sydney Melanoma Unit experience. Aust N Z J Surg. 1999;69:121-126. [pmid: 10030812].
98 Holden R, Damato B. Preventable delays in the treatment of intraocular melanoma in the UK. Eye. 1996;10:127-129. [pmid: 8763318].
99 Bennett DR, Wasson D, MacArthur JD, McMillen MA. The effect of misdiagnosis and delay in diagnosis on clinical outcome in melanomas of the foot. J Am Coll Surg. 1994;179:279-284. [pmid: 8069422].
100 Baccard M, Chevret S, Chemaly P, Morel P. [Delay in diagnosing melanoma. A prospective study in 102 patients]. Ann Dermatol Venereol. 1997;124:601-606. [pmid: 9739920].
101 Epstein DS, Lange JR, Gruber SB, Mofid M, Koch SE. Is physician detection associated with thinner melanomas?. JAMA. 1999;281:640-643. [pmid: 10029126].
102 Richard MA, Grob JJ, Avril MF, et al. Melanoma and tumor thickness: challenges of early diagnosis. Arch Dermatol. 1999;135:269-274. [pmid: 10086447].
103 Freedberg K. Screening for melanoma: A cost-effectiveness analysis. J Am Acad Dermatol. 1999;41:738-745. [pmid: 10534637].