# Discussion

Table 4 summarizes the literature review by describing the evidence for each link in the analytic framework (see Figures 3 and 4). The quality of the evidence at each link ranged from poor to fair and is explained in Table 4.

Table 4 Summary of Evidence for Screening for SkinCancer

Linkage in Analytic Framework. | Evidence Code* | Quality of Evidence
1a. Accuracy of total-body skinexamination: evidence that total-body skin examination can detect skin cancer. | II-2 | Fair: The accuracy of a total-body skin examination by primary care physicians in unselected patients may be low. Reliability of pathologic diagnosis in community practice in the U.S. is not clear.
1b. Accuracy of risk assessment: evidence that in selected patients, a questionnaire or interview, followed by exam, can detect skin cancer. | II-2 | Fair: Mole counts and other factors predict elevated risk over time, but no study has determined the accuracy of risk stratification followed by total-body skin examination in selected patients as a screening method.
2. Adverse effects of screening: evidence that screening causes significant harms. | III | Poor: Most postulated adverse effects have not been evaluated in studies.
3. Effectiveness of early detection: evidence that persons detected through screening have better outcomes than those who are not screened. | II-3 | Poor: No studies directly link screening to lower mortality and morbidity. Most well-done population-based studies concern promotion of self-care behaviors such as self-examination rather than universal screening.
4a. Effectiveness of treatment of nonmelanoma skin cancer found by screening. | III | Poor: The hypothesis that early detection by screening could reduce mortality and morbidity is plausible but has not been examined in studies.
4b. Effectiveness of treatment of melanoma found by screening. | II-1, III | Fair: There are no controlled studies of treatment in patients found by screening to have thin melanomas, but epidemiologic studies, studies of skin health behaviors, and studies of factors associated with advanced melanoma suggest that elderly men are at high risk and are unlikely to benefit from health promotion efforts. Studies of delay in diagnosis have conflicting results, and the ability of screening to reach individuals at high risk and to find aggressive tumors while they are still curable have not been established.

* I, randomized controlled trial; II-1, controlled trial without randomization; II-2, cohort or case-control analytic studies; II-3, multiple time series, dramatic uncontrolled experiments; III, opinions of respected authorities, descriptive epidemiology.

The case for screening is based on the assumption that melanoma and other skin cancers have a long latency period during which they can be treated with a high rate of success. Another assumption is that early detection prevents progression of early-stage cancers to advanced, lethal stages. These assumptions are reasonable, but studies of early detection have not focused on screening and have not adequately linked it with reduced incidence of invasive disease.

Despite these information gaps, skin cancer screening, perhaps by means of a risk-assessment technique to identify high-risk patients who are seeing the physician for other reasons, is the most promising strategy for addressing the excess burden of disease in older individuals. This group has substantial morbidity and mortality from skin cancer. By themselves, primary prevention efforts and promotion of self-examination seem unlikely to change these rates substantially. Although the efficacy of screening has not been established, the screening procedures themselves are noninvasive, and the follow-up test, skin biopsy, has low morbidity.

## Future Research Needs

The agenda for future research for skin cancer screening is a rich one, but one complicated by the low incidence of melanoma and the enormous study sample sizes required for vigorous demonstration of screening efficacy. We have identified numerous potentially promising research directions.

- First, more research should focus on the elderly. Advanced melanoma and invasive squamous cell carcinoma occur most often in the elderly, especially older men, and older men are less likely than other groups to take part in mass-screening programs. Therefore, we especially need to learn more about primary-care-based strategies for identifying high-risk men older than 65 years of age and for referring them for screening and surveillance. As part of this effort, we need better information about the natural history of thick nodular melanoma typically found in the elderly, since currently, there is little evidence that lethal tumors in this group could be detected in a curable state. We also need to know more about reductions in disfigurement for NMSC in this group.
- Second, well-designed, prospective, population-based studies that compare incidence of lethal melanoma in screened and unscreened groups are needed to provide information about the consequences of delay and how much it can be reduced by screening. In theory, screening can find melanoma earlier than would occur without screening. But to date, studies have examined neither the average difference in time to diagnosis between screened and unscreened populations nor the rate of progression of undetected tumors during this interval.
- Third, in the absence of evidence for the accuracy, efficacy, or feasibility of total-body skin examination of unselected patients by primary care clinicians, more research attention should be given to identifying only patients at high risk for melanoma for routine primary care screening and with the primary care provider either performing a total-body skin examination or referring the patient to a dermatologist for periodic skin examinations.
- Fourth, at least two types of research are needed: observational studies and validated risk-assessment program studies. Observational studies should assess the validity, reliability, and feasibility of standardized brief risk assessments to identify patients at high risk for melanoma. By use of a patient questionnaire and possibly limited examination, these studies would assess the risk levels of patients seen in primary care clinics and would monitor patients in the high- and the low-risk groups. No longitudinal studies of the use of a risk-assessment tool in primary care practice have been reported.

Studies of validated risk-assessment programs in the primary care setting are needed to identify high-risk patients. However, as this review shows, prospective randomized trials of screening with risk-assessment instruments would need to include tens of thousands of patients in the treatment and in the control arms.

Future research also is needed to address whether screening increases the number of precancerous lesions removed and ultimately reduces the incidence of skin cancer. This will require population-based studies that carefully track removal of precancerous lesions and measure the effect on incidence of skin cancer in screened and unscreened groups. The case-control study of skin self-examination for melanoma conducted by Berwick et al.^ 46 ^ provides some evidence that patients who self-examined their skin had more precancerous lesions removed than those who did not self-examine their skin. However, it was unclear how removal of these lesions related to the incidence of melanoma.

Finally, as with other screening protocols, patient behavior plays a critical role in determining the ultimate effect of screening on morbidity and mortality. Three important behavioral issues merit study:

### Strategies for improving patient risk assessment

Given the unknown and uncertain yield of primary care skin examinations, it becomes particularly important to examine strategies for improving patient risk assessment. In fact, as noted above, the strongest available evidence that early detection of melanoma reduces mortality comes from a case-control study of skin self-examination. Although this study itself is problematic, it points out the need for a better understanding of the behavioral processes that could link self-examination to reduced incidence of lethality of melanoma. To prevent melanoma or to detect it earlier, patient self-examination must lead to activities such as the identification of suspicious lesions, self-referral to a physician, earlier treatment of precancerous lesions, and even health behavior changes to prevent the development of new melanomas. Therefore, clinicians must learn how best to teach or prompt this chain of behavior. There is also much for clinicians to learn about ways to improve the accuracy of patient self-examination (mole counts, identification of suspicious lesions) and ways to improve the effect of targeted media campaign for mass screening. These campaigns must do a better job of helping people to identify whether they are at high risk and to take part in mass screening, and, if necessary, in follow-up physician visits.

### Explanation of the rates of compliance with referral

Clearly, whether primary care screening and early detection can reduce morbidity and mortality depends on whether it leads to referral for follow-up and biopsy—especially among high-risk groups. Rates of compliance with referral for follow-up skin examination or biopsy ranged from 45% to 95% in the studies reviewed; to explain these variations, we need to learn more about the characteristics of the screening programs and of the patients. What can providers do or say to promote follow-up? What systems supports must be in place to prompt and support patients and providers?

### Emphasis on patient education and motivation

As noted in this review, little is known about the effect of screening on patients' skin knowledge and skin health behaviors. The yield of mass screening and casefinding could be improved by capitalization on primary care specialty screening as a teachable moment to communicate risk status, to motivate and educate patients about regular skin examination, and to promote sun-protection measures.