# Results

## Accuracy of Screening Tests

Before considering the consequences of screening, we raised and attempted to answer the following questions about the accuracy of the screening tests most commonly used in detecting skin cancers.

### How Accurate Is Total-Body Skin Examination in the Detection of Skin Cancer?

Table 1 summarizes 5 recent prospective studies^31-34,37^ of the accuracy of skin examination in screening programs. In all the studies the participants were self-selected individuals who responded to an advertisement that may have emphasized skin cancer risk factors. In some studies, total-body skin examinations were performed on all participants; in others, the examination focused on specific lesions identified by the patient.^32,33^ Few data from screening studies exist on the accuracy of skin cancer screening by primary care physicians; in all but 1 study,^ 31 ^ the skin examinations were conducted by dermatologists.

In these studies, a positive screening test result was defined as the clinical diagnosis of a suspicious skin lesion. Histologic diagnosis on skin biopsy was the gold standard determination of disease. In 4 of the studies, skin examination was considered positive if the lesion was suspected of being any type of skin cancer.^32-36^ In these studies, from 4.2% to 28.4% of subjects had suspicious lesions, and from 1% to 6% proved to have skin cancer. Basal cell cancer accounted for 74% to 93% of the confirmed skin cancer cases; melanoma, 7% to 27%; and squamous cell cancer, 0% to 4%. This suggests that basal cell cancers contributed heavily to the summary estimates of the accuracy of skin examination reported in these studies.

Workup bias was present in all of these studies—that is, only suspicious lesions were biopsied. This design permits measurement of the PV+ of screening, but not of the false-negative rate. In Table 1, High PV+ estimates (as defined in Chapter 2, “Methods”) for all types of skin cancer values ranged from 0.30 to 0.58, indicating that between 30% and 58% of patients found to have a suspicious lesion were eventually diagnosed to have skin cancer on biopsy.^31-35^ The variation in High PV+ may be related to variation in the prevalence of disease, which, in turn, could be related to the type of patients recruited (high risk or not targeted).

The Low PV+ (also defined in Chapter 2, “Methods”) takes into account the effect of noncompliance with the recommendation to have a biopsy done. The 2 smallest studies^31,34^ had great differences between the lower and the upper estimates of PV. In both of these small studies the percentage of patients who had suspicious lesions was high (21%^ 31 ^ and 28%^ 34 ^), but the percentage of those patients who went on for biopsy was low (36%^ 34 ^ and 65%^ 31 ^). The clinicians in these studies^31,34^ appeared to have less rigid criteria for diagnosing skin cancer from skin examinations than was used in the other, larger studies,^32,33,37^ since they were 4 times as likely to find a suspicious lesion. Low PV+ results may better represent the actual effect of mass screening in which the patient must comply with referral to a physician for biopsy for screening to affect follow-up and treatment.

The last study shown in Table 1 focuses on detection of melanoma in self-selected individuals.^ 36 ^ The study demonstrated that dermatologists found lesions suspected of being melanoma in a very small proportion of individuals (0.03%). In this study, 282,555 members of the general public were recruited for free examinations without regard to risk factors for skin cancer. Clinical suspicion was classified as suspected melanoma or rule-out melanoma. Only 0.3% (n = 763) of the participants had a clinical diagnosis of suspected melanoma at the skin examination. Of the 679 patients who went on for biopsies, 130 patients had melanoma (PV+ of 0.191). Although the use of a lower cutoff, rule-out melanoma, identified an additional 234 patients who had melanoma, an additional 2,316 patients who do not have melanoma were biopsied, and the PV was 0.09. Interestingly, compliance with biopsy was significantly lower for participants given a diagnosis of rule-out melanoma—0.69, compared with 0.89 for patients who had a diagnosis of suspected melanoma.

Table 1. Skin Cancer Screening Accuracy

Author, Year | Study Sample and Setting | Recruitment Focus | Patients | Index Test | P or D | Defn. of Susp. Lesion | Suspicious Lesions | | Probability of Cancer | BCC/ Skin Cancer | MM/ Skin Cancer | SCC/ Skin Cancer | Positive Predictive Value | | Biopsy Rate* | Likelihood Ratio**
| | | (n) | | | | (n | %) | | % | % | % | (Low | High)
Screening for All Skin Cancer
de Rooij et al.,^ 33 ^ 1995 Rampen et al.,^ 37 ^ 1995 | Volunteers for skin cancer screening in the Netherlands | Patients who have skin cancer risks | 1,961 | Lesion-specific exam or TSE | d | Skin cancer | 93 | 4.7% | 0.031 | 85.1% | 12.8% | 2.1% | 0.51 | 0.54 | 0.935 | 37.32
Limpert,^ 31 ^ 1995 | Free skin cancer clinic at family physician's office | Not reported | 247 | TSE | p | Skin cancer | 51 | 20.6% | 0.057 | 92.9% | 7.1% | 0.0% | 0.27 | 0.42 | 0.647 | 12.26
de Rooij et al.,^ 32 ^ 1997 | Vounteer melanoma screenings in the Netherlands following a public campaign on melanoma and risk factors | Patients who have melanoma risks | 4,146 | Lesion-specific exam or TSE | d | Skin cancer | 173 | 4.2% | 0.011 | 73.5% | 26.5% | 0.0% | 0.28 | 0.30 | 0.912 | 37.95
Jonna et al.,^ 34 ^ 1998 | Free skin cancer screening in San Diego for self-selected high risk | Patients who have skin cancer risks | 464 | TSE | d | Skin cancer | 132 | 28.4% | 0.060 | 85.2% | 11.1% | 3.7% | 0.21 | 0.58 | 0.364 | 21.80
Screening for Melanoma
Koh et al.,^ 36 ^ 1996 | Volunteer skin cancer education and screenings by the American Academy of Dermatology | Not targeted | 282,555 | Not reported | d | Suspected Melanoma | 763 | 0.3% | 0.001 | | | | 0.17 | 0.19 | 0.890 | 183.57
Koh et al., ^ 36 ^ 1996 | Volunteer skin cancer education and screenings by the American Academy of Dermatology | Not targeted | 282,555 | Not reported | d | Rule-out melanoma | 3,695 | 1.3% | 0.001 | | | | 0.06 | 0.09 | 0.690 | 78.33

MM, malignant melanoma; BCC, basal cell carcinoma; SCC, squamous cell carcinoma; TSE, total-skin examination, p, Primary care provider; d, dermatologist;

Defn. of Susp. Lesion, Definition of suspicious lesion. The overall probability of cancer was calculated as the total number of cancers diagnosed divided by the number of patients screened.

For the first group of studies, all skin cancers are included in the numerator. For the Koh et al. studies, only melanomas are included.

Methods for calculating the high and low estimates of predictive value and likelihood ratios are described in the text.

* Proportion of patients referred for biopsy who actually had one.

** Method for estimating likelihood ratio of a positive test is described in the text.

Although data are sparse, the sensitivity of a complete skin examination performed by a dermatologist is thought to be high.^ 37 ^ One of the studies in Table 1 provided an indirect measure of sensitivity and specificity through registry data.^ 37 ^ In this study, performed in the Netherlands, 1,551 of 1,763 participants who had negative screening examinations consented to be followed through 2 population-based cancer registries for 42 months. Similarly, 87 of 93 patients who had positive tests were also followed. Fifteen patients who had negative screening results (approximately 1%) appeared in at least 1 of the cancer registries to have skin cancer. Review of medical records revealed that 12 of the patients had new lesions, whereas 3 patients had documented lesions that had been misdiagnosed: 1 patient had a basal cell carcinoma, diagnosed as a common nevus, on his back; 1 patient had a squamous cell carcinoma, recorded as a seborrheic keratosis, on his wrist; and 1 patient had a basal cell carcinoma, originally diagnosed as an actinic keratosis, on the forehead. Overall sensitivity of the initial examination was 0.940, and specificity was 0.975. For a patient who had a negative initial skin examination, the probability of having no skin cancer on follow-up was 0.998.

Although this follow-up study^ 37 ^ provides the best available data on sensitivity and specificity in a screening setting, caution should be raised about generalizing this study to screening in a primary care setting because the examiners were dermatologists rather than general practitioners (GPs). Additionally, it unclear how many lesions diagnosed as precursor lesions were, in fact, skin cancer. Patients who had precursor lesions (n = 111) were excluded from the study.

Since PV+s highly depend on the probability of skin cancer in each study, positive LRs were computed. The positive LRs in Table 1 ranged from 12 to 38 for patients screened for all types of skin cancer.^31-34,37^ Thus, according to the conditional probability definition of LR,

p(positive test| skin cancer)/p(positive test| no skin cancer),

patients who had suspicious lesions for any type of skin cancer were 12 to 38 times more likely to have skin cancer than not to have skin cancer. When screened specifically for melanoma, patients who had a suspected melanoma diagnosis were 184 times more likely to have melanoma than not to have melanoma.^ 36 ^ Patients who had a rule-out melanoma diagnosis were 78 times more likely to have melanoma than not to have melanoma.

Most LR results shown in Table 1 must be considered with caution. With the exception of 1 study,^ 37 ^ the computation of LRs assumed there were no false-negative results. In this study, 3 of 50 skin cancer patients had false-negative results, suggesting that skin examinations have a false-negative rate of 6%.^ 37 ^ When the LR was recomputed in this study with the assumption that the false-negative rate was 0%, the LR increased from 37.32 (using false-negative rate of 6%) to 39.78 (assuming 0% false-negative rate). Similarly, if the false-negative rate had actually been 10%, the LR for this study would be 35.84. If it had been assumed to be 0%, the computed LR would be 39.78. Taken to an extreme, if the examiner missed 1 of every 5 patients who had skin cancer (a false-negative rate of 20%), the computed LR would be overestimated by 27%. However, if the false-negative rate found in the follow-up study^ 37 ^ can be generalized to the studies that did not identify false negatives,^31,32,34,36^ the inflation may be approximately 6%.

In summary, estimates of accuracy are based on a handful of mass-screening, cross-sectional studies. All studies suffer from workup bias. However, 1 study^ 37 ^ attempted to reduce this bias by following all patients who had negative tests to determine how many patients who had skin cancer were missed. Also, all studies except 1 (Ref. 31) provided accuracy measures for dermatologists in mass-screening settings but not for primary care physicians. Accuracy for dermatologists screening patients is thought to be high, with a sensitivity of 0.94 and a specificity of 0.975.^ 37 ^

#### Nonscreening studies

Several studies have examined the accuracy of nondermatologists' assessments of photographs of skin lesions or of preselected patients who have lesions, with the histologic diagnosis used as the reference standard. One recent review summarized studies that used color slides (rather than actual patients) to test physicians' accuracy in predicting the histologic diagnosis (mostly NMSC).^ 39 ^ When these studies were combined, dermatologists performed better (93% correct) than family medicine attending physicians (70% correct) and internal medicine attending physicians (52% correct). Another recent review found that, in studies in which photographs or in which selected patients who had known lesions were used, use of the ABCD(E) or the 7-point checklist had a sensitivity of 50% to 97% and a specificity of 96% to 99% for the histologic diagnosis of skin cancer.^ 19 ^ Nondermatologists' examinations were less sensitive than examinations performed by dermatologists. Many of these studies were small and used convenience samples of attending physicians at academic medical centers. More important, these studies did not examine the accuracy of a total-body skin examination or the ability of physicians to identify suspicious lesions efficiently in the setting of a screening program.^ 19 ^

One well-designed prospective study of the accuracy of total-body skin examination found that skin cancer specialists' decisions about biopsy were more sensitive and much more specific than those of GPs.^ 40 ^ In Australia, 4 skin cancer specialists and 63 randomly selected GPs performed total-body skin examinations on 109 selected patients, 43 of whom had suspicious pigmented lesions diagnosed previously by a skin specialist. The sensitivity of total-body skin examination for detecting suspicious lesions was 0.72 for the GPs, versus 0.97 for 4 skin specialists. The PV+ for the GPs was 0.39. Of the 43 patients, 12 (28%) who had suspicious lesions had melanomas. Although the GPs' diagnoses were highly sensitive for melanomas (0.97), they classified approximately 11 benign lesions as suspicious for each melanoma. For the 4 dermatologists, the ratio was 2.1 benign lesions to 1 melanoma. Because the proportion of patients who had suspicious lesions (and melanoma) was much higher in this study than would occur in unselected patients, the PV+ of primary care physicians' examinations would be lower in an actual screening study.

### How Accurate Are Risk-Assessment Tools as a Screening Test for Skin Cancer?

Another screening strategy is to use a questionnaire or interview to identify a group of high-risk patients. In this strategy, only high-risk patients would have total-body skin examinations. Potentially, such a strategy could reduce the cost of screening because fewer total-body skin examinations and biopsies would be needed to diagnose patients who have skin cancer. The association of demographic, behavioral, and clinical factors with the risk of skin cancer has been well studied, and studies have established that physicians and patients can reliably measure some of these factors. As discussed below, however, the validity of formal risk-assessment tools to screen unselected patients in primary care has not been established.

#### Risk factors for nonmelanoma skin cancer

A history of skin cancer or of actinic keratoses (AK) and white race are the strongest risk factors for NMSC. Among whites who have no history of skin cancer or AK, sun exposure is the most important risk factor for NMSC. Cumulative sun exposure and possibly intermittent intense sun exposure,^ 41 ^ total time spent outdoors,^ 42 ^ geographic area of residence,^ 43 ^ and lifetime number of severe sunburns^ 43 ^ have all been shown to be associated with higher risk of NMSC. Other risk factors include history of NMSC,^ 44 ^ light-colored or red hair,^42,43^ propensity to sunburn,^43,44^ and family history of skin cancer.

#### Risk factors for melanoma

A high count of common moles larger than 2 mm and the presence of atypical moles are risk factors for melanoma.^45-48^ The risk of malignant melanoma rises with the number of common moles, with relative risks of 1.7 to 1.9 for 11 to 50 moles, 3.2 to 3.7 for 51 to 100 moles, and 7.6 to 7.7 for more than 100 moles, compared with the risk to people with less than 10 common moles.^45,47^ Similarly, the likelihood of melanoma increases several times (OR range, 1.6-7.3) for patients who have 1 to 4 atypical moles compared with patients who have no atypical moles.^45,47^

Other risk factors for melanoma are red or light-colored hair (OR ranged from 1.4 to 3.5); a few (OR 1.9) or many actinic lentigines (OR 3.5); heavy sun exposure (OR 2.63); reported growth of a mole (OR 2.3); skin that does not tan easily (OR 1.98); a family history of melanoma (OR 1.81); light-colored eyes (OR ranged from 1.55 to 1.60); and light-colored skin, (OR ranged from 1.40 to 1.42).^45-47,49,50^ The validity of some risk factors, such as hair color and sun exposure, is lower in the elderly.^45,51^

The relation of sun exposure to melanoma is complex. Since the second edition of the U.S. Preventive Services Task Force's Guide to Clinical Preventive Services was published in 1996, a meta-analysis of case-control studies found intermittent sun exposure was associated with increased risk of melanoma, whereas heavy occupational exposure was found to be slightly protective.^ 52 ^ This meta-analysis included 23 case-control studies on intermittent sun exposure; 20 case-control studies on occupational sun-exposure; and 21 case-control studies on sunburn, all completed by 1992. Intermittent exposure was defined as recreational and vacation sun exposure. Patients who had the highest level of intermittent exposure had nearly twice the risk of melanoma as those who had the lowest intermittent exposure (OR 1.71; 95% confidence interval [CI], 1.54-1.90). Patients who had heavy occupational exposure were at slightly decreased risk compared with those who had low occupational exposure (OR 0.86, 95% CI, 0.77-0.96). Patients who had histories of sunburn (usually a result of intermittent sun exposure) were at increased risk for melanoma (OR was 1.91) compared with those who did not have a history of sunburn. Since the meta-analysis^ 52 ^ was published, an analysis of body site distribution among incident melanoma cases in British Columbia found that intermittent sun exposure was a risk factor for melanoma in individuals younger than 50 years of age.^ 53 ^ A recent case-control study also supported the hypothesis that intermittent ultraviolet exposure is a risk factor for melanoma in younger (<50 years of age) individuals who are susceptible to burning.^ 54 ^

#### Reliability of risk-assessment tools

To be useful as practical tools for classifying patients into risk groups, risk factors must be reliably assessed by patients or physicians. As noted above, the 2 strongest risk factors for melanoma are presence of atypical moles and a large number of common moles.

Several studies have examined the reliability of mole counts by patients, interviewers, and dermatologists. In these studies, having a trained interviewer or the patient count the moles on the arm was not useful as an indicator of total-body mole count,^55-57^ but patients' counts of moles on the trunk or total body were more reliable.^56-58^ In a large, population-based prospective study, 670 Swedish women completed a melanoma risk-assessment questionnaire twice (1-3 years apart). The test-retest reliability of a mole count by the patient was high (kappa = 0.52-0.83).^ 56 ^ In a worksite screening study, 104 of 125 employees correctly placed themselves in high- or low-risk melanoma categories based on a count of total-body moles larger than 5 mm.^ 58 ^ Of 104 lower-risk patients (had fewer than 6 large moles), 92 correctly assessed themselves when compared with a dermatology fellow's assessment. However, only 12 of 21 high-risk patients (more than 6 large moles) correctly assessed themselves. This suggests that patients can screen themselves for large-mole-count risk with specificity of 0.88 and sensitivity of 0.57. Women tended to overcount moles and men tended to undercount moles. Untrained patients cannot accurately distinguish atypical moles from others.^ 59 ^

There is less information on the reliability of self-report of other risk factors. In the Swedish study^ 56 ^ described above, response agreement was good for questions related to hair color (kappa = 0.77) and freckles (kappa = 0.83), but only fair for the number of raised nevi on the left arm (none, 1-3, or >3) (kappa = 0.40) and for sunburn history (kappa = 0.54). In another study, the agreement between patients' self-appraisal of skin characteristics and clinical skin examinations by a physician was reflected in kappa values of 0.67 for freckles and 0.43 for atypical nevi.^ 60 ^

#### Use of risk-assessment tools in practice

The ideal study to measure the accuracy of risk-assessment tools would assign risk levels for patients in a primary care setting, perform total-body skin examinations on patients classified as high and low risk, and then monitor the patients regularly to determine what proportion of incident melanomas occurred in the high-risk group. In fact, no longitudinal studies of the use of a risk-assessment tool in primary care practice have been reported.

Although it was not done in a primary care setting, a large, prospective study validated the use of an initial count of atypical moles in predicting the incidence of melanoma over 5 years.^ 61 ^ In that study, 3,889 employees at the Lawrence Livermore National Laboratory had total-body skin examinations performed by a dermatology fellow specializing in melanoma. Atypical moles were diagnosed clinically by use of previously defined criteria^ 62 ^: ill-defined border; irregular border; irregularly distributed pigmentation; a diameter more than 5 mm; erythema (blanchable in lesion or at edge); and accentuated skin markings. Seven percent of the subjects were in the highest-risk category—that is, had few to many moles that met 5 or more of these criteria. This highest-risk group accounted for 56% (5/9) of the subjects who developed melanoma over 5 years. By contrast, 64% of the patients were in the lowest-risk category—had no atypical moles. This lowest-risk group accounted for 11% (1/9) of the patients who developed melanoma.^ 61 ^

Two recent cross-sectional studies have examined the reliability and practicality of classifying primary care patients into risk groups by use of a standardized, self-administered instrument.^57,60^ Jackson et al^60,63^ applied a melanoma risk-assessment questionnaire^ 64 ^ in 16 randomly selected group practices in Cheshire, United Kingdom. Patients were asked about freckling propensity, number of moles, existence of large moles with irregular borders or colors, and history of sunburn. Their responses were compared with the results of a physical examination by a physician.

Although this study did not track the incidence of melanoma over time, it did provide data on the proportion of primary care patients who would be classified as high risk. A total of 3,105 patients completed the questionnaire. According to their responses, patients were then placed into the following risk groups: marginally increased risk (49.2%); increased risk (26.6%); very increased risk (4.4%); worrying high risk (4.3%). Most patients in the 2 highest-risk groups were unaware of their high-risk status.

In summary, several recent case-control studies confirm earlier evidence that patients who have atypical moles, many (>50) common moles, or both are at increased risk for melanoma. Evidence suggests that patients can count the number of moles 5 mm or larger with reasonable agreement with physicians, but that they cannot accurately distinguish atypical moles from others. No prospective evidence is available linking risk assessment by limited physical examination with incidence of melanoma, but 1 well-done prospective study demonstrated that this strategy could identify a relatively small (<10%) group of primary care patients for more thorough evaluation.

## Consequences of Screening

We examined the consequences of screening reported in 24 recent studies of screening programs (Table 2).^31-34,36,37,61,65-83^ In these studies, we examined (1) how often skin cancer is suspected in individuals who are screened, (2) how often melanoma and NMSCs are diagnosed, (3) how often referrals for follow up and biopsies are performed, and (4) how the type of skin examination, examiner, and compliance affect the yield of screening. This information is summarized in Table 2. We also examined the distribution of thickness and stage of lesions found through screening versus usual care (Table 3) and the adverse effects of screening.

Table 2. Studies of Screening for Skin Cancer

| | | | | | Results (probability)
Author, Year | Population/Setting/ Recruitment | Screening Test, Examiner | Media Target; Reported Risk Factors | Referral Procedure (Patient's PCP, Pt's dermatologist, Study PCP/Derm, Reminder, No Reminder) | Referral (probability) | Suspected melanoma | Confirmed melanoma | Confirmed Melanoma In Situ | Suspected basal cell/squamous cell carcinoma | Suspected actinic keratosis | Negative Screen | Biopsy | Melanoma Biopsy Suspected Melanoma Only | Melanoma Biopsy All Suspicious Lesions
Mass Screening
Jonna et al., ^ 34 ^ 1998 | 464 volunteers, hospital, US; 72% <65, 94% white, 43% male | TSE, dermatologists | Targeted high risk | Patient's PCP or dermatologist, no reminder | | 0.08 | 0.002 | 0.002 | 0.21 | | 0.42 | 0.21 | 0.15 | 0.04
Limpert, ^ 31 ^ 1995 | 247 volunteers, PCP clinic, US; mean age 53.5 (range 4-84), 100% white, 38% male | TSE, family physician | Not targeted | Patient's PCP, Patient's dermatologist, or study PCP, reminder | | | 0.004 | | | | 0.57 | 0.18 | | 0.02
Rampen et al., ^ 37 ^ 1995 | 1961 volunteers, hospital, Netherlands | TSE or Partial skin exam, dermatologists | Targeted high risk | Not specified | 0.1 | 0.003 | 0.003 | 0.001 | 0.02 | | 0.9
McGee et al., ^ 66 ^ 1994 | 279 volunteers, New Zealand; 41% age 40-59, 29% >/= age 60 | Not specified, general medical practitioners | 42% came because of a “worrying mark,” 25% fair skin, 53% history of severe sunburn, 22% fair or red hair, 8% personal history squamous cell carcinoma, 20% family history squamous cell carcinoma | Patient's PCP, no reminder | 0.2 | 0.03 | | | 0.08
Koh et al., ^ 36 ^ 1996 | 282 555 volunteers, hospitals, US | Not specified | Not targeted | Patient's PCP or dermatologist, no reminder | | 0.02 | 0.001 | 0.001 | | | | | 0.11
de Rooij et al., ^ 33 ^ 1995 | 2463 volunteers, hospital, Netherlands; 53% >age 50 | Lesion-specific TSE | Not targeted | Patient's PCP, no reminder | | 0.01 | 0.003 | 0.001 | 0.04 | 0.06
de Rooij et al., ^ 32 ^ 1997 | 4146 volunteers, hospital, Netherlands; 34% >age 50 | Lesion-specific TSE | Targeted high risk | Patient's PCP, no reminder | 0.12 | 0.02 | 0.001 | 0.002 | 0.02 | 0.02 | | 0.08 | 0.17 | 0.03
Hourani et al., ^ 67 ^ 1995 | 351 volunteers, hospital, US; 30% > age 50 | Not specified | Not targeted; 36% reported possible change in mole; residents of county considered to be at extremely high risk for squamous cell carcinoma | Patient's PCP or study PCP | 0.34 | 0.001 | | | 0.1 | 0.1 | 0.52
Katris et al., ^ 68 ^ 1996 | 3379 volunteers, hospital and community, Australia; 35% >/= age 50, 16% >/= age 60 | TSE | Targeted high risk | Not specified | | 0.02 | 0.08 | 0.038 | 0.13 | | 0.83 | | 0.08
Katris et al., ^ 69 ^ 1998 | 256 volunteers, hospital and community, Australia | TSE, nurses and plastic surgeons | Targeted high risk | Not specified | | 0.05 | | | Surgeon: 0.10 Nurse: 0.07 | Nurse: .03 | Surgeon: 0.70 Nurse: 0.60
Rivers and Gallagher ^ 70 ^ 1995 | 1681 volunteers, community, Canada; 16% >/= age 65 | TSE partial skin exam, lesion specific, dermatolotists | Beachgoers; 33% had 2 or more risk factors (blond or red hair, blue or green eyes, propensity to sunburn) | Patient's PCP | | 0.005
Dozier et al., ^ 71 ^ 1997 | 1) 49 volunteers, community, US; mean age 29.7 2) 53 volunteers, hospital, US; mean age 35.4 | 1) partial skin exam 2) TSE dermatologists | 1) Surfers 2) Not targeted | 1) Patient's PCP, reminder 2) Patient's PCP, no reminder | | 1) 0.0 2) 0.0 | | | 1) 0.16 2) 0.02 | 1) 0.41 2) 0.15
Population-Based Screening
Harvey et al., ^72,73^ 1996a, 1996b | 560 random population sample, community, UK; 100% >/= age 60 | Partial skin exam, dermatologists | NA | Patient's PCP, reminder | 0.02 | 0.004 | | | 0.02 | 0.23 | 0.75
Ichihashi et al., ^ 74 ^ 1995 | 4736 consecutive attendees at regional health exam, Japan | Partial skin exam, dermatologists | NA | Study dermatologist, no reminder | | 0 | | | 0.0004 | 0.01
Tornberg et al., ^ 75 ^ 1996 | 1654 random sample, hospital, Sweden; 100% age 40-54 | Not specified, nurses, dermatolotist, oncologist | NA | Study dermatologist, no reminder | 0.05 | 0.09 | 0 | | | | 0.91 | 0.04 | 0
Bergenmar et al., ^ 76 ^ 1997 | 501 random sample, hospital, Sweden; 100% age 40-54 | NA
Casefinding
Ruskiewicz, ^ 77 ^ 1998 | 1000 consecutive patients, optometrist office, US; mean age 66.3 (range 35-96) | Partial skin exam, optometrist | NA; 0.096 had prior diagnosis of squamous cell carcinoma or actinic keratosis | Dermatologist | | 0 | | | 0.1 | 0.003 | 0.9
Whited et al., ^ 78 ^ 1997 | 190 consecutive patients,PCP and specialty clinic, US | Partial skin exam, dermatologists, internists, physician assistants | NA | | | | | | | | | 0.31 | | 0
Worksite Screening
Friedman et al., ^ 79 ^ 1995 | 421 hospital employees, identified as high risk and invited, US; mean age 41 (standard deviation 10.6) | Not specified, dermatologists | Targeted high risk | Patient's dermatologist or study dermatologist | 0.32 | 0.002 | | | 0.02 | 0.09
Schneider et al., ^ 61 ^ 1994 | 3889 laboratory employees, 9% of employees age 20-24, 56% of employees age 70 and older | Not specified, dermatologist | NA; participants classified according to number of atypical moles: 64% none, 29% possible or probable, 7% clear pattern of marked atypical moles
Other
Herd et al., ^ 80 ^ 1995 | 421 patients who have suspected melanoma, specialty clinic, UK | TSE, dermatologists | NA | Study dermatologist | | | | | | | | | 0.036
Marghoob et al., ^ 81 ^ 1995 | 290 patients who have basal cell or squamous cell carcinoma, dermatology practice, US | TSE (melanoma only), dermatologists | All had basal cell and/or squamous cell carcinoma | Study dermatologist | | 0.22 | 0.034 | | | | | | 0.15
van der Spek-Keijser et al., ^ 82 ^ 1997 | Pathology study of all melanomas diagnosed from 1980-92 after regional preventive skin cancer campaign, Netherlands, 95% Caucasians | NA | NA | NA
Veierod et al., ^ 83 ^ 1997 | Follow-up study of 50, 759 participants in health screening from 1977-83, Norway, age 16-56 | NA | NA | NA | | 0.002

Table 3. Thickness of Malignant Melanoma Lesions Found in Screening Studies N (p) in mm

Study | 0.5-1 | 1.0-1.5 | 1.5-2 | 2-2.5 | 2.5-3 | 3-3.5 | 3.5-4 | á4
De Rooij et al.,^ 32 ^ 1997 | 12 (0.92) | 1 (0.08)
Herd et al.,^ 80 ^ 1995 | 82 (0.76) | | 26 (0.24)
Katris et al.,^ 68 ^ 1998 | 4 (1.0) | 0 (0)
Jonna et al.,^ 34 ^ 1998 | 1 (1.0) | 0 (0)
Schneider et al., ^ 61 ^ 1994 | 9 (1.0) | 0 (0)
Koh et al., ^ 36 ^ 1996 | 180 (0.87) | | 22 (0.11) | | | | | 4 (0.02)
Marghoob et al., ^ 81 ^ 1995 | 10 (1.0) | 0 (0)
van der Spek Keijser et al., ^ 82 ^ 1997 | 1451 (0.67) | | 506 (0.23) | | | | 206 (0.10)

There are limitations in using data from these studies to draw conclusions about screening in a casefinding setting. The majority of recently published studies were in a mass-screening setting. To be effective in reducing morbidity and mortality, it is necessary to screen those who are at high risk both for developing skin cancer and for presenting with thicker lesions in the absence of screening. People who attend mass screening are a self-selected group, tend to be more skin-aware, and may come because they are worried about a lesion that they have already discovered and for which they would have sought medical attention anyway.^ 66 ^ Although some mass-screening programs tend to attract a relatively high risk group,^66,67^ others do not, and very high risk individuals, particularly ill elderly individuals, may be underrepresented.^84,85^

### How Often Does Screening Detect Suspicious Lesions?

Rates of suspected melanoma in mass screening, casefinding, and population-based screening ranged from 0 to 9 per 100 people screened, with the most common findings between 1 and 3 per 100. Most studies found from 2 to 10 suspected NMSCs per 100 screened. In some populations, the rate of suspected basal or squamous cell carcinoma was much lower (4 per 10,000 in a Japanese study^ 74 ^) or higher (21 per 100 screened in surfers).^ 71 ^ Studies did not report the prevalence of NMSC by age, and we found no clear difference in prevalence between studies of mostly older individuals and studies of younger individuals.

Suspected AK was generally the most frequent finding in these studies, but rates were variable. The highest rates were 41 per 100 screened in the surfers,^ 71 ^ 23 per 100 in a population sample of people older than 59 years of age,^71-73^ and 15 per 100 in a small mass-screening study.^ 71 ^

### How Often Does Screening Result in a Diagnosis of Cancer?

Rates of confirmed melanoma and melanoma in situ were consistently in the range of 1 to 4 per 1,000 people screened, with 2 exceptions. An Australian study that targeted high-risk people^ 68 ^ had a rate of 8 confirmed melanomas per 100 people screened. The other, a population-based study in Sweden,^ 75 ^ had no confirmed melanomas of 152 suspected melanomas in 1,654 people screened. In the largest screening study, 213 confirmed melanomas were diagnosed in 282,555 people screened, from 4,458 people with lesions suspected of being melanoma.

Eight studies reported the number of histologically confirmed NMSCs.^31,33,34,37,68,74,77,79^ The prevalence varied widely, from 0.05 (of people screened) to 0.0004, with most reporting between 0.01 and 0.05.

### How Often Does Screening Lead to Referral for Follow Up and Biopsy?

Among all the studies that we reviewed, rates of referral for follow-up care of suspicious lesions ranged from 2 to 34 per 100 people screened. Two studies reported rates of compliance with a recommendation to see a physician for follow-up. In 1 mass-screening study,^ 32 ^ 95% of people complied with recommended follow-up, and in a worksite program,^ 79 ^ 45% complied.

As for biopsies, 5 studies reported the number of biopsies performed as a result of screening.^31,32,34,75,78^ In these studies, from 4 to 31 biopsies per 100 people screened were performed. Among patients who had suspected melanoma, from 0% to 17% had a final diagnosis of melanoma. Among all patients who underwent a biopsy, about 3% proved to have a melanoma.

### How Do Characteristics of the Screening Program Affect the Yield of Screening

Certain characteristics of a screening program could affect compliance with follow-up recommendations and, ultimately, with the yield of screening. We consider 3 such characteristics below: (1) the type of skin examination, (2) the recruitment strategy, and (3) the procedure for referring patients for follow up.

#### Type of skin examination

Examiners conducted either total-body skin examination,^31,34,68,69,71,80,81^ partial skin examination (eg, only above the waist or on sun-exposed areas),^71-74,77,78^ examination only of lesions the participant was worried about,^32,33^ or some combination^32,33,37,70,71^ (see Table 2). Overall, compared with partial skin examination or examination of lesions the patient was worried about, the use of total-body skin examination did not appear to increase the rate of confirmed melanomas. In 1 study,^ 84 ^ the question, “In self-selected patients who have noticed a skin lesion, does total-body skin examination increase the likelihood of finding skin cancers?” was specifically addressed. In that study, 2,910 (70%) of 4,146 people screened complained of at least 1 skin lesion. When these lesions were examined, 13 melanomas and 44 NMSCs were diagnosed on biopsy. For these patients who originally came in with specific lesions, an additional total-body skin examination was offered. For the 1,356 patients who went on for a total-body skin examination, no malignant melanomas and 3 basal cell carcinomas were identified. This finding raises doubts about the benefits of conducting total-body skin examinations rather than lesion-specific examinations on everyone.

#### Recruitment strategy

In 12 studies,^31-34,36,37,66-71^ screening involved a media campaign to encourage individuals to seek a skin examination (mass screening) (see Table 2); in 7 of these programs,^32,34,37,68-71^ the media campaign targeted individuals who had suspicious lesions on self-examination or risk factors for melanoma, whereas 6 were not targeted.^31,33,36,66,67,71^ We found no systematic relation between these characteristics and the proportion of individuals eventually diagnosed to have cancer. However, most studies did not report sufficient information to determine how well targeting succeeded in recruiting a high-risk population, and the description of the study samples were not adequate to exclude differences in baseline risk factors between studies as the main cause of observed differences in results.

#### Procedure for referring patients for follow-up

In most studies the patient was instructed to see a primary care clinician or a dermatologist for follow up of suspicious lesions. In some studies, the patient's physician was contacted directly or the patient was sent to a study dermatologist. Some studies used reminders such as letters to the patient.

Although not depicted in the Table 2, we collected information on compliance rates for screening, follow up, and biopsy when possible. Three population-based studies invited a target group of people to be screened and reported response rates.^38,72,73,75,85^ In these studies, between 60% and 70% of those invited attended screening. One worksite screening program that identified and invited high-risk people reported a lower response rate of 19%.^ 78 ^ The mean age of this sample was somewhat lower than that in the population-based studies.

### Compared with Usual Care, How Much Earlier Does Screening Detect Skin Cancers and Precancerous Lesions?

Eight studies^32,34,36,61,68,80-82^ reported the thickness of melanoma lesions found through screening (Table 3). In 4 studies,^34,61,68,81^ all detected melanoma lesions were 1.0 mm or thinner, and in a fifth study,^ 32 ^ 92% were 1.0 mm or thinner. In 3 other studies that used 1.5 mm as the cutoff, the proportion of melanomas 1.5 mm or less was 67% to 87%.^36,80,82^

No study of screening directly followed an unscreened population to compare the distribution of thickness or the stage of melanomas detected. Nonetheless, the proportion of thin melanomas is clearly higher in screening programs than in usual care. SEER data from 1992 to 1994 were analyzed. (The SEER registry routinely reports the TNM stage, but not the thickness, of melanomas at the time of diagnosis. From 1989 to 1994, 81% of melanomas detected through usual care were localized, 9% regional, 4% distant, and 6% unstaged.^ 3 ^) The results of this analysis are as follows: 57% of melanomas were thinner than 0.76 mm, 23% were 0.76 to 1.5 mm, 15% were 1.51 to 3.99 mm, and 5% were 4.0 mm or thicker.^ 36 ^ Moreover, in population-based studies, the incidence of melanoma detected by screening is higher than base rates, and the increase is almost entirely attributable to thin melanomas.

### What Is the Effect of Screening on Patients' Skin Knowledge and Self-Care Behavior?

Advocates of screening note that having a total-body skin examination could improve morbidity and mortality indirectly by promoting skin-awareness and sun-protection measures. In a follow-up study to the American Academy of Dermatology's Melanoma/Skin Cancer Screening Programs (see the first reference to Koh et al., 1996 in Table 1), 1,049 self-selected participants who had skin lesions were surveyed 2 months after undergoing a total-body skin examination. Among the 643 respondents, the proportion of individuals who regularly checked their skin increased from 60% to 84% after screening.^ 86 ^

### What Are the Adverse Effects of Screening?

Patient unease is a possible adverse effect of screening, despite total-body skin examination being noninvasive. In 1 study of self-selected participants found to have skin lesions by screening, patient satisfaction was high (81%), and only a small proportion of patients reported embarrassment or discomfort as a result of screening (4.8%).^ 86 ^

False-positive skin examination results might also be considered an adverse effect. In any screening program, most lesions referred for biopsy because of clinical suspicion of skin cancer are false positives. No studies exist by which to judge the extent of harm, if any, related to these tests.

Misdiagnosis is another potential adverse effect of screening. It is known to occur, but no studies have been done on its rate of occurrence. The diagnosis of melanoma has a serious emotional and financial effect for the patient, and even when the melanoma is very thin and has an excellent prognosis, obtaining insurance can be very difficult.^ 8 ^ Critics worry that, if screening becomes widespread, pathologists may set the threshold low for diagnosing borderline lesions as melanoma, since the risk to the patient and the potential legal cost to the pathologists for missing melanoma are overwhelming.^ 11 ^ However, there are no data about the frequency with which misdiagnosis occurs in community practice settings. The effects on diagnostic criteria of widespread screening are hard to predict, but uncertainty about these effects should be considered when one weighs a recommendation to screen.

Some experts consider diagnosis of common, nonmalignant skin lesions found incidentally in screening to be a costly adverse effect of screening. Screening detects large numbers of benign skin conditions, especially seborrheic keratoses, which are very common in the elderly. Detection of these lesions could be considered an adverse effect of screening if it leads to additional biopsies and unnecessary or expensive procedures. Although this has been shown to occur in usual care,^ 87 ^ none of the screening studies examined the rate at which this occurred.

### Is There Direct Evidence That Screening for Skin Cancers Leads to Reduced Morbidity and Mortality?

No data exists providing direct evidence that screening for skin cancer leads to reduced morbidity and mortality. No randomized trials or case-control studies of screening for skin cancer have been completed. Well-done, frequently cited observational studies of the relation between early detection and mortality have been done,^ 88 ^ but in such studies the effect of promoting primary prevention and self-examination cannot be distinguished from that of routine screening in patients seeing the physician for unrelated reasons.^ 89 ^ The lack of data reflects the lack of population-based programs that focus on routine total-body skin examination by a physician.

The absence of randomized trials is also not surprising since melanoma is relatively rare in the general population. A recent review by Elwood^ 90 ^ examined the options for conducting a randomized trial of screening in detail. Elwood calculated that, to have a 90% chance of detecting a one-third reduction in mortality, a trial of screening with total-body skin examination in the general population 45 to 69 years of age would require 400,000 subjects in each group. Put differently, approximately 21,000 people would need to be screened to prevent 1 death.

An alternative would be to conduct a trial in patients classified as high risk by means of a risk-assessment questionnaire. Using this approach, Elwood^ 90 ^ assumed that 7% of the population would be classified as high risk; 35% of all melanomas occur in this high-risk group; 60% of patients complete the questionnaire; and 80% of the high-risk patients would comply with total-body skin examination. He calculated that, to have a 90% chance of detecting a one-third reduction in mortality, 6 million questionnaires would need to be administered to enroll 100,000 high-risk subjects in each group.

In fact, a trial involving 600,000 subjects has begun in Australia.^ 90 ^ It is expected that it will take 9 more years to complete.

## Effectiveness of Screening in Early Detection and Early Treatment

Screening in a population is justified if there is evidence that early detection and treatment improve outcomes such as mortality and quality of life. Other considerations include consequences of false-negative and false-positive tests, acceptability of the test, and the risks of screening and of treatment.

### Does Treatment of Nonmelanoma Skin Cancer Found by Screening Reduce Morbidity and Mortality?

Early treatment of basal and squamous cell carcinoma might reduce morbidity and disfigurement, but no studies have evaluated whether screening improves the outcomes of these cancers. Basic information, such as the proportion of Medicare patients who have NMSC who suffer disfigurement or death, is lacking. If we assume that 20% of squamous cell cancers in the elderly are either lethal or disfiguring (assumes a prevalence of 0.025 for men and women combined) and that screening would reduce this by 50%, approximately 400 patients would need to be screened to prevent 1 lethal or disfiguring case. These calculations, while theoretical, do suggest that screening is potentially beneficial and that a trial of early detection in the elderly should examine outcomes in NMSC rather than just in melanoma.

### Does Early Detection and Treatment of Melanoma Found by Screening Reduce Morbidity and Mortality?

Well-designed observational studies can provide persuasive information about the effect of early detection on mortality. For some cancers, notably colon cancer, observational studies make a convincing case for the effectiveness of early detection, even in the absence of randomized controlled trials. Such a conclusion must be based on data that link actions taken as a result of screening to health outcomes.

In the absence of randomized trials and case-control studies of screening or of early treatment, the inference that earlier treatment as a result of screening improves health outcomes must rely on 3 lines of indirect evidence: (1) a case-control study^ 46 ^ in which skin self-examination reduces the incidence of lethal melanoma, (2) comparison of the stages of cancers and mortality found in screening^88,92^ with those found in usual practice, and (3) evidence from studies of the consequences of delay in diagnosis. These are summarized below.

#### Case-control study of self-examination

Although there are no case-control studies of screening, 1 case-control study^ 46 ^ has examined the effect of skin self-examination on mortality from melanoma. In this study, 650 incident cases of melanoma in 1987-1989 were identified through the Connecticut Tumor Registry and compared with randomly selected, age- and sex-matched controls. After 5 years of follow-up, cases were classified as lethal if the individual died or had distant metastases.

A structured questionnaire was used to assess skin self-examination attitudes and behavior. The question used to determine skin self-examination in this study was “did you ever (in your life) carefully examine your own skin? By this I mean actually check surfaces of your skin deliberately and purposely?” Based on subjects' responses to this and related questions, 13% of the cases and 17.5% of the control subjects were classified as careful or rigorous examiners, and an additional 57.4% of the cases and 66.7% of control subjects were classified as casual examiners. The questionnaire also assessed potential confounding factors, such as risk factors for skin cancer, but did not assess general health behaviors, such as diet, exercise, and medical-care-seeking behavior that might affect the risk of cancer and the likelihood of early detection.

The investigators performed 2 multivariate analyses: 1 for primary prevention, and 1 for secondary prevention. In the first analysis, after adjustment for sun exposure, skin color, the number of nevi, and other risk factors, skin self-examination was negatively associated with incidence of melanoma (OR 0.66, CI, 0.44-0.99).

In the second analysis, after adjustment for confounding risk factors, skin self-examination was associated with a reduced risk of lethal melanoma (OR 0.37, CI, 0.16-0.84). Survival analysis comparing patients who practiced skin self-examination with those who did not suggested that, after an average of 5.4 years, self-examination was associated with a lower probability of lethal melanoma. The authors noted that the shape of the survival curves—the curve for the self-examination group plateaus after 3 years, whereas survival continues to decrease to 5 years in the patients who did not practice self-examination—offers some reassurance that the observed benefit is caused by actual improvement in survival rather than to lead-time bias.

As noted by the authors, this case-control study provides suggestive, rather than definitive, evidence for the effectiveness of skin self-examination. More direct evidence is needed to link self-examination behaviors to specific actions that could reduce the incidence or lethality of melanoma. To prevent melanoma, self-examination on the part of the patient must lead to actions—such as identification of a suspicious lesion, self-referral to the physician, earlier treatment of precancerous lesions, and health behavior changes—to prevent the development of new melanomas. Although the study indicates that patients who practiced self-examination had undergone more biopsies than those who had not, it does not report the frequency of these intermediate steps or whether their frequency was different enough from that of other patients to explain the observed differences in outcome.

Apart from concerns about the strength of the study design, how relevant is a study of skin self-examination to screening by primary care providers? If skin self-examination prevents death from melanoma, it may be more likely that examination by a physician could also prevent deaths, especially if examination by a physician promotes more accurate self-examination. In fact, casefinding by a physician might be expected to be more effective because it reaches patients, especially elderly men, who are at high risk and are the least likely to practice self-examination effectively^ 91 ^ or to respond to an invitation or health-promotion campaign. However, self-examination occurs much more frequently (monthly, on average, in the case-control study) than screening by a physician, and by means of self-examination, patients can note findings—in particular, changes in size, border, or color of lesions—that cannot be recognized easily by infrequent examinations by physicians. Nevertheless, this case-control study^ 46 ^ provides the strongest available evidence that early detection of melanoma reduces mortality.

#### Comparing stages of cancers and mortality found in screening with those found in usual practice

Advocates cite the results of public information campaigns in Australia^ 92 ^ and in the United Kingdom^ 88 ^ as evidence of the potential benefits of screening. In Australia, public information campaigns have promoted sun-protection behaviors and early detection for more than 15 years. Melanoma mortality, which had increased for decades, reached a plateau in 1985 and, in recent years, has decreased slightly.^ 92 ^ It is thought that this trend is related to skin health-promotion activities, including primary prevention and self-examination; however, because it is not a prominent feature of these campaigns, it is not possible to determine what role, if any, screening by physicians has played.

In the United Kingdom, registry data were used to compare rates of invasive melanoma before and after public information campaigns to promote early detection of skin cancers. In the west of Scotland, community-based, skin health-promotion campaigns compared melanoma thickness and mortality before and after implementing a public information campaign and rapid referral system in 1985.^ 88 ^ The number and proportion of thin melanomas diagnosed yearly in the population increased immediately afterward. The response to the public information campaign was stronger in women than in men. In women, within 2 years the rate of diagnosis of thick melanomas (>3.5 mm) began to decrease, and within 5 years sustained decreases in thick melanomas and in melanoma mortality were observed. In men, the rate of diagnosis of thick melanomas did not change, and the melanoma mortality rate rose. As in Australia, the role of screening by physicians in these results is unclear.^ 93 ^

A subsequent implementation of a similar program in 7 British districts failed to replicate these results.^80,93,94^ The incidence rates of both thin and thick melanomas increased during the public information campaign (1987-1989) and have remained higher than before the program began.

In contrast to these health-promotion efforts, mass-screening programs cannot be evaluated with population-based registries. Mass screening increases the proportion of melanomas detected in an early stage (see Table 3), but the significance of this finding is unclear. Survival is strongly related to lesion thickness at the time of resection, but it is difficult to know the extent to which comparison of the distribution of the stage of cancers found by screening with those found in usual care is affected by lead-time bias or length bias. The natural history of melanoma, and in particular the significance of the many additional thin melanomas found in screened populations, is another source of uncertainty.

#### Retrospective studies of the consequences of delay in diagnosis

The argument for screening would be strengthened if evidence pointed to a consistent relation between a delay of diagnosis and the thickness of melanoma. Nine case series examined the causes and consequences of apparent delay in the diagnosis of melanoma. The validity of these studies is questionable because all of them assessed delay retrospectively. The 2 largest studies, 1 from Scotland and 1 from Australia, found no relation between delay in diagnosis and tumor thickness.^17,80^ The Australian study found that male sex, nodular melanoma, and location on the head and the neck (but not delay) were associated with thick melanoma.

Five studies, which were performed in specialty clinics, observed patients who had melanoma of the hand, foot, eye, penis, or nailbeds.^95-99^ In these studies, misdiagnosis was a common cause of delay in treatment. Effects of delay on tumor thickness or survival were reported in 3 of the studies, and the results were inconsistent. In a study of 83 patients who had acral melanomas, 17 of 33 subungual melanomas and 10 of 50 palmoplantar melanomas were clinically misdiagnosed by physicians.^ 95 ^ Misdiagnosis caused a median delay of 12 months in the diagnosis of palmoplantar melanomas and of 18 months in the diagnosis of subungual melanomas. Delay in diagnosis was associated with increased tumor thickness, more advanced stage at time of melanoma diagnosis, and a lower estimated 5-year survival rate (15.4% versus 68.9% for palmoplantar; 68.5% versus 90.9% for subungual). In another series of 140 patients who had melanoma of the foot, delay in diagnosis had no effect on clinical outcome.^ 99 ^ Another series of 102 consecutive melanoma patients found no relation between delay in diagnosis and tumor thickness.^ 100 ^

Two recent case series from specialized clinics in major referral centers reported that lesions detected by physicians were thinner than those detected by patients.^101,102^ In 1 of these cases,^ 101 ^ 24 of 102 consecutive patients had physician-detected melanomas; the median thickness was 0.23 versus 0.9 mm in self-detected melanomas. Of the 24 physician-detected melanomas, 11 were in situ. In the other study,^ 102 ^ 172 of 590 consecutive patients had physician-detected melanomas; these were significantly thinner, but the difference was not as striking (0.9 versus 1.3 mm).

The latter study^ 102 ^ also carefully examined the relation between melanoma thickness and delay either in seeking medical advice or after seeking medical care, and concluded that poor prognosis was due to rapidly growing tumors rather than to delays. They examined 4 time intervals:

1. From the time the patient first noticed a lesion to the time they considered it to be suspicious;
2. From the time that the patient considered the lesion suspicious to the time that the patient saw a physician;
3. From the time that the patient saw a physician to the time that the physician proposed removal; and
4. From the time that the physician proposed removal of the lesion to the time of surgical resection.

In the 418 patients who had self-detected cancers, the first, the third, and the fourth intervals were not associated with tumor thickness. Not surprisingly, once a lesion was recognized as being dangerous, patients who had thicker lesions sought medical attention more quickly (ie, for the second interval, thinner lesions had the longest delay). In a subgroup of 247 patients who reported a delay of less than 5 years between the time they noticed the lesion and the time they believed it to be dangerous, the time between noticing a lesion and considering it dangerous was longest for lesions 1.5 to 2.99 mm thick, but the time was shorter for lesions thicker and thinner than that.

## Costs and Cost Effectiveness

A CE analysis^ 103 ^ of screening for malignant melanoma found that the average projected discounted life expectancy without screening was 15.0963, versus 15.0975 with screening. This difference is equivalent to an increase of approximately 9 hours per person screened or 337 days for each person who had melanoma.

Assuming that a screening examination by a dermatologist costs $30, the incremental CE ratio was $29,170 per year of life saved. The CE ratio was unexpectedly low because, in the model, savings from prevention of late-stage melanomas offset most of the costs of screening. Thus the key assumptions in the model, affecting the calculation of both effectiveness and cost, were that the proportion of late-stage melanomas would decrease from 6.1% without screening to 1.1% with screening. Similarly, the model assumed that invasive cancers would decrease from 70.3% to 58.1% and that melanomas thicker than 1.5 mm would decrease from 20.1% to 12.6% of invasive melanomas. These assumptions are based on comparison of cross-sectional data on the stages of melanoma in individuals who attended the American Academy of Dermatology's mass-screening programs with data on usual care from the SEER registry.^ 3 ^