# Introduction

In the United States in 1999, approximately 1 million new cases of basal cell and squamous cell carcinoma, and approximately 44,000 new cases of malignant melanoma, were expected to be diagnosed.^ 1 ^ Malignant melanoma is often lethal, and its incidence in the United States has increased rapidly over the past 2 decades. Nonmelanoma skin cancer is seldom lethal, but, if advanced, can cause severe disfigurement and morbidity.

Advanced melanoma and invasive squamous cell carcinoma of the skin occur most often in the elderly, especially elderly men. Early detection and treatment of melanoma might reduce mortality, whereas early detection and treatment of squamous cell carcinoma and basal cell carcinoma might prevent major disfigurement and reduce the need for expensive reconstructive surgery and, to a lesser extent, prevent mortality.

In this paper, we examine published data on the effectiveness of screening for skin cancer by primary care physicians. Specifically, we examine the accuracy of the tests used for screening, the diagnostic yield of screening in the general population, and the evidence that treatment of cancers found by screening improves outcomes.

We use the term screening to denote a systematic effort to detect unsuspected disease by either performing a total-body skin examination or assessing the risk for skin cancer in all patients seen in the primary care setting. We did not examine the effect of skin surveillance in children or in patients who had familial syndromes or who have a history of medical treatments such as UV-A radiation or immunosuppressive therapy that confer a high risk of melanoma. Monitoring in these very high-risk patients was judged to be beyond the scope of this report.

We also did not examine the value of routine diagnosis and treatment of skin cancer in clinical practice. In everyday primary care, the clinician sees the skin of every patient's face; in many cases, the clinicians also see the skin of their patients' extremities, chest, and back. Clinicians almost universally agree that incidental discovery of a suspicious skin lesion should prompt an evaluation, including a skin biopsy and a thorough inspection of the skin. The data we reviewed about screening do not address the value of attention to the skin as part of conscientious clinical care.

Other strategies to prevent skin cancer, such as promotion and counseling to reduce risky health behaviors and skin self-examination, are not addressed in this review. Many studies combine screening with health-promotion programs, and screening may itself contribute to primary prevention, because it provides the primary care provider with an opportunity to increase awareness of skin cancer and to demonstrate examination techniques that patients can apply themselves.

## Epidemiology and Burden of Suffering

### Melanoma

In the United States, the lifetime risk of being diagnosed with melanoma is 1.74% in white men and 1.28% in white women. The lifetime risk of dying of melanoma is 0.36% in white men and 0.21% in white women. According to data from the California Cancer Registry, from 1988 to 1993, average, annual, age-adjusted incidence rates per 100,000 population were 17.2 for men and 11.3 for women for non-Hispanic whites; 2.8 for men and 3.0 for women for Hispanics; 0.9 for men and 0.8 for women for Asians; and 1.0 for men and 0.7 for women for non-Hispanic blacks.^ 2 ^

Between 1973 and 1995, the incidence of melanoma in the United States increased approximately 4% per year, from 5.7 per 100,000 in 1973 to 13.3 in 1995, according to data from the Surveillance, Epidemiology, and End Results (SEER) program of the National Cancer Institute^ 3 ^; by comparison, the overall rate in Queensland, Australia is 55 per 100,000.

The elderly and, in particular, elderly men, bear a disproportionate burden of morbidity and mortality from melanoma. As shown in Figure 1, older men have the highest incidence of invasive melanoma. In 1995, the age-adjusted incidence rate was 68.7 per 100,000 in white men older than 65 years of age and 30.6 in white women older than 65 years of age. Men older than 65 years of age, who constitute 5.2% of the U.S. population, have 22% of newly diagnosed malignant melanomas each year; women older than 65 years of age, who constitute 7.4% of the population, have 14%.

Figure 1. Melanoma age-specific incidence and mortality

Melanoma in the elderly is not only more common but also more lethal than in younger populations. In Australia, where for many years public education about melanoma has been intense, 75% of thick (>3 mm) melanoma lesions and 75% of deaths occur in people older than 50 years of age, and 50% of deaths occur in men older than 50 years of age.^ 4 ^ Similarly, in the United States, approximately 50% of deaths from melanoma are in men older than 50 years of age.^ 3 ^ Figure 2 shows that melanoma in the elderly, particularly in elderly men, is more likely to be detected in advanced stages. For men in their 40s, for example, there were 6 times as many cancers diagnosed as there were deaths; for men in their 70s, there were approximately 4 times as many cancers diagnosed per death. Some experts argue that the elderly, particularly elderly men, may have lower skin awareness and lower rates of skin self-examination, resulting in higher rates of advanced melanoma.^ 5 ^

Figure 2. Ratio of incidence to mortality by age

Overall mortality from melanoma has increased. Between 1973 and 1995, overall mortality rates for melanoma increased by 1.3% per year, from 1.6 per 100,000 in 1973 to 2.2 in 1995. Nearly all of the increase was in white men (2.2%-3.6%), especially older white men. Currently, 5-year survival for melanoma has improved to 88% from the 80% it was 20 years ago. During this time, the rate of diagnosis of early or thin melanoma increased sharply, but so did the incidence of thicker (>3 mm) melanomas.^ 6 ^ According to data from the California Cancer Registry, among men, melanoma is diagnosed after it has metastasized to a remote site for 15% of Hispanics, 13% of Asians, and 12% of blacks, compared with 6% of non-Hispanic whites. Among women, diagnosis is late stage in 7% of Hispanics, 21% of Asians, and 19% of blacks, compared with 4% of non-Hispanic whites.^ 2 ^

Several experts have commented that changes over time in ascertainment, diagnostic criteria, self-examination, and registry procedures make it difficult to draw reliable inferences about the effectiveness of early detection from epidemiologic data.^6-8^ In an analysis of trends in Australia and New Zealand, Burton and Armstrong^ 9 ^ noted that, although there has been a huge increase in the incidence of very thin melanomas, the incidence of thick melanomas has increased as well. Some experts interpret this to mean that increased surveillance in the population may detect a relatively unaggressive, unimportant type of thin melanoma.^8-11^ According to this view, increased detection of these very thin, nonmetastasizing melanomas would increase the incidence and 5-year survival rates of melanoma but would have little effect on mortality. However, in contrast to prostate and thyroid cancers, in which a large reservoir of unaggressive cancers are known to exist, longitudinal studies of melanoma have not established the frequency or existence of histologically malignant, but behaviorally benign, melanoma in the general population.

### Nonmelanoma Skin Cancer

Rates of nonmelanoma skin cancer (NMSC) in the United States are difficult to determine because these cancers are not typically tracked by cancer registries. Cancer registries in Denmark and Canada do include NMSC. In British Columbia, Canada, the age-standardized incidence rate for basal cell cancer in men was 70.7 per 100,000 in 1973, increasing to 120.4 per 100,000 in 1987.^ 12 ^ In women, basal cell cancer incidence rose from 61.5 to 92.2 per 100,000 over the same period. Squamous cell cancer incidence rose from 16.6 to 31.2 per 100,000 in men and from 9.4 to 16.9 per 100,000 in women.

A survey of 1 large health plan in Albuquerque, NM, which was not population-based, found age-standardized basal cell cancer rates of 1,073 per 100,000 in non-Hispanic white men and 415 per 100,000 in non-Hispanic white women. Squamous cell cancer rates were 214 and 50 per 100,000 for non-Hispanic white men and women, respectively.

Rates are much lower in other U.S. studies. A population-based study in Rochester, Minn, covering the years 1976 to 1984, found that age-standardized incidence rates per year of basal cell cancer were 175 per 100,000 in men and 124 per 100,000 in women.^13,14^ Rates of squamous cell cancer were 63.1 per 100,000 in men and 22.5 in women. Rates of both basal cell cancer and squamous cell cancer rose with advancing age. A population-based study of NMSC in New Hampshire suggests that incidence rates are increasing. This study looked at incidence rates for 2 time periods, 1979-1980 and 1993-1994.^ 15 ^ In men, the age-adjusted incidence of basal cell cancer increased from 170 per 100,000 in 1979-1980 to 310 per 100,000 in 1993-1994, and in women, basal cell cancer incidence rose from 91 to 166 per 100,000. For squamous cell cancer, incidence rates in men rose from 29 to 97 per 100,000 over the 2 periods, and in women squamous cell cancer incidence rose from 7 to 32 per 100,000.

## Natural History, Diagnosis, and Staging of Skin Cancer

### Melanoma

There are 4 major subtypes of melanoma: superficial spreading, nodular, lentigo maligna, and acral lentiginous.^ 16 ^ Superficial spreading melanoma, the most common subtype in whites, is usually diagnosed in an early (thin) stage, before there is a high risk of metastasis. Nodular melanoma is the second most common subtype in whites. Nodular melanomas are difficult for patients to find and are usually diagnosed in a more advanced stage.^ 17 ^ The natural history of nodular melanoma is controversial.^ 18 ^ The prevailing view is that nodular melanoma is characterized by rapid, early vertical growth and lack of an identifiable radial growth phase.

To determine which skin lesions are suspicious for melanoma, some clinicians in the United States use the ABCD checklist for detecting melanoma.^ 19 ^ In this system, pigmented lesions are classified as suspicious for melanoma if they have an asymmetric shape (A); an irregular border that is scalloped, uneven, or ragged (B); varied color (C); or a diameter larger than 6 mm (D). Some add a fifth criterion (E) for elevation or enlargement. Some clinicians in the United Kingdom use a 7-point checklist that consists of change in mole size, shape, and color; crusting or bleeding; sensory change; and a mole larger in diameter than 7 mm.^ 19 ^

Once a lesion suspected of being cancerous is identified, one of several biopsy techniques is employed to obtain tissue for analysis. The pathologic diagnosis of suspicious pigmented lesions can be difficult, especially for borderline and in situ neoplasms. In 1 recent study, 4 histopathologists evaluated 140 slides and classified each lesion as melanoma or other pigmented lesion; they were in agreement on diagnoses for 74% (kappa = 0.61) of the slides.^ 20 ^ Similarly, when 8 expert pathologists (recruited based on publications and reputations) classified 37 slides as benign, malignant, or indeterminate, they had almost complete agreement—only one discordant—on 62% (kappa = 0.50) of the cases.^ 21 ^

Stage is the most important prognostic factor in melanoma. The American Joint Commission on Cancer classification, which is based on the tumor, node, metastasis (TNM) system, describes the stages from I to IV. Stage I is a primary tumor less than 1.5 mm in thickness with no regional lymph-node metastases; Stage II is a primary tumor 1.5 to 4.0 mm in thickness with no regional lymph-node metastases; Stage III is any primary tumor with regional lymph-node metastases or in-transit metastases; and Stage IV is any primary tumor with distant metastases.^ 22 ^ According to SEER data through 1995, 5-year relative survival rates for localized, regional, and distant disease were 96%, 59%, and 12%, respectively.^ 3 ^

The thickness of the primary tumor is the strongest predictor of prognosis. To measure thickness of a melanoma, the pathologist uses a device called a micrometer, which is similar to a small ruler under the microscope. This technique is called the Breslow measurement.^ 23 ^ In general, melanomas less than 1 mm in depth have a very small chance of metastasizing. For those who have melanomas between 1.5 and 4 mm, 5-year survival is approximately 70%; for those who have melanomas thicker than 4 mm, 5-year survival is approximately 45%. Thickness of the melanoma also guides the choice of therapy.

### Nonmelanoma Skin Cancer

Basal cell carcinoma and squamous cell carcinoma are the most common forms of skin cancer. Despite their very high incidence, they account for fewer than 0.1% of cancer deaths. There are several morphologic types of basal cell cancer, such as nodular, ulcerative, and plaquelike; but regardless of type, metastasis is very rare. Basal cell carcinoma can be locally destructive and frequently recurs.

Squamous cell cancers usually occur in chronically sun-exposed areas of the skin, especially on the face, ears, or backs of the hands. Squamous cell cancer has the potential to metastasize and may account for as much as 20% of deaths from skin cancer. Nonmelanoma skin cancer accounts for the majority of skin cancer deaths in very elderly men and blacks.^ 24 ^ A large primary tumor (>2 cm) is associated with an increased risk of metastasis.

There are few data on the natural history of squamous cell cancer in the general population. Most studies of the natural history of squamous cell cancer have been done in selected patients who have an elevated risk owing to environmental exposures, such as Psorolen plus UV-A radiation for psoriasis.^25,26^ Although there is strong suspicion on clinical grounds that advanced locally invasive or metastatic squamous cell cancers result from medical neglect, careful studies of the rate of progress of squamous cell cancers in the elderly are lacking.

## Previous Task Force Recommendations and Recommendations of Others

Current recommendations of professional societies regarding screening for skin cancer vary. The U.S. Preventive Services Task Force^ 27 ^ (1996) and the American College of Preventive Medicine recommend total-body skin examination in high-risk individuals who see a physician for other reasons, but they do not recommend routine screening. The American Cancer Society recommends skin examination every 3 years for people between 20 and 40 years old and yearly for anyone older than 40 years of age. All of these organizations advise some form of public or patient education to change behaviors that may increase the risk of skin cancer and to increase the likelihood of early self-detection.

## Analytic Framework and Key Questions

Before the consequences of screening can be estimated, a necessary first step is to formulate the screening problem by specifying the target population that will be reached by screening; the screening tests, follow-up tests, and treatments that will be used; and the types of outcomes that will be affected by screening.

The analytic framework in Figure 3 shows the interventions, intermediate outcome measures, and health outcome measures we examined. The accompanying key questions (Figure 4) correspond to the numbered arrows in the analytic framework and articulate the main questions that guided our literature review and that we address in Chapter 3, “Results,” of this review.

Figure 3. Analytic framework

Figure 4. Key questions in analytic framework

Accuracy of Screening

Arrow 1

Is there direct evidence that screening for skin cancers leads to reduced morbidity and mortality?

Arrow 2a

1. How accurate is total-body skin examination in the detection of cancer?
2. How accurate are risk-assessment tools as a screening test for skin cancer?

Consequences of Screening

Arrow 2b

1. How often does screening detect suspicious lesions?
2. How often does screening result in a diagnosis of melanoma?
3. How often does screening result in a diagnosis of nonmelanoma skin cancer?
4. How often does screening lead to referral for follow up and biopsy?
5. How do characteristics of the screening program affect the yield of screening?
6. Compared with usual care, how much earlier does screening detect skin cancers and precancerous lesions?

Arrow 2c

What is the effect of screening on patients' skin knowledge and self-care behavior?

Arrow 3

What are the adverse effects of screening?

Effectiveness of Early Treatment

Arrow 4a

Does treatment of nonmelanoma skin cancer found by screening reduce morbidity and mortality?

Arrow 4b

Does treatment of malignant melanoma found by screening reduce morbidity and mortality?

We studied screening in the general adult population and in the elderly, the group with the highest prevalence and mortality from skin cancer. We have included studies of both mass screening and casefinding programs to detect and treat melanoma and NMSC in the general population. We sought studies of the accuracy of 2 methods of screening for skin cancer (Figure 3, Arrow 2[a]): (1) performing a total-body skin examination in all patients seen in the primary care setting and (2) assessing the risk for skin cancer in all patients, followed by a total-body skin examination in those found to be high risk. The primary aim in using these strategies is earlier detection of melanoma; with examinations that are confined to areas not covered by clothing, a high proportion of potentially lethal cancers is likely to be missed.^ 28 ^ To assess the accuracy of these methods, both for melanoma and for NMSC, we sought studies that used these initial tests to screen in the general population or in the elderly and then confirmed positive screening test results with skin biopsy results.

We examined the consequences of screening on detection of squamous cell carcinoma, basal cell carcinoma, and malignant melanoma (Figure 3, Arrow 2[b]). Specifically, we examined how often patients are found to have skin cancer, how often suspected skin cancer is confirmed by biopsy, and at what stage cancer is found.

In addition to early detection, screening itself might confer a potential benefit by improving patients' knowledge and self-examination skills. We therefore sought evidence about the effect of screening on patients' health beliefs and practices regarding skin cancer prevention (Figure 3, Arrow 1[c]). We also considered the adverse effects of screening, including the frequency and the consequences of false-positive examinations or biopsies and the diagnosis of noncancerous lesions that may not require treatment (Figure 3, Arrow 3).

In considering outcomes, we sought, but did not find, direct evidence from controlled studies of the effect of screening on health outcomes (Figure 3, Arrow 1) such as mortality and quality of life. In the absence of randomized trials of screening, these links may be made by studies of the association between a delay of diagnosis and the outcome of cancer or of screened versus nonscreened populations.

Note that we did not examine the effectiveness or the adverse consequences of various treatments for skin cancer. We investigated the evidence that detection of earlier cancers by screening in the general population is associated with reduced mortality and morbidity.