# Appendix 1. Strategy for Skin Cancer Search

1. 1 skin neoplasms
2. exp mass screening
  - genetic screening
  - mass chest x-ray
  - multiphasic screening
  - vision screening
  - mandatory screening
3. screen$.tw. (Text word taken from title and abstract of article)
4. exp physical examination
  - self-examination
  - skinfold thickness
5. exp neoplasms metastasis
  - lymphatic metastasis
  - neoplasm circulating cells
  - neoplasm seeding
  - neoplasms, unknown primary
6. neoplasm recurrence, local
7. recurrence
8. exp morbidity
  - incidence
  - prevalence
9. exp sensitivity and specificity
  - predictive value of tests
  - ROC curve
10. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. skin neoplasms/mo (mortality)
12. skin neoplasms/ep (epidemiology)
13. 10 or 11 or 12
14. 1 and 13
15. limit 14 to human
16. limit 15 to english language
17. looked at english abstracts for foreign language articles