# References

1 Jonas DE, Feltner C, Amick HR, . Screening for asymptomatic carotid artery stenosis: a systematic review and meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;161(5):336–46. PMID: 25004169. 10.7326/M14-0530 25004169
2 Jonas DE, Feltner C, Amick HR, . Screening for Asymptomatic Carotid Artery Stenosis: A Systematic Review and Meta-Analysis for the U.S. Preventive Services Task Force. Evidence Synthesis, No. 111. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014.
3 LeFevre ML, U.S. Preventive Services Task Force. Screening for asymptomatic carotid artery stenosis: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(5):356–62. PMID: 25003392. 10.7326/M14-1333 25003392
4 McCarron M, Goldstein L, Matchar D. Screening for asymptomatic carotid artery stenosis. https://www.uptodate.com/contents/screening-for-asymptomatic-carotid-artery-stenosis. Accessed: Dec 15, 2019.
5 Flaherty ML, Kissela B, Khoury JC, . Carotid artery stenosis as a cause of stroke. Neuroepidemiology. 2013;40(1):36–41. PMID: 23075828. 10.1159/000341410 23075828
6 Ricotta JJ, Aburahma A, Ascher E, . Updated Society for Vascular Surgery guidelines for management of extracranial carotid disease. J Vasc Surg. 2011;54(3):e1–31. PMID: 21889701. 10.1016/j.jvs.2011.07.031 21889701
7 de Weerd M, Greving JP, Hedblad B, . Prevalence of asymptomatic carotid artery stenosis in the general population: an individual participant data meta-analysis. Stroke. 2010;41(6):1294–7. PMID: 20431077. 10.1161/STROKEAHA.110.581058 20431077
8 Rockman CB, Hoang H, Guo Y, . The prevalence of carotid artery stenosis varies significantly by race. J Vasc Surg. 2013;57(2):327–37. PMID: 23177534. 10.1016/j.jvs.2012.08.118 23177534
9 Naylor AR. Why is the management of asymptomatic carotid disease so controversial? Surgeon. 2015;13(1):34–43. PMID: 25439170. 10.1016/j.surge.2014.08.004 25439170
10 Abbott AL, Brunser AM, Giannoukas A, . Misconceptions regarding the adequacy of best medical intervention alone for asymptomatic carotid stenosis. J Vasc Surg. 2020;71(1):257–69. PMID: 31564585. 10.1016/j.jvs.2019.04.490 31564585
11 Halliday A, Harrison M, Hayter E, . 10-year stroke prevention after successful carotid endarterectomy for asymptomatic stenosis (ACST-1): a multicentre randomised trial. Lancet. 2010;376(9746):1074–84. PMID: 20870099. 10.1016/S0140-6736(10)61197-X 20870099
12 Qaja E, Tadi P, Theetha Kariyanna P. Carotid Artery Stenosis. StatPearls. Treasure Island (FL); 2019.
13 National Institutes for Health, National Heart Lung and Blood Institute. Carotid Artery Disease. https://www.nhlbi.nih.gov/health-topics/carotid-artery-disease. Accessed: Dec 15, 2019.
14 Meschia JF, Bushnell C, Boden-Albala B, . Guidelines for the primary prevention of stroke: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014;45(12):3754–832. PMID: 25355838. 10.1161/STR.0000000000000046 25355838
15 Spence JD, Song H, Cheng G. Appropriate management of asymptomatic carotid stenosis. Stroke Vasc. 2016;1(2):64–71. PMID: 28959466. 10.1136/svn-2016-000016 28959466
16 Goessens BM, Visseren FL, Kappelle LJ, . Asymptomatic carotid artery stenosis and the risk of new vascular events in patients with manifest arterial disease: the SMART study. Stroke. 2007;38(5):1470–5. PMID: 17363718. 10.1161/STROKEAHA.106.477091 17363718
17 Chimowitz MI, Weiss DG, Cohen SL, . Cardiac prognosis of patients with carotid stenosis and no history of coronary artery disease. Veterans Affairs Cooperative Study Group 167. Stroke. 1994;25(4):759–65. PMID: 8160217. 10.1161/01.str.25.4.759 8160217
18 Wolf PA, Kannel WB, Sorlie P, . Asymptomatic carotid bruit and risk of stroke. The Framingham study. JAMA. 1981;245(14):1442–5. PMID: 7206146.7206146
19 McColgan P, Bentley P, McCarron M, . Evaluation of the clinical utility of a carotid bruit. QJM. 2012;105(12):1171–7. PMID: 22886230. 10.1093/qjmed/hcs140 22886230
20 Kaufmann TJ, Huston J, 3rd, Mandrekar JN, . Complications of diagnostic cerebral angiography: evaluation of 19,826 consecutive patients. Radiology. 2007;243(3):812–9. PMID: 17517935. 10.1148/radiol.2433060536 17517935
21 Alakbarzade V, Pereira AC. Cerebral catheter angiography and its complications. Pract Neurol. 2018;18(5):393–8. PMID: 3021800. 10.1136/practneurol-2018-001986 30021800
22 Paraskevas KI, Veith FJ, Ricco JB. Best medical treatment alone may not be adequate for all patients with asymptomatic carotid artery stenosis. J Vasc Surg. 2018;68(2):572–5. PMID: 29773432. 10.1016/j.jvs.2018.02.046 29773432
23 Gaba K, Ringleb PA, Halliday A. Asymptomatic carotid stenosis: intervention or best medical therapy? Curr Neurol Neurosci Rep. 2018;18(11):80. PMID: 30251204. 10.1007/s11910-018-0888-5 30251204
24 Abbott AL, Paraskevas KI, Kakkos SK, . Systematic review of guidelines for the management of asymptomatic and symptomatic carotid stenosis. Stroke. 2015;46(11):3288–301. PMID: 26451020. 10.1161/STROKEAHA.115.003390 26451020
25 Schwartz AL, Landon BE, Elshaug AG, . Measuring low-value care in Medicare. JAMA Intern Med. 2014;174(7):1067–76. PMID: 24819824. 10.1001/jamainternmed.2014.1541 24819824
26 Keyhani S, Cheng EM, Naseri A, . Common reasons that asymptomatic patients who are 65 years and older receive carotid imaging. JAMA Intern Med. 2016;176(5):626–33. PMID: 27088224. 10.1001/jamainternmed.2016.0678 27088224
27 Virani SS, Alonso A, Benjamin EJ, . Heart disease and stroke statistics-2020 update: a report from the American Heart Association. Circulation. 2020;141(9):e139–e596. PMID: 31992061. 10.1161/CIR.0000000000000757 31992061
28 Lichtman JH, Jones MR, Leifheit EC, . Carotid endarterectomy and carotid artery stenting in the US Medicare population, 1999-2014. JAMA. 2017;318(11):1035–46. PMID: 28975306. 10.1001/jama.2017.12882 28975306
29 Patnode CD, Eder ML, Walsh ES, . The use of rapid review methods for the U.S. Preventive Services Task Force. Am J Prev Med. 2018;54(1S1):S19–S25. PMID: 29254522. 10.1016/j.amepre.2017.07.024 29254522
30 United Nations Development Programme. Human Development Report 2019. New York, NY: United Nations Development Programme; 2019.
31 U.S. Preventive Services Task Force. U.S. Preventive Services Task Froce Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
32 Wells GA, Shea BJ, O’Connell DP, . The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analysis. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: June 27, 2017.
33 Eckstein HH, Reiff T, Ringleb P, . SPACE-2: A missed opportunity to compare carotid endarterectomy, carotid stenting, and best medical treatment in patients with asymptomatic carotid stenoses. Eur J Vasc Endovasc Surg. 2016;51(6):761–5. PMID: 27085660. 10.1016/j.ejvs.2016.02.005 27085660
34 Kolos I, Loukianov M, Dupik N, . Optimal medical treatment versus carotid endarterectomy: the rationale and design of the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis (AMTEC) study. Int J Stroke. 2015;10(2):269–74. PMID: 23490405. 10.1111/ijs.12019 23490405
35 Kolos I, Troitskiy A, Balakhonova T, . Modern medical treatment with or without carotid endarterectomy for severe asymptomatic carotid atherosclerosis. J Vasc Surg. 2015;62(4):914–22. PMID: 26410046. 10.1016/j.jvs.2015.05.005 26410046
36 Reiff T, Eckstein HH, Amiri H, . Modification of SPACE-2 study design. Int J Stroke. 2014;9(3):E12–3. PMID: 24636584. 10.1111/ijs.12253 24636584
37 Reiff T, Eckstein HH, Mansmann U, . Angioplasty in asymptomatic carotid artery stenosis vs. endarterectomy compared to best medical treatment: one-year interim results of SPACE-2. Int J Stroke. 2019:15(6):638–349. PMID: 30873912. 10.1177/1747493019833017 30873912
38 Reiff T, Stingele R, Eckstein HH, . Stent-protected angioplasty in asymptomatic carotid artery stenosis vs. endarterectomy: SPACE2 - a three-arm randomised-controlled clinical trial. Int J Stroke. 2009;4(4):294–9. PMID: 19689759. 10.1111/j.1747-4949.2009.00290.x 19689759
39 Boitano LT, Ergul EA, Tanious A, . A regional experience with carotid endarterectomy in patients with a history of neck radiation. Ann Vasc Surg. 2019;54:12–21. PMID: 30223012. 10.1016/j.avsg.2018.08.069 30223012
40 Garcia RM, Yoon S, Cage T, . Ethnicity, race, and postoperative stroke risk among 53,593 patients with asymptomatic carotid stenosis undergoing revascularization. World Neurosurg. 2017;108:246–53. PMID: 28890012. 10.1016/j.wneu.2017.08.184 28890012
41 Glousman BN, Sebastian R, Macsata R, . Carotid endarterectomy for asymptomatic carotid stenosis is safe in octogenarians. J Vasc Surg. 2019;27:27. PMID: 31471235. 10.1016/j.jvs.2019.05.054 31471235
42 Hicks CW, Nejim B, Aridi HD, . Transfemoral carotid artery stents should be used with caution in patients with asymptomatic carotid artery stenosis. Ann Vasc Surg. 2019;54:1–11. PMID: 30339900. 10.1016/j.avsg.2018.10.001 30339900
43 Mayor JM, Salemi JL, Dongarwar D, . Sex-based differences in ten-year nationwide outcomes of carotid revascularization. J Am Coll Surg. 2019;229(1):38–46.e4. PMID: 30922980. 10.1016/j.jamcollsurg.2019.02.054 30922980
44 Nejim B, Alshwaily W, Dakour-Aridi H, . Age modifies the efficacy and safety of carotid artery revascularization procedures. J Vasc Surg. 2019;69(5):1490–503.e3. PMID: 31010514. 10.1016/j.jvs.2018.07.062 31010514
45 O’Donnell TF, Schermerhorn ML, Liang P, . Weekend effect in carotid endarterectomy. Stroke. 2018;49(12):2945–52. PMID: 30571415. 10.1161/STROKEAHA.118.022305 30571415
46 Rao V, Liang P, Swerdlow N, . Contemporary outcomes after carotid endarterectomy in high-risk anatomic and physiologic patients. J Vasc Surg. 2019;20:20. PMID: 31443978. 10.1016/j.jvs.2019.05.041 31443978
47 Liang P, Solomon Y, Swerdlow NJ, . In-hospital outcomes alone underestimate rates of 30-day major adverse events after carotid artery stenting. J Vasc Surg. 2020;71(4):1233–1241. PMID: 32063441. 10.1016/j.jvs.2019.06.201 32063441
48 Dansey KD, Pothof AB, Zettervall SL, . Clinical impact of sex on carotid revascularization. J Vasc Surg. 2020;31:31. PMID: 32014286. 10.1016/j.jvs.2019.07.088 32014286
49 Smith SC, Jr., Allen J, Blair SN, . AHA/ACC guidelines for secondary prevention for patients with coronary and other atherosclerotic vascular disease: 2006 update: endorsed by the National Heart, Lung, and Blood Institute. Circulation. 2006;113(19):2363–72. PMID: 16702489. 10.1161/CIRCULATIONAHA.106.174516 16702489
50 Eckstein HH, Ringleb P, Allenberg JR, . Results of the Stent-Protected Angioplasty versus Carotid Endarterectomy (SPACE) study to treat symptomatic stenoses at 2 years: a multinational, prospective, randomised trial. Lancet Neurol. 2008;7(10):893–902. PMID: 18774746. 10.1016/S1474-4422(08)70196-0 18774746
51 Hertzer NR. The Nationwide Inpatient Sample may contain inaccurate data for carotid endarterectomy and carotid stenting. J Vasc Surg. 2012;55(1):263–6. PMID: 22035762. 10.1016/j.jvs.2011.08.059 22035762
52 Bensley RP, Yoshida S, Lo RC, . Accuracy of administrative data versus clinical data to evaluate carotid endarterectomy and carotid stenting. J Vasc Surg. 2013;58(2):412–9. PMID: 23490294. 10.1016/j.jvs.2013.01.010 23490294
53 Johnston LE, Robinson WP, Tracci MC, . Vascular Quality Initiative and National Surgical Quality Improvement Program registries capture different populations and outcomes in open infrainguinal bypass. J Vasc Surg. 2016;64(3):629–37. PMID: 27374064. 10.1016/j.jvs.2016.03.455 27374064
54 Aiello FA, Shue B, Kini N, . Outcomes reported by the Vascular Quality Initiative and the National Surgical Quality Improvement Program are not comparable. J Vasc Surg. 2014;60(1):152–9, 9 e1–3. PMID: 24630871. 10.1016/j.jvs.2014.01.046 24630871
55 Sedrakyan A, Campbell B, Graves S, . Surgical registries for advancing quality and device surveillance. Lancet. 2016;388(10052):1358–60. PMID: 27707478. 10.1016/S0140-6736(16)31402-7 27707478
56 [No author listed]. Endarterectomy for asymptomatic carotid artery stenosis. Executive Committee for the Asymptomatic Carotid Atherosclerosis Study. JAMA. 1995;273(18):1421–8. PMID: 7723155.7723155
57 Halliday A, Mansfield A, Marro J, . Prevention of disabling and fatal strokes by successful carotid endarterectomy in patients without recent neurological symptoms: randomised controlled trial. Lancet. 2004;363(9420):1491–502. PMID: 15135594. 10.1016/S0140-6736(04)16146-1 15135594
58 Hobson RW, 2nd, Weiss DG, Fields WS, . Efficacy of carotid endarterectomy for asymptomatic carotid stenosis. The Veterans Affairs Cooperative Study Group. N Engl J Med. 1993;328(4):221–7. PMID: 8418401. 10.1056/NEJM199301283280401 8418401
59 Barkat M, Roy I, Antoniou SA, . Systematic review and network meta-analysis of treatment strategies for asymptomatic carotid disease. Sci Rep. 2018;8(1):4458. PMID: 29535395. 10.1038/s41598-018-22356-z 29535395
60 Brott TG, Halperin JL, Abbara S, . 2011 ASA/ACCF/AHA/AANN/AANS/ACR/ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS guideline on the management of patients with extracranial carotid and vertebral artery disease. Stroke. 2011;42(8):e464–540. PMID: 21282493. 10.1161/STR.0b013e3182112cc2 21282493
61 Whitlock EP, Eder M, Thompson JH, . An approach to addressing subpopulation considerations in systematic reviews: the experience of reviewers supporting the U.S. Preventive Services Task Force. Syst Rev. 2017;6(1):41. PMID: 28253915. 10.1186/s13643-017-0437-3 28253915
62 Goldstein LB. Screening for asymptomatic carotid artery stenosis: caveat emptor. Ann Intern Med. 2014;161(5):370–1. PMID: 25003272. 10.7326/M14-1332 25003272
63 Yang Q, Tong X, Schieb L, . Vital Signs: recent trends in stroke death rates - United States, 2000-2015. MMWR Morb Mortal Wkly Rep. 2017;66(35):933–9. PMID: 28880858. 10.15585/mmwr.mm6635e1 28880858
64 Hankey GJ. Impact of treatment of people with transient ischaemic attacks on stroke incidence and public health. Cerebrovasc Dis. 1996;6(26–33). PMID: None. 10.1159/000108068
65 Munster AB, Franchini AJ, Qureshi MI, . Temporal trends in safety of carotid endarterectomy in asymptomatic patients: systematic review. Neurology. 2015;85(4):365–72. PMID: 26115734. 10.1212/WNL.0000000000001781 26115734
66 Hadar N, Raman G, Moorthy D, . Asymptomatic carotid artery stenosis treated with medical therapy alone: temporal trends and implications for risk assessment and the design of future studies. Cerebrovasc Dis. 2014;38(3):163–73. PMID: 25300534. 10.1159/000365206 25300534
67 Greco G, Egorova NN, Moskowitz AJ, . A model for predicting the risk of carotid artery disease. Ann Surg. 2013;257(6):1168–73. PMID: 23333880. 10.1097/SLA.0b013e31827b9761 23333880
68 Poorthuis M, Massa S, Sherliker P, . Diagnostic prediction models for the detection of asymptomatic carotid artery stenosis: a systematic review and external validation study. PROSPERO 2019 CRD42019108136 https://www.crd.york.ac.uk/prospero/display_record.php?ID=CRD42019108136.
69 Nicolaides AN, Kakkos SK, Kyriacou E, . Asymptomatic internal carotid artery stenosis and cerebrovascular risk stratification. J Vasc Surg. 2010;52(6):1486–96 e1–5. PMID: 21146746. 10.1016/j.jvs.2010.07.021 21146746
70 Madani A, Beletsky V, Tamayo A, . High-risk asymptomatic carotid stenosis: ulceration on 3D ultrasound vs TCD microemboli. Neurology. 2011;77(8):744–50. PMID: 21849642. 10.1212/WNL.0b013e31822b0090 21849642
71 Gupta A, Kesavabhotla K, Baradaran H, . Plaque echolucency and stroke risk in asymptomatic carotid stenosis: a systematic review and meta-analysis. Stroke. 2015;46(1):91–7. PMID: 25406150. 10.1161/STROKEAHA.114.006091 25406150
72 Hawkins BM, Kennedy KF, Giri J, . Pre-procedural risk quantification for carotid stenting using the CAS score: a report from the NCDR CARE Registry. J Am Coll Cardiol. 2012;60(17):1617–22. PMID: 22999733. 10.1016/j.jacc.2012.07.026 22999733
73 Gupta PK, Ramanan B, Mactaggart JN, . Risk index for predicting perioperative stroke, myocardial infarction, or death risk in asymptomatic patients undergoing carotid endarterectomy. J Vasc Surg. 2013;57(2):318–26. PMID: 23159474. 10.1016/j.jvs.2012.08.116 23159474
74 Sridharan ND, Chaer RA, Wu BB, . An accumulated deficits model predicts perioperative and long-term adverse events after carotid endarterectomy. Ann Vasc Surg. 2018;46:97–103. PMID: 28689950. 10.1016/j.avsg.2017.06.150 28689950
75 Kallmayer MA, Salvermoser M, Knappich C, . Quality appraisal of systematic reviews, and meta-analysis of the hospital/surgeon-linked volume-outcome relationship of carotid revascularization procedures. J Cardiovasc Surg (Torino). 2019;60(3):354–63. PMID: 30916529. 10.23736/S0021-9509.19.10943-3 30916529
76 Keyhani S, Cheng EM, Hoggatt KJ, . Comparative effectiveness of carotid endarterectomy vs initial medical therapy in patients with asymptomatic carotid stenosis. JAMA Neurol. 2020;77(9):1110–21. PMID: 32478802. 10.1001/jamaneurol.2020.1427 32478802
77 Malas MB, Dakour-Aridi H, Wang GJ, . Transcarotid artery revascularization versus transfemoral carotid artery stenting in the Society for Vascular Surgery Vascular Quality Initiative. J Vasc Surg. 2019;69(1):92–103.e2. PMID: 29941316. 10.1016/j.jvs.2018.05.011 29941316
78 Burton BN, Finneran Iv JJ, Harris KK, . Association of primary anesthesia type with postoperative adverse events after transcarotid artery revascularization. J Cardiothorac Vasc Anesth. 2019;31:31. PMID: 31445834. 10.1053/j.jvca.2019.07.142 31445834
79 Schermerhorn ML, Liang P, Dakour-Aridi H, . In-hospital outcomes of transcarotid artery revascularization and carotid endarterectomy in the Society for Vascular Surgery Vascular Quality Initiative. J Vasc Surg. 2019;18:18. PMID: 31227410. 10.1016/j.jvs.2018.11.029 31227410
80 Dakour-Aridi H, Kashyap VS, Wang GJ, . The impact of age on in-hospital outcomes after transcarotid artery revascularization, transfemoral carotid artery stenting, and carotid endarterectomy. J Vasc Surg. 2020. PMID: 32035784. 10.1016/j.jvs.2019.11.037 32035784
81 Schermerhorn ML, Liang P, Eldrup-Jorgensen J, . Association of transcarotid artery revascularization vs transfemoral carotid artery stenting with stroke or death among patients with carotid artery stenosis. JAMA. 2019;322(23):2313–22. PMID: 31846015. 10.1001/jama.2019.18441 31846015
82 Meltzer AJ, Agrusa C, Connolly PH, . Impact of provider characteristics on outcomes of carotid endarterectomy for asymptomatic carotid stenosis in New York state. Ann Vasc Surg. 2017;45:56–61. PMID: 28577790. 10.1016/j.avsg.2017.05.015 28577790
83 Dakour-Aridi H, Nejim B, Locham S, . Complication-specific in-hospital costs after carotid endarterectomy vs carotid artery stenting. J Endovasc Ther. 2018;25(4):514–21. PMID: 29893167. 10.1177/1526602818781580 29893167
84 Choi JC, Johnston SC, Kim AS. Early outcomes after carotid artery stenting compared with endarterectomy for asymptomatic carotid stenosis. Stroke. 2015;46(1):120–5. PMID: 25424479. 10.1161/STROKEAHA.114.006209 25424479
85 Howard VJ, Meschia JF, Lal BK, . Carotid revascularization and medical management for asymptomatic carotid stenosis: protocol of the CREST-2 clinical trials. Int J Stroke. 2017;12(7):770–8. PMID: 28462683. 10.1177/1747493017706238 28462683
86 ClinicalTrials.gov. Carotid Revascularization and Medical Management for Asymptomatic Carotid Stenosis Trial (CREST-2). https://clinicaltrials.gov/ct2/show/NCT02089217. Accessed: Dec 15, 2019.
87 [No author listed]. The 2nd European Carotid Surgery Trial (ECST-2): Protocol Summary: Version 3.10. 11th November 2015. http://s489637516.websitehome.co.uk/ECST2/protocolsummary.htm. Accessed: Dec 15, 2019.
88 ISRCTN Registry. European Carotid Surgery Trial 2. http://www.isrctn.com/ISRCTN97744893. Accessed: Dec 15, 2019.
89 ClinicalTrials.gov. Endarterectomy Combined With Optimal Medical Therapy (OMT) vs OMT Alone in Patients With Asymptomatic Severe Atherosclerotic Carotid Artery Stenosis at Higher-than-average Risk of Ipsilateral Stroke (ACTRIS). https://clinicaltrials.gov/ct2/show/NCT02841098. Accessed: Dec 15, 2019.
90 Lal BK, Roubin GS, Rosenfield K, . Quality assurance for carotid stenting in the CREST-2 Registry. J Am Coll Cardiol. 2019;74(25):3071–9. PMID: 31856962. 10.1016/j.jacc.2019.10.032 31856962
91 James Meschia. Personal Communication. Feb 18, 20202020. PMID.
92 Marshall RS, Lazar RM, Liebeskind DS, . Carotid revascularization and medical management for asymptomatic carotid stenosis - hemodynamics (CREST-H): study design and rationale. Int J Stroke. 2018;13(9):985–91. PMID: 30132751. 10.1177/1747493018790088 30132751
93 ClinicalTrials.gov. Carotid Revascularization and Medical Management for Asymptomatic Carotid Stenosis Trial - Hemodynamics (CREST-H) (CREST-H). https://clinicaltrials.gov/ct2/show/NCT03121209. Accessed: Dec 15, 2019.
94 AIUM Practice parameter for the performance of an ultrasound examination of the extracranial cerebrovascular system. J Ultrasound Med. 2016;35(9):1–11. PMID: 27574121. 10.7863/ultra.35.9.1 27574121