# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Kathleen Irwin, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Ethan Halm, MD, MPH, MBA, James F. Meschia, MD, John J. Ricotta, MD, FACS, DFSVS, and Nicholas J. Swerdlow, MD, who provided expert review of the draft report; the National Institute of Neurological Disorders and Stroke, National Institutes of Health, for providing federal partner review of the draft report; Jennifer S. Lin, MD, MCR, for mentoring and project oversight; and Melinda Davies, MAIS, and Katherine Essick, BS, for technical and editorial assistance at the Center for Health Research.