# Chapter 4 Discussion

## Summary of Findings and Comparison to Last Review

Since the previous review on this topic, two new trials and five studies using administrative or surgical registry data were identified. The overall conclusions from this review are consistent with those of the previous review^2^ (Table 17). No population based trials of screening versus no screening for carotid artery stenosis have ever been conducted. The two new trials that were identified addressed the comparison of revascularization with medical treatment for asymptomatic carotid artery stenosis; however, both trials were limited due to methodological concernss.^33–38^ The SPACE-2 trial showed no difference in a composite outcome of stroke or death at 1 year in the revascularization (CEA or CAS) and BMT groups,^37^ the 5 year outcomes have yet to be published. The small AMTEC trial specifically recruiting a high risk population showed statistically significant benefits in stroke or death at 3.3 year median followup in the CEA arm; however, AMTEC’s conclusions are limited by validity and applicability issues as well as small sample size.^35^

Table 17 Summary of Previous 2014 USPSTF Review and New Evidence Identified in This Review

| Rationale and foundational evidence | New evidence findings | Limitations of new evidence | Consistency of new evidence with foundational evidence and current understanding
Benefits of screening | No direct evidence | No new evidence. | NA | NA
Harms of screening | No studies examined direct harms of screening.; Two trials reported 0.4% and 1.2% of patients had a stroke following angiography. | No new evidence. | NA | NA
Incremental benefit of revascularization | Pooled results from 3 RCTs (N= 5226) found CEA resulted in a 3.5% (95% CI 1.8% to 5.1%) absolute reduction of perioperative stroke or death at approximately 5 years compared with medical management available at the time of these trials (1990’s).; No studies compared CAS with medical management. | Two contemporary, prematurely terminated trials comparing revascularization plus BMT to BMT alone report mixed results. The larger but underpowered SPACE-2 trial (N=513) reported no difference in the composite outcome of stroke or death between the two groups. The small AMTEC trial (N=55) in high risk patients reported a statistically significantly lower composite outcome of stroke or death in the CEA group.; SPACE-2 reported no difference in the primary composite outcome (stroke or death [30-d] or ipsilateral ischemic stroke [1-yr]) between the CAS and BMT groups. | Underpowered, prematurely terminated trials. | New trials have mixed results and do not definitively change previous conclusions.
Harms of revascularization | Pooled results from 8 cohorts (N=16,967) estimated a 30-day perioperative stroke/death rate of 3.32% (95% CI, 2.73% to 3.91%). Pooled results of 6 trials (N= 3,436) estimated a 30-d perioperative stroke/death rate of 2.41% (95% CI, 1.71% to 3.12%).; One cohort study on harms from CAS (N= 1,151) found a 30-day stroke or death rate of 3.8% (95% CI, 2.9% to 5.1%). A meta-analysis of 2 trials (n = 6,152) found a stroke or death rate of 3.1% (95% CI, 2.7% to 3.6%) after CAS.; Other important potential harms of CEA or CAS include nonfatal perioperative myocardial infarction, cranial nerve injury, pulmonary embolism, pneumonia, local hematoma requiring surgery, and psychological harms. | 30-d postoperative stroke or death for CEA were highest in the national databases (Medicare and NIS) compared to the trial data and vascular surgery registries: Medicare and NIS reported 30-d postoperative stroke or death rates of 3.5% and 3.09%, respectively, the SPACE-2 trial reported 2.5% while VQI and VSGNE reported lower rates of 1.4 to 1.8%.; For the CAS procedure, 30-d stroke or death was again highest in Medicare at 5.1% and lowest in a VQI analysis at 2.6%. | Wide variation in 30-d stroke/death rates reported in trial and registries compared to national administrative Medicare and NIS databases. | Single additional trial SPACE-2 showed 30-d stroke/death of 2.5% which is similar to previous reviews MA of trials.; Contemporary national databases (NIS and Medicare) showing similar 30-d stroke/death rates compared to previous MA of cohorts.; CAS 30-d stroke/death in Medicare registry higher than previous meta-analysis of 2 trials.; However contemporary vascular registries showing lower complication rates.

Abbreviations: AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BMT = best medical treatment; CAS = carotid artery stenting; CEA = carotid endarterectomy; MA = meta-analysis; NA = not applicable; NIS = National Inpatient Sample; RCT = randomized controlled trial; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; vs = verse; VSGNE = Vascular Study Group of New England; VQI = Vascular Quality Initiative; yr = year

New evidence related to revascularization harms is available from contemporary analyses of national databases and surgical registries.^28,^ ^35,^ ^39–46^ Rates of 30-day postoperative stroke or death for CEA were highest in the analyses of national databases (Medicare and NIS) compared with the trial data and surgical registries. Medicare and NIS reported rates of 3.5^28^ and 3.1^43^ percent, respectively. The SPACE-2 trial^37^ reported 2.5 percent 30-day stroke or death rate, while the VQI and VSGNE reported lower rates of 1.1^44^ to 1.8 percent.^39^ For the CAS procedure, 30-day stroke or death was again highest in Medicare at 5.1 percent^28^ and lowest in a VQI analysis of only individuals with less than 60 percent stenosis of 1.9 percent.^42^ Previous analyses addressing the wide variations in estimates of vascular revascularization complications have cited concerns about administrative data’s ability to categorize patients’ symptomatic status and identify perioperative complications.^51,^ ^52^ Administrative data has shown poor concordance compared with surgical registries utilizing chart review (like the VQI and NSQIP) due to data collection methods and variable definitions for postoperative complications. However, these outcomes discrepancies are most apparent for postoperative complications other than distinct clinical outcomes such as death or MI.^53,^ ^54^ Others have suggested that participation in surgical registries may improve outcomes with active engagement in quality improvement initiatives.^55^ While we presented administrative and registry data in an effort to reflect complication rates in real-world practice, selection and measurement bias from these data sources remain serious concerns.

The two new recent trials add little to the evidence base on effectiveness of revascularization compared with BMT (KQ3), which consists of the historical trials (ACAS, ACST, VACS) with larger study sizes and longer followup showing the long term benefits of CEA compared to BMT,^11,^ ^56–58^ included in the previous review. Estimates of surgical harms following CEA are also consistent with the previous review. The SPACE-2 trial^37^ reported a 30-day stroke/death rate of 2.5 percent, which is similar to previous reviews’^2^ meta-analysis of trials (2.4% [95% CI, 1.7 to 3.1%]). While our analysis did not pool the results of these trials, one recent network meta-analysis included the historical trials plus AMTEC and SPACE-2 reporting no differences in 30-day stroke and mortality, but lower rates of 30-day MI and higher rates of 30-day TIA in the CEA group compared with the BMT group.^59^

Contemporary national databases (NIS and Medicare) now represent a substantially larger population (over 1.7 million procedures) than in the previous review and showed similar stroke/death rates following CEA (3.1^43^ [in-hospital stroke, MI, or death]) to 3.5^28^% [30-day ischemic stroke/death]) compared with previous MA of Medicare data (3.3% [95% CI, 2.6 to 3.9%]).^2^ The rates reported in the national administrative databases remain higher than the recommended 3 percent threshold specified in expert guidelines as the acceptable rate of morbidity and mortality under which prophylactic CEA may be considered in those with at least a 3-5 year life expectancy.^60^ The VSGNE and VQI report lower 30-day stroke/death rates ranging from 1.1^39^ to 1.8^44^ percent, perhaps reflecting select high-volume centers with experienced surgeons and highly selected surgical patients.

In addition, there is more evidence available related to the use of CAS in asymptomatic carotid artery stenosis than in the previous review. The previous review included no trials examining the effectiveness of CAS compared with medical therapy alone. New evidence from the SPACE-2 trial concluded that there was no difference in stroke between the CAS group compared with BMT group within one year.^37^ The rate of 30-day stroke/death within the SPACE-2 trial was 2.5 percent, slightly lower than the rate found in trials in the previous review (3.1% [95% CI, 2.7 to 3.6%]).^2^ However, the contemporary national databases (NIS and Medicare) including 300,000 procedures identified a rate of stroke/death of 3.6^28^ to 5.1^43^ percent. Rates were lower within the VQI at 2.6 percent (1.9% among those with >60% stenosis).^42,^ ^44^

## Limitations

The scope of this rapid review was limited to screening in the general population. Therefore, we did not address the benefits/harms of screening high-risk subpopulations, and the conclusions of this review may not necessarily apply to patients at high risk of asymptomatic carotid stenosis or who have had prior stroke or TIA contralateral to the asymptomatic stenosis. Such an analysis is highly clinically relevant and would require careful consideration of epidemiologic factors, ideally validated risk assessment pools alongside the results from ongoing trials.^61^

One salient argument against general population screening is that stroke caused by carotid artery stenosis has a low population attributable risk.^9,^ ^62^ Stroke remains a major cause of disability and death, and after more than four decades in decline, rates recently have stalled or reversed among some populations.^63^ Approximately 12 percent of strokes are preceded by a TIA and 23 percent by a previous stroke.^64^ One analysis estimated that about 34 percent of strokes are attributed to ICA thromboembolism and only 11 percent of strokes are associated with significant, previously asymptomatic stenosis.^9^ Applying the absolute risk difference seen in the historical trials (ARD= 0.03 [0.05 to 0.00] in any stroke/death),^2^ very few patients would realize benefit, particularly in light of perioperative complications and even with contemporary improvements in surgical techniques.^65^ Many have argued that the historical trials have a more optimistic CEA benefit than would be expected with contemporary aggressive medical management of atherosclerotic risk factors,^66^ as seen in the temporal decline in stroke risk in those with carotid artery stenosis. Thus, even if surgical operators and patients are carefully selected, few would benefit.^65^

A 2020 review analyzed data from 12 trials and observational studies of participants with asymptomatic carotid stenosis (N=3600) with 1.9 to 6.2 year mean or median followup.^10^ They reported annual ipsilateral stroke risk of 0.3 to 3.1 percent for those with ≥50 percent stenosis and 0 to 3.3 percent risk for those with ≥60 or ≥75 percent stenosis.^10^ Given the low risk of stroke overall in asymptomatic patients, one would ideally focus screening on those at high risk for stenosis and then identify those at high risk for progression to stroke. Among those asymptomatic patients with clinically significant carotid artery stenosis at higher risk of stroke, those with an acceptably low surgical risk profile could then be considered for CEA/CAS with operators who had favorable procedural complication rates.^6,^ ^14^ First, while there are some proposed risk models for carotid artery stenosis,^67^ we are not aware of any externally validated risk models for identifying those at high risk for carotid artery stenosis, although one systematic review and external validation study is planned.^68^ Second, there are no externally validated risk tools for stroke prediction in persons with carotid artery stenosis. In fact, the definition of ‘clinically significant stenosis’ is not entirely certain. Some models have been developed suggesting patient characteristics (e.g., age, systolic blood pressure) and radiographic characteristics (e.g., degree of stenosis, microemboli, plaque characteristics) that may predict risk of stroke in individuals with asymptomatic carotid artery stenosis however none have been externally validated.^69–71^ Other models have been developed to estimate postoperative outcomes and 5-year survival following surgical repair.^72–74^ To date, the SVS recommends consideration of CEA for asymptomatic patients with stenosis of 60 to 99 percent if perioperative stroke/death is less than 3 percent,^6^ and the AHA/ASA^14^ similarly recommends consideration of CEA in asymptomatic carotid artery stenosis of at least 70 percent stenosis on doppler ultrasound for highly selected patients if the risk of perioperative stroke, MI, and death is low. Implementation of these guidelines has been challenging due to limitations in the availability of risk-prediction tools.

Carotid artery stenosis is a manifestation of systemic atherosclerotic disease so identifying this condition may potentially lead to changes in medical management to prevent future CVD events in patients otherwise not known to have preexisting atherosclerotic disease. Because it was outside of the scope of this review, we did not explore use of carotid artery stenosis screening (degree of stenosis or carotid intima medial thickening) as a CVD risk-stratification tool to identify those with elevated 10-year CVD risk who are eligible for statin use. Many patients with clinically important CAS may already meet the 7.5 percent threshold in the Pooled Cohort Equation; however, the degree of overlap is uncertain.

There remain generalizability concerns about how the complication rates reported in these studies would translate to truly asymptomatic, screen-detected populations undergoing revascularization in low volume community hospitals (which may be expected to have higher complication rates compared with high volume academic centers).^75^ Screen-detected cases would be expected to have lower complication rates compared with populations with any neurologic symptoms or remote history of TIA, stroke, or contralateral disease. The newer included and historical studies included patients with a history of these conditions. For KQ3, selection bias (asymptomatic case definition, patient/case selection, surgeon/operator selection) and measurement bias (omissions in data abstraction of postoperative complications) were serious concerns for the administrative databases and surgical registries. Nonetheless, these included studies represent the best-quality available evidence. Well-designed surgical registries with independent abstractors and data quality checks from geographically diverse regions would be ideal to capture real-practice complication rates for patients undergoing revascularization in community as well as academic centers in rural and urban centers in the United States.

The limited nature of this update also led to the exclusion of some studies related to revascularization harms. For example, one small retrospective analysis from the Veterans Affairs (N=5221) reported a 2.5% (95% CI, 2.0 to 3.1) 30 day stroke or death rate; 5 year stroke risk was not statistically significantly different between the CEA and OMT groups when controlled for competing causes of nonstroke mortality.^76^ Additionally, no studies examining the benefits and harms of TCAR met inclusion criteria; however, a few publications from VQI and NSQIP registries of TCAR were excluded based on the size.^77–81^ Likewise, smaller statewide^82^ and multistate administrative databases^83,^ ^84^ were not included because CMS and NIS together contributed over 1 million asymptomatic patients and were considered more nationally representative. We also did not include non-US databases or registries as we sought to capture postoperative complication rates most representative of contemporary U.S. practice. We selected administrative databases and surgical registries with the most contemporary and largest datasets, therefore there may be older publications of these databases/registries that reported more details on adverse events; we focused on postoperative stroke and mortality. Finally, this review did not include harms from comparative effectiveness trials of CEA and CAS nor did it address the harms of BMT.

## Ongoing Studies

For KQ1, we did not identify any published or ongoing trials of screening versus no screening in unselected general populations. For KQ3, there were few new trials examining the important question of the comparative effectiveness of revascularization compared with best medical treatment, although ongoing trials are imminent. We identified three important ongoing trials that address the effectiveness of revascularization compared with contemporary best medical treatment alone (Appendix F).^85–89^ The CREST-2 trial (NCT02089217; N planned 2480) is being conducted as two parallel multicenter randomized clinical trials comparing best medical management alone to CEA or CAS plus best medical management. Participants will include individuals with at least 70 percent stenosis and no stroke or TIA within 180 of randomization. Medical management includes aggressive antihypertensive and anti-lipid treatment as well as lifestyle management programs for weight loss, smoking cessation, exercise, and diabetes management. The CREST-2 Registry is intended to credential interventionalists for the trial and optimize patient selection, procedural technique, and outcomes.^90^ Primary outcomes will include composite endpoint of stroke/death within 44 days of randomization or ipsilateral stroke up to 4 years after randomization. Secondary outcomes include cognitive function, various severities and definitions of stroke; subgroup analyses are planned. The estimated primary enrollment completion date is December 2022.^86,^ ^91^ CREST-H (NCT03121209) is an add-on study to CREST-2 addressing whether cognitive impairment can be reversed by revascularization when cerebral blood flow is low on the side of a high-grade carotid stenosis.^92,^ ^93^

The ECST-2 Trial (N planned 2000), an ongoing randomized trial comparing optimized medical management alone with CEA or CAS plus medical management. Participants have asymptomatic or symptomatic carotid artery stenosis with at least 50 percent stenosis and a 5-year ipsilateral stroke risk of less than 20 percent. Medical management in this trial includes antihypertensive and anti-lipid treatment as well as lifestyle counseling. Primary outcomes include any stroke during followup and nonstroke death within 30 days of revascularization. The trial will also measure longer-term outcomes including stroke, revascularization, and functional status/cognitive impairment, and a subset set of patients will have MRI followup to assess rates of new cerebral infarction, hemorrhage, or white matter changes. The estimated primary completion date is March 2022.^87,^ ^88^

The Endarterectomy Combined With Optimal Medical Therapy (OMT) vs OMT Alone in Patients With Asymptomatic Severe Atherosclerotic Carotid Artery Stenosis at Higher-than-Average Risk of Ipsilateral Stroke (ACTRIS) trial (N planned 700) will compare best medical management alone with CEA combined with best medical therapy. This trial intends to enroll 700 participants with 70 to 99 percent stenosis and at least one marker of increased stroke risk (e.g., silent brain infarction on MRI, rapid progression, history of contralateral stroke TIA or ischemic stroke). All participants will receive medical management with antiplatelet, antihypertensive, and antilipid treatment along with lifestyle counseling. Primary outcomes include ipsilateral stroke or procedural stroke or death. This trial is not planned to be completed until December 2025.^89^

## Conclusions

Population-based screening trials addressing the benefits and harms of screening for carotid artery stenosis have never been conducted. Since the last review, little new indirect evidence has emerged that answers the critical question of whether carotid revascularization is superior to contemporary best medical management. The ongoing CREST-2 and ECST-2 trials will be the largest contemporary trials to address this issue. Large national administrative databases and vascular surgery registries suggest that postoperative 30-day stroke/death complication rates vary widely—1.4 to 3.5 percent for CEA and 2.6 to 5.1 percent for CAS—suggesting that careful surgeon/operator and patient selection is critical to realize benefits from screening and revascularization.