# Chapter 3 Results

## Literature Search

Results of this search represent literature published since the previous review on this topic. We screened 2,374 abstracts and assessed 144 full-text articles for inclusion; no articles were reviewed for KQs 1–2, 20 were reviewed for KQ3, and 143 were reviewed for KQ4 (Appendix B Figure 1). After screening the full-text articles, we included two small trials (published in 6 articles)^33–38^ for KQ3 and seven studies (in 17 articles)^28,^ ^33–48^ for KQ4. The full list of included studies and their ancillary articles is available in Appendix C. The list of excluded studies (with reasons for exclusion) is available in Appendix D.

## KQ1 Is There Direct Evidence That Screening Asymptomatic Adults for Carotid Artery Stenosis With Duplex Ultrasonography Improves Health Outcomes?

No eligible studies were identified that directly examined the benefits of screening for asymptomatic carotid artery stenosis.

## KQ2 What Are the Harms Associated With Screening or Confirmatory Testing for Asymptomatic Carotid Artery Stenosis?

No eligible studies were identified that directly examined the harms of screening for asymptomatic carotid artery stenosis.

## KQ3 For Asymptomatic Persons With Carotid Artery Stenosis, Does Revascularization Provide Incremental Benefit Beyond Current Medical Treatment?

### Summary of Results

Since the previous review for the USPSTF on this topic, two small fair-quality, prematurely terminated trials reported mixed results for the comparative effectiveness of carotid revascularization compared with best medical treatment (BMT).^33–38^ The larger, European multinational SPACE-2 trial^37^ (N=316 reported 1 year interim findings of no difference in composite outcome of stroke or death (30 days) or ipsilateral ischemic stroke (1 year) between the CEA and BMT groups (unadjusted hazard ratio [HR] 2.82 [95% CI, 0.33 to 24.07]), while the small Russian AMTEC trial^35^ (N=55) reported a statistically significant lower composite risk of nonfatal ipsilateral stroke or death among the CEA arm at 3.3 median years of followup (calculated unadjusted HR 0.20 [95% CI, 0.06 to 0.65]). SPACE-2^37^ (N=310) additionally reported no difference in the primary composite outcome (stroke or death [30 days] or ipsilateral ischemic stroke [1 year]) between the CAS and BMT groups (unadjusted HR 3.50 [95% CI, 0.42 to 29.11]). Both trials have risk of bias in important domains that limit validity or applicability of findings. Both trials were terminated early due to slow recruitment (SPACE-2) or apparent superiority of CEA over BMT (AMTEC).

### Characteristics of Included Studies

Two fair-quality, prematurely terminated trials addressed the stroke and mortality effects of best medical therapy (BMT) compared with revascularization (Table 2; Appendix E Table 1). The SPACE-2 trial^37^ (N=513) was designed as a three-arm study (CEA vs. CAS vs. BMT) but was converted to two separate trials (CEA vs. BMT and CAS vs. BMT) following low recruitment into the study. The trial was prematurely terminated in 2014 due to slow recruitment; specifically, a fraction of the numbers required for adequate power were recruited (513 enrolled vs. 3,550 planned). SPACE-2 recruited adults ages 50 to 85 years with asymptomatic carotid artery stenosis (≥70% stenosis) from 36 study centers in Germany, Switzerland, and Austria. The Russian AMTEC trial^35^ (N=55) recruited high-risk individuals from surgical and medical clinics with 70 to 79 percent stenosis on ultrasound. AMTEC was prematurely terminated following an interim analysis of the first 55 individuals because the BMT group had an unexpectedly high ipsilateral stroke/death rate that was much higher than that of the CEA group; the data safety and monitoring board concluded that CEA had clear advantages over BMT in this trial population.^35^

Table 2 Study Characteristics of Included Randomized, Controlled Trials of Revascularization vs. BMT, KQ 3

Study Name; Author, Year; Quality | Country | N randomized | Study aim | Brief pop description | Recruitment setting | Pre-randomization evaluation & required stenosis | FU timepoints (Mean FU) | Early termination description
SPACE-2; Reiff, 2019^37^; Fair | Germany, Switzerland, and Austria | 513 | To compare the stroke preventive effects of BMT alone with that of BMT in combination with CEA or CAS | Adults patients aged 50 to 85, with asymptomatic carotid artery stenosis (≥70%) | Hospital (multisite) | Carotid artery stenosis of ≥70% following ultrasound criteria | 30-d, 1-yr (NR) | Originally designed as a 3 arm trial. Due to low recruitment it was changed to two separate trials (CEA vs BMT, CAS vs BMT). continuing low recruitment rates led to the premature termination of enrollment of the SPACE-2 study in 2014
AMTEC; Kolos, 2015^35^; Fair | Russia | 55 | To assess the value of BMT with and without CEA in patients with asymptomatic severe carotid artery stenosis^*^ | Adults aged 40 to 80 years old, with asymptomatic CAS (70-79% stenosis) | Surgical & medical clinics | 70–79% on ultrasonography and 60–79% on CTA, contrast MRA, or 60–79% on angiography in common carotid artery and/or internal carotid artery.^†^ | 3.3-yr cumulative (Median: 3.3 (range, 1.5-5.0-yr) | Data and Safety Monitoring Board voted to terminate trial: Given the clear advantages of CEA, all BMT patients were advised to undergo carotid revascularization after the study termination.

* CEA was preferred to CAS because of doubts concerning the quality of CAS in Russia at the beginning of the study.

† Patients with 70% to 79% stenosis were included because in 2009, CEA was strongly recommended (Class IA) in patients with severe carotid atherosclerosis, and the committee decided that BMT in patients with stenosis of >80% was unethical. Patients with stenosis of 60% to 70% were not included in the study because the committee considered that CEA would also be unethical.

Abbreviations: AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BMT = best medical treatment; CAS = carotid artery stenting; CEA = carotid endarterectomy; CTA = computerized tomography angiography; FU = followup; KQ = key question;; MRA = magnetic resonance angiography; NR = not reported; pop = population; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; vs = verse; yr = year

Both trials excluded individuals with stroke or TIA in the previous 6 months/180 days, prior ipsilateral carotid procedures (CEA, CAS), or history of neck irradiation. SPACE 2 excluded individuals with a history of intracranial bleed within the previous 90 days or a life expectancy of less than 5 years. The AMTEC excluded people with “poor surgical risk” (e.g., due to recent MI), life expectancy of less than 6 months, or severe classes of heart failure, coronary disease, angina, lung and renal disease, and atrial fibrillation. The mean ages were 70 and 66.6 years in SPACE-2^37^ and AMTEC,^35^ respectively. In both trials, approximately three-quarters of the participants were male, and one-quarter had diabetes. Most participants in the SPACE-2 trial had hypertension (89.5%) and hypercholesterolemia (79.3%). Within the AMTEC trial, participant characteristics were less well reported. Smoking rates were much higher in AMTEC compared with SPACE-2 (58.2% ever-smokers compared with 19.5% current smokers), as were rates of coronary heart disease (70.9% compared with 35.5%). In addition, over half of AMTEC participants had had a previous coronary artery bypass grafting or percutaneous coronary intervention (52.7%). Only 3.5 percent of SPACE-2 participants had prior contralateral carotid occlusion. Median stenosis in SPACE 2 was 80 percent, and the vast majority were taking antiplatelet (96.5%), antihypertensive (87.3%) and lipid-lowering agents (81.5%) at baseline. In AMTEC, BMI was significantly lower in the BMT group compared with the CEA group (26.8 vs. 29.9, p=0.0008) and 16.4 percent had had a prior stroke. See Appendix E Table 2 for detailed population characteristics of included trials.

In SPACE-2,^37^ the revascularization groups received a CEA or CAS in addition to BMT within a median time of 14 days after randomization. The CEA group received aspirin or clopidogrel at least 3 days before surgery. The CAS group received dual antiplatelet therapy (aspirin and clopidogrel) for at least 3 days before the procedure and 6 weeks after CAS. In SPACE-2, surgeons were required to have conducted 40 consecutive procedures or 20 consecutive procedures with perisurgical complication rates of less than 6 percent in the SPACE-1 study.^38^ In AMTEC,^35^ the surgery group received a CEA in addition to BMT. Surgeries were conducted in five centers with a minimum of 150 procedures per year and less than 3 percent complications and death rates in asymptomatic carotid artery stenosis.^34^

In both trials, the intervention and control groups received BMT. In SPACE-2,^37^ BMT was based on evidence-based guidelines current at that time in accordance with their individual risk-factor profile, including the treatment of risk factors (i.e., smoking cessation, weight reduction, blood pressure lowering, glycemic management, lipid lowering, and counseling about physical activity and alcohol consumption) and antiplatelet medication. In AMTEC,^35^ BMT included lifestyle modification training (i.e., counseling about diet, exercise, and smoking cessation), obesity and diabetes mellitus management according to 2006 AHA/ACC guidelines,^49^ and treatment with aspirin and aggressive lipid-lowering and antihypertensive therapy.

The planned primary outcome in SPACE-2 was the cumulative 30-day stroke or death plus ipsilateral ischemic stroke within 5 years, which the authors state will still be performed. Currently, only outcomes after 1 year of followup have been reported. The primary outcome in AMTEC was nonfatal ipsilateral stroke and death at study termination. Secondary outcome was a composite of nonfatal stroke, carotid revascularization and death.

### Study Quality and Applicability

Both studies had some important limitations. The trials excluded those with recent stroke or TIA but did not exclude those with any history of these diagnoses. SPACE-2^37^ recruited patients from surgery centers, so it is unclear if the participants were truly “screen-detected.” Individuals with a recent stroke or TIA were excluded; however, the trial did not exclude those with any history of these diagnoses. The SPACE-2 trial was limited by change in study design and early termination due to inadequate recruitment with short term 1 year results reported. The trial had protocol violations in 34 patients who received therapy different than randomized; however, the per-protocol and intention-to-treat analyses both showed similar results. Operators were carefully selected and requirements for participation included: at least 40 consecutive surgical or endovascular carotid procedures or at least 20 CEA or CAS with intervention complication rates of less than 6 percent in the prior SPACE-1 study.^50^ Stroke was clinically defined and outcomes abstracted from medical records by separate but unblinded physicians.^37^

AMTEC^35^ screened patients with high risk for CAS and selected participants with favorable perioperative risk and centers with less than 3 percent complication rates for asymptomatic carotid artery stenosis. As in the SPACE-2 trial, individuals with a recent stroke or TIA were excluded; but not those with any history of these diagnoses. This trial included participants with high prevalence of cardiovascular disease burden (half of participants had a previous coronary artery bypass grafting or percutaneous coronary intervention). This very small study presents concerns for selection bias: Less than 20 percent of those with stenosis of 70 to 79 percent based on ultrasound received confirmatory imaging required for consideration. The population is more selective for this trial, with an age range of 40 to 80 years and a narrower 70- to 79-percent stenosis window. The trial was conducted in highly selected centers, i.e., those with a less than 3 percent complication rate. In addition, the higher than expected mortality rate in the BMT group and small study size make result validity questionable. Early termination limited outcome reporting at planned followup time so reported results were short term. Blinded outcome adjudicators were used, and the study defined stroke as the presence of symptoms followed by a stroke-specific examination and confirmed with imaging.

### Detailed Results by Outcome

#### CEA vs. BMT

In SPACE-2,^37^ there was no statistically significant difference in the primary composite outcome (stroke or death [30 days] or ipsilateral ischemic stroke [1 year]) between the CEA (5/203 [2.5%]) and BMT arms (1/113 [0.9%]) (unadjusted HR 2.82 [95% CI, 0.33 to 24.07]) (Table 3). In addition, no difference was found in the individual outcomes of stroke (unadjusted HR 4.51 [95% CI, 0.56 to 36.09] or ipsilateral stroke (unadjusted HR 2.24 [95% CI, 0.25 to 20.04]) for the CEA group compared with the BMT group. Mortality was reported as 2.5 percent (5/203) in the surgery group and 3.5 percent (4/113) in the best medical management group, with no hazard ratio reported.^37^

Table 3 Health Outcomes Reported in Trials of CEA vs. BMT, KQ 3

Study Name; Author, Year; Quality | Followup | Outcome | IG n analyzed | IG events (%) | CG n analyzed | CG events (%) | HR (95% CI) | P-value
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Composite (stroke or death (30-d) or ipsilateral ischemic stroke (1-yr)) | 203 | 5 (2.5%) | 113 | 1 (0.9%) | 2.82 (0.33, 24.07) | P=0.345
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Stroke^*^ | 203 | 8 (3.9%) | 113 | 1 (0.9%) | 4.51 (0.56, 36.09) | P=0.155
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Ipsilateral stroke | 203 | 4 (2.0%) | 113 | 1 (0.9%) | 2.24 (0.25, 20.04) | P=0.471
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Mortality | 203 | 5 (2.5%) | 113 | 4 (3.5%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Disabling stroke^†^ | 203 | 2 (1.0%) | 113 | 1 (0.9%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | TIA | 203 | 4 (2.0%) | 113 | 6 (5.3%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Ipsilateral TIA | 203 | 2 (1.0%) | 113 | 6 (5.3%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | MI | 203 | 1 (0.5%) | 113 | 0 (0%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Restenosis | 203 | 4 (2.0%) | NA | NA | NA | NA
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Re- or progressive stenosis | 203 | 4 (2.0%) | 113 | 5 (4.4%) | NR | NR
AMTEC; Kolos, 2015^35^; Fair | 3.3-yr (cumulative)^‡^ | Nonfatal Stroke or death | 31 | 2 (6.5%) | 24 | 9 (37.5%) | 0.20 (0.06, 0.65)^§^ | P=0.008
AMTEC; Kolos, 2015^35^; Fair | 3.3-yr (cumulative)^‡^ | Nonfatal Stroke | 31 | 1 (3.2%) | 24 | 5 (20.8%) | 0.20 (0.04, 0.995)^§^ | P=0.0493
AMTEC; Kolos, 2015^35^; Fair | 3.3-yr (cumulative)^‡^ | Nonfatal stroke, carotid revascularization, and death | 31 | 4 (12.9%) | 24 | 12 (50.0%) | 0.24 (0.09, 0.65)^§^ | P=0.0048
AMTEC; Kolos, 2015^35^; Fair | 3.3-yr (cumulative)^‡^ | ACM^ǁ^ | 31 | 1 (3.3%) | 24 | 4 (16.7%) | 0.23 (0.04, 1.35)^§^ | P=0.105
AMTEC; Kolos, 2015^35^; Fair | 3.3-yr (cumulative)^‡^ | Major adverse cardiac events^#^ | 31 | 4 (12.9%) | 24 | 14 (58.3%) | 0.21 (0.08, 0.54)^§^ | P=0.0012

* Three strokes in the CEA arm and 1 stroke in the BMT arm occurred after day 30 (HR: 1.70 (0.18-16.37) p=0.645)

† Defined as mRS 30 days after stroke >2

‡ The median follow-up period was 3.3 years (range, 1.5-5.0 years)

§ Calculated unadjusted HRs. Study reported unadjusted HRs: Nonfatal stroke: 5.07 (1.005, 25.6); Nonfatal stroke or death: 5.1 (1.53, 16.79); Nonfatal stroke, carotid revascularization, and death: 4.2 (1.55, 11.53); ACM: 4.3 (0.74, 24.15)

ǁ Death in the CEA group was a fatal stroke 28 days after surgery; 4 sudden deaths in BMT group but exact cause of death was not established.

# Death, nonfatal MI, nonfatal stroke, carotid revascularization, and coronary revascularization

Abbreviations: ACM = all-cause mortality; AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BMT = best medical treatment; CEA = carotid endarterectomy; CG = control group; CI = confidence interval; IG = intervention group; HR = hazard ratio; KQ = key question; MI = myocardial infarction; mRS = modified Rankin Scale; NA = not applicable; NR = not reported; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; TIA = transient ischemic attack; vs = verse; yr = year

In AMTEC,^35^ cumulative composite of nonfatal stroke or death at median 3.3 years’ followup was lower in the CEA group (2/31 [6.5%]) compared with the BMT group (9/24 [37.5%]) (calculated unadjusted HR 0.20 [95% CI, 0.06 to 0.65]) (Table 3). The major adverse cardiac event rate at 3.3 median years was 12.9 percent and 58.3 percent in the CEA and BMT groups, respectively. The individual outcome of nonfatal stroke was lower in the CEA group compared with the BMT group (calculated unadjusted HR 0.20 [95% CI, 0.04 to 0.995). There was no statistically significant difference in mortality between the groups (calculated unadjusted HR 0.23 [95% CI, 0.04 to 1.35]).^35^

#### CAS vs. BMT

SPACE-2^37^ additionally reported 1-year outcomes for CAS compared with BMT. No difference in the primary composite outcome (stroke or death [30 days] or ipsilateral ischemic stroke [1 year] was reported between the CAS (6/197 [3.05%]) and BMT groups (1/113 [0.9%]) (unadjusted HR 3.50 [95% CI, 0.42 to 29.11]) (Table 4). In addition, there was no difference in the individual outcomes of stroke (HR 4.70 [95% CI, 0.59 to 37.61]) or ipsilateral stroke (HR 3.47, [0.42 to 28.84]). Mortality was reported as 1.0 percent (2/197) and 3.5 percent (4/113) in the CAS and BMT groups respectively, with no hazard ratio reported.^37^

Table 4 Health Outcomes Reported in Trials of CAS vs. BMT, KQ 3

Study Name; Author, Year; Quality | Followup | Outcome | IG n analyzed | IG events (%) | CG n analyzed | CG events (%) | HR (95% CI) | P-value
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Composite (stroke or death (30-d) or ipsilateral ischemic stroke (1-yr)) | 197 | 6 (3.05%) | 113 | 1 (0.9%) | 3.50 (0.42, 29.11) | P=0.246
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Stroke^*^ | 197 | 8 (4.1%) | 113 | 1 (0.9%) | 4.70 (0.59, 37.61) | P=0.144
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Ipsilateral stroke | 197 | 6 (3.0%) | 113 | 1 (0.9%) | 3.47 (0.42, 28.84) | P=0.249
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Mortality | 197 | 2 (1.0%) | 113 | 4 (3.5%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Disabling stroke^†^ | 197 | 1 (0.5%) | 113 | 1 (0.9%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | TIA | 197 | 5 (2.5%) | 113 | 6 (5.3%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Ipsilateral TIA | 197 | 4 (2.0%) | 113 | 6 (5.3%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | MI | 197 | 0 (0%) | 113 | 0 (0%) | NR | NR
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Restenosis | 197 | 11 (5.6%) | NA | NA | NA | NA
SPACE-2; Reiff, 2019^37^; Fair | 1-yr | Re- or progressive stenosis | 197 | 11 (5.6%) | NA | NA | NA | NA

* Three strokes in the CAS arm and 1 stroke in the BMT arm occurred after day 30 (HR: 1.79 (0.19-17.24) p=0.613)

† Defined as mRS 30 days after stroke >2

Abbreviations: ACM = all-cause mortality; AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BMT = best medical treatment; CAS = carotid artery stenting; CG = control group; CI = confidence interval; IG = intervention group; HR = hazard ratio; KQ = key question; MI = myocardial infarction; mRS = modified Rankin Scale; NA = not applicable; NR = not reported; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; TIA = transient ischemic attack; vs = verse; yr = year

## KQ4 What Are the Harms Associated With Revascularization of Asymptomatic Carotid Artery Stenosis?

### Summary of Results

Since the previous review for the USPSTF on this topic, two fair-quality trials (reported in 6 articles),^33–38^ two national datasets,^28,^ ^43^ and three vascular registries (reported in 9 articles)^39–42,^ ^44–48^ reporting procedural harms from CEA (N= 1,903,761) or CAS (N= 332,103) met inclusion criteria. Overall, the highest rates of postoperative adverse events reported in analyses of national databases (Medicare data and NIS), with lower rates reported in trials and vascular surgical registries. Within the administrative databases and surgical registries, rates of 30-day postoperative stroke or death following CEA ranged from as low as 1.4 percent (Vascular Quality Initiative [VQI])^44^ to as high as 3.5 percent (Medicare data).^28^ Thirty-day postoperative mortality ranged from 0.5 percent in the VSGNE^39^ to as high as 1.1 percent in the Medicare database.^28^ Thirty-day postoperative stroke rates ranged from 0.5 percent in the VSGNE^39^ to 1.5 percent in the ACS NSQIP.^40^ Thirty-day postoperative cardiac events in ACS NSQIP publications ranged from 1.4 to 1.7 percent.^41,^ ^46,^ ^48^

For the CAS procedure, the rate of 30-day stroke or death was lowest in the VQI analysis^44^ at 2.6 percent and highest in Medicare dataset at 5.1 percent.^28^ Thirty-day postoperative mortality ranged from 1.1 percent in the VQI^44^ to 3.1 percent in the Medicare database.^28^ Thirty-day postoperative stroke rates following CAS were only reported in the VQI^44^ at 1.8 percent.

Rates of postoperative harms within the trials were generally underpowered to detect outcomes such as postoperative mortality. Within the SPACE-2 trial, the composite outcome of 30-day postoperative stroke or death was reported at 2.5 percent following both CAS and CEA. Perioperative stroke was reported in one patient (3.2%) following CEA in the AMTEC trial. The other most common harms reported within trials included hematoma, facial nerve lesion, and contrast agent incompatibility.

### Characteristics of Included Studies

In addition to the two trials from KQ3 (SPACE-2, AMTEC)^35,^ ^37^ (described above and in Table 2 and Appendix E Table 1), we identified data reported from two U.S. national databases (Medicare and NIS)^28,^ ^43^ and analyses of three U.S. surgery registries (the American College of Surgeons National Surgical Quality Improvement Program [ACS NSQIP], Vascular Quality Initiative [VQI], and the Vascular Study Group of New England [VSGNE])^39,^ ^40,^ ^44^ (Table 5, Appendix E Tables 3 and 4). We selected the most contemporary and comprehensive publications from these national databases and registries.

Table 5 Study Characteristics of Included Administrative Data and Vascular Registry Studies, KQ 4

Registry; Author, Year; Quality | Procedure type(s) | Years of data collection | Setting and source population | Total n | Total Asymptomatic n | Definition of symptomatic | Included stenosis^*^ and determination method
ACS NSQIP; Garcia, 2017^40^; Fair | CEA | 2008 to 2015 | National voluntary database for major surgical procedures | 53,593 | 53,593 | Previous stroke or TIA | NR
Medicare; Lichtman, 2017^28^; Fair | CAS, CEA | 1999 to 2014 | Medicare data for beneficiaries aged 65 years or older enrolled in fee-for-service Medicare for 1 month or longer between January 1999 and December 2014. | 1,168,188 | 1,007,102 (CAS: 192,014; CEA: 815,088) | Patients were considered symptomatic if they had an ICD-9-CM principal discharge diagnosis code indicating occlusion or stenosis of the precerebral or cerebral arteries with cerebral infarction or a secondary diagnosis code indicating prior stroke transient ischemic attack or amaurosis fugax | NR
NIS; Mayor, 2019^43^; Fair | CAS, CEA | 2005 to 2015 | NIS, an all-payer inpatient healthcare database in the US. | 1,242,688 (CEA: 1,083,912 CAS: 158,776) | 1,101,704 (CAS: 132,051; CEA: 969,653)^†^ | Symptomatic carotid artery stenosis was differentiated from asymptomatic based on the presence of 1 or more diagnosis codes indicative of amaurosis fugax, transient ischemic attack, or stroke | NR
VSGNE; Boitano, 2019^39^; Fair | CEA | 2003 to 2017^†^ | The VSGNE CEA and long-term follow-up databases were queried to identify all patients undergoing CEA from 2011 to 2017. | 18,832 | 12,392 | Patients were considered symptomatic if they experienced ipsilateral cortical or eye symptoms before the procedure. | Preoperative carotid artery stenosis was dichotomized to ≥70% stenosis and <70% stenosis. The most severe stenosis documented on preoperative duplex ultrasound, computed tomography angiography, magnetic resonance angiography, or angiography was used.
VQI; Nejim, 2019^44^; Fair | CAS, CEA | 2005 to 2017 | Prospective registry of multicenter collaboration across the United States and the Province of Ontario in Canada that captures various vascular interventions. | 89,853 | 61,073 (CAS: 8038; CEA: 53,035) | Symptomatic status was defined as the presence of ipsilateral symptoms before the procedure: amaurosis fugax, transient ischemic attack, and minor or major stroke. | Degree of stenosis was defined as the most severe stenosis of each patient carotid artery measured by duplex ultrasound, magnetic resonance angiography, computed tomography angiography, or arteriogram.

* Percent stenosis to get into the analysis NR in included studies

† Per author communication

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CAS = carotid artery stenting; CEA = carotid endarterectomy; KQ = key question; NIS = National Inpatient Sample; NA = not applicable; NR = not reported; TIA = transient ischemic attack; VSGNE = Vascular Study Group of New England; US= United States; VQI = Vascular Quality Initiative

The two largest sources of data were the national databases, which reported on both CEA and CAS. An analysis of Medicare data^28^ (1999–2014; N=1,007,102 asymptomatic adults) reported claims for beneficiaries age 65 years and older enrolled in the fee-for-service Medicare who underwent either CEA or CAS during an index hospitalization without any concomitant major surgery. Asymptomatic status was determined if their International Classification of Disease (ICD)-9 principal discharge codes for index hospitalization did not include precerebral/cerebral occlusion, cerebral infarction, TIA, or amaurosis fugax.^28^ The NIS database^43^ (2005–2015; N=1,101,704 asymptomatic adults) reported data for adults 18 years and older with ICD-9 diagnosis codes for carotid artery stenosis or a CEA or CAS procedure code. This analysis included all-payer inpatient health care services at participating institutions with unweighted data from more than 7 million hospital admissions each year. This dataset represents a 20 percent sample of hospitalizations from nonfederal U.S. community hospitals. In the analysis of NIS data, asymptomatic status was based on lack of diagnosis codes for stroke, TIA, amaurosis fugax.^43^

In addition to the two national administrative datasets, analyses related to revascularization harms were also included from three surgical registries. The VQI^44^ (2005–2017; N=61,073 asymptomatic adults) is a prospective multicenter collaborative registry across the United States and Ontario, Canada, that includes patients ages 19 to 89 years undergoing CEA or CAS. Clinical professionals extract patient- and procedure-related information from medical charts and data are validated by comparing the registry data to claims data with corrections made for any errors. Mortality data is abstracted from the Social Security Death Index. Asymptomatic status was defined by the lack of ipsilateral symptoms before the procedure (timing not specified), including stroke, TIA, or amaurosis.^44^ The VSGNE^39^ (2002–2017; N=12,392 asymptomatic adults), a subset of the VQI located in New England, is a prospectively maintained quality improvement registry for patients undergoing vascular procedures including CEA with linkage to the Social Security Death Index Master file for mortality data.^39^ The ACS NSQIP^40^ (2008–2015; N=53,593 asymptomatic adults) is a national voluntary database for major surgical procedures, including CEA, in which ICD-9 codes identify patients undergoing CEA with trained clinical extractors responsible for data reporting. Within the ASC NSQIP, asymptomatic status is determined by lack of previous TIA or stroke (timing not specified).^40^

The baseline participant data in the two trials was previously discussed in Key Question 3 (Appendix E Table 2). See Appendix E Table 5 for details on population characteristics of included administrative database and vascular registry studies. There was heterogeneity in the publications’ reporting of population characteristics: The VSGNE and NSQIP reported baseline characteristics for those with asymptomatic carotid artery stenosis undergoing CEA; Medicare and VQI reported outcomes combining asymptomatic and symptomatic populations but stratified by type of revascularization (CEA and CAS combined); and NIS reported population characteristics for all patients without stratifying by symptomatology or type of revascularization.

In examining population characteristics contributing to high CAS or stroke risk, AMTEC had a high-risk population compared to SPACE-2 and the observational studies however, amongst the observational data, no single administrative database or registry clearly had higher or lower risk population compared to the others.

For the four administrative datasets and registries reporting characteristics of those under CEA,^28,^ ^39,^ ^40,^ ^44^ the reported mean ages ranged from 70.1^39^ to 75.8 years^28^ and the ACS NSQIP reported that 68.7 percent of individuals were between 60 and 80 years.^40^ A little over one-half of participants were male, ranging from 57.3 percent^28^ to 60.5^44^ percent. Over 90 percent of participants were white (ranging from 91.2%^40^ to 96.5%^39^). Among the studies, approximately one-third of participants had diabetes and over three-quarters had hypertension. Current smoking was reported as 27.8 percent in NSQIP^40^ and ever-smoker as 75.6 and 79.2 percent in the VQI^44^ and VSGNE,^39^ respectively. Only VQI^44^ and VSGNE^39^ reported statin use; 80.3 and 84.1 percent of patients were taking statins preoperatively. Within the VSGNE, 62.8 percent had CAD, and history of congestive heart failure (CHF) was relatively rare at 10 percent or less across studies.^28,^ ^39,^ ^40,^ ^44^ The degree of stenosis or history of prior carotid revascularization was only reported within the VQI and VSGNE. Within the VQI, 61 percent had stenosis greater than 80 percent, while in VSGNE, 36.8 percent had at least 70 percent stenosis. A history of prior CEA or CAS was reported in VQI and VSGNE at approximately 15^44^ and 9^39^ percent, respectively.

Two of the administrative datasets (Medicare and VQI) provided baseline characteristics for individuals undergoing CAS; however, these characteristics pool together symptomatic and asymptomatic cases. Within the Medicare study^28^ the mean age was 75.4 percent and the VQI analysis^44^ was limited to those older than 65. Similar to the CEA population, over half of the participants were male (51–64%) and white (86–93%) with similar rates of diabetes and hypertension. Only the VQI^44^ reported the percent of individuals with a history of ever smoking (75.8%), preoperative statin use (79.8%), history of CHF (15.2%), and history of prior carotid revascularization (15.4%).

The NIS administrative database provided baseline characteristics for all patients combined: asymptomatic and symptomatic patients undergoing CEA or CAS.^43^ Mean age was 71.2 years, and over half were male (58.5%). NIS reported rates of diabetes (32.2%), hypertension (80.4%), hypercholesterolemia (58.0%), coronary artery disease (44.2%), heart failure (8.0%), COPD (18.0%), and chronic kidney disease (8.9%).^43^

Limited details were reported in these publications to further describe operative or operator characteristics (e.g., NSQIP^40,^ ^41^ and VSGNE^39^ publications report surgical technique and time; VQI^45^ reports surgeon volume).

Outcomes included stroke, death, MI, cardiac events in hospital and/or at 30 days. Other adverse events like blood transfusion, reoperation, readmission, wound infection, cranial nerve injuries were reported in the included contemporary NSQIP and VSGNE registries of asymptomatic patients.

### Study Quality and Applicability

Measurement bias is a concern for all of the included administrative databases and registries for KQ4 (Appendix E Table 4). Because data from the national administrative databases (Medicare and NIS) are extracted from administrative data used primarily for billing, there is some concern about omission or coding errors. ACS NSQIP uses trained clinical reviewers, and VSGNE and VQI data abstraction is performed by clinical professionals (often the surgeons themselves), so while data abstraction comes from patient charts in addition to billing codes, there is a lack of blinding and concerns about potential measurement bias.

Selection bias is a major concern for all included studies for KQ4. Registry patient selection varied from 100 percent capture from voluntary physicians in VQI to “systematic sampling” in ACS NSQIP. While we abstracted outcomes solely for the asymptomatic population in this review, the designation of “asymptomatic” status was variably defined and, when reported, it was largely was based on history of TIA, stroke, or prior carotid procedures. The administrative databases are limited to diagnosis codes for stroke or TIA during the index admissions and may therefore miss prior neurologic events or symptoms. There remains some concern about selection bias when highly selected surgeons participate in the registries; these surgeons’ complication rates may or may not be representative of national rates. Furthermore, careful patient selection in these registries may contribute to the lower estimates seen in registries compared to the administrative databases.

### Detailed Results by Outcome in Asymptomatic Population

#### CEA

##### 30-Day Stroke or Death

One trial reported composite stroke or death outcomes (Table 6). Two studies of administrative data and three vascular registry studies reported composite outcomes of stroke or death (Table 7). The SPACE-2 trial reported that 5/203 (2.5%) individuals in the CEA arm met the composite endpoint of 30-day stroke or death rate.^37^ A higher rate of 3.5 percent was reported by the large Medicare administrative database.^28^ However, the vascular registries reported rates as low as 1.4^44^ to 1.7^47^ percent. The low rate in the primary VQI study is similar in other VQI publications at 1.1 percent to 1.6 percent.^42,^ ^45,^ ^48^ One VQI analysis^42^ reported no significant difference in adjusted risk of stroke or death based on degree of stenosis (severe [60-79%] vs. very severe stenosis [≥80%]). While the NIS did not report 30-day outcomes, the rate of major adverse events (including stroke, acute MI, or mortality) occurring in-hospital was 3.1 percent.^43^

Table 6 Postoperative Harms Reported in Trials of CEA vs. BMT, KQ 4

Study Name; Author, Year; Quality | Outcome | Followup | N analyzed | N with outcome (%)
SPACE-2; Reiff, 2019^37^; Fair | Stroke or death | 30-d | 203 | 5 (2.5%)
SPACE-2; Reiff, 2019^37^; Fair | Stroke | Day of intervention | 203 | 4 (2.0%)
SPACE-2; Reiff, 2019^37^; Fair | Stroke | 30-d | 203 | 5 (2.5%)
SPACE-2; Reiff, 2019^37^; Fair | Ipsilateral stroke | 30-d | 203 | 4 (2.0%)
SPACE-2; Reiff, 2019^37^; Fair | Mortality | 30-d | 203 | 0 (0%)
SPACE-2; Reiff, 2019^37^; Fair | MI | 30-d | 203 | 0 (0%)
SPACE-2; Reiff, 2019^37^; Fair | Other Peri/postoperative complications: | 30-d | 203 | 10 (4.9%)
SPACE-2; Reiff, 2019^37^; Fair | Lesion vagal nerve | 30-d | 203 | 10 (4.9%)
SPACE-2; Reiff, 2019^37^; Fair | Lesion hypoglossal nerve | 30-d | 203 | 7 (3.4%)
SPACE-2; Reiff, 2019^37^; Fair | Lesion facial nerve | 30-d | 203 | 14 (6.9%)
SPACE-2; Reiff, 2019^37^; Fair | Wound hematoma * | 30-d | 203 | 24 (11.8%)
SPACE-2; Reiff, 2019^37^; Fair | Facial hypesthesia | 30-d | 203 | 4 (2.0%)
SPACE-2; Reiff, 2019^37^; Fair | Dissection of carotid artery | 30-d | 203 | 1 (0.5%)
SPACE-2; Reiff, 2019^37^; Fair | Hypotonia/vasovagal reaction | 30-d | 203 | 1 (0.5%)
AMTEC; Kolos, 2015^35^; Fair | Fatal stroke | 30-d | 31 | 1 (3.2%)
AMTEC; Kolos, 2015^35^; Fair | Other complications: | Perioperative^§^ | 31 | 1 (3.2%)
AMTEC; Kolos, 2015^35^; Fair | Cranial nerve palsy | Perioperative^§^ | 31 | 1 (3.2%)
AMTEC; Kolos, 2015^35^; Fair | >70% Restenosis of the ICA | Perioperative^§^ | 31 | 2 (6.5%)
AMTEC; Kolos, 2015^35^; Fair | Acute occlusion of ICA | Perioperative^§^ | 31 | 1 (3.2%)

* Reoperation and hematoma evacuation in one patient

§ Timing not specified

Abbreviations: AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BMT = best medical treatment; CAS = carotid artery stenting; ICA = internal carotid artery KQ = key question; MI = myocardial infarction; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; vs = verse; yr = year

Table 7 Postoperative Adverse Composite Outcomes Reported in CEA Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Study reported outcome | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
ACS NSQIP^†^; Liang 2020^47^ | Stroke/Death | 30-d | 14,756 | 225 | 1.7%
ACS NSQIP^†^; Liang 2020^47^ | MAE (composite of stroke, death, cardiac event) | 30-d | 14,756 | 478 | 3.2%
Medicare; Lichtman, 2017^28^; Fair | Ischemic stroke or death^‡^ | 30-d | 815,088 | 28,212 | 3.5%
Medicare; Lichtman, 2017^28^; Fair | Ischemic stroke, MI or death^‡^ | 30-d | 815,088 | 30,564 | 3.7%
NIS; Mayor, 2019^43^; Fair | MAE (stroke, acute MI, in-hospital mortality) | In Hospital | 969,653^§^ | 29,962 | 3.1%
VSGNE; Boitano, 2019^39^; Fair | MAE (Composite of stroke, MI, or death.) | 30-d | 12,392 | 228 | 1.8%
VQI; Nejim, 2019^42,^ ^44^; Fair | Stroke/death | 30-d | 53,035 | 735 | 1.4%

* Data was calculated across subgroups for all studies except ACS NSQIP (Liang 2020)

† Data for stroke/death composite outcome taken from ancillary publication of ACS NSQIP, patients undergoing CEA from 2011-2017.

‡ Ischemic stroke and MI events were determined from the date of hospital discharge for the index carotid procedure. Death was determined from the date of hospital admission for the index carotid procedure

§ Asymptomatic n was provided by authors

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CEA = carotid endarterectomy; KQ = key question; MAE = major adverse event; NIS = National Inpatient Sample; VSGNE = Vascular Study Group of New England; VQI = Vascular Quality Initiative

##### 30-Day Mortality

One trial reported results for 30-day mortality (Table 6). Two studies of administrative data and three vascular registry studies reported 30-day or in-hospital mortality (Table 8). There were no deaths reported at 30 days within the CEA arm of the SPACE-2 trial.^37^ The highest rate of 30-day mortality was reported within the Medicare database at 1.1 percent.^28^ Lower rates were reported within the three surgical registries and ranged from 0.5^39^ to 0.7^40^ percent. Thirty-day mortality rates were not reported by the NIS; however, the in-hospital mortality rate was 0.3 percent.^43^

Table 8 Postoperative Mortality Reported in CEA Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
ACS NSQIP; Garcia, 2017^40^; Fair | 30-d | 53,593 | 396 | 0.7%
Medicare; Lichtman, 2017^28^; Fair | 30-d^†^ | 815,088 | 9144 | 1.1%
Medicare; Lichtman, 2017^28^; Fair | In Hospital^‡^ | 815,088 | 4444 | 0.5%
NIS; Mayor, 2019^43^; Fair | In Hospital | 969,653^§^ | 2,521 | 0.3%
VSGNE; Boitano, 2019^39^; Fair | 30-d | 12,392 | 58 | 0.5%
VQI; Nejim, 2019^44^; Fair | 30-d | 53035 | 320 | 0.6%

* Data was calculated across subgroups for all studies

† Death was determined from the date of hospital admission for the index carotid procedure

‡ Death was determined from Discharge disposition

§ Asymptomatic n was provided by authors

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CEA = carotid endarterectomy; KQ = key question; NIS = National Inpatient Sample; VSGNE = Vascular Study Group of New England; VQI = Vascular Quality Initiative

##### 30-Day Stroke

One trial reported 30-day stroke outcomes (Table 6). One study of administrative data and three vascular registry studies reported 30-day or in-hospital stroke outcomes (Table 9). In the SPACE-2 trial, 5/203 (2.5%) of individuals in the CEA arm had a stroke within 30 days of the procedure; the majority (4/5) of these strokes occurred on the day of the intervention.^37^ The AMTEC trial did not report 30-day stroke rates; however, the trial did report one fatal stroke within 30 days of surgery.^35^ Thirty-day stroke rates were reported in all three surgical registries and ranged from 0.5 percent in the VSGNE^39^ to 1.5 percent in ACS NSQIP.^40^ Three smaller ACS NSQIP publications showed similar 30-day stroke rates (1.2%^41^ and 1.3%^46,^ ^47^). Neither of the administrative databases reported 30-day stroke rates.^28,^ ^43^ The NIS study reported in-hospital stroke rate at 0.3 percent.^43^

Table 9 Postoperative Stroke Reported in CEA Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Study reported outcome | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
ACS NSQIP; Garcia, 2017^40^; Fair | Stroke | 30-d | 53,593 | 788^†^ | 1.5%
NIS; Mayor, 2019^43^; Fair | Stroke | In Hospital | 969,653^‡^ | 2,909 | 0.3%
VSGNE; Boitano, 2019^39^; Fair | Stroke | 30-d | 12,392 | 57 | 0.5%
VSGNE; Boitano, 2019^39^; Fair | Stroke or TIA | 30-d | 12,392 | 163 | 1.3%
VSGNE; Boitano, 2019^39^; Fair | Ipsilateral Stroke | 30-d | 12,392 | 66 | 0.5%
VQI; Nejim, 2019^44^; Fair | Stroke | 30-d | 53035 | 416 | 0.8%

* Data was calculated across subgroups for all studies

† Number of events confirmed by author communication

‡ Asymptomatic n was provided by authors

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CEA = carotid endarterectomy; KQ = key question; NIS = National Inpatient Sample; TIA = transient ischemic attack; VSGNE = Vascular Study Group of New England; VQI = Vascular Quality Initiative

##### Postoperative Cardiovascular Events

One trial reported postoperative cardiovascular events (Table 6). One study of administrative data and two vascular registry studies reported postoperative CV events (Table 10). There were no MIs reported within 30 days in the SPACE-2 trial.^37^ The NIS reported in hospital acute MI or other cardiac complications of 2.7 percent^43^. Lower rates of cardiovascular events were reported in the vascular registries compared with NIS with in-hospital MIs reported in VSGNE as 0.8 percent^39^ and 30-day cardiac events were reported in ACS NSQIP publications as 1.4^41^ and 1.7^46,^ ^47^ percent. The primary ACS NSQIP study reported 30-day postoperative rate of MI, pneumonia, DVT/thrombophlebitis, PE, or renal failure of 2.0 percent.^40^

Table 10 Postoperative Cardiovascular Events Reported in CEA Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Study reported outcome | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
ACS NSQIP; Garcia, 2017^40^; Fair | MI, PNA, DVT/thrombophlebitis, PE, renal failure | 30-d^†^ | 53,593 | 1063 | 2.0%
NIS; Mayor, 2019^43^; Fair | MI^‡^ | In Hospital | 969,653^§^ | 26,084 | 2.7%
VSGNE; Boitano, 2019^39^; Fair | MI | In Hospital | 12,392 | 101 | 0.8%

* Data was calculated across subgroups for all studies

† Outcome assessment timing confirmed by author

‡ Postoperative MI included both acute MI and other cardiac complications

§ Asymptomatic n was provided by authors

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CEA = carotid endarterectomy; DVT = deep venous thrombosis; KQ = key question; MI = Myocardial infarction; NIS = National Inpatient Sample; PE = pulmonary embolism; PNA = pneumonia; VSGNE = Vascular Study Group of New England

##### Other Adverse Events

Both included trials (Table 6) and two vascular registry studies (Table 11) reported additional adverse events. SPACE-2 reported the most common complication at 30 days to be wound hematoma (11.8%) followed by facial nerve lesion (6.9%).^37^ Carotid dissections were reported in 1/203 (0.5%) individuals undergoing CEA. AMTEC reported one patient (3.2%) had cranial nerve palsy and two (6.5%) had >70% restenosis of the ICA (CAS was successfully performed in both patients), and an acute occlusion of the ICA was identified 12 hours after CEA in one patient (3.2%).^35^ ACS NSQIP and VSGNE reported other complications: Cranial nerve injury rates were reported at 4.0 percent in the VSGNE^39^ and 2.9 percent in an ACS NSQIP publication^46^; 30-day reoperations occurred in 3.2 percent of cases in the ACS NSQIP;^40^ and in-hospital return to the operating room occurred in 1.4 percent of cases in the VSGNE.^39^ The overall 30-day readmission rate in the ACS NSQIP was 5.2 percent.^40^

Table 11 Other Postoperative Adverse Events Reported in CEA Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Study reported outcome | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
ACS NSQIP; Garcia, 2017^40^; Fair | Blood transfusion | Operative/Postoperative (timing not specified) | 53,593 | 954 | 1.8%
ACS NSQIP; Garcia, 2017^40^; Fair | Reoperation | 30-d | 53,593 | 1727 | 3.2%
ACS NSQIP; Garcia, 2017^40^; Fair | Readmission | 30-d | 53,593 | 2798 | 5.2%
ACS NSQIP; Garcia, 2017^40^; Fair | SSI | Postoperative (timing not specified) | 53,593 | 209 | 0.4%
VSGNE; Boitano, 2019^39^; Fair | Return to OR | In Hospital | 12,392 | 174 | 1.4%
VSGNE; Boitano, 2019^39^; Fair | Dysrhythmia | In Hospital | 12,392 | 174 | 1.4%
VSGNE; Boitano, 2019^39^; Fair | Reperfusion syndrome | In Hospital | 12,392 | 20 | 0.2%
VSGNE; Boitano, 2019^39^; Fair | Wound infection | In Hospital | 12,392 | 7 | 0.06%
VSGNE; Boitano, 2019^39^; Fair | Cranial nerve injury | In Hospital | 12,392 | 494 | 4.0%

* Data was calculated across subgroups for all studies

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CEA = carotid endarterectomy; KQ = key question; MI = myocardial infarction; OR = operating room; SSI = surgical-site infection VSGNE = Vascular Study Group of New England

#### CAS

##### 30-Day Stroke or Death

One trial, two administrative database studies, and one vascular registry study reported composite stroke or death outcomes (Table 12 and Table 13). Within the SPACE-2 trial stroke or death occurred within 30-days of stenting in 5/197 (2.5%) individuals^37^. The Medicare administrative database 30-day stroke or death rate of 5.1 percent was double that of the SPACE-2 trial.^28^ Rates in the VQI were similar to the trial data; VQI reported 30 day stroke or death of at 2.6 percent.^44^ One VQI analysis of only >60% stenosis showed a 30 day stroke or death rate of 1.9 percent.^42^ Another VQI analysis^42^ reported no significant difference in adjusted risk of stroke or death based on degree of stenosis (severe [60–79%] vs. very severe stenosis [≥80%]). A smaller, more contemporary analysis (2012-2017) found females experienced a higher rate of perioperative stroke/death (2.9% vs 1.9%) following CAS.^48^ While 30-day outcomes were not reported in the NIS, rates of reported in-hospital acute MI, stroke, or death as were 3.6 percent.^43^

Table 12 Postoperative Harms Reported in Trials of CAS vs. BMT, KQ 4

Study Name; Author, Year; Quality | Outcome | Followup | N analyzed | N with outcome (%)
SPACE-2; Reiff, 2019^37^; Fair | Stroke or death | 30-d | 197 | 5 (2.5%)
SPACE-2; Reiff, 2019^37^; Fair | Stroke | Day of intervention | 197 | 3 (1.5%)
SPACE-2; Reiff, 2019^37^; Fair | Stroke | 30-d | 197 | 5 (2.5%)
SPACE-2; Reiff, 2019^37^; Fair | Ipsilateral stroke | 30-d | 197 | 5 (2.5%)
SPACE-2; Reiff, 2019^37^; Fair | MI | 30-d | 197 | 0 (0%)
SPACE-2; Reiff, 2019^37^; Fair | Mortality | 30-d | 197 | 0 (0%)
SPACE-2; Reiff, 2019^37^; Fair | Other peri/postoperative complications: | 30-d | 197 | 2 (1.0%)
SPACE-2; Reiff, 2019^37^; Fair | Aneurysm of femoral artery | 30-d | 197 | 2 (1.0%)
SPACE-2; Reiff, 2019^37^; Fair | Nerve injury | 30-d | 197 | 1 (1.0%)
SPACE-2; Reiff, 2019^37^; Fair | Incompatibility of contrast agent | 30-d | 197 | 3 (1.5%)
SPACE-2; Reiff, 2019^37^; Fair | Hematoma of femoral artery | 30-d | 197 | 4 (2.0%)
SPACE-2; Reiff, 2019^37^; Fair | Hypotonia/ vasovagal reaction | 30-d | 197 | 2 (1.5%)
SPACE-2; Reiff, 2019^37^; Fair | Delirium | 30-d | 197 | 2 (1.0%)

Abbreviations: BMT = best medical treatment; CAS = carotid artery stenting; KQ = key question; MI = myocardial infarction; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; vs = verse;

Table 13 Postoperative Adverse Composite Outcomes Reported in CAS Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Study reported outcome | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
Medicare; Lichtman, 2017^28^; Fair | Ischemic stroke or death^†^ | 30-d | 192,014 | 9711 | 5.1%
Medicare; Lichtman, 2017^28^; Fair | Ischemic stroke, MI or death^†^ | 30-d | 192,014 | 10,369 | 5.4%
NIS; Mayor, 2019^43^; Fair | MAE^‡^ | In Hospital | 132,051^§^ | 4,807 | 3.6%
VQI; Nejim, 2019^44^; Fair | Stroke/death | 30-d | 8038 | 212 | 2.6%

* Data was calculated across subgroups for all studies

† Ischemic stroke and MI events were determined from the date of hospital discharge for the index carotid procedure. Death was determined from the date of hospital admission for the index carotid procedure

‡ A major adverse event constituted a composite variable reflecting one or more of the other outcomes (stroke, acute MI, in-hospital mortality)

§ Asymptomatic n was provided by authors

Abbreviations: CAS = carotid artery stenting; KQ = key question; MAE = major adverse event; MI = myocardial infarction; NIS = National Inpatient Sample; VQI = Vascular Quality Initiative

##### 30-Day Mortality

One trial, one vascular registry study and two administrative database studies reported mortality outcomes (Table 12 and Table 14). There were no deaths within 30 days of stenting in the SPACE-2 trial.^37^ 30-day mortality was reported as low as 1.1 percent^44^ in VQI and as high as 3.1 percent^28^ in Medicare data. In-hospital deaths were as low as 0.4 percent^43^ in the NIS and as high as 1.5 percent^28^ in Medicare administrative data.

Table 14 Postoperative Mortality Reported in CAS Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
Medicare; Lichtman, 2017^28^; Fair | 30-d^†^ | 192,014 | 5910 | 3.1%
Medicare; Lichtman, 2017^28^; Fair | In Hospital^‡^ | 192,014 | 2920 | 1.5%
NIS; Mayor, 2019^43^; Fair | In Hospital | 132,051^§^ | 475 | 0.4%
VQI; Nejim, 2019^44^; Fair | 30-d | 8038 | 87 | 1.1%

* Data was calculated across subgroups for all studies

† Death was determined from the date of hospital admission for the index carotid procedure

‡ Death was determined from discharge disposition

§ Asymptomatic n was provided by authors

Abbreviations: CAS = carotid artery stenting; KQ = key question; NIS = National Inpatient Sample; VQI = Vascular Quality Initiative

##### 30-Day Stroke

One trial, one administrative database study, and one vascular registry study reported ≤30-day stroke outcomes (Table 12 and Table 15). The 30-day stroke rate in SPACE-2 was 5/197 (2.5%); all of the strokes were ipsilateral.^37^ VQI reported a 30-day stroke rate of 1.8 percent,^44^ and the NIS reported the rate of in-hospital stroke of 0.4 percent.^43^

Table 15 Postoperative Stroke Reported in CAS Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
NIS; Mayor, 2019^43^; Fair | In Hospital | 132,051^†^ | 581 | 0.4%
VQI; Nejim, 2019^44^; Fair | 30-d | 8038 | 143 | 1.8%

* Data was calculated across subgroups for all studies

† Asymptomatic n was provided by authors

Abbreviations: CAS = carotid artery stenting; KQ = key question; NIS = National Inpatient Sample; VQI = Vascular Quality Initiative

##### Postoperative Cardiac Events

One trial and one administrative database study reported postoperative cardiac events (Table 12 and Table 16). There were no MIs within 30 days of CAS in the SPACE-2 trial.^37^ The NIS reported a rate of in-hospital acute MI and other cardiac complications of 3.1 percent.^43^

Table 16 Postoperative Cardiovascular Outcomes Reported in CAS Registries and Administrative Data, KQ 4

Registry; Author, Year; Quality | Study reported outcome | Followup | N analyzed^*^ | Events^*^ | Event rates^*^
NIS; Mayor, 2019^43^; Fair | MI^†^ | In Hospital | 132,051^‡^ | 4,146 | 3.1%

* Data was calculated across subgroups for all studies

† Postoperative MI included both acute MI and other cardiac complications

‡ Asymptomatic n was provided by authors

Abbreviations: CAS = carotid artery stenting; KQ = key question; MI = myocardial infarction; NIS = National Inpatient Sample

##### Other Adverse Events

One trial reported other postprocedural adverse events (Table 12). SPACE-2 reported the most common complication at 30 days to be femoral artery hematoma (2.0%) followed by contrast agent incompatibility (1.5%), hypotonia/vagal reaction (1.5%), and nerve injury (1.0%), and delirium (1.0%).^37^ None of the surgical registries reported other adverse events for the CAS procedure.