# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence report to update its 2014 D recommendation on screening for asymptomatic carotid artery stenosis. Given that this topic was commissioned as a targeted, rapid update of screening in the general population, we only updated key questions for benefits and harms of screening and treatment.^29^ The results discussed in this report are limited to studies published since the previous review to support the 2014 recommendation.

## Key Questions and Analytic Framework

In consultation with members of the USPSTF, we developed an analytic framework (Figure 1) and four Key Questions (KQs) to guide our focused evidence update.

Figure 1 Analytic Framework

Figure 1 is the analytic framework that depicts the four Key Questions to be addressed in the review. The figure illustrates how screening for carotid artery stenosis may result in improved health outcomes, including reducing mortality and stroke rate as well as improving quality of life, functional status, or cognitive status (KQ1). Additionally, the figure depicts the effects of revascularization of carotid artery stenosis on health outcomes in a previously screened, asymptomatic population (KQ3), as well as harms associated with screening (KQ2) and treatment (KQ4).

### KQs

1. Is there direct evidence that screening asymptomatic adults for carotid artery stenosis with duplex ultrasonography improves health outcomes?
2. What are the harms associated with screening or confirmatory testing for asymptomatic carotid artery stenosis?
3. For asymptomatic persons with carotid artery stenosis, does revascularization provide incremental benefit beyond current medical treatment?
4. What are the harms associated with revascularization of asymptomatic carotid artery stenosis?

## Data Sources and Searches

We conducted a literature search of MEDLINE, PubMed Publisher-Supplied Records, and the Cochrane Central Register of Controlled Trials (CENTRAL) from January 1, 2014, to February 14, 2020, to identify literature published since the previous review for the USPSTF. We worked with a research librarian to develop our search strategy, which was peer-reviewed by a second research librarian (Appendix A). We supplemented these searches by examining reference lists of recent reviews and primary studies. We limited our searches to articles published in English and managed search results using Endnote® version X7 (Thomson Reuters, New York, NY). Additionally, we conducted ongoing surveillance for relevant literature through November 20, 2020.

## Study Selection

We developed specific inclusion criteria to guide study selection (Appendix A Table 1). Two reviewers independently reviewed the title and abstracts of all identified articles using DistillerSR (Evidence Partners, Ottawa, Canada). Two reviewers then independently evaluated the full text of all potentially relevant articles, with differences reviewed by discussion.

For evidence on the benefits (KQ1) and potential harms (KQ2) of screening for asymptomatic carotid artery stenosis, we included randomized controlled trials of screening with carotid duplex ultrasonography compared with no screening. Ultrasound was the only screening modality considered for this review. Ideally, eligible populations would include unselected or community-dwelling adults without neurologic symptoms or a known history of stroke or TIA (at any time). However, the definition of “asymptomatic” status varied within trials and generally included those without a history of TIA, stroke, or symptoms in the previous 6 months. Likewise, observational studies for harms (KQ4) variably defined “asymptomatic.”

For evidence on the incremental benefits of revascularization beyond current medical treatment (KQ3), we included randomized trials of revascularization versus medical management. Populations included in trials were required to be generally asymptomatic adults (>80% of participants were asymptomatic or outcomes were stratified based on asymptomatic status) with clinically important CAS (as defined by the trials). Eligible carotid interventions included carotid endarterectomy (CEA), carotid artery stenting (CAS), and transcarotid artery revascularization (TCAR). Eligible comparison groups were those that included best medical treatment or usual care. Studies of the comparative effectiveness of surgical treatments were excluded.

For evidence on harms of revascularization (KQ4), we included any adverse events reported in the trials included for KQ3. In addition, we considered retrospective analyses of the two largest U.S.-based nationally representative administrative databases (Medicare, National Inpatient Sample [NIS]) as well as surgical registries with at least 10,000 asymptomatic cases. Due to the limited scope of this targeted, rapid review, we used an auditing process to select the most recent comprehensive publication from each national database or registry (Appendix A Table 2).

Outcomes for studies of benefit (KQ1, KQ3) included stroke, mortality, quality of life, functional status, and cognitive status. For studies on potential screening harms (KQ2), we included adverse outcomes related to the screening test as well as any subsequent confirmatory testing. For studies of procedural harms (KQ4), we included perioperative complications occurring up to 30 days following the procedure.

For randomized trials we limited studies to those conducted in countries categorized as “very high” on the Human Development Index.^30^ For surgical registries or hospital outcome data, we included studies in which the majority of individuals received treatment in the United States.

## Quality Assessment and Data Abstraction

Two reviewers independently assessed the methodological quality of each included study using predefined criteria (Appendix A Table 3). We assigned each study a quality rating of “good,” “fair,” or “poor” according to the USPSTF’s study design-specific criteria.^31^ All studies identified in this review were rated as fair quality. We supplemented these criteria with modified questions from the Newcastle-Ottawa Scale.^32^ Disagreements were resolved by discussion. We abstracted details on the study’s design, patient characteristics, intervention characteristics, and outcomes specified in the inclusion criteria.

## Data Synthesis and Analysis

This report is a rapid review to provide an overview of evidence published since the USPSTF last considered this topic in 2014. Therefore, it narratively describes the results of newly identified publications only. Results of studies included in previous evidence reviews are not pulled forward into the report, and no pooled analyses were conducted. Where necessary, results from included studies were recalculated so that they were comparable across studies (e.g., intervention and comparator groups were reversed to create comparable summary statistics). Any calculated outcomes are indicated in the evidence tables with footnotes. We included a summary table comparing the conclusions of this review to the previous review.^2^

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from August 15 through September 11, 2019. The draft Research Plan was additionally reviewed by USPSTF Federal Partners from the CDC and clarifications were made as appropriate. A final research plan was posted on the USPSTF’s Web site on November 14, 2019.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. Additionally, a draft of this report was posted for public comment on the USPSTF Web site from August 4, 2020 to August 31, 2020. Few comments were received during this public comment period; minor clarifications and editorial changes were made to the report based on these comments, but no changes were made to the included evidence or to our conclusions. Comments suggested that ongoing research may help clarify those groups at high-risk for stroke that may benefit most from screening for carotid artery stenosis.

## USPSTF Involvement

This evidence update was funded by an AHRQ contract to support the USPSTF. We consulted with USPSTF members during the development of the research plan, including the analytic framework, KQs, and inclusion criteria. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the evidence update, and assisted with public comment on the research plan and draft report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the evidence update.