# Chapter 1 Introduction

## Purpose

The Agency for Healthcare Research and Quality (AHRQ) has requested a targeted, rapid update focused on screening and treatment of asymptomatic carotid artery stenosis in the general population. This topic was last reviewed in 2014.^1,^ ^2^ The report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2014 recommendation on this topic.^3^

## Condition Background

### Condition Definition

Carotid artery stenosis is atherosclerotic systemic disease manifesting in the extracranial carotid arteries. Asymptomatic carotid atherosclerotic disease refers to the presence of stenosis in individuals without a history of ischemic stroke, transient ischemic attack (TIA), or other neurologic signs or symptoms.^4^ The definition of “asymptomatic” status varies within trials of carotid artery stenosis treatment and generally includes those without a history of TIA, stroke, or symptoms in the previous 6 months. Severe narrowing of the carotid artery is clinically significant due to its correlation with stroke risk.^5^ The clinically important degree of stenosis is considered the percentage of stenosis that corresponds to a substantial increased risk for stroke. The USPSTF recommendations^3^ consider 60 to 99 percent stenosis to be clinically important. Some earlier trials of treatment considered a lower threshold of 50 to 99 percent stenosis to be clinically important.^2^ The categories of stenosis severity which are historically based on duplex ultrasound estimates are as follows: moderate (50% to 69%) and severe (70% to 99%); severity estimation may vary by imaging modality with magnetic resonance angiography (MRA) leading to overestimates in degree of stenosis.^6^ The USPSTF defines persons with asymptomatic carotid artery stenosis as those without a history of transient ischemic attack, stroke, or other neurologic signs or symptoms.^3^

### Prevalence and Burden

The prevalence of asymptomatic carotid artery stenosis is low in the general population but increases with age. Population-based studies define asymptomatic carotid artery stenosis as a lack of history of TIA, stroke, or carotid revascularization, or do not clearly report how asymptomatic status was defined. As a result, the prevalence of asymptomatic carotid artery stenosis (60-99%) as defined above by the USPSTF may be lower than that published in population-based studies. A 2010 individual participant data meta-analysis (IPD-MA)^7^ of four population-based studies of over 23,000 participants found the prevalence estimates of moderate asymptomatic carotid artery stenosis (defined as ≥50 percent stenosis) increased with age and was more common among men; the majority of participants in these cohorts were Caucasian. Among men, prevalence of carotid artery stenosis increased from 0.2 percent among those under age 50 years to 7.5 percent in men age 80 years and older. Similarly, among women the prevalence increased from essentially no cases to 5 percent after age 80 years. The prevalence of severe stenosis (defined as ≥70 percent stenosis) was even lower in this population but also increased with age to approximately 3 percent and 1 percent for men and women age 80 and older, respectively.^7^ One U.S. study of self-referred individuals (n=3,291,382), found the prevalence of clinically significant carotid artery stenosis (≥50% stenosis) of 3.4 percent in women and 4.2 percent in men. These rates varied significantly by race, with Native American and white individuals having the highest prevalence and African American males and Asian females having the lowest. Prevalence trends remained the same in their analysis of more severe degrees of stenosis (≥80%).^8^ There is limited data estimating the prevalence of asymptomatic carotid artery stenosis in nonwhite populations.

The most serious consequence of carotid artery stenosis is ischemic stroke; however, only 11% of strokes are attributable to asymptomatic carotid artery stenosis.^9^ Furthermore, among patients who have at least 50 percent stenosis, one analysis estimates the risk of stroke is low at less than one percent annually, and about 5.5 percent of individuals in reasonably good health become symptomatic with stroke from the lesion during their lifetime.^10^ The Asymptomatic Carotid Surgery Trial 1 (ACST-1) reports that 11.7 percent in the best medical therapy group required CEA for symptoms over 10 years.^11^ These estimates are based on older studies and may overestimate the risk of individuals treated with current best medical management.

### Risk Factors

Risk factors for the development of carotid artery stenosis are similar to those for coronary artery disease (CAD) and other peripheral vascular disease (e.g., advanced age, hypertension, smoking, diabetes, high cholesterol).^12,^ ^13^ Numerous individual risk factors can contribute to stroke risk but generally, major risk factors include hypertension, heart disease, smoking, diabetes, high cholesterol, advanced age, and male sex.^14^ The current review solely addresses screening in the general asymptomatic population.

### Rationale for Screening and Screening Strategies

Carotid artery stenosis is a known risk factor for stroke and a marker of increased risk for myocardial infarction (MI) and vascular death.^15–17^ The potential benefit of screening for stenosis would be to reduce risk of these events in asymptomatic patients. Screening and confirmation testing using noninvasive imaging studies of the carotid artery can be accomplished with carotid duplex ultrasonography, magnetic resonance angiography (MRA) and computed tomography angiography (CTA). Auscultation for carotid bruits alone during physical examination has been found to be a poor predictor of underlying carotid stenosis or stroke risk in asymptomatic populations and is therefore not considered a reasonable screening approach.^18,^ ^19^. Conventional cerebral angiography is the gold standard for imaging but is not recommended for screening as it is costly and invasive and has risk of stroke and morbidity. Studies have shown this procedure to have risk of permanent neurological complications (at approximately 1%).^20,^ ^21^

### Treatment Approaches

Uncertainty exists about the optimal treatment modality for clinically significant asymptomatic carotid artery stenosis in order to prevent future stroke. Both medical and revascularization options are available. Meta-analysis of three landmark trials (ACST, ACAS, VA) (N=5226) estimate that CEA is associated with a 3.5% (1.8 to 5.1%) absolute reduction in stroke or death at 5 years compared to BMT. (Jonas); however, currently, there are not consistent opinions on which management strategy is best.^10,^ ^22^ One approach to managing asymptomatic carotid stenosis centers on best medical therapy which involves statins, antiplatelets, treatment of hypertension or diabetes, and lifestyle modification counseling.^23^ This approach aims to reduce not only future stroke but also overall CVD-related morbidity and mortality. The best medical therapy approach can be used alone or in combination with one of the revascularization techniques. Potential procedural options include revascularization with carotid endarterectomy (CEA) and carotid artery stenting (CAS). CEA can be performed under general or local anesthesia and involves open surgical exposure of the carotid artery and the removal of plaque to improve arterial patency. CAS is usually performed under local anesthesia and involves femoral or brachial arterial catheter approaches to carotid angiography, angioplasty, and stent placement. There is much debate about the comparative benefits and risks of CEA versus CAS.^23,^ ^24^ Additionally, transcarotid artery revascularization (TCAR) is a newer procedural approach in which stenting is performed via direct arterial access in the common carotid artery from a supraclavicular area.

### Current Clinical Practice in the United States

#### Screening

Data from 2009 Medicare claims found that screening for asymptomatic carotid artery stenosis (defined as screening among those without a history of stroke, TIA, or focal neurological symptoms) occurred in 6.6 per 100 beneficiaries.^25^ An analysis of Veterans Health Administration patients age 65 years and older undergoing carotid revascularization for asymptomatic carotid stenosis between 2005 and 2009 found that the rates of appropriate, uncertain, and inappropriate imaging were 5.4 percent, 83.4 percent, and 11.3 percent, respectively, based on expert opinion.^26^ The most common indications listed for carotid imaging were carotid bruit (30.2% of indications) and followup of patients who had previously documented carotid stenosis (20.8% of indications).^26^

#### Surgical Repair

A recent report from the American Heart Association found that in 2014,^27^ the most frequently performed surgical procedure to prevent stroke in the United States was CEA; an estimated 86,000 inpatient procedures were performed (tabulation of Healthcare Cost and Utilization Project, National Heart, Lung, and Blood Institute). This report also tabulated that trends of this procedure decreased annually between 1997 and 2014, while the use of CAS increased between 2004 and 2014.^27^ Accurate data on current rates of CEA and CAS for asymptomatic patients in the general population are limited as symptomatic status is generally not detailed in large registries or administrative data sets. However, a recent study of Medicare claims data between 1999 and 2014 reported that 815,088 CEA procedures were performed, compared with 192,014 CAS procedures, in asymptomatic patients, defined as individuals without a principal discharge coding indicating cerebral infarction or a secondary diagnosis code indicating prior stroke, TIA, or amaurosis fugax.^28^ Observations over 16 years showed a decline in CEA procedures performed in asymptomatic patients, while carotid artery stenting trends increased between 1999 and 2006 and decreased from 2007–2014.^28^

### Recent Recommendations

No professional society recommends screening in the general population. National guidelines are not consistent regarding the role of screening in an asymptomatic population. The USPSTF and American Heart Association/American Stroke Association (AHA/ASA) recommend against routine screening of asymptomatic patients for carotid artery stenosis; however, the American Institute of Medicine and joint guidelines of multiple U.S. professional societies concluded that screening is indicated (or reasonable) for asymptomatic patients with a carotid bruit. While the Society for Vascular Surgery (SVS) and joint guidelines from multiple U.S. professional societies recommend consideration of screening in those with multiple risk factors and those with other known peripheral arterial disease or cardiovascular disease. (Table 1).

Table 1 Summary of Recommendations for Screening for Asymptomatic Carotid Artery Stenosis

Organization, Year | Summary of recommendation
United States Preventive Services Task Force, 2014^3^ | The USPSTF recommends against screening for asymptomatic carotid artery stenosis in the general adult population. (D Recommendation)
American Heart Association / American Stroke Association, 2014^14^ | Screening low-risk populations for asymptomatic carotid stenosis is not recommended.
American Heart Association / American Stroke Association, 2014^14^ | In asymptomatic patients at high risk of complications for carotid revascularization by either CEA or CAS, the effectiveness of revascularization versus medical therapy alone is not well established
American Heart Association / American Stroke Association, 2014^14^ | It is reasonable to consider performing CEA in asymptomatic patients who have >70% stenosis of the internal carotid artery if the risk of perioperative stroke, MI, and death is low (<3%). However, its effectiveness compared with contemporary best medical management alone is not well established
American Institute of Ultrasound Medicine (AIUM), 2016^94^ | Ultrasound examination of the extracranial cerebrovascular system is indicated in patients with a carotid bruit.
Joint guidelines from multiple US societies (ASA/ACCF/AHA/AANN/AANS/ACR/ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS), 2011^60^ | It is reasonable to perform duplex ultrasonography to detect hemodynamically significant carotid stenosis in asymptomatic patients with carotid bruit.
Joint guidelines from multiple US societies (ASA/ACCF/AHA/AANN/AANS/ACR/ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS), 2011^60^ | Duplex ultrasonography to detect hemodynamically significant carotid stenosis may be considered in asymptomatic patients with symptomatic peripheral arterial disease, coronary artery disease, or atherosclerotic aortic aneurysm, but because such patients already have an indication for medical therapy to prevent ischemic symptoms, it is unclear whether establishing the additional diagnosis of extracranial carotid and vertebral artery disease in those without carotid bruit would justify actions that affect clinical outcomes.
Joint guidelines from multiple US societies (ASA/ACCF/AHA/AANN/AANS/ACR/ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS), 2011^60^ | Duplex ultrasonography might be considered to detect carotid stenosis in asymptomatic patients without clinical evidence of atherosclerosis who have ≥2 of the following risk factors: hypertension, hyperlipidemia, tobacco smoking, family history in a 1st-degree relative of atherosclerosis manifested before age 60 years, or family history of ischemic stroke. However, it’s unclear whether establishing a diagnosis of extracranial carotid and vertebral artery disease would justify actions that affect clinical outcomes.
Joint guidelines from multiple US societies (ASA/ACCF/AHA/AANN/AANS/ACR/ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS), 2011^60^ | Carotid duplex ultrasonography is not recommended for routine screening of asymptomatic patients who have no clinical manifestations of or risk factors for atherosclerosis.
Society for Vascular Surgery, 2011^6^ | Routine screening is not recommended to detect clinically asymptomatic carotid stenosis in the general population. Screening is not recommended for presence of a neck bruit alone without other risk factors.
Society for Vascular Surgery, 2011^6^ | Screening for asymptomatic clinically significant carotid bifurcation stenosis should be considered in certain groups of patients with multiple risk factors that increase the incidence of disease as long as the patients are fit for and willing to consider carotid intervention if a significant stenosis is discovered. Such groups of patients include those with clinically significant peripheral vascular disease and those age ≥65 years with a history of ≥1 of the following atherosclerotic risk factors: coronary artery disease, smoking, or hypercholesterolemia.
Society for Vascular Surgery, 2011^6^ | Carotid screening may be considered in patients prior to coronary artery bypass. Screening is most likely to be fruitful if the patient is age ≥65 years, has left main disease, or has a history of peripheral vascular disease. The strongest indication for screening these patients from the data available is to identify patients at high risk of perioperative stroke.

Abbreviations: AANN = American Association of Neuroscience Nurses; AANS = American Association of Neurological Surgeons; ACCF = American College of Cardiology Foundation; ACR = American College of Radiology; AHA = American Heart Association; ASA = American Stroke Association; ASNR = American Society of Neuroradiology; CAS = carotid artery stenting; CEA = carotid endarterectomy; CNS = Congress of Neurological Surgeons; SAIP = Society of Atherosclerosis Imaging and Prevention; SCAI = Society of Cardiovascular Angiography and Interventions; SIR = Society of Interventional Radiology; SNIS = Society of NeuroInterventional Surgery; SVM = Society of Vascular Medicine; SVS = Society for Vascular Surgery

### Previous USPSTF Recommendation

In 2014, the USPSTF recommended against screening for asymptomatic carotid artery stenosis in the general adult population (D recommendation). This recommendation was based on low prevalence of stroke related to asymptomatic carotid artery stenosis in the general population, the small benefit of CEA and/or CAS compared with medical therapy from older trials, and the potential for harms. The USPSTF did not issue a recommendation in 2014 for screening high risk populations. The USPSTF noted the need for valid and reliable tools to determine which people are at high risk for carotid artery stenosis or related stroke as well as modern studies comparing CEA or CAS with current standard medical therapy.