# Appendix F Ongoing Studies

Appendix F Table 1 Ongoing Studies Table

Study reference/ trial identifier; Primary Investigator | Study name | Location | Estimated N | Intervention Description | Relevant Outcomes | Status (as of Sep 2020)
NCT00883402; Alison Halliday | Carotid Endarterectomy Versus Carotid Artery Stenting in Asymptomatic Patients (ACST-2) | UK | 3600 | 2-arm trial comparing 1) carotid artery stenting with 2) carotid endarterectomy | Stroke and death; MI; Quality of life | Recruiting: Est. study completion date December 2020
NCT02089217; Thomas G. Brott | Carotid Revascularization and Medical Management for Asymptomatic Carotid Stenosis Trial (CREST-2) | USA | 2480 | 2-arm treatment trial comparing 1) carotid revascularization and intensive medical management, 2) medical management alone | Stroke and death; Cognitive function | Recruiting: Est. completion date December 2022
NCT03121209; Randolph S. Marshall | Carotid Revascularization and Medical Management for Asymptomatic Carotid Stenosis Trial - Hemodynamics (CREST-H) (CREST-H) | USA | 500 | Cohort study addressing whether cognitive impairment can be reversed when it arises from abnormal cerebral hemodynamic perfusion in a hemodynamically impaired subset of the CREST-2 -randomized patients | Cognitive function | Recruiting: Est. completion date March 2022
ISRCTN97744893; Ekaterina Biggs | European Carotid Surgery Trial 2 (ECST-2) | UK | 200 | 2-arm treatment trial comparing 1) immediate endartorectomy to 2) medical treatment alone. | Stroke and death; Functional status (mRS) | Recruiting: Est. completion date March 2022
NCT02841098; Jean-Louis MAS | Endarterectomy Combined With Optimal Medical Therapy Versus Optimal Medical Therapy Alone in Patients With Asymptomatic Severe Atherosclerotic Carotid Artery Stenosis at Higher-than-average Risk of Ipsilateral Stroke (ACTRIS) | France | 700 | 2-arm treatment trial comparing 1) carotid endarterectomy (CEA) combined with optimal medical therapy (OMT), 2) optimal medical therapy. | Stroke and death; MI; Other AEs including haematoma and cranial nerve palsy | Not yet recruiting: Est. completion date December 2025
NCT00772278; Dallit Manheim | Comparing Carotid Stenting With Endarterectomy in Severe Asymptomatic Carotid Stenosis | Israel | 137 | 2-arm trial comparing 1) carotid artery stenting with 2) carotid endarterectomy | Mortality; Morbidity; Cranial nerves damage | Recruitment completed: Est. study completion date September 2015; No results published