# Appendix E Additional Evidence Tables

Appendix E Table 1 Inclusion and Exclusion Criteria for Included Randomized, Controlled Trials, KQ3

Study Name; Author, Year; Quality | Country | Inclusion criteria | Exclusion criteria | Intervention description | Surgeon selection
SPACE-2; Reiff, 2019^37^; Fair | Germany, Switzerland, and Austria | Carotid artery stenosis of ≥70% following ultrasound criteria with no stroke or stroke-like symptoms within the last 180 days, stenosis treatable with CEA and CAS, available for follow-up examinations, informed consent, adequate contraception among women with childbearing potential | Stroke or stroke-like symptoms due to the stenosis within the last 180 days, nonatherosclerotic stenosis (e.g. dissection, floating thrombus, fibromuscular dysplasia), stenosis following radiotherapy, previous CEA or CAS in the artery to be randomized, additional higher grade intracranial or intrathoracic stenosis (tandem stenosis), intracranial bleeding within the last 90 days, known intracranial angioma or aneurysms, preexisting disability (modified Rankin scale >1), contraindications for heparin, aspirin, clopidogrel or contrast media, indication for anticoagulation with phenprocoumon or warfarin, life expectancy of <5 years, recent history of a malignant tumor, major surgery (with the exception of trial-related procedures) planned within 8 weeks after randomization, previously enrollment in SPACE-2 Trial. | All patients received BMT according to current evidence based guidelines in accordance with their individual risk factor profile including the treatment of risk factors, lipid-lowering and anti-platelet medication.; CEA: Aspirin (ASA) or clopidogrel (but not dual antiplatelet therapy) had to be administered for at least 3 days before CEA, as well as during and after surgery. 67% of cases were performed with general anesthesia. Median time from randomization to treatment was 14 days.; CAS: All patients had to receive dual antiplatelet therapy (ASA and clopidogrel) for at least 3 days before and for at least 6 weeks after CAS. Cerebral protection devices were used in 36% of cases based on the discretion of the endovascular specialist. Median time from randomization to treatment was 14 days. | All participating interventionalists have to achieve the following standards: at least 40 CAS procedures within 24 months, evaluated by an independent neurologist, or at least 20 CAS procedures with a perinterventional complication rate below 6% within the SPACE-1 study.
AMTEC; Kolos, 2015^35^; Fair | Russia | Unilateral or bilateral carotid artery stenosis that was considered to be severe (carotid artery diameter reduction 70–79% on ultrasound and 60–79% on computed tomographic angiography/ magnetic resonance angiography (CTA/MRA), if the risk of perioperative stroke or death is less than 3%; this stenosis had not caused any stroke, transient cerebral ischemia, or other relevant neurological symptoms in the last six-months; arterial hypertension: systolic blood pressure (BP) >140 mmHg and diastolic BP >90 mmHg at office visit or regular antihypertensive treatment; age from 40 to 80 years; Both the physician and the surgeon were substantially uncertain on whether to choose immediate CEA or deferral of any CEA; and the patient had no known circumstance or condition likely to preclude long-term follow-up | Stroke/transient cerebral ischemia in the last 6 months, restenosis after prior carotid artery stenting (CAS) or CEA, high surgical risk, assessed as a lesion at C2 or higher, a lesion below the clavicle, prior radical neck surgery or radiotherapy, contralateral carotid occlusion, prior ipsilateral CEA, contralateral laryngeal nerve palsy, tracheostoma, age >=80 years, New York Heart Association Functional Class III/IV congestive heart failure, class III/IV angina pectoris, left main or coronary disease in two or more vessels, urgent (<30 days) heart surgery, left ventricular ejection fraction <=30%, recent (<30 days) myocardial infarction, severe chronic lung disease, severe renal disease, and atrial fibrillation. | All patients received lifestyle modification training: Mediterranean diet, regular exercise, smoking cessation consult, obesity and diabetes mellitus management according to the current guidelines (2006 AHA/ACC cited); All patients received antiplatelet therapy with aspirin at a dose of 81 to 325 mg/d, aggressive therapy to lower low-density lipoprotein (LDL) cholesterol levels with atorvastatin (10-80 mg/d), with a target LDL level of <2.6 mmol/L (ideally <2.0 mmol/L), and antihypertensive therapy with amlodipine (5-10 mg/d) and losartan (50-100 mg/d) to lower the blood pressure (BP) to a target level of <140/90 mm Hg, and hydrochlorothiazide (12.5 mg/d) was added if the target BP was not achieved. (2006 AHA/ACC cited) | Selected five centers that perform more than 150 CEA per year, with the rates of complications and death less than 3% among patients with asymptomatic carotid atherosclerosis.

Abbreviations: AHA = American Heart Association; ACC = American College of Cardiology; AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BMT = best medical treatment; BP = blood pressure; CAS = carotid artery stenting; CEA = carotid endarterectomy; CTA = computerized tomography angiography; FU = followup; KQ = key question; mm Hg = millimeters of Mercury; MMT = modern medical treatment; MRA = magnetic resonance angiography; NR = not reported; pop = population; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; vs = verse; yr = year

Appendix E Table 2 Baseline Population Characteristics of Included Randomized, Controlled Trials, KQ3

Study Name; Author, Year; Quality | Mean age (range) | Male, n (%) | White ethnicity, n (%) | DM, n (%) | HTN, n (%) | High chol, n %) | Smoker, n (%) | Statin use, n (%) | CHD, n (%) | Prior contralateral CEA, TIA/stroke | Contralateral occlusion | Additional BL characteristics or comorbidities
SPACE-2; Reiff, 2019^37^; Fair | 70^*^ (50 to 80) | 381 (74.3%) | NR (NR) | 151 (29.4%) | 459 (89.5%) | 407 (79.3%) | 100 (19.5%)^†^ | 397 (77.4%)^‡^ | 182 (35.5%) | NR^§^ | 18 (3.5%) | Grade of stenosis (Median (IQR)): 80 (75-85); Number of vascular risk factors (median): 3; BMI (median (IQR)): 27 (25, 30); Medications at baseline: antiplatelet: 495 (96.5%); anticoagulants 12 (2.3%); antihypertensive: 448 (87.3%); lipid lowering: 418 (81.5%); antidiabetic: 134 (26.1%)
AMTEC; Kolos, 2015^35^; Fair | 66.6 (40 to 80) | 40 (72.7%) | NR (NR) | 14 (25.5%) | Duration of arterial HTN, yrs: 13.7 | NR | 32 (58.2%) | NR | 39 (70.9%) | NR | NR | BMI: 28.5 kg/m2 (BMI significantly lower in MMT group (26.8) than CEA group (29.9) (p=0.0008); Previous PCI/CABG: 29 (52.7%); Prior MI: 17 (30.9%); Prior stroke: 9 (16.4%); CKD: 1 (1.8%)

* Median

† Current smoker

‡ 35 (6.8%) on other lipid lowering drugs

§ Ipsilateral symptoms >180 days on side of randomized artery: 29 (5.7%)

Abbreviations: AMTEC = the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial; BL = baseline; BMI = body mass index; BP = blood pressure; CABG = coronary artery bypass grafting; CAS = carotid artery stenting; CEA = carotid endarterectomy; CHD = coronary heart disease; chol = cholesterol; CKD = chronic kidney disease; DM = diabetes mellitus; FU = followup; HTN = hypertension; IQR = interquartile range; KQ = key question; MI = myocardial infarction; mm Hg = millimeters of Mercury; MMT = modern medical treatment; NR = not reported; PCI = percutaneous coronary intervention; SPACE-2: Stent Protected Angioplasty versus Carotid Endarterectomy trial; TIA = transient ischemic attack

Appendix E Table 3 Additional Study Details of Included Administrative Database and Vascular Registry Studies Reporting Outcomes for Asymptomatic Patients, KQ 4

Registry; Author, Year; Quality | Database or registry methods | Inclusion Criteria | Exclusion criteria | Urgency of procedure
ACS NSQIP; Garcia, 2017^40^; Fair | Trained clinical extractors | Patients undergoing CEA | Patients were excluded if assigned a postoperative single ICD-9 diagnosis unrelated to carotid stenosis, had previous history of stroke or transient ischemic attack, or underwent carotid stenting | Elective, Emergency, Urgent
Medicare; Lichtman, 2017^28^; Fair | For patients undergoing multiple carotid procedures during the study period, the first procedure was selected as the index admission. | Age 65 years or older, enrolled in fee-for-service Medicare for 1 month or longer between January 1999 and December 2014, undergoing carotid endarterectomy or carotid artery stenting in US acute care hospitals. | Patients were excluded if they underwent both carotid endarterectomy and carotid artery stenting during the index hospitalization or received any other concomitant major interventions (eg, coronary artery bypass grafting) during the index admission | Elective, Emergency, Urgent
NIS; Mayor, 2019^43^; Fair | Unweighted data from more than 7 million hospital admissions each year (20% sample of hospitalizations from non-federal US community hospitals).^*^ | All adult (18 years of age and older) admissions for carotid revascularization between January 1, 2005 and September 30, 2015. | NR | Elective, Emergency, Urgent
VSGNE; Boitano, 2019^39^; Fair | Prospectively maintained quality improvement registry which includes patients undergoing vascular operative procedures across New England. Linkage of the registry with the Social Security Death Index Master File allows accurate mortality and survival analysis | Patients undergoing CEA within the VSGNE cohort from 2011-2017. | Patients were excluded if they had a prior ipsilateral CEA; underwent a concomitant procedure including CABG, proximal angioplasty, stenting of the carotid artery, carotid-carotid bypass, carotid subclavian bypass, or carotid axillary bypass, if they did not have a surgical side (right or left) denoted or documentation regarding previous neck radiation | Elective, Emergency, Urgent
VQI; Nejim, 2019^44^; Fair | Clinical professionals extract patient- and procedure-related information from medical charts of the participating centers. Data validation is accomplished by comparing the data entered in the VQI registry with claims data provided from the participating center on an annual basis and rectifies any inconsistency if found. Mortality data in the VQI are obtained from the Social Security Death Index | All patients between 19 and 89 years old were included. Patients of age 90 or older were coded as 89 years to avoid identification | Prospective registry of multicenter collaboration across the United States and the Province of Ontario in Canada that captures various vascular interventions. | Elective, Emergency, Urgent

* The fourth quarter of 2015 was excluded to remove extraneous influence on study findings due to the transition ICD-9-CM to ICD-10-CM, which occurred October 1, 2015.

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CABG = coronary artery bypass grafting; CAS = carotid artery stenting; CEA = carotid endarterectomy; KQ = key question; MAE = major adverse event; NIS = National Inpatient Sample; NA = not applicable; NR = not reported; VSGNE = Vascular Study Group of New England; US= United States; US = United States; VQI = Vascular Quality Initiative

Appendix E Table 4 Assessment of Patient Characteristics and Outcomes in Trials, Administrative Database, and Vascular Registries, KQ4

Study/Registry | Assessment of stenosis | Assessment of asymptomatic status | Assessment of outcomes | Sampling frame
SPACE-2^37^ | Trial inclusion criteria: >70% stenosis (ECST criteria) on ultrasound (equivalent to >50% NASCET criteria) | Trial inclusion criteria: No stroke or stroke-like symptoms due to stenosis within 180 days | Review of medical records | NA
AMTEC^35^ | Trial inclusion criteria: 70–79% stenosis (NASCET criteria) on ultrasound and 60–79% on CTA/MRA confirmation | Trial inclusion criteria: No stroke, transient cerebral ischemia, or relevant neurological symptoms in previous 6 months | Review of medical records; nonfatal strokes confirmed with CT/MRI | NA
ACS NSQIP^40^ | NR | Patients considered asymptomatic if they had a previous history of stroke or transient ischemic attack (timing not specified) | Assessment by trained Surgical Clinical Reviewer based on patient medical charts | Randomly assigned patients (details NR)
Medicare^28^ | NR | Considered symptomatic if they had an ICD-9-CM principal discharge diagnosis code indicating occlusion or stenosis of the precerebral or cerebral arteries with cerebral infarction or a secondary diagnosis code indicating prior stroke, transient ischemic attack, or amaurosis fugax. | ICD-9 codes | All Medicare beneficiaries with inpatient claims for CEA and CAS (based on ICD-9 codes)
NIS^43^ | NR | Symptomatic status based on the presence of 1 or more diagnosis codes indicative of amaurosis fugax, transient ischemic attack, or stroke. | ICD-9 codes | Sample of hospitalizations selected from all hospitals participating in HCUP
VSGNE^39,^ ^94^ | NR | Patients considered symptomatic if they experienced ipsilateral cortical or eye symptoms before the procedure (timing not specified). | Data input completed by nurses, research personnel, surgeons, or chart abstractors. Linked to Social Security Death Index. | All patients undergoing CEA at participating institutions
VQI^44,^ ^95^ | Most severe stenosis of each patient measured by duplex ultrasound, MRA, CTA, or arteriogram (criteria NR) | Symptomatic status was defined as the occurrence of pre-procedural amaurosis fugax, transient ischemic attack, and minor or major stroke (timing not specified). | Clinical abstraction from medical chart and linked to Social Security Death Index. | All eligible procedures at participating institute

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; CAS = carotid artery stenting; CEA = carotid endarterectomy; CTA = computerized tomography angiography; ECST = the European Carotid Surgery Trial; HCUP = the Healthcare Cost and Utilization Project; ICD-9 = The International Classification of Diseases, ninth revision; KQ = key question; MRA = magnetic resonance angiography; NASCET = the North American Symptomatic Carotid Endarterectomy Trial; NIS = National Inpatient Sample; NA = not applicable; NR = not reported; VSGNE = Vascular Study Group of New England; US= United States; US = United States; VQI = Vascular Quality Initiative

Appendix E Table 5 Baseline Population Characteristics of Included Administrative Database and Vascular Registry Studies, KQ 4

Registry; Author, Year; Quality | Cohort (n) | Mean age (Range) | Male, n (%) | White ethnicity, n (%); Black ethnicity, n (%) | DM, n (%) | HTN, n (%) | High chol, n (%) | Smoker, n (%) | Statin use, n (%) | CAD, n (%) | CHD, n (%) | CHF, n (%) | COPD, n (%) | CKD, n (%) | BMI | Additional characteristic or comorbidities
ACS NSQIP; Garcia, 2017^40^; Fair | CEA (n=53,593)^*^ | NR^†^ | 31,996 (59.7%) | 48,875 (91.2%); 2428 (4.5%) | 15,842 (29.6%) | 45,522 (84.9%)^‡^ | NR | 14,893 (27.8%)^§^ | NR | NR | NR | Hx of CHF: 648 (1.2%) | Severe COPD: 6089 (11.4%) | History of dialysis: 566 (1.1%) | BMI >30: 18,551 (34.6%) | NR
Medicare; Lichtman, 2017^28^; Fair | CEA (n=937,111)^ǁ#^ | 75.8 (≥65) | 536,617 (57.3%) | 877,925 (93.7%); 31,833 (3.4%) | 294,295 (31.4%) | 704,146 (75.1%) | NR | NR | NR | NR | NR | 69,251 (7.4%) | 192,313 (20.5%) | Kidney failure: 45,587 (4.9%) | NR | Chronic atherosclerosis (53.7%), prior MI (4.5%), prior Stroke (6.1%), PVD (21.9%)
Medicare; Lichtman, 2017^28^; Fair | CAS (n=231,077)^**^ | 75.4 (≥65) | 118,476 (51.3%) | 198,648 (86.0%); 21,890 (9.5%) | 85,493 (37.0%) | 159,837 (69.2%) | NR | NR | NR | NR | NR | 37,215 (16.1%) | 55,800 (24.1%) | Kidney failure 33,216 (14.4%) | NR | Chronic atherosclerosis (46.5%), prior MI (2.5%), prior Stroke (9.7%), PVD (7.9%)
NIS; Mayor, 2019^43^; Fair | CEA and CAS cohort (n=1,242,688)^††^ | 71.2^‡‡^ (IQR 64.3 to 77.4) | 726,972 (58.5%) | NR (NR); NR (NR) | 400,146 (32.2%) | 999,121 (80.4%) | 720,759 (58.0%) | NR | NR | 549,268 (44.2%) | NR | 99,415 (8.0%) | 223,684 (18.0%) | 110,599 (8.9%) | NR | NR
VSGNE; Boitano, 2019^39^; Fair | CEA (12,392)^§§^ | 70.1 (NR) | 7433 (60.0%) | 11,954 (96.5%); NR (NR) | 4056 (32.7%) | 11,002 (88.8%) | NR | 9820 (79.2%)^ǁǁ^ | 10,419 (84.1%)^##^ | 7782 (62.8%)^†††^ | NR | 1049 (8.5%) | 2673 (21.6%) | 3737 (30.1%) | 28.3 | Stenosis ≥70%: 4,565 (36.8%))^†††,^***; Prior CEA: 1124 (9.1%); Prior CAS: 42 (0.3%)
VQI; Nejim, 2019^44^; Fair | CEA (n=76,081)^‡‡‡^ | NR (>65) | 46,026 (60.55) | Non-white: 4416 (5.8%) | DM on Rx: 23,221 (30.5%) | 67,580 (88.8%) | NR | Ever smoker: 57,550 (75.6%) | Preop statin: 61,130 (80.3%) | NR | NR | 7784 (10.2%) | 16,890 (22.2%) | Hemodialysis: 818 (1.1%) | NR | Prior CEA or CAS: 11,690 (15.4%); Degree of stenosis >80%: 46,403 (61.0%),
VQI; Nejim, 2019^44^; Fair | CAS (n=13,772)^‡‡‡^ | NR (>65) | 8764 (63.6%) | Non-white: 1004 (7.3%) | DM on Rx: 4465 (32.4%) | 12,259 (89.0%) | NR | Ever smoker: 10,440 (75.8%) | Preop statin: 10,997 (79.8%) | NR | NR | 2097 (15.2%) | 3548 (25.8%) | Hemodialysis: 182 (1.3%) | NR | Prior CEA or CAS: 11,690 (15.4%); Degree of stenosis >80%: 8993 (65.3%)

* Baseline characteristics calculated across race/ethnicity groups

† <60 years (11.5%), 60-80 years (68.7%), >80 years (19.8%)]

‡ HTN requiring medication

§ Current smoker

ǁ Baseline characteristics calculated across time spans.

# Demographics only reported for entire CEA cohort, including symptomatic pts (n=122,023 (13.0%))

** Demographics only reported for entire CAS sample, including symptomatic (n=1,168,188)

†† Demographics and comorbidities For entire cohort, including Symptomatic 140,424 (11.3%) and both procedure types (CEA: 87.2%) and CAS: 12.8%)

‡‡ Median

§§ Baseline characteristics calculated across subgroups

ǁǁ Any smoking history

## Preop meds

*** Additional co-morbidities reported: Contralateral carotid occlusion: 340 (2.7%); ASA class 4 or 5: 885 (7.1%); CABG/PCI: 2214 (17.9%); Arterial Bypass (Non-Cardiac): 801 (6.5%); PTA/stent (NonCardiac)t: 1020 (8.2%); Aneurysm repair: 350 (2.8%); Prior CEA: 1124 (9.1%); Prior CAS: 42 (0.3%)

††† These absolute numbers and percentages are shown as published in the study. Denominators that authors used to calculate these percentages were not reported.

‡‡‡ Baseline characteristics calculated across groups and includes 30% symptomatic

Abbreviations: ACS NSQIP = American College of Surgeons National Surgical Quality Improvement Program; BMI = body mass index; CAD = coronary artery disease; CAS = carotid artery stenting; CEA = carotid endarterectomy; CHD = coronary heart disease; CHF = congestive heart failure; CKD = chronic kidney disease; COPD = chronic obstructive pulmonary disorder; DM = diabetes mellitus; KQ = key question; MI = myocardial infarction; NIS = National Inpatient Sample; NR = not reported; PVD = peripheral vascular disease; Rx = prescription; VSGNE = Vascular Study Group of New England; US= United States; VQI = Vascular Quality Initiative