# Appendix D Excluded Studies List

Exclusion Code | Definition
E1 | Aim not relevant
E2 | Study design
E3 | Population (general)
E3a | Asymptomatic n is <10,000
E3b | Population not stratified by number symptomatic or percent asymptomatic not reported
E3c | Population is ≤80 percent asymptomatic and not stratified
E3d | Smaller administrative databases
E4 | No relevant outcomes; or outcomes not reported as absolute rates
E4a | Reported only cost and/or utilization outcomes
E5 | Setting not in “very-high” HDI country
E6 | Poor Quality
E7 | Publication Type (Abstract only)
E8 | Publication overlasps with a more recent (and/or complete) registry publication
E9 | A more recent analysis of a previously included trial

1 Adegbala O, Martin KD, Otuada D, . Diabetes mellitus with chronic complications in relation to carotid endarterectomy and carotid artery stenting outcomes. J Stroke Cerebrovasc Dis. 2017;26(1):217–24. PMID: 27810149. 10.1016/j.jstrokecerebrovasdis.2016.09.012 KQ4E8.27810149
2 Al-Damluji MS, Dharmarajan K, Zhang W, . Readmissions after carotid artery revascularization in the Medicare population. J Am Coll Cardiol. 2015;65(14):1398–408. PMID: 25857904. 10.1016/j.jacc.2015.01.048 KQ4E8.25857904
3 Alhaidar M, Algaeed M, Amdur R, . Early outcomes after carotid endarterectomy and carotid artery stenting for carotid stenosis in the ACS-NSQIP database. J Vasc Interv Neurol. 2018;10(1):52–6. PMID: 29922406. KQ4E3c.29922406
4 Arhuidese IJ, Faateh M, Nejim BJ, . Risks associated with primary and redo carotid endarterectomy in the endovascular era. JAMA Surg. 2018;153(3):252–9. PMID: 29117272. 10.1001/jamasurg.2017.4477 KQ4E8.29117272
5 Arous EJ, Simons JP, Flahive JM, . National variation in preoperative imaging, carotid duplex ultrasound criteria, and threshold for surgery for asymptomatic carotid artery stenosis. J Vasc Surg. 2015;62(4):937–44. PMID: 26067201. 10.1016/j.jvs.2015.04.438 KQ4E4.26067201
6 Aziz F, Lehman EB, Reed AB. Increased duration of operating time for carotid endarterectomy is associated with increased mortality. Ann Vasc Surg. 2016;36:166–74. PMID: 27395809. 10.1016/j.avsg.2016.02.043 KQ4E3b.27395809
7 Badheka AO, Chothani A, Panaich SS, . Impact of symptoms, gender, co-morbidities, and operator volume on outcome of carotid artery stenting (from the Nationwide Inpatient Sample [2006 to 2010]). Am J Cardiol. 2014;114(6):933–41. PMID: 25208563. 10.1016/j.amjcard.2014.06.030 KQ4E3b.25208563
8 Boitano LT, DeCarlo C, Schwartz MR, . Surgeon specialty significantly affects outcome of asymptomatic patients after carotid endarterectomy. J Vasc Surg. 2019;09:09. PMID: 31831310. 10.1016/j.jvs.2019.04.489 KQ4E8.31831310
9 Brinjikji W, El-Sayed AM, Kallmes DF, . Racial and insurance based disparities in the treatment of carotid artery stenosis: a study of the Nationwide Inpatient Sample. J Neurointerv Surg. 2015;7(9):695–702. PMID: 25015114. 10.1136/neurintsurg-2014-011294 KQ4E4.25015114
10 Brinjikji W, Kallmes DF, Lanzino G, . Carotid revascularization treatment is shifting to low volume centers. J Neurointerv Surg. 2015;7(5):336–40. PMID: 24714610. 10.1136/neurintsurg-2014-011180 KQ4E8.24714610
11 Burton BN, Finneran Iv JJ, Harris KK, . Association of primary anesthesia type with postoperative adverse events after transcarotid artery revascularization. J Cardiothorac Vasc Anesth. 2019;31:31. PMID: 31445834. 10.1053/j.jvca.2019.07.142 KQ4E3a.31445834
12 Chandler JV, George BP, Kelly AG, . For-profit hospital status and carotid artery stent utilization in US hospitals performing carotid revascularization. Stroke. 2017;48(11):3161–4. PMID: 28939675. 10.1161/STROKEAHA.117.017556 KQ4E4.28939675
13 Chaudhry SA, Afzal MR, Kassab A, . A new risk index for predicting outcomes among patients undergoing carotid endarterectomy in large administrative data sets. J Stroke Cerebrovasc Dis. 2016;25(8):1978–83. PMID: 27216378. 10.1016/j.jstrokecerebrovasdis.2016.01.023 KQ4E3b.27216378
14 Cheng TW, Farber A, Kalish JA, . Carotid endarterectomy performed before the weekend is associated with increased length of stay. Ann Vasc Surg. 2018;48:119–26. PMID: 29217437. 10.1016/j.avsg.2017.09.028 KQ4E8.29217437
15 Choi JC, Johnston SC, Kim AS. Early outcomes after carotid artery stenting compared with endarterectomy for asymptomatic carotid stenosis. Stroke. 2015;46(1):120–5. PMID: 25424479. 10.1161/STROKEAHA.114.006209 KQ4E3d.25424479
16 Choi JH, Pile-Spellman J, Brisman JL. US nationwide trends in carotid revascularization: is there a clinical opportunity cost associated with the introduction of novel medical devices? Acta Neurol Scand. 2014;129(2):94–101. PMID: 23772989. 10.1111/ane.12152 KQ4E3b.23772989
17 Choi JH, Pile-Spellman J, Brisman JL. US nationwide trends in carotid revascularization: hospital outcome and predictors of outcome from 1998 to 2007. Acta Neurol Scand. 2014;129(2):85–93. PMID: 23834476. 10.1111/ane.12163 KQ4E3b.23834476
18 Chou EL, Sgroi MD, Chen SL, . Influence of gender and use of regional anesthesia on carotid endarterectomy outcomes. J Vasc Surg. 2016;64(1):9–14. PMID: 27183853. 10.1016/j.jvs.2016.03.406 KQ4E3c.27183853
19 Clouse WD, Boitano LT, Ergul EA, . Contralateral occlusion and concomitant procedures drive risk of non-ipsilateral stroke after carotid endarterectomy. Eur J Vasc Endovasc Surg. 2019;57(5):619–25. PMID: 30940430. 10.1016/j.ejvs.2018.11.009 KQ4E8.30940430
20 Clouse WD, Ergul EA, Patel VI, . Characterization of perioperative contralateral stroke after carotid endarterectomy. J Vasc Surg. 2017;66(5):1450–6. PMID: 28697940. 10.1016/j.jvs.2017.04.059 KQ4E3a.28697940
21 Columbo JA, Martinez-Camblor P, MacKenzie TA, . A comparative analysis of long-term mortality after carotid endarterectomy and carotid stenting. J Vasc Surg. 2019;69(1):104–9. PMID: 29914828. 10.1016/j.jvs.2018.03.432 KQ4E8.29914828
22 Columbo JA, Martinez-Camblor P, MacKenzie TA, . Comparing long-term mortality after carotid endarterectomy vs carotid stenting using a novel instrumental variable method for risk adjustment in observational time-to-event data. JAMA Netw. 2018;1(5):e181676. PMID: 30646140. 10.1001/jamanetworkopen.2018.1676 KQ4E8.30646140
23 Dakour Aridi H, Locham S, Nejim B, . Comparison of 30-day readmission rates and risk factors between carotid artery stenting and endarterectomy. J Vasc Surg. 2017;66(5):1432–44.e7. PMID: 28865979. 10.1016/j.jvs.2017.05.097 KQ4E3d.28865979
24 Dakour Aridi H, Paracha N, Nejim B, . Anesthetic type and hospital outcomes after carotid endarterectomy from the Vascular Quality Initiative database. J Vasc Surg. 2018;67(5):1419–28. PMID: 29242070. 10.1016/j.jvs.2017.09.028 KQ4E3c.29242070
25 Dakour-Aridi H, Faateh M, Kuo PL, . The Vascular Quality Initiative 30-day stroke/death risk score calculator after transfemoral carotid artery stenting. J Vasc Surg. 2019;13:13. PMID: 31526692. 10.1016/j.jvs.2019.05.051 KQ4E3a.31526692
26 Dakour-Aridi H, Gaber MG, Khalid M, . Examination of the interaction between method of anesthesia and shunting with carotid endarterectomy. J Vasc Surg. 2019;04:04. PMID: 31699512. 10.1016/j.jvs.2019.08.248 KQ4E8.31699512
27 Dakour-Aridi H, Kashyap VS, Wang GJ, . The impact of age on in-hospital outcomes after transcarotid artery revascularization, transfemoral carotid artery stenting, and carotid endarterectomy. J Vasc Surg. 2020;72(3):931–942.e2. PMID: 32035784. 10.1016/j.jvs.2019.11.037 KQ4E3c.32035784
28 Dakour-Aridi H, Nejim B, Locham S, . Complication-specific in-hospital costs after carotid endarterectomy vs carotid artery stenting. J Endovasc Ther. 2018;25(4):514–21. PMID: 29893167. 10.1177/1526602818781580 KQ4E3d.29893167
29 Dakour-Aridi H, Ou M, Locham S, . Outcomes following eversion vs. conventional endarterectomy in the Vascular Quality Initiative Database. Ann Vasc Surg. 2019;15:15. PMID: 31626932. 10.1016/j.avsg.2019.07.021 KQ4E3c.31626932
30 Dakour-Aridi H, Rizwan M, Nejim B, . Association between the choice of anesthesia and in-hospital outcomes after carotid artery stenting. J Vasc Surg. 2019;69(5):1461–70.e4. PMID: 31010512. 10.1016/j.jvs.2018.07.064 KQ4E3a.31010512
31 de Waard DD, de Borst GJ, Bulbulia R, . Diastolic blood pressure is a risk factor for peri-procedural stroke following carotid endarterectomy in asymptomatic patients. Eur J Vasc Endovasc Surg. 2017;53(5):626–31. PMID: 28318997. 10.1016/j.ejvs.2017.02.004 KQ3E9, KQ4E9.28318997
32 DeMartino RR, Brooke BS, Neal D, . Development of a validated model to predict 30-day stroke and 1-year survival after carotid endarterectomy for asymptomatic stenosis using the Vascular Quality Initiative. J Vasc Surg. 2017;66(2):433–44.e2. PMID: 28583737. 10.1016/j.jvs.2017.03.427 KQ4E8.28583737
33 Dhillon AS, Li S, Lewinger JP, . Comparison of devices used in carotid artery stenting: a vascular quality initiative analysis of commonly used carotid stents and embolic protection devices. Catheter Cardiovasc Interv. 2018;92(4):743–9. PMID: 30019819. 10.1002/ccd.27646 KQ4E3b.30019819
34 Dua A, Desai SS, Seabrook GR, . The effect of Surgical Care Improvement Project measures on national trends on surgical site infections in open vascular procedures. J Vasc Surg. 2014;60(6):1635–9. PMID: 25454105. 10.1016/j.jvs.2014.08.072 KQ4E3b.25454105
35 Dua A, Romanelli M, Upchurch GR, Jr., . Predictors of poor outcome after carotid intervention. J Vasc Surg. 2016;64(3):663–70. PMID: 27209401. 10.1016/j.jvs.2016.03.428 KQ4E8.27209401
36 Edenfield L, Blazick E, Eldrup-Jorgensen J, . Outcomes of carotid endarterectomy in the Vascular Quality Initiative based on patch type. J Vasc Surg. 2019;03:03. PMID: 31492613. 10.1016/j.jvs.2019.05.063 KQ4E4.31492613
37 Edenfield L, Blazick E, Healey C, . Long-term impact of the Vascular Study Group of New England carotid patch quality initiative. J Vasc Surg. 2019;69(6):1801–6. PMID: 31159983. 10.1016/j.jvs.2018.07.078 KQ4E3c.31159983
38 Enomoto LM, Hill DC, Dillon PW, . Surgical specialty and outcomes for carotid endarterectomy: evidence from the National Surgical Quality Improvement Program. J Surg Res. 2014;188(1):339–48. PMID: 24480081. 10.1016/j.jss.2013.11.1119 KQ4E3b.24480081
39 Epstein AJ, Yang L, Yang F, . A comparison of clinical outcomes from carotid artery stenting among US hospitals. Circ Cardiovasc Qual Outcomes. 2014;7(4):574–80. PMID: 24895452. 10.1161/CIRCOUTCOMES.113.000819 KQ4E3b.24895452
40 Eslami MH, Reitz KM, Rybin DV, . Improved access to health care in Massachusetts after 2006 Massachusetts Healthcare Reform Law is associated with a significant decrease in mortality among vascular surgery patients. J Vasc Surg. 2018;68(4):1193–202.e1. PMID: 29615354. 10.1016/j.jvs.2017.12.066 KQ4E3b.29615354
41 Eslami MH, Rybin D, Doros G, . Care of patients undergoing vascular surgery at safety net public hospitals is associated with higher cost but similar mortality to nonsafety net hospitals. J Vasc Surg. 2014;60(6):1627–34. PMID: 25441012. 10.1016/j.jvs.2014.08.055 KQ4E3b.25441012
42 Eslami MH, Rybin D, Doros G, . An externally validated robust risk predictive model of adverse outcomes after carotid endarterectomy. J Vasc Surg. 2016;63(2):345–54. PMID: 26804216. 10.1016/j.jvs.2015.09.003 KQ4E3a.26804216
43 Eslami MH, Rybin DV, Doros G, . The association of publication of Center for Medicaid and Medicare Services guidelines for carotid artery angioplasty and stenting (CAS) and CREST results on the utilization of CAS in carotid revascularization. Ann Vasc Surg. 2015;29(8):1606–13. PMID: 26315795. 10.1016/j.avsg.2015.06.091 KQ4E8.26315795
44 Fokkema M, Hurks R, Curran T, . The impact of the present on admission indicator on the accuracy of administrative data for carotid endarterectomy and stenting. J Vasc Surg. 2014;59(1):32–8.e1. PMID: 23993438. 10.1016/j.jvs.2013.07.006 KQ4E8.23993438
45 Fry DE, Nedza SM, Pine M, . Risk-adjusted hospital outcomes in elective carotid artery surgery in patients with Medicare. Surgery. 2018;163(3):606–11. PMID: 29229316. 10.1016/j.surg.2017.09.054 KQ4E3b.29229316
46 Fry DE, Pine M, Locke D, . Medicare inpatient and 90-day postdischarge adverse outcomes in carotid artery surgery. Surgery. 2015;158(4):1056–62; discussion 62-4. PMID: 26162940. 10.1016/j.surg.2015.06.005 KQ4E3c.26162940
47 Galinanes EL, Dombroviskiy VY, Hupp CS, . Evaluation of readmission rates for carotid endarterectomy versus carotid artery stenting in the US Medicare population. Vasc Endovascular Surg. 2014;48(3):217–23. PMID: 24407509. 10.1177/1538574413518120 KQ4E8.24407509
48 Geraghty PJ, Brothers TE, Gillespie DL, . Preoperative symptom type influences the 30-day perioperative outcomes of carotid endarterectomy and carotid stenting in the Society for Vascular Surgery Vascular Registry. J Vasc Surg. 2014;60(3):639–44. PMID: 25154963. 10.1016/j.jvs.2014.03.237 KQ4E3a.25154963
49 Giri J, Kennedy KF, Weinberg I, . Comparative effectiveness of commonly used devices for carotid artery stenting: an NCDR Analysis (National Cardiovascular Data Registry). JACC Cardiovasc Interv. 2014;7(2):171–7. PMID: 24440025. 10.1016/j.jcin.2013.10.014 KQ4E3a.24440025
50 Giri J, Parikh SA, Kennedy KF, . Proximal versus distal embolic protection for carotid artery stenting: a national cardiovascular data registry analysis. JACC Cardiovasc Interv. 2015;8(4):609–15. PMID: 25907088. 10.1016/j.jcin.2015.02.001 KQ4E4.25907088
51 Giri J, Yeh RW, Kennedy KF, . Unprotected carotid artery stenting in modern practice. Catheter Cardiovasc Interv. 2014;83(4):595–602. PMID: 23804411. 10.1002/ccd.25090 KQ4E3a.23804411
52 Grieff AN, Dombrovskiy V, Beckerman W, . Regional anesthesia is associated with cranial nerve injury in carotid endarterectomy. Ann Vasc Surg. 2020;06:06. PMID: 31917229. 10.1016/j.avsg.2019.12.033 KQ4E8.31917229
53 Gupta A, Mushlin AI, Kamel H, . Cost-effectiveness of carotid plaque MR imaging as a stroke risk stratification tool in asymptomatic carotid artery stenosis. Radiology. 2015;277(3):763–72. PMID: 26098459. 10.1148/radiol.2015142843 KQ3E2, KQ4E2.26098459
54 Hawkins BM, Kennedy KF, Aronow HD, . Hospital variation in carotid stenting outcomes. JACC Cardiovasc Interv. 2015;8(6):858–63. PMID: 25999111. 10.1016/j.jcin.2015.01.026 KQ4E3a.25999111
55 Hicks CW, Nejim B, Locham S, . Association between Medicare high-risk criteria and outcomes after carotid revascularization procedures. J Vasc Surg. 2018;67(6):1752–61.e2. PMID: 29361324. 10.1016/j.jvs.2017.10.066 KQ4E4.29361324
56 Hicks CW, Nejim B, Obeid T, . Use of a primary carotid stenting technique does not affect perioperative outcomes. J Vasc Surg. 2018;67(6):1736–43.e1. PMID: 29398315. 10.1016/j.jvs.2017.09.056 KQ4E3a.29398315
57 Huibers A, de Borst GJ, Bulbulia R, . Plaque echolucency and the risk of ischaemic stroke in patients with asymptomatic carotid stenosis within the first Asymptomatic Carotid Surgery Trial (ACST-1). Eur J Vasc Endovasc Surg. 2016;51(5):616–21. PMID: 26725253. 10.1016/j.ejvs.2015.11.013 KQ3E9, KQ4E9.26725253
58 Huibers A, de Borst GJ, Thomas DJ, . The mechanism of procedural stroke following carotid endarterectomy within the Asymptomatic Carotid Surgery Trial 1. Cerebrovasc Dis. 2016;42(3–4):178–85. PMID: 27111809. 10.1159/000444651 KQ3E9, KQ4E9.27111809
59 Huibers A, de Waard D, Bulbulia R, . Clinical experience amongst surgeons in the Asymptomatic Carotid Surgery Trial-1. Cerebrovasc Dis. 2016;42(5–6):339–45. PMID: 27322379. KQ3E9, KQ4E9.27322379
60 Jalbert JJ, Gerhard-Herman MD, Nguyen LL, . Relationship between physician and hospital procedure volume and mortality after carotid artery stenting among Medicare beneficiaries. Circ Cardiovasc Qual Outcomes. 2015;8(6 Suppl 3):S81–9. PMID: 26515214. 10.1161/CIRCOUTCOMES.114.001668 KQ4E3c.26515214
61 Jalbert JJ, Nguyen LL, Gerhard-Herman MD, . Outcomes after carotid artery stenting in Medicare beneficiaries, 2005 to 2009. JAMA Neurol. 2015;72(3):276–86. PMID: 25580726. 10.1001/jamaneurol.2014.3638 KQ4E8.25580726
62 Jones DW, Goodney PP, Conrad MF, . Dual antiplatelet therapy reduces stroke but increases bleeding at the time of carotid endarterectomy. J Vasc Surg. 2016;63(5):1262–70.e3. PMID: 26947237. 10.1016/j.jvs.2015.12.020 KQ4E8.26947237
63 Keyhani S, Cheng EM, Hoggatt KJ, . Comparative effectiveness of carotid endarterectomy vs initial medical therapy in patients with asymptomatic carotid stenosis. JAMA Neurol. 2020;77(9):1110–21. PMID: 32478802. 10.1001/jamaneurol.2020.1427 KQ3E3, KQ4E3a.32478802
64 Kfoury E, Dort J, Trickey A, . Carotid endarterectomy under local and/or regional anesthesia has less risk of myocardial infarction compared to general anesthesia: an analysis of national surgical quality improvement program database. Vascular. 2015;23(2):113–9. PMID: 24875185. 10.1177/1708538114537489 KQ4E8.24875185
65 Kim LK, Yang DC, Swaminathan RV, . Comparison of trends and outcomes of carotid artery stenting and endarterectomy in the United States, 2001 to 2010. Circulation. 2014;7(5):692–700. PMID: 25116802. 10.1161/CIRCINTERVENTIONS.113.001338 KQ4E8.25116802
66 Kim Y, Gani F, Canner JK, . Hospital readmission after multiple major operative procedures among patients with employer provided health insurance. Surgery. 2016;160(1):178–90. PMID: 27085686. 10.1016/j.surg.2016.01.025 KQ4E3a.27085686
67 Kolos I, Boytsov S, Deev A. Medical treatment versus carotid endarterectomy in patients with severe asymptomatic carotid atherosclerosis: randomized clinical trial. Eur Heart J. 2014;35:637. 10.1093/eurheartj/ehu324 KQ3E7, KQ4E7.
68 Kolos I, Boytsov S, Deev A, . Preventive stroke strategies efficacy and safety carotid endarterectomy and medical treatment in patients with severe asymptomatic carotid atherosclerosis: randomized clinical trial. Int J Stroke. 2014;9:280. 10.1111/ijs.12375 KQ3E7, KQ4E7.
69 Krafcik BM, Farber A, Eberhardt RT, . Preoperative antiplatelet and statin use does not affect outcomes after carotid endarterectomy. Ann Vasc Surg. 2018;46:43–52. PMID: 29100876. 10.1016/j.avsg.2017.10.002 KQ4E3c.29100876
70 Kuy S, Dua A, Desai SS, . Carotid endarterectomy national trends over a decade: does sex matter? Ann Vasc Surg. 2014;28(4):887–92. PMID: 24321266. 10.1016/j.avsg.2013.08.016 KQ4E8.24321266
71 Lal BK, Roubin GS, Rosenfield K, . Quality assurance for carotid stenting in the CREST-2 Registry. J Am Coll Cardiol. 2019;74(25):3071–9. PMID: 31856962. 10.1016/j.jacc.2019.10.032 KQ3E2, KQ4E3a.31856962
72 Liu J, Martinez-Wilson H, Neuman MD, . Outcome of carotid endarterectomy after regional anesthesia versus general anesthesia - a retrospective study using two independent databases. Transl Perioper Pain Med. 2014;1(2):14–21. PMID: 26023678. KQ4E3b.26023678
73 Malas MB, Dakour-Aridi H, Wang GJ, . Transcarotid artery revascularization versus transfemoral carotid artery stenting in the Society for Vascular Surgery Vascular Quality Initiative. J Vasc Surg. 2019;69(1):92–103.e2. PMID: 29941316. 10.1016/j.jvs.2018.05.011 KQ4E3a.29941316
74 Malik OS, Brovman EY, Urman RD. The use of regional or local anesthesia for carotid endarterectomies may reduce blood loss and pulmonary complications. J Cardiothorac Vasc Anesth. 2019;33(4):935–42. PMID: 30243870. 10.1053/j.jvca.2018.08.195 KQ4E3b.30243870
75 Mayor J, Salemi J, Dongarwar D, . Sex-based differences in ten-year nationwide outcomes of carotid revascularization. J Vasc Surg. 2019;70(3):1009-. 10.1016/j.jvs.2019.06.097 KQ4E3a.
76 McDonald JS, McDonald RJ, Fan J, . Effect of CREST findings on carotid revascularization practice in the United States. J Stroke Cerebrovasc Dis. 2015;24(6):1390–6. PMID: 25840953. 10.1016/j.jstrokecerebrovasdis.2015.02.020 KQ4E3d.25840953
77 McDonald RJ, McDonald JS, Therneau TM, . Comparative effectiveness of carotid revascularization therapies: evidence from a National Hospital Discharge Database. Stroke. 2014;45(11):3311–9. PMID: 25300973. 10.1161/STROKEAHA.114.006323 KQ4E3d.25300973
78 Melin AA, Schmid KK, Lynch TG, . Preoperative frailty Risk Analysis Index to stratify patients undergoing carotid endarterectomy. J Vasc Surg. 2015;61(3):683–9. PMID: 25499711. 10.1016/j.jvs.2014.10.009 KQ4E4.25499711
79 Meltzer AJ, Agrusa C, Connolly PH, . Impact of provider characteristics on outcomes of carotid endarterectomy for asymptomatic carotid stenosis in New York state. Ann Vasc Surg. 2017;45:56–61. PMID: 28577790. 10.1016/j.avsg.2017.05.015 KQ4E3d.28577790
80 Meschia J, Lal B, Howard G, . Carotid revascularization and medical management for asymptomatic carotid stenosis: CREST-2 update. Neurology. 2019;92(15). KQ3E7, KQ4E7.
81 Minc SD, Misra R, Holmes SD, . Impact of rural versus urban geographic location on length of stay after carotid endarterectomy. Vascular. 2019;27(4):390–6. PMID: 30845899. 10.1177/1708538119835402 KQ4E3b.30845899
82 Mistry EA, Khoury JC, Kleindorfer D. Carotid endarterectomy and concurrent clopidogrel use: national practice patterns in the United States. World Neurosurg. 2018;116:e315–e20. PMID: 29747016. 10.1016/j.wneu.2018.04.199 KQ4E3d.29747016
83 Modrall JG, Chung J, Kirkwood ML, . Low rates of complications for carotid artery stenting are associated with a high clinician volume of carotid artery stenting and aortic endografting but not with a high volume of percutaneous coronary interventions. J Vasc Surg. 2014;60(1):70–6. PMID: 24657297. 10.1016/j.jvs.2014.01.044 KQ4E3a.24657297
84 Nejim B, Obeid T, Arhuidese I, . Predictors of perioperative outcomes after carotid revascularization. J Surg Res. 2016;204(2):267–73. PMID: 27565060. 10.1016/j.jss.2016.04.074 KQ4E3c.27565060
85 Obeid T, Alshaikh H, Nejim B, . Fixed and variable cost of carotid endarterectomy and stenting in the United States: a comparative study. J Vasc Surg. 2017;65(5):1398–406.e1. PMID: 28216356. 10.1016/j.jvs.2016.11.062 KQ4E4a.28216356
86 Otite FO, Khandelwal P, Malik AM, . National patterns of carotid revascularization before and after the Carotid Revascularization Endarterectomy vs Stenting Trial (CREST). JAMA Neurol. 2018;75(1):51–7. PMID: 29204653. 10.1001/jamaneurol.2017.3496 KQ4E4.29204653
87 Pan H, Gottsater A, Sneade M, . Effect of carotid endarterectomy on dementia incidence: 20-year follow-up of the asymptomatic carotid surgery trial (ACST-1). Eur Stroke J. 2019;4:(Suppl 1):786. KQ3E9, KQ4E9.
88 Panchap L, Safavynia SA, Tangel V, . Socioeconomic disparities in carotid revascularization procedures. J Cardiothorac Vasc Anesth. 2019;06:06. PMID: 31917077. 10.1053/j.jvca.2019.11.038 KQ4E4.31917077
89 Pandit V, Lee A, Zeeshan M, . Effect of frailty syndrome on the outcomes of patients with carotid stenosis. J Vasc Surg. 2020;71(5):1595–1600. PMID: 31668557. 10.1016/j.jvs.2019.08.235 KQ4E3c.31668557
90 Parr MS, Dombrovskiy VY, Nagarsheth KH, . Diabetes control decreases morbidity and mortality after carotid endarterectomy. Surgery. 2018;163(2):404–8. PMID: 29129364. 10.1016/j.surg.2017.08.017 KQ4E8.29129364
91 Patel AR, Dombrovskiy VY, Vogel TR. A contemporary evaluation of carotid endarterectomy outcomes in patients with chronic kidney disease in the United States. Vascular. 2017;25(5):459–65. PMID: 28181855. 10.1177/1708538117691430 KQ4E3b.28181855
92 Perri JL, Nolan BW, Goodney PP, . Factors affecting operative time and outcome of carotid endarterectomy in the Vascular Quality Initiative. J Vasc Surg. 2017;66(4):1100–8. PMID: 28712813. 10.1016/j.jvs.2017.03.426 KQ4E3b.28712813
93 Pothof AB, O’Donnell TF, Swerdlow NJ, . Risk of insulin-dependent diabetes mellitus in patients undergoing carotid endarterectomy. J Vasc Surg. 2019;69(3):814–23. PMID: 30714571. 10.1016/j.jvs.2018.05.250 KQ4E3a.30714571
94 Pothof AB, Soden PA, Deery SE, . The impact of race on outcomes after carotid endarterectomy in the United States. J Vasc Surg. 2018;68(2):426–35. PMID: 29482877. 10.1016/j.jvs.2017.11.087 KQ4E8.29482877
95 Pothof AB, Soden PA, Fokkema M, . The impact of contralateral carotid artery stenosis on outcomes after carotid endarterectomy. J Vasc Surg. 2017;66(6):1727–34.e2. PMID: 28655552. 10.1016/j.jvs.2017.04.032 KQ4E8.28655552
96 Pothof AB, van Koeverden ID, Pasterkamp G, . Overtreatment or undertreatment of carotid disease: a transatlantic comparison of carotid endarterectomy patient cohorts. Circ Cardiovasc Qual Outcomes. 2018;11(4):e004607. PMID: 29654001. 10.1161/CIRCOUTCOMES.118.004607 KQ4E8.29654001
97 Pothof AB, Zwanenburg ES, Deery SE, . An update on the incidence of perioperative outcomes after carotid endarterectomy, stratified by type of preprocedural neurologic symptom. J Vasc Surg. 2018;67(3):785–92. PMID: 29074118. 10.1016/j.jvs.2017.07.132 KQ4E3a.29074118
98 Qureshi AI, Chaudhry SA, Qureshi MH, . Rates and predictors of 5-year survival in a national cohort of asymptomatic elderly patients undergoing carotid revascularization. Neurosurgery. 2015;76(1):34–40; discussion -1. PMID: 25525692. 10.1227/NEU.0000000000000551 KQ4E8.25525692
99 Rasheed AS, White RS, Tangel V, . Carotid revascularization procedures and perioperative outcomes: a multistate analysis, 2007-2014. J Cardiothorac Vasc Anesth. 2019;33(7):1963–72. PMID: 30773439. 10.1053/j.jvca.2019.01.022 KQ4E8.30773439
100 Reiff T, Eckstein H, Mansmann U, . Space-2: stent-protected angioplasty in asymptomatic carotid artery stenosis vs. endarterectomy compared to best medical treatment. One year results. Eur Stroke J. 2017;2(1):486. 10.1177/2396987317706897 KQ3E7, KQ4E7.
101 Ringleb P. Stent-protected angioplasty in asymptomatic carotid artery stenosis vs. endarerectomy first results from the SPACE-2 study. Int J Stroke. 2015;10:(Suppl 2):15. KQ3E7, KQ4E7.
102 Rizwan M, Faateh M, Dakour-Aridi H, . Statins reduce mortality and failure to rescue after carotid artery stenting. J Vasc Surg. 2019;69(1):112–9. PMID: 29914834. 10.1016/j.jvs.2018.03.424 KQ4E3d.29914834
103 Ross EG, Mell MW. Evaluation of regional variations in length of stay after elective, uncomplicated carotid endarterectomy in North America. J Vasc Surg. 2019. PMID: 31280981. 10.1016/j.jvs.2019.02.071 KQ4E8.31280981
104 Schermerhorn ML, Liang P, Dakour-Aridi H, . In-hospital outcomes of transcarotid artery revascularization and carotid endarterectomy in the Society for Vascular Surgery Vascular Quality Initiative. J Vasc Surg. 2019;18:18. PMID: 31227410. 10.1016/j.jvs.2018.11.029 KQ4E3a.31227410
105 Schermerhorn ML, Liang P, Eldrup-Jorgensen J, . Association of transcarotid artery revascularization vs transfemoral carotid artery stenting with stroke or death among patients with carotid artery stenosis. JAMA. 2019;322(23):2313–22. PMID: 31846015. 10.1001/jama.2019.18441 KQ4E3a.31846015
106 Schneider JR, Helenowski IB, Jackson CR, . A comparison of results with eversion versus conventional carotid endarterectomy from the Vascular Quality Initiative and the Mid-America Vascular Study Group. J Vasc Surg. 2015;61(5):1216–22. PMID: 25925539. 10.1016/j.jvs.2015.01.049 KQ4E3b.25925539
107 Schneider JR, Jackson CR, Helenowski IB, . A comparison of results of carotid endarterectomy in octogenarians and nonagenarians to younger patients from the Mid-America Vascular Study Group and the Society for Vascular Surgery Vascular Quality Initiative. J Vasc Surg. 2017;65(6):1643–52. PMID: 28259574. 10.1016/j.jvs.2016.12.118 KQ4E8.28259574
108 Schneider JR, Wilkinson JB, Rogers TJ, . Results of carotid endarterectomy in patients with contralateral internal carotid artery occlusion from the Mid-America Vascular Study Group and the Society for Vascular Surgery Vascular Quality Initiative. J Vasc Surg. 2019;21:21. PMID: 31445827. 10.1016/j.jvs.2019.05.040 KQ4E3b.31445827
109 Seicean A, Kumar P, Seicean S, . Surgeon specialty and patient outcomes in carotid endarterectomy. J Neurosurg. 2018:1–10. PMID: 30095343. 10.3171/2018.2.Jns173014 KQ4E3b.30095343
110 Sgroi MD, Darby GC, Kabutey NK, . Experience matters more than specialty for carotid stenting outcomes. J Vasc Surg. 2015;61(4):933–8. PMID: 25600333. 10.1016/j.jvs.2014.11.066 KQ4E3b.25600333
111 Shah VS, Kreatsoulas D, Dornbos D, 3rd, . The impact of pre-operative symptoms on carotid endarterectomy Outcomes: Analysis of the ACS-NSQIP carotid endarterectomy database. J Clin Neurosci. 2020. PMID: 32019726. 10.1016/j.jocn.2020.01.077 KQ4E8.32019726
112 Shean KE, McCallum JC, Soden PA, . Regional variation in patient selection and treatment for carotid artery disease in the Vascular Quality Initiative. J Vasc Surg. 2017;66(1):112–21. PMID: 28359719. 10.1016/j.jvs.2017.01.023 KQ4E3b.28359719
113 Shean KE, O’Donnell TF, Deery SE, . Regional variation in patient outcomes in carotid artery disease treatment in the Vascular Quality Initiative. J Vasc Surg. 2018;68(3):749–59. PMID: 29571620. 10.1016/j.jvs.2017.11.080 KQ4E8.29571620
114 Siddiq F, Adil MM, Malik AA, . Effect of Carotid Revascularization Endarterectomy Versus Stenting Trial results on the performance of carotid artery stent placement and carotid endarterectomy in the United States. Neurosurgery. 2015;77(5):726–32; discussion 32. PMID: 26308633. 10.1227/NEU.0000000000000905 KQ4E8.26308633
115 Sneade M, Bulbulia R, Pan H, . Lifetime risk of dementia in patients with severe carotid stenosis: extended post-trial follow-up of patients in the first asymptomatic carotid surgery trial (ACST-1). Eur Stroke J. 2018;3(1):92–3. 10.1177/2396987318770127 KQ3E9, KQ4E9.31008339
116 Spangler EL, Goodney PP, Schanzer A, . Outcomes of carotid endarterectomy versus stenting in comparable medical risk patients. J Vasc Surg. 2014;60(5):1227–31.e1. PMID: 24953899. 10.1016/j.jvs.2014.05.044 KQ4E3a.24953899
117 Steely AM, Callas PW, Neal D, . Regional variation in postoperative myocardial infarction in patients undergoing vascular surgery in the United States. Ann Vasc Surg. 2017;40:63–73. PMID: 27908815. 10.1016/j.avsg.2016.07.099 KQ4E3b.27908815
118 Streifler JY, den Hartog AG, Pan S, . Ten-year risk of stroke in patients with previous cerebral infarction and the impact of carotid surgery in the Asymptomatic Carotid Surgery Trial. Int J Stroke. 2016;11(9):1020–7. PMID: 27435205. KQ3E9, KQ4E9.27435205
119 Turley RS, Freischlag K, Truong T, . Carotid stenting and endarterectomy and contralateral carotid occlusion. J Vasc Surg. 2019. PMID: 30922764. 10.1016/j.jvs.2018.12.039 KQ4E3a.30922764
120 Vogel TR, Kruse RL, Kim RJ, . Racial and socioeconomic disparities after carotid procedures. Vasc Endovascular Surg. 2018;52(5):330–4. PMID: 29554858. 10.1177/1538574418764063 KQ4E3b.29554858
121 Wang GJ, Beck AW, DeMartino RR, . Insight into the cerebral hyperperfusion syndrome following carotid endarterectomy from the national Vascular Quality Initiative. J Vasc Surg. 2017;65(2):381–9.e2. PMID: 27707618. 10.1016/j.jvs.2016.07.122 KQ4E8.27707618
122 Wang LJ, Ergul EA, Conrad MF, . Addition of proximal intervention to carotid endarterectomy increases risk of stroke and death. J Vasc Surg. 2019;69(4):1102–10. PMID: 30553728. 10.1016/j.jvs.2018.07.042 KQ4E8.30553728
123 Watanabe M, Chaudhry SA, Adil MM, . The effect of atrial fibrillation on outcomes in patients undergoing carotid endarterectomy or stent placement in general practice. J Vasc Surg. 2015;61(4):927–32. PMID: 25814367. 10.1016/j.jvs.2014.11.001 KQ4E8.25814367
124 Wiske C, Arhuidese I, Malas M, . Comparing the efficacy of shunting approaches and cerebral monitoring during carotid endarterectomy using a national database. J Vasc Surg. 2018;68(2):416–25. PMID: 29571621. 10.1016/j.jvs.2017.11.077 KQ4E3b.29571621
125 Wu TY, Akopian G, Katz SG. Patients at elevated risk of major adverse events following endarterectomy for asymptomatic carotid stenosis. Am J Surg. 2015;209(6):1069–73. PMID: 25510477. 10.1016/j.amjsurg.2014.07.011 KQ4E8.25510477
126 Young E, Youpeng L, Da Rocha-Franco JA, . Higher long-term mortality with carotid artery stenting in asymptomatic male compared to female patients in the Southeastern Vascular Study Group. Ann Vasc Surg. 2020;03:03. PMID: 32027990. 10.1016/j.avsg.2020.01.090 KQ4E3a.32027990