# Appendix C Included Studies Lists

## Included trials for KQ1, by author

### Ancillary publication(s) indented under primary article

No studies included

## Included trials for KQ2, by author

### Ancillary publication(s) indented under primary article

No studies included

## Included Trials for KQ3 and KQ4, by Trial

### Ancillary publication(s) indented under primary article

The Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis trial (AMTEC)

- Kolos I, Troitskiy A, Balakhonova T, . Modern medical treatment with or without carotid endarterectomy for severe asymptomatic carotid atherosclerosis. J Vasc Surg. 2015;62(4):914–22. PMID: 26410046. 10.1016/j.jvs.2015.05.005 26410046
  - Kolos I, Loukianov M, Dupik N, . Optimal medical treatment versus carotid endarterectomy: the rationale and design of the Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis (AMTEC) study. Int J Stroke. 2015;10(2):269–74. PMID: 23490405. 10.1111/ijs.12019 23490405

Stent Protected Angioplasty versus Carotid Endarterectomy trial (SPACE-2)

- Reiff T, Eckstein HH, Mansmann U, . Angioplasty in asymptomatic carotid artery stenosis vs. endarterectomy compared to best medical treatment: one-year interim results of SPACE-2. Int J Stroke. 2019:1747493019833017. PMID: 30873912. 10.1177/1747493019833017 30873912
  - Eckstein HH, Reiff T, Ringleb P, . SPACE-2: a missed opportunity to compare carotid endarterectomy, carotid stenting, and best medical treatment in patients with asymptomatic carotid stenoses. Eur J Vasc Endovasc Surg. 2016;51(6):761–5. PMID: 27085660. 10.1016/j.ejvs.2016.02.005 27085660
  - Reiff T, Eckstein HH, Amiri H, . Modification of SPACE-2 study design. Int J Stroke. 2014;9(3):E12–3. PMID: 24636584. 10.1111/ijs.12253 24636584
  - Reiff T, Stingele R, Eckstein HH, . Stent-protected angioplasty in asymptomatic carotid artery stenosis vs. endarterectomy: SPACE2 - a three-arm randomised-controlled clinical trial. Int J Stroke. 2009;4(4):294–9. PMID: 19689759. 10.1111/j.1747-4949.2009.00290.x 19689759

## Included Registry Studies for KQ4, by Registry

### Ancillary publication(s) indented under primary article

American College of Surgeons National Surgical Quality Improvement Program (ACS NSQIP)

- Garcia RM, Yoon S, Cage T, . Ethnicity, race, and postoperative stroke risk among 53,593 patients with asymptomatic carotid stenosis undergoing revascularization. World Neurosurg. 2017;108:246–53. PMID: 28890012. 10.1016/j.wneu.2017.08.184 28890012
  - Glousman BN, Sebastian R, Macsata R, . Carotid endarterectomy for asymptomatic carotid stenosis is safe in octogenarians. J Vasc Surg. 2019;27:27. PMID: 31471235. 10.1016/j.jvs.2019.05.054 31471235
  - Liang P, Solomon Y, Swerdlow NJ, . In-hospital outcomes alone underestimate rates of 30-day major adverse events after carotid artery stenting. J Vasc Surg. 2020;71(4):1233–1241. PMID: 32063441. 10.1016/j.jvs.2019.06.201 32063441
  - Rao V, Liang P, Swerdlow N, . Contemporary outcomes after carotid endarterectomy in high-risk anatomic and physiologic patients. J Vasc Surg. 2019;20:20. PMID: 31443978. 10.1016/j.jvs.2019.05.041 31443978

Medicare

- Lichtman JH, Jones MR, Leifheit EC, . Carotid endarterectomy and carotid artery stenting in the US Medicare population, 1999-2014. JAMA. 2017;318(11):1035–46. PMID: 28975306. 10.1001/jama.2017.12882 28975306

National Inpatient Sample (NIS)

- Mayor JM, Salemi JL, Dongarwar D, . Sex-based differences in ten-year nationwide outcomes of carotid revascularization. J Am Coll Surg. 2019;229(1):38–46.e4. PMID: 30922980. 10.1016/j.jamcollsurg.2019.02.054 30922980

Vascular Study Group of New England (VSGNE)

- Boitano LT, Ergul EA, Tanious A, . A Regional experience with carotid endarterectomy in patients with a history of neck radiation. Ann Vasc Surg. 2019;54:12–21. PMID: 30223012. 10.1016/j.avsg.2018.08.069 30223012

Vascular Quality Initiative (VQI)

- Nejim B, Alshwaily W, Dakour-Aridi H, . Age modifies the efficacy and safety of carotid artery revascularization procedures. J Vasc Surg. 2019;69(5):1490–503.e3. PMID: 31010514. 10.1016/j.jvs.2018.07.062 31010514
  - Dansey KD, Pothof AB, Zettervall SL, . Clinical impact of sex on carotid revascularization. J Vasc Surg. 2020;31:31. PMID: 32014286. 10.1016/j.jvs.2019.07.088 32014286
  - Hicks CW, Nejim B, Aridi HD, . Transfemoral carotid artery stents should be used with caution in patients with asymptomatic carotid artery stenosis. Ann Vasc Surg. 2019;54:1–11. PMID: 30339900. 10.1016/j.avsg.2018.10.001 30339900
  - O’Donnell TFX, Schermerhorn ML, Liang P, . Weekend effect in carotid endarterectomy. Stroke. 2018;49(12):2945–52. PMID: 30571415. 10.1161/STROKEAHA.118.022305 30571415