# Appendix A Detailed Methods

## Literature search strategy

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword

Sources Searched
MEDLINE - Indexed
MEDLINE – non-indexed
PUBMED NOTE: Legacy Pubmed was used
Cochrane Central Register of Controlled Clinical Trials
Cochrane Database of Systematic Reviews

### MEDLINE

#### Bridge and modified search

Database: Ovid MEDLINE(R) <1946 to January February 1 2020>, Ovid MEDLINE(R) Daily Update <February 14, 2020>

Search Strategy:

------------------------------------------------------------

1. Carotid Stenosis/ or Carotid Artery Diseases/ (36561)
2. (carotid adj3 stenos$).ti. (3714)
3. (carotid adj3 stenos$).ti,ab. (9926)
4. limit 3 to (“in data review” or in process or publisher or “pubmed not medline”) (0)
5. carotid Atherosclero$.ti. (2123)
6. carotid Atherosclero$.ti,ab. (4300)
7. limit 6 to (“in data review” or in process or publisher or “pubmed not medline”) (0)
8. 1 or 2 or 4 or 5 or 7 (36749)
9. Mass screening/ (101017)
10. screen$.ti,ab. (619754)
11. test$.ti. (368769)
12. confirmatory test$.ti,ab. (3238)
13. ultrasonography/ or ultraso$.ti,ab. (380599)
14. or/9-13 (1342469)
15. 8 and 14 (9130)
16. Endarterectomy, Carotid/ (8641)
17. endarterectom$.ti,ab. (13414)
18. Angioplasty/ (7147)
19. Angioplasty, Balloon/ (17309)
20. angioplasty.ti,ab. (39163)
21. (Balloon$ or Transluminal Arterial Dilation).ti,ab. (61103)
22. Stents/ (65623)
23. (stent or stents or stenting or stented).ti,ab. (83162)
24. (Revasculari?ation or Recanali?ation or Percutaneous).ti,ab. (167061)
25. or/16-24 (299073)
26. 8 and 25 (13577)
27. Carotid Stenosis/su or Carotid Artery Diseases/su [Surgery] (11437)
28. 26 or 27 (16739)
29. 15 or 28 (23334)
30. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (321250)
31. meta-analysis as topic/ (17589)
32. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt. (938072)
33. random$.ti,ab. (937349)
34. control groups/ or double-blind method/ or single-blind method/ (184785)
35. clinical trial$.ti,ab. (300236)
36. controlled trial$.ti,ab. (185776)
37. (metaanaly$ or meta analy$).ti,ab. (131986)
38. (dummy or placebo).ti,ab. (193650)
39. trial.ti. (182540)
40. or/30-39 (1808812)
41. 29 and 40 (3415)
42. Long Term Adverse Effects/ (527)
43. Postoperative Complications/ or Intraoperative Complications/ (379698)
44. (harm or harms or harmful or harmed).ti,ab. (92224)
45. Endarterectomy, Carotid/ae [Adverse Effects] (2477)
46. Angioplasty, Balloon/ae [Adverse Effects] (3983)
47. Stents/ae [Adverse Effects] (8591)
48. Mortality/ (43069)
49. Morbidity/ (29686)
50. death/ (17388)
51. (death or deaths).ti,ab. (696577)
52. adverse*.ti,ab. (442084)
53. complication$.ti,ab. (761472)
54. side effect$.ti,ab. (211943)
55. safety.ti,ab. (405799)
56. postoperative event$.ti,ab. (608)
57. Risk factors/ or Risk assessment/ (985343)
58. risk$.ti. (412304)
59. (MACEs or myocardial infarction or arrhythmia or ipsilateral stroke or transient ischemic attack).ti,ab. (197182)
60. or/42-59 (3479126)
61. 28 and 60 (8819)
62. exp cohort studies/ (1955143)
63. evaluation studies/ or evaluation study/ (249661)
64. (cohort adj (study or studies)).ti,ab. (160529)
65. cohort analy*.ti,ab. (6379)
66. (follow up adj (study or studies)).ti,ab. (44447)
67. treatment group$.ti,ab. (83001)
68. subgroup$.ti,ab. (190396)
69. retrospective.ti,ab. (425951)
70. longitudinal.ti,ab. (197093)
71. prospective.ti,ab. (481670)
72. retrospective.ti,ab. (425951)
73. or/62-72 (2644879)
74. 40 or 73 (3984551)
75. 61 and 74 (5018)
76. 41 or 75 (6572)
77. limit 76 to (english language and yr="2014 -Current") (1473)
78. exp Databases as Topic/ or Multilevel Analysis/ or Registries/ or Comparative Study.pt. or (multivar$ or Univar$ or Vascular Quality Initiative or Logistic regression or registr$).ti,ab. (2614182)
79. (“Healthcare Cost and Utilization Project” or HCUP or National Inpatient Sample or Nationwide Inpatient Sample or State Inpatient Database* or National Hospital Discharge Survey or NHDS or National Hospital Care Survey or NHCS or Medicare Claims Data or Military Health System Tricare Encounter Data or Veterans Affairs Surgical Quality Improvement Program or VASQIP or National Surgical Quality Improvement Program or NSQIP or Vascular Study Group of Northern New England or VSGNE or VSGNNE or Vascular Quality Initiative or VQI or University Health System Consortium or Private analytics database* or PearlDiver or MarketScan or Premier or Vizient or large administrative or administrative data$).ti,ab. (25366)
80. 78 or 79 (2625707)
81. 61 and 80 (2269)
82. limit 81 to (english language and yr="2014 -Current") (648)
83. 29 and 79 (153)
84. limit 83 to (english language and yr="2014 -Current") (105)
85. 82 or 84 (656)
86. 85 not 77 (130)
87. (201908* or 201909* or 201910*).ed. (249714)
88. 77 and 87 (58)
89. 86 or 88 (188)
90. carotid.ti,ab. (106005)
91. 25 and 90 (22932)
92. 27 or 91 (26449)
93. 79 and 92 (269)
94. limit 93 to (english language and yr="2014 -Current") (152)
95. 89 or 94 (307)
96. (201910* or 201911* or 201912* or 2020*).ed. (346582)
97. 77 or 86 or 94 (1651)
98. 96 and 97 (145)

#### Bridge Indexed Feb 2020

Database: Ovid MEDLINE(R) Epub Ahead of Print <February 14, 2020>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to February 14, 2020>

Search Strategy:

------------------------------------------------------------

1. Carotid Stenosis/ or Carotid Artery Diseases/ (0)
2. (carotid adj3 stenos$).ti. (418)
3. (carotid adj3 stenos$).ti,ab. (1071)
4. limit 3 to (“in data review” or in process or publisher or “pubmed not medline”) (1063)
5. carotid Atherosclero$.ti. (226)
6. carotid Atherosclero$.ti,ab. (480)
7. limit 6 to (“in data review” or in process or publisher or “pubmed not medline”) (478)
8. 1 or 2 or 4 or 5 or 7 (1480)
9. Mass screening/ (0)
10. screen$.ti,ab. (104859)
11. test$.ti. (40650)
12. confirmatory test$.ti,ab. (511)
13. ultrasonography/ or ultraso$.ti,ab. (54286)
14. or/9-13 (193238)
15. 8 and 14 (398)
16. Endarterectomy, Carotid/ (0)
17. endarterectom$.ti,ab. (1188)
18. Angioplasty/ (0)
19. Angioplasty, Balloon/ (0)
20. angioplasty.ti,ab. (3150)
21. (Balloon$ or Transluminal Arterial Dilation).ti,ab. (7677)
22. Stents/ (0)
23. (stent or stents or stenting or stented).ti,ab. (13697)
24. (Revasculari?ation or Recanali?ation or Percutaneous).ti,ab. (22510)
25. or/16-24 (38558)
26. 8 and 25 (670)
27. Carotid Stenosis/su or Carotid Artery Diseases/su [Surgery] (0)
28. 26 or 27 (670)
29. 15 or 28 (960)
30. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (0)
31. meta-analysis as topic/ (0)
32. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt. (529)
33. random$.ti,ab. (172485)
34. control groups/ or double-blind method/ or single-blind method/ (0)
35. clinical trial$.ti,ab. (54968)
36. controlled trial$.ti,ab. (36725)
37. (metaanaly$ or meta analy$).ti,ab. (34315)
38. (dummy or placebo).ti,ab. (21174)
39. trial.ti. (31135)
40. or/30-39 (235497)
41. 29 and 40 (153)
42. Long Term Adverse Effects/ (0)
43. Postoperative Complications/ or Intraoperative Complications/ (0)
44. (harm or harms or harmful or harmed).ti,ab. (19521)
45. Endarterectomy, Carotid/ae [Adverse Effects] (0)
46. Angioplasty, Balloon/ae [Adverse Effects] (0)
47. Stents/ae [Adverse Effects] (0)
48. Mortality/ (0)
49. Morbidity/ (0)
50. death/ (0)
51. (death or deaths).ti,ab. (92977)
52. adverse*.ti,ab. (78743)
53. complication$.ti,ab. (119417)
54. side effect$.ti,ab. (30106)
55. safety.ti,ab. (78542)
56. postoperative event$.ti,ab. (106)
57. Risk factors/ or Risk assessment/ (0)
58. risk$.ti. (63073)
59. (MACEs or myocardial infarction or arrhythmia or ipsilateral stroke or transient ischemic attack).ti,ab. (21781)
60. or/42-59 (416687)
61. 28 and 60 (354)
62. exp cohort studies/ (1)
63. evaluation studies/ or evaluation study/ (26)
64. (cohort adj (study or studies)).ti,ab. (35733)
65. cohort analy*.ti,ab. (1342)
66. (follow up adj (study or studies)).ti,ab. (4044)
67. treatment group$.ti,ab. (10773)
68. subgroup$.ti,ab. (31209)
69. retrospective.ti,ab. (84803)
70. longitudinal.ti,ab. (40344)
71. prospective.ti,ab. (72828)
72. retrospective.ti,ab. (84803)
73. or/62-72 (234615)
74. 40 or 73 (428577)
75. 61 and 74 (146)
76. 41 or 75 (215)
77. limit 76 to (english language and yr="2014 -Current") (150)
78. exp Databases as Topic/ or Multilevel Analysis/ or Registries/ or Comparative Study.pt. or (multivar$ or Univar$ or Vascular Quality Initiative or Logistic regression or registr$).ti,ab. (133118)
79. (“Healthcare Cost and Utilization Project” or HCUP or National Inpatient Sample or Nationwide Inpatient Sample or State Inpatient Database* or National Hospital Discharge Survey or NHDS or National Hospital Care Survey or NHCS or Medicare Claims Data or Military Health System Tricare Encounter Data or Veterans Affairs Surgical Quality Improvement Program or VASQIP or National Surgical Quality Improvement Program or NSQIP or Vascular Study Group of Northern New England or VSGNE or VSGNNE or Vascular Quality Initiative or VQI or University Health System Consortium or Private analytics database* or PearlDiver or MarketScan or Premier or Vizient or large administrative or administrative data$).ti,ab. (6737)
80. 78 or 79 (137740)
81. 61 and 80 (66)
82. limit 81 to (english language and yr="2014 -Current") (55)
83. 29 and 79 (10)
84. limit 83 to (english language and yr="2014 -Current") (10)
85. 82 or 84 (58)
86. 85 not 77 (25)
87. (201908* or 201909* or 201910*).ed. (11298)
88. 77 and 87 (0)
89. 86 or 88 (25)
90. carotid.ti,ab. (10209)
91. 25 and 90 (2477)
92. 27 or 91 (2477)
93. 79 and 92 (44)
94. limit 93 to (english language and yr="2014 -Current") (43)
95. 89 or 94 (62)
96. 77 or 86 or 94 (209)

#### Bridge and modified search: Oct 2019

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R) <1946 to October 23, 2019>

Search Strategy:

------------------------------------------------------------

1. Carotid Stenosis/ or Carotid Artery Diseases/ (36134)
2. (carotid adj3 stenos$).ti. (4058)
3. (carotid adj3 stenos$).ti,ab. (10797)
4. limit 3 to (“in data review” or in process or publisher or “pubmed not medline”) (1002)
5. carotid Atherosclero$.ti. (2305)
6. carotid Atherosclero$.ti,ab. (4696)
7. limit 6 to (“in data review” or in process or publisher or “pubmed not medline”) (464)
8. 1 or 2 or 4 or 5 or 7 (37728)
9. Mass screening/ (99767)
10. screen$.ti,ab. (705651)
11. test$.ti. (403988)
12. confirmatory test$.ti,ab. (3661)
13. ultrasonography/ or ultraso$.ti,ab. (426422)
14. or/9-13 (1503805)
15. 8 and 14 (9403)
16. Endarterectomy, Carotid/ (8513)
17. endarterectom$.ti,ab. (14388)
18. Angioplasty/ (7057)
19. Angioplasty, Balloon/ (17150)
20. angioplasty.ti,ab. (41951)
21. (Balloon$ or Transluminal Arterial Dilation).ti,ab. (67614)
22. Stents/ (64537)
23. (stent or stents or stenting or stented).ti,ab. (94574)
24. (Revasculari?ation or Recanali?ation or Percutaneous).ti,ab. (185716)
25. or/16-24 (331040)
26. 8 and 25 (14017)
27. Carotid Stenosis/su or Carotid Artery Diseases/su [Surgery] (11304)
28. 26 or 27 (17158)
29. 15 or 28 (23951)
30. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (318080)
31. meta-analysis as topic/ (17321)
32. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt. (925795)
33. random$.ti,ab. (1082326)
34. control groups/ or double-blind method/ or single-blind method/ (182479)
35. clinical trial$.ti,ab. (345233)
36. controlled trial$.ti,ab. (215083)
37. (metaanaly$ or meta analy$).ti,ab. (158011)
38. (dummy or placebo).ti,ab. (211662)
39. trial.ti. (206780)
40. or/30-39 (2001318)
41. 29 and 40 (3520)
42. Long Term Adverse Effects/ (497)
43. Postoperative Complications/ or Intraoperative Complications/ (374478)
44. (harm or harms or harmful or harmed).ti,ab. (107892)
45. Endarterectomy, Carotid/ae [Adverse Effects] (2427)
46. Angioplasty, Balloon/ae [Adverse Effects] (3916)
47. Stents/ae [Adverse Effects] (8483)
48. Mortality/ (42384)
49. Morbidity/ (29356)
50. death/ (17231)
51. (death or deaths).ti,ab. (772153)
52. adverse*.ti,ab. (505358)
53. complication$.ti,ab. (860315)
54. side effect$.ti,ab. (237346)
55. safety.ti,ab. (468930)
56. postoperative event$.ti,ab. (690)
57. Risk factors/ or Risk assessment/ (967587)
58. risk$.ti. (462348)
59. (MACEs or myocardial infarction or arrhythmia or ipsilateral stroke or transient ischemic attack).ti,ab. (215153)
60. or/42-59 (3809621)
61. 28 and 60 (9004)
62. exp cohort studies/ (1914283)
63. evaluation studies/ (246756)
64. (cohort adj (study or studies)).ti,ab. (186835)
65. cohort analy*.ti,ab. (7346)
66. (follow up adj (study or studies)).ti,ab. (47718)
67. treatment group$.ti,ab. (91905)
68. subgroup$.ti,ab. (215039)
69. retrospective.ti,ab. (491318)
70. longitudinal.ti,ab. (230247)
71. prospective.ti,ab. (540111)
72. retrospective.ti,ab. (491318)
73. or/62-72 (2811985)
74. 40 or 73 (4313965)
75. 61 and 74 (5043)
76. 41 or 75 (6651)
77. limit 76 to (english language and yr="2014 -Current") (1498)
78. exp Databases as Topic/ or Multilevel Analysis/ or Registries/ or Comparative Study.pt. or (multivar$ or Univar$ or Vascular Quality Initiative or Logistic regression or registr$).ti,ab. (2705425)
79. (“Healthcare Cost and Utilization Project” or HCUP or National Inpatient Sample or Nationwide Inpatient Sample or State Inpatient Database* or National Hospital Discharge Survey or NHDS or National Hospital Care Survey or NHCS or Medicare Claims Data or Military Health System Tricare Encounter Data or Veterans Affairs Surgical Quality Improvement Program or VASQIP or National Surgical Quality Improvement Program or NSQIP or Vascular Study Group of Northern New England or VSGNE or VSGNNE or Vascular Quality Initiative or VQI or University Health System Consortium or Private analytics database* or PearlDiver or MarketScan or Premier or Vizient or large administrative or administrative data$).ti,ab. (30541)
80. 78 or 79 (2720814)
81. 61 and 80 (2275)
82. limit 81 to (english language and yr="2014 -Current") (644)
83. 29 and 79 (150)
84. limit 83 to (english language and yr="2014 -Current") (102)
85. 82 or 84 (654)
86. 85 not 77 (144)
87. (201908* or 201909* or 201910*).ed. (235118)
88. 77 and 87 (50)
89. 86 or 88 (194)
90. carotid.ti,ab. (114442)
91. 25 and 90 (24957)
92. 27 or 91 (28451)
93. 79 and 92 (296)
94. limit 93 to (english language and yr="2014 -Current") (178)
95. 89 or 94 (335)

#### Original search

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R) <1946 to August 01, 2019>

Search Strategy:

------------------------------------------------------------

1. Carotid Stenosis/ or Carotid Artery Diseases/ (35865)
2. (carotid adj3 stenos$).ti. (4020)
3. (carotid adj3 stenos$).ti,ab. (10699)
4. limit 3 to (“in data review” or in process or publisher or “pubmed not medline”) (995)
5. carotid Atherosclero$.ti. (2287)
6. carotid Atherosclero$.ti,ab. (4654)
7. limit 6 to (“in data review” or in process or publisher or “pubmed not medline”) (470)
8. 1 or 2 or 4 or 5 or 7 (37452)
9. Mass screening/ (98406)
10. screen$.ti,ab. (694500)
11. test$.ti. (400788)
12. confirmatory test$.ti,ab. (3587)
13. ultrasonography/ or ultraso$.ti,ab. (421694)
14. or/9-13 (1485202)
15. 8 and 14 (9343)
16. Endarterectomy, Carotid/ (8434)
17. endarterectom$.ti,ab. (14286)
18. Angioplasty/ (6994)
19. Angioplasty, Balloon/ (17068)
20. angioplasty.ti,ab. (41755)
21. (Balloon$ or Transluminal Arterial Dilation).ti,ab. (67067)
22. Stents/ (63757)
23. (stent or stents or stenting or stented).ti,ab. (93545)
24. (Revasculari?ation or Recanali?ation or Percutaneous).ti,ab. (183770)
25. or/16-24 (327733)
26. 8 and 25 (13881)
27. Carotid Stenosis/su or Carotid Artery Diseases/su [Surgery] (11226)
28. 26 or 27 (17012)
29. 15 or 28 (23758)
30. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (314090)
31. meta-analysis as topic/ (17115)
32. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt. (913982)
33. random$.ti,ab. (1065326)
34. control groups/ or double-blind method/ or single-blind method/ (180260)
35. clinical trial$.ti,ab. (338856)
36. controlled trial$.ti,ab. (209876)
37. (metaanaly$ or meta analy$).ti,ab. (153046)
38. (dummy or placebo).ti,ab. (209115)
39. trial.ti. (202838)
40. or/30-39 (1974179)
41. 29 and 40 (3488)
42. Long Term Adverse Effects/ (480)
43. Postoperative Complications/ or Intraoperative Complications/ (370637)
44. (harm or harms or harmful or harmed).ti,ab. (105554)
45. Endarterectomy, Carotid/ae [Adverse Effects] (2404)
46. Angioplasty, Balloon/ae [Adverse Effects] (3892)
47. Stents/ae [Adverse Effects] (8393)
48. Mortality/ (41848)
49. Morbidity/ (29024)
50. death/ (17065)
51. (death or deaths).ti,ab. (761575)
52. adverse*.ti,ab. (495899)
53. complication$.ti,ab. (849195)
54. side effect$.ti,ab. (234610)
55. safety.ti,ab. (460269)
56. postoperative event$.ti,ab. (675)
57. Risk factors/ or Risk assessment/ (952588)
58. risk$.ti. (454985)
59. (MACEs or myocardial infarction or arrhythmia or ipsilateral stroke or transient ischemic attack).ti,ab. (212877)
60. or/42-59 (3757473)
61. 28 and 60 (8907)
62. exp cohort studies/ (1881908)
63. evaluation studies/ (244805)
64. (cohort adj (study or studies)).ti,ab. (181586)
65. cohort analy*.ti,ab. (7171)
66. (follow up adj (study or studies)).ti,ab. (47307)
67. treatment group$.ti,ab. (90750)
68. subgroup$.ti,ab. (211156)
69. retrospective.ti,ab. (481085)
70. longitudinal.ti,ab. (226145)
71. prospective.ti,ab. (532052)
72. retrospective.ti,ab. (481085)
73. or/62-72 (2769621)
74. 40 or 73 (4251917)
75. 61 and 74 (4992)
76. 41 or 75 (6591)
77. limit 76 to (english language and yr="2014 -Current") (1444)

#### PUBMED – no changes for Bridges

- #1: (carotid[tiab] AND (stenos*[tiab] OR Atherosclero*[tiab]))
- #2: ((screen*[tiab] OR ultrason*[tiab])
- #3: (endarterectom*[tiab] OR angioplasty[tiab] OR Balloon*[tiab] OR Transluminal Arterial Dilation[tiab] OR stent[tiab] OR stents[tiab] OR stenting[tiab] OR stented[tiab] OR Revascularization[tiab] OR recanalisation[tiab] OR Percutaneous[tiab]))
- #4: #2 OR #3
- #5: #1 AND #4
- #6: #5 AND publisher[sb] AND eng[la]

#### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

- #1 (carotid near/3 stenosis):ti,ab,kw 1467
- #2 (carotid near/3 atherosclero*):ti,ab,kw 895
- #3 #1 or #2 2201
- #4 screen*:ti,ab,kw 63474
- #5 test:ti 10453
- #6 (confirmatory next test*):ti,ab,kw 172
- #7 (ultrasonog* or untrasound*):ti,ab,kw 15280
- #8 endarterectom*:ti,ab,kw 1936
- #9 (angioplasty or balloon or Transluminal Arterial Dilation):ti,ab,kw 13417
- #10 (stent or stents or stenting or stented):ti,ab,kw 14232
- #11 (Revasculari?ation or Recanali?ation or Percutaneous):ti,ab,kw 26028
- #12 {or #4-#11} 124050
- #13 #3 AND #12 with Publication Year from 2014 to 2019, in Trials 426
- #14 #3 AND #12 with Cochrane Library publication date Between Jan 2014 and Aug 2019, in Cochrane Reviews 3

#### Cochrane Bridge: Oct 2019

- ID Search Hits
- #1 (carotid near/3 stenosis):ti,ab,kw 1496
- #2 (carotid near/3 atherosclero*):ti,ab,kw 913
- #3 #1 or #2 2243
- #4 screen*:ti,ab,kw 65252
- #5 test:ti 10696
- #6 (confirmatory next test*):ti,ab,kw 181
- #7 (ultrasonog* or untrasound*):ti,ab,kw 15589
- #8 endarterectom*:ti,ab,kw 1954
- #9 (angioplasty or balloon or Transluminal Arterial Dilation):ti,ab,kw 13582
- #10 (stent or stents or stenting or stented):ti,ab,kw 14472
- #11 (Revasculari?ation or Recanali?ation or Percutaneous):ti,ab,kw 26504
- #12 {or #4-#11} 126989
- #13 #3 AND #12 with Publication Year from 2014 to 2019, in Trials 454
- #14 #3 AND #12 with Cochrane Library publication date Between Jan 2014 and Aug 2019, in Cochrane Reviews 3
- #15 #3 AND #12 with Cochrane Library publication date Between Aug 2019 and Oct 2019, in Trials

#### Cochrane Bridge: Feb 2020

- #1 (carotid near/3 stenosis):ti,ab,kw 1564
- #2 (carotid near/3 atherosclero*):ti,ab,kw 954
- #3 #1 or #2 2340
- #4 screen*:ti,ab,kw 70418
- #5 test:ti 11010
- #6 (confirmatory next test*):ti,ab,kw 189
- #7 (ultrasonog* or untrasound*):ti,ab,kw 16054
- #8 endarterectom*:ti,ab,kw 2024
- #9 (angioplasty or balloon or Transluminal Arterial Dilation):ti,ab,kw 14186
- #10 (stent or stents or stenting or stented):ti,ab,kw 15546
- #11 (Revasculari?ation or Recanali?ation or Percutaneous):ti,ab,kw 28120
- #12 {or #4-#11} 135078
- #13 #3 AND #12 with Publication Year from 2014 to 2019, in Trials 500
- #14 #3 AND #12 with Cochrane Library publication date Between Jan 2014 and Aug 2019, in Cochrane Reviews 3
- #15 #3 AND #12 with Publication Year from 2014 to 2020, with Cochrane Library publication date Between Oct 2019 and Feb 2020, in Trials 45

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Populations | KQs 1, 2: Unselected or community-dwelling, generally asymptomatic adults (i.e., without neurologic symptoms referable to the carotid artery or a history of a stroke or transient ischemic attack); KQs 3, 4: Unselected or community-dwelling, generally asymptomatic adults with clinically important CAS (defined as 60% to 99% stenosis) | All KQs: Children and adolescents; symptomatic adults with CAS; adults with history of stroke or transient ischemic attacks; KQs 1, 2: People with known carotid occlusion; with known CVD; who are undergo CAS testing for pre-operative planning; or have had CEA or CAAS and are undergoing surveillance for restenosis
Interventions | KQs 1, 2: Screening with carotid duplex ultrasonography; KQs 3, 4: surgical repair including carotid endarterectomy (CEA) or carotid angioplasty and stenting (CAS), transcarotid artery revascularization (TCAR) | KQs 1, 2: Physical examination for carotid bruit; CIMT for CVD risk prediction
Comparisons | KQs 1, 2: No screening; KQ 3: Medical treatment/usual care (e.g., statins, antiplatelet medications); KQ 4: Medical treatment/usual care or noncomparative studies reporting rates of harms | KQs 3, 4: Comparative studies of CEA versus CAS
Outcomes | KQs 1, 3: CAS-related stroke, mortality, quality of life, functional status, cognitive status; KQ 2: Adverse outcomes related to screening tests or subsequent confirmatory testing (i.e., angiography); KQ 4: Perioperative complications (e.g., stroke, mortality, myocardial infarction, cranial nerve injuries) | KQs 1, 2: Diagnostic accuracy, CVD risk prediction
Study designs | KQs 1-3: Randomized, controlled trials; KQ 4: Randomized, controlled trials; large cohort studies or registries | All KQs: Cost-effectiveness analyses; KQs 1-3: All designs other than randomized, controlled trials; KQ 4: Case reports, small observational studies
Countries | Studies conducted in countries categorized as “very high” on the Human Development Index (as defined by the United Nations Development Programme)
Language | English only | Non-English languages
Years | 2014-present | Publications prior to 2014

Abbreviations: CAS = carotid artery stenting; CEA = carotid endarterectomy; CIMT = carotid intima-media thickness test; CVD = cardiovascular disease; KQ = key question

Appendix A Table 2 Audit Criteria

Topic | Criteria
Initial eligibility criteria for Key Question 4 audit | - ≥ 10,000 asymptomatic surgeries; - U.S. data; - Large national administrative databases or smaller surgical registries
Audit prioritization criteria for each vascular registry | - Primary study was the largest, most recent population study; ○ If a more recent but smaller study was available, it was included as an ancillary article to compare similarities or changes in trends; - Results were stratified by symptomatic status; - If no studies stratified by symptomatic status, we selected studies with >80 percent asymptomatic cases

Appendix A Table 3 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^31^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - Controlled Clinical Trial only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Registry studies, adapted from the Newcastle-Ottawa Scale^32^ | - Does the cohort appear to be valid?; - Is the cohort representative of the average-risk patient?; - Did the study adjust for prognostic variables?; - Can we be confident in the assessment of the presence or absence of prognostic factors?; - Can we be confident in the assessment of outcomes?

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.