# References

1 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2020. CA: A Cancer Journal for Clinicians. 2020;70(1):7–30. doi: 10.3322/caac.21590.31912902
2 Jeon J, Holford TR, Levy DT, . Smoking and Lung Cancer Mortality in the United States From 2015 to 2065: A Comparative Modeling Approach. Ann Intern Med. 2018 Nov 20;169(10):684–93. doi: 10.7326/m18-1250. PMID: 30304504.30304504
3 Moyer VA, U. S. Preventive Services Task Force. Screening for lung cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014 Mar 4;160(5):330–8. doi: 10.7326/M13-2771. PMID: 24378917.24378917
4 National Lung Screening Trial Research Team, Aberle DR, Adams AM, . Reduced lung-cancer mortality with low-dose computed tomographic screening. N Engl J Med. 2011 Aug 4;365(5):395–409. doi: 10.1056/NEJMoa1102873. PMID: 21714641.21714641
5 Pinsky PF, Church TR, Izmirlian G, . The National Lung Screening Trial: results stratified by demographics, smoking history, and lung cancer histology. Cancer. 2013 Nov 15;119(22):3976–83. doi: 10.1002/cncr.28326. PMID: 24037918.24037918
6 The National Lung Screening Trial Research Team. Lung Cancer Incidence and Mortality with Extended Follow-up in the National Lung Screening Trial. J Thorac Oncol. 2019 Oct;14(10):1732–42. doi: 10.1016/j.jtho.2019.05.044. PMID: 31260833.31260833
7 Kazerooni EA, Armstrong MR, Amorosa JK, . ACR CT Accreditation Program and the Lung Cancer Screening Program Designation. J Am Coll Radiol. 2016 Feb;13(2 Suppl):R30–4. doi: 10.1016/j.jacr.2015.12.010. PMID: 26846533.26846533
8 Pinsky PF, Gierada DS, Black W, . Performance of Lung-RADS in the National Lung Screening Trial: a retrospective assessment. Ann Intern Med. 2015 Apr 7;162(7):485–91. doi: 10.7326/m14-2086. PMID: 25664444.25664444
9 de Koning HJ, van der Aalst CM, de Jong PA, . Reduced Lung-Cancer Mortality with Volume CT Screening in a Randomized Trial. N Engl J Med. 2020 Feb 6;382(6):503–13. doi: 10.1056/NEJMoa1911793. PMID: 31995683.31995683
10 Becker N, Motsch E, Trotter A, . Lung cancer mortality reduction by LDCT screening-Results from the randomized German LUSI trial. Int J Cancer. 2020 Mar 15;146(6):1503–13. doi: 10.1002/ijc.32486. PMID: 31162856.31162856
11 Huo J, Shen C, Volk RJ, . Use of CT and chest radiography for lung cancer screening before and after publication of screening guidelines: intended and unintended uptake. JAMA Intern Med. 2017 Mar 1;177(3):439–41. doi: 10.1001/jamainternmed.2016.9016. PMID: 28135349.28135349
12 Kinsinger LS, Anderson C, Kim J, . Implementation of lung cancer screening in the Veterans Health Administration. JAMA Intern Med. 2017 Mar 1;177(3):399–406. doi: 10.1001/jamainternmed.2016.9022. PMID: 28135352.28135352
13 Richards TB, Doria-Rose VP, Soman A, . Lung Cancer Screening Inconsistent With U.S. Preventive Services Task Force Recommendations. Am J Prev Med. 2019 Jan;56(1):66–73. doi: 10.1016/j.amepre.2018.07.030. PMID: 30467092.30467092
14 Jemal A, Fedewa SA. Lung Cancer Screening With Low-Dose Computed Tomography in the United States-2010 to 2015. JAMA Oncol. 2017 Sep 1;3(9):1278–81. doi: 10.1001/jamaoncol.2016.6416. PMID: 28152136.28152136
15 Lung cancer screening rates: data from the lung cancer screening registry. ASCO Annual Meeting; 2018; Chicago, IL. J Clin Oncol.
16 National Cancer Institute. Lung cancer screening. Washington, DC: U.S. Department of Health and Human Services; 2019. https://progressreport.cancer.gov/detection/lung_cancer. Accessed May 16, 2019.
17 Brasher P, Tanner N, Yeager D, . Adherence to Annual Lung Cancer Screening within the Veterans Health Administration Lung Cancer Screening Demonstration Project. CHEST. 2018;154(4):636A–7A. doi: 10.1016/j.chest.2018.08.576.29705221
18 Zahnd WE, Eberth JM. Lung Cancer Screening Utilization: A Behavioral Risk Factor Surveillance System Analysis. Am J Prev Med. 2019 Aug;57(2):250–5. doi: 10.1016/j.amepre.2019.03.015. PMID: 31248742.31248742
19 Richards TB, Soman A, Thomas CC, . Screening for Lung Cancer - 10 States, 2017. MMWR Morb Mortal Wkly Rep. 2020 Feb 28;69(8):201–6. doi: 10.15585/mmwr.mm6908a1. PMID: 32106215.32106215
20 Pinsky PF, Kramer BS. Lung cancer risk and demographic characteristics of current 20–29 pack-year smokers: implications for screening. J Natl Cancer Inst. 2015 Nov;107(11)doi: 10.1093/jnci/djv226. PMID: 26483244.26483244
21 Fiscella K, Winters P, Farah S, . Do lung cancer eligibility criteria align with risk among Blacks and Hispanics? PLoS One. 2015;10(11):e0143789. doi: 10.1371/journal.pone.0143789. PMID: 26618478.26618478
22 Holford TR, Levy DT, Meza R. Comparison of Smoking History Patterns Among African American and White Cohorts in the United States Born 1890 to 1990. Nicotine Tob Res. 2016 Apr;18 Suppl 1:S16–29. doi: 10.1093/ntr/ntv274. PMID: 26980861.26980861
23 Wang Y, Midthun DE, Wampfler JA, . Trends in the proportion of patients with lung cancer meeting screening criteria. JAMA. 2015 Feb 24;313(8):853–5. doi: 10.1001/jama.2015.413. PMID: 25710663.25710663
24 Kovalchik SA, Tammemagi M, Berg CD, . Targeting of low-dose CT screening according to the risk of lung-cancer death. N Engl J Med. 2013 Jul 18;369(3):245–54. doi: 10.1056/NEJMoa1301851. PMID: 23863051.23863051
25 Tammemagi MC, Church TR, Hocking WG, . Evaluation of the lung cancer risks at which to screen ever- and never-smokers: screening rules applied to the PLCO and NLST cohorts. PLoS Med. 2014 Dec;11(12):e1001764. doi: 10.1371/journal.pmed.1001764. PMID: 25460915.25460915
26 Cheung LC, Katki HA, Chaturvedi AK, . Preventing Lung Cancer Mortality by Computed Tomography Screening: The Effect of Risk-Based Versus U.S. Preventive Services Task Force Eligibility Criteria, 2005–2015. Ann Intern Med. 2018;168(3):229–32. doi: 10.7326/m17-2067. PMID: 29297008.29297008
27 Tammemagi MC, Katki HA, Hocking WG, . Selection criteria for lung-cancer screening. N Engl J Med. 2013 Feb 21;368(8):728–36. doi: 10.1056/NEJMoa1211776. PMID: 23425165.23425165
28 Kumar V, Cohen JT, van Klaveren D, . Risk-targeted lung cancer screening: a cost-effectiveness analysis. Ann Intern Med. 2018;168(3):161–9. doi: 10.7326/M17-1401. PMID: 29297005.29297005
29 ten Haaf K, Jeon J, Tammemagi MC, . Risk prediction models for selection of lung cancer screening candidates: a retrospective validation study. PLoS Med. 2017 Apr;14(4):e1002277. doi: 10.1371/journal.pmed.1002277. PMID: 28376113.28376113
30 ten Haaf K, Bastani M, Cao P, . A Comparative Modeling Analysis of Risk-Based Lung Cancer Screening Strategies. JNCI: Journal of the National Cancer Institute. 2019;112(5):466–79. doi: 10.1093/jnci/djz164.
31 Rivera MP, Tanner NT, Silvestri GA, . Incorporating Coexisting Chronic Illness into Decisions about Patient Selection for Lung Cancer Screening. An Official American Thoracic Society Research Statement. Am J Respir Crit Care Med. 2018 Jul 15;198(2):e3–e13. doi: 10.1164/rccm.201805-0986ST. PMID: 30004250.30004250
32 Howard DH, Richards TB, Bach PB, . Comorbidities, smoking status, and life expectancy among individuals eligible for lung cancer screening. Cancer. 2015 Dec 15;121(24):4341–7. doi: 10.1002/cncr.29677. PMID: 26372542.26372542
33 Cheung LC, Berg CD, Castle PE, . Life-Gained-Based Versus Risk-Based Selection of Smokers for Lung Cancer Screening. Ann Intern Med. 2019 Nov 5;171(9):623–32. doi: 10.7326/m19-1263. PMID: 31634914.31634914
34 Caverly TJ, Cao P, Hayward RA, . Identifying Patients for Whom Lung Cancer Screening Is Preference-Sensitive: A Microsimulation Study. Ann Intern Med. 2018 Jul 3;169(1):1–9. doi: 10.7326/m17-2561. PMID: 29809244.29809244
35 Tanner NT, Dai L, Bade BC, . Assessing the Generalizability of the National Lung Screening Trial: Comparison of Patients with Stage 1 Disease. Am J Respir Crit Care Med. 2017 Sep 1;196(5):602–8. doi: 10.1164/rccm.201705-0914OC. PMID: 28722466.28722466
36 de Koning HJ, Meza R, Plevritis SK, . Benefits and harms of computed tomography lung cancer screening strategies: a comparative modeling study for the U.S. Preventive Services Task Force. Ann Intern Med. 2014 Mar 4;160(5):311–20. doi: 10.7326/M13-2316. PMID: 24379002.24379002
37 Knudsen AB, Zauber AG, Rutter CM, . Estimation of Benefits, Burden, and Harms of Colorectal Cancer Screening Strategies: Modeling Study for the US Preventive Services Task Force. Jama. 2016 Jun 21;315(23):2595–609. doi: 10.1001/jama.2016.6828. PMID: 27305518.27305518
38 Kim JJ, Burger EA, Regan C, . Screening for Cervical Cancer in Primary Care: A Decision Analysis for the US Preventive Services Task Force. Jama. 2018 Aug 21;320(7):706–14. doi: 10.1001/jama.2017.19872. PMID: 30140882.30140882
39 Mandelblatt JS, Stout NK, Schechter CB, . Collaborative Modeling of the Benefits and Harms Associated With Different U.S. Breast Cancer Screening Strategies. Ann Intern Med. 2016 Feb 16;164(4):215–25. doi: 10.7326/m15-1536. PMID: 26756606.26756606
40 Jonas D. Lung Screening Systematic Review - UPDATE WHEN READY. 2019.
41 McMahon PM, Meza R, Plevritis SK, . Comparing benefits from many possible computed tomography lung cancer screening programs: extrapolating from the National Lung Screening Trial using comparative modeling. PLoS One. 2014;9(6):e99978. doi: 10.1371/journal.pone.0099978. PMID: 24979231.24979231
42 Moolgavkar SH, Holford TR, Levy DT, . Impact of reduced tobacco smoking on lung cancer mortality in the United States during 1975–2000. J Natl Cancer Inst. 2012 Apr 4;104(7):541–8. doi: 10.1093/jnci/djs136. PMID: 22423009.22423009
43 Tam J, Levy DT, Jeon J, . Projecting the effects of tobacco control policies in the USA through microsimulation: a study protocol. BMJ Open. 2018 Mar 23;8(3):e019169. doi: 10.1136/bmjopen-2017-019169. PMID: 29574440.29574440
44 de Koning HJ, Meza R, Plevritis SK, . Benefits and harms of computed tomography lung cancer screening programs for high-risk populations. AHRQ Publication. 2013;No. 13-05196-EF-2:Rockville, MD: Agency for Healthcare Research and Quality.
45 Rachet B, Siemiatycki J, Abrahamowicz M, . A flexible modeling approach to estimating the component effects of smoking behavior on lung cancer. J Clin Epidemiol. 2004 Oct;57(10):1076–85. doi: 10.1016/j.jclinepi.2004.02.014. PMID: 15528059.15528059
46 Remen T, Pintos J, Abrahamowicz M, . Risk of lung cancer in relation to various metrics of smoking history: a case-control study in Montreal. BMC Cancer. 2018 Dec 19;18(1):1275. doi: 10.1186/s12885-018-5144-5. PMID: 30567516.30567516
47 Katki HA, Kovalchik SA, Petito LC, . Implications of Nine Risk Prediction Models for Selecting Ever-Smokers for Computed Tomography Lung Cancer Screening. Ann Intern Med. 2018 Jul 3;169(1):10–9. doi: 10.7326/m17-2701. PMID: 29800127.29800127
48 Bach PB, Kattan MW, Thornquist MD, . Variations in lung cancer risk among smokers. J Natl Cancer Inst. 2003 Mar 19;95(6):470–8. PMID: 12644540.12644540
49 National Comprehensive Cancer Network. Clinical practice guidelines in oncology: lung cancer screening. Version 2.2018. Fort Washington, PA: National Comprehensive Cancer Network; 2018. https://www.nccn.org/professionals/physician_gls/pdf/lung_screening.pdf. Accessed January 11, 2018.
50 Charnes A, Cooper WW, Rhodes E. Measuring the efficiency of decision making units. European Journal of Operational Research. 1978 1978/11/01/;2(6):429–44. doi: 10.1016/0377-2217(78)90138-8.
51 Criss SD, Cao P, Bastani M, . Cost-Effectiveness Analysis of Lung Cancer Screening in the United States: A Comparative Modeling Study. Ann Intern Med. 2019 Dec 3;171(11):796–804. doi: 10.7326/m19-0322. PMID: 31683314.31683314
52 Aldrich MC, Mercaldo SF, Sandler KL, . Evaluation of USPSTF Lung Cancer Screening Guidelines Among African American Adult Smokers. JAMA Oncol. 2019 Jun 27doi: 10.1001/jamaoncol.2019.1402. PMID: 31246249.31246249
53 Wu GX, Goldstein L, Kim JY, . Proportion of non-small-cell lung cancer patients that would have been eligible for lung cancer screening. Clin Lung Cancer. 2016;17(5):e131–e9. doi: 10.1016/j.cllc.2016.01.001.26872765
54 Vu C, Lin S, Chang C-F. Gender gaps in care: lung cancer screening criteria in women. Chest. 2019 2019/10/01/;156(4, Supplement):A407. doi: 10.1016/j.chest.2019.08.444.
55 Bach PB, Gould MK. When the average applies to no one: personalized decision making about potential benefits of lung cancer screening. Ann Intern Med. 2012 Oct 16;157(8):571–3. doi: 10.7326/0003-4819-157-8-201210160-00524. PMID: 22893040.22893040
56 Bibbins-Domingo K, Grossman DC, Curry SJ, . Screening for Colorectal Cancer: US Preventive Services Task Force Recommendation Statement. Jama. 2016 Jun 21;315(23):2564–75. doi: 10.1001/jama.2016.5989. PMID: 27304597.27304597
57 Siu AL. Screening for Breast Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016 Feb 16;164(4):279–96. doi: 10.7326/m15-2886. PMID: 26757170.26757170
58 Patz EF, Jr., Pinsky P, Gatsonis C, . Overdiagnosis in low-dose computed tomography screening for lung cancer. JAMA Intern Med. 2014 Feb 1;174(2):269–74. doi: 10.1001/jamainternmed.2013.12738. PMID: 24322569.24322569
59 Criss SD, Cao P, Bastani M, . Cost-effectiveness analysis of lung cancer screening in the United States: a comparative modeling study. Ann Intern Med. 2019 Nov 5doi: 10.7326/m19-0322. PMID: 31683314.31683314
60 Meza R, ten Haaf K, Kong CY, . Comparative analysis of 5 lung cancer natural history and screening models that reproduce outcomes of the NLST and PLCO trials. Cancer. 2014 Jun 1;120(11):1713–24. doi: 10.1002/cncr.28623. PMID: 24577803.24577803
61 Blom EF, Ten Haaf K, Arenberg DA, . Treatment capacity required for full-scale implementation of lung cancer screening in the United States. Cancer. 2019 Jun 15;125(12):2039–48. doi: 10.1002/cncr.32026. PMID: 30811590.30811590
62 Vachani A, Saia C, Schnall MD, . Adherence to Annual Lung Cancer Screening. C30. LUNG CANCER SCREENING: LESSONS FROM THE FRONT-LINE.A4488-A.
63 Wildstein KA, Faustini Y, Yip R, . Longitudinal predictors of adherence to annual follow-up in a lung cancer screening programme. J Med Screen. 2011;18(3):154–9. doi: 10.1258/jms.2011.010127. PMID: 22045825.22045825
64 Spalluto L, Lewis J, Sandler K, . P3.11-23 Adherence to Annual Low-Dose CT Lung Cancer Screening at a Large Academic Institution. Journal of Thoracic Oncology. 2018;13(10):S967–S8. doi: 10.1016/j.jtho.2018.08.1819.
65 Pinsky PF. Assessing the benefits and harms of low-dose computed tomography screening for lung cancer. Lung cancer management. 2014;3(6):491–8. doi: 10.2217/LMT.14.41. PMID: 26617677.26617677
66 Han SS, Chow E, ten Haaf K, . Disparities of national lung cancer screening guidelines in the U.S. population. JNCI: Journal of the National Cancer Institute. 2020doi: 10.1093/jnci/djaa013.
67 Meza R, Meernik C, Jeon J, . Lung cancer incidence trends by gender, race and histology in the United States, 1973–2010. PLoS One. 2015;10(3):e0121323. doi: 10.1371/journal.pone.0121323. PMID: 25822850.25822850
68 Crosbie PA, Balata H, Evison M, . Implementing lung cancer screening: baseline results from a community-based ‘Lung Health Check’ pilot in deprived areas of Manchester. Thorax. 2019 Apr;74(4):405–9. doi: 10.1136/thoraxjnl-2017-211377. PMID: 29440588.29440588
69 Field JK, Duffy SW, Baldwin DR, . UK Lung Cancer RCT Pilot Screening Trial: baseline findings from the screening arm provide evidence for the potential implementation of lung cancer screening. Thorax. 2016;71(2):161–70. doi: 10.1136/thoraxjnl-2015-207140. PMID: 26645413.26645413
70 Tammemagi MC. Selecting lung cancer screenees using risk prediction models-where do we go from here. Transl Lung Cancer Res. 2018 Jun;7(3):243–53. doi: 10.21037/tlcr.2018.06.03. PMID: 30050763.30050763
71 Tammemagi MC, Schmidt H, Martel S, . Participant selection for lung cancer screening by risk modelling (the Pan-Canadian Early Detection of Lung Cancer [PanCan] study): a single-arm, prospective study. Lancet Oncol. 2017 Nov;18(11):1523–31. doi: 10.1016/s1470-2045(17)30597-1. PMID: 29055736.29055736
72 Lau YK, Caverly TJ, Cao P, . Evaluation of a Personalized, Web-Based Decision Aid for Lung Cancer Screening. Am J Prev Med. 2015 Dec;49(6):e125–9. doi: 10.1016/j.amepre.2015.07.027. PMID: 26456873.26456873
73 Joseph AM, Rothman AJ, Almirall D, . Lung Cancer Screening and Smoking Cessation Clinical Trials. SCALE (Smoking Cessation within the Context of Lung Cancer Screening) Collaboration. Am J Respir Crit Care Med. 2018 Jan 15;197(2):172–82. doi: 10.1164/rccm.201705-0909CI. PMID: 28977754.28977754
74 Taylor KL, Deros DE, Fallon S, . Study protocol for a telephone-based smoking cessation randomized controlled trial in the lung cancer screening setting: The lung screening, tobacco, and health trial. Contemp Clin Trials. 2019 May 23;82:25–35. doi: 10.1016/j.cct.2019.05.006. PMID: 31129371.31129371
75 Taylor KL, Hagerman CJ, Luta G, . Preliminary evaluation of a telephone-based smoking cessation intervention in the lung cancer screening setting: A randomized clinical trial. Lung Cancer. 2017 Jun;108:242–6. doi: 10.1016/j.lungcan.2017.01.020. PMID: 28216065.28216065
76 Minnix JA, Karam-Hage M, Blalock JA, . The importance of incorporating smoking cessation into lung cancer screening. Transl Lung Cancer Res. 2018 Jun;7(3):272–80. doi: 10.21037/tlcr.2018.05.03. PMID: 30050765.30050765
77 Kathuria H, Detterbeck FC, Fathi JT, . Stakeholder Research Priorities for Smoking Cessation Interventions within Lung Cancer Screening Programs. An Official American Thoracic Society Research Statement. Am J Respir Crit Care Med. 2017 Nov 1;196(9):1202–12. doi: 10.1164/rccm.201709-1858ST. PMID: 29090963.29090963
78 Cadham CJ, Jayasekera JC, Advani SM, . Smoking cessation interventions for potential use in the lung cancer screening setting: A systematic review and meta-analysis. Lung Cancer. 2019 Sep;135:205–16. doi: 10.1016/j.lungcan.2019.06.024. PMID: 31446996.31446996
79 Cao P, Jeon J, Levy DT, . Potential Impact of Cessation Interventions at the Point of Lung Cancer Screening on Lung Cancer and Overall Mortality in the United States. J Thorac Oncol. 2020;.doi: 10.1016/j.jtho.2020.02.008. PMID: 32160967.32160967
80 Meza R, Hazelton WD, Colditz GA, . Analysis of lung cancer incidence in the Nurses’ Health and the Health Professionals’ Follow-Up Studies using a multistage carcinogenesis model. Cancer Causes Control. 2008 Apr;19(3):317–28. doi: 10.1007/s10552-007-9094-5. PMID: 18058248.18058248
81 Holford TR, Levy DT, McKay LA, . Patterns of birth cohort-specific smoking histories, 1965–2009. Am J Prev Med. 2014 Feb;46(2):e31–7. doi: 10.1016/j.amepre.2013.10.022. PMID: 24439359.24439359