# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their support, commitment, and contributions: Howard Tracer, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; expert reviewers William C. Black, MD, Dartmouth-Hitchcock Medical Center, Gerard A. Silvestri, MD, MS, Medical University of South Carolina, and Ann Zauber, PhD, Memorial Sloan Kettering Cancer Center; National Cancer Institute Federal reviewers Paul Pinsky, PhD, Chief, Early Detection Research Branch, and Kathy Cronin, PhD, Deputy Associate Director, Surveillance Research Program; Sharon Barrell, MA, editor, Loraine Monroe, publications specialist; and Carol Woodell, RTI-UNC EPC Program Manager.