# Chapter 4 Discussion

This report summarizes a comparative modeling DA of the long-term benefits and harms of LDCT screening for lung cancer in the United States to inform the USPSTF lung cancer screening recommendations. The analysis extends the corresponding 2013 DA,^36,^ ^44^ which focused on the benefits and harms of screening strategies with eligibility criteria based on age, cumulative smoking exposure (pack-years), and time since quitting for former smokers by also considering strategies with eligibility based on individual lung cancer risk (probability of detection or dying from lung cancer within 6 years). Moreover, three of the CISNET lung cancer natural history models were updated to consider current practice and the management of screening results and pulmonary nodules using the Lung-RADS criteria, modeling the Lung-RADS protocols explicitly or indirectly via the associated rates of false-positive tests, and the expected changes in screening sensitivity relative to NLST (Table 1).^8^ The other model allows for comparison with and consideration of screening outcomes based on NLST protocols. In addition, this analysis considered the long-term impacts of lung cancer screening in two U.S. birth cohorts, 1950 and 1960, further extending the previous DA that focused only on the 1950 birth cohort.

The results are consistent with the previous comparative modeling DA for risk factor–based strategies evaluated on the 1950 birth cohort. In particular, the relative ranking of risk factor–based strategies and the characteristics of consensus-efficient scenarios are consistent with the previous DA. In addition, the projected benefits and harms of the 2013 USPSTF-recommended strategy for the 1950 birth cohort are similar, although with some slight variations due to the use of one fewer CISNET model here, the updates made to the screening simulation models to reflect current practice, and the changes to the CISNET SHG and the corresponding mortality rates to reflect more current patterns of smoking and overall and tobacco-related mortality.^2,^ ^43^ For example, in 2013, the DA projected that 19.3 percent of the 1950 birth cohort would be eligible according to the 2013 USPSTF-recommended strategy, resulting in 286,813 LDCT screens per 100,000, 521 lung cancer deaths averted per 100,000 (a 14.0% mortality reduction), 5,517 LYG per 100,000, an NNS of 37, 3.5 false-positive screens per screened individual, 190 overdiagnosed cases per 100,000 (9.9% overdiagnosis rate per screen-detected lung cancer), and 24 radiation-related lung cancer deaths per 100,000.^36^ In comparison, here we project that 20.8 percent of the 1950 birth cohort would be eligible, resulting in 333,300 LDCT screens per 100,000, 612 lung cancer deaths averted per 100,000 (a 12.2% mortality reduction), 7,956 LYG per 100,000, an NNS of 34, 1.9 false-positive screens per screened individual, 117 overdiagnosed cases per 100,000 (6.5% overdiagnosis rate per screen-detected lung cancer), and 28.9 radiation-related lung cancer deaths per 100,000 (Appendix C Tables 23 and 24). The higher absolute numbers of lung cancer deaths prevented and LYG per 100,000 population in the current DA are due to the CISNET SHG updates mentioned above, which resulted in slightly higher eligibility, lower competing mortality rates, and larger life expectancies for the simulated population. The lower percentage mortality reduction is largely due to the absence of the Fred Hutchinson Cancer Research Center CISNET model in the current DA, which had the highest percentage mortality reduction in the 2013 DA.^36^ The lower overdiagnosis rate is due also to the exclusion of the Fred Hutchinson Cancer Research Center model, which had the highest overdiagnosis rate in the 2013 DA, and due to the slightly longer life expectancies in the newer version of the SHG. Finally, the lower rate of false-positive screens is due to the model updates to reflect Lung-RADS.

The current DA suggests that, if adopted by those eligible, LDCT screening could lead to reductions of lung cancer mortality and result in significant LYG in the United States. Although still present, overdiagnosis and radiation-related lung cancer deaths would be relatively limited, irrespective of age. Although the number of false-positive screens per person screened would be lower than earlier projections because of improvements in clinical practice, these would still remain a concern because each person adhering to annual screening for multiple years would be expected to receive a false-positive result at some point. However, the population impacts of screening, and its level of benefits and potential harms, are modulated by the eligibility criteria, which can greatly affect the proportion of the population that would be eligible for screening and the underlying lung cancer risk of that eligible population. Although this analysis cannot identify a single optimal scenario, it identified a set of scenarios that were determined as efficient for a level of screening (number of LDCT screens) by at least three of the four simulation models used in this analysis, providing some guidance on general features of the consensus-efficient scenarios.

When focusing only on scenarios with eligibility based on age, pack-years and time since quitting smoking for former smokers (risk factor based), most consensus-efficient strategies had stopping screening age as 80 years and starting screening age as 50 or 55 years. Annual screening strategies performed better when using lung cancer deaths averted as the benefit metric, while biennial strategies improved in their ranking when using LYG as the benefit metric. Consistent with the 2013 DA, the 2013 USPSTF-recommended eligibility criteria, annual screening of individuals between the ages of 55 and 80 years with at least 30 pack-years of smoking history and no more than 15 years since quitting smoking (A-55-80-30-15), was among the consensus-efficient strategies when using lung cancer deaths averted as the benefit metric. However, it decreased in efficiency ranking when including or considering exclusively LYG as the metric.

Recent studies have suggested that expanding eligibility to include ever smokers with 20 to 29 pack-years of exposure would increase the proportion of lung cancers preventable by screening in the United States and also reduce disparities in eligibility by race/ethnicity and gender.^20,^ ^22,^ ^23,^ ^52–54^ In particular, using data from the 2010 National Health Interview Survey, Pinsky et al showed that reducing the minimum pack-years to 20 would increase the percentage of women and minorities who would be eligible for screening.^20^ They also used PLCO data to show that the risk of 20 to 29 pack-year current smokers is comparable to that of screening eligible former smokers based on the 2013 USPSTF-recommended criteria, providing an additional argument for considering expanding the eligibility criteria. Aldrich et al recently evaluated the percentage of lung cancers that would have been eligible for screening under the 2013 USPSTF-recommended strategy in a predominantly African American and low-income cohort.^52^ They found that proportionally, fewer African Americans with lung cancer would have been eligible for screening vs. whites with lung cancer. And that expanding the criteria to include 20 to 29 pack-year ever smokers would increase considerably the screening sensitivity for African Americans.^52^ This difference was attributed to the lower pack-year levels among African Americans with lung cancer vs. whites with lung cancer. The lower cumulative smoking exposure (pack-years) among African Americans vs. whites has also been observed in national data.^22^ In addition, the recently published NELSON trial, which found a 24 percent lung cancer mortality relative reduction at 10 years after four rounds of LDCT screening vs. a no-screening arm, included ever smokers of ages 50 to 74 years, with lower smoking exposure criteria than the NLST and current recommendations. This study provides additional empirical evidence supporting expanding eligibility criteria to include smokers with fewer pack-years than current screening guidelines and starting screening at age 50 years.^9^

Based on these studies and on our finding that a majority of selected consensus-efficient scenarios for the 1960 birth cohort had a minimum pack-year criterion of 20, we conducted a comparison of the eligibility and the benefits and harms of selected consensus-efficient 20 pack-year scenarios vs. those of the 2013 USPSTF-recommended criteria. In particular, we focused on risk factor–based strategies with 20 pack-years and at least 15 years since quitting smoking, annual frequency, starting age of 50 or 55 years, and stopping age of 80 years. Our analysis suggests that consistent with the literature reducing the minimum pack-year criteria would result in considerable increases in eligibility with a larger increase in women vs. men. In addition, we found that including 20 to 29 pack-year smokers would result in considerable increases in the benefits of screening, but also in more harms. Although we did not consider different racial or ethnic groups in the DA, comparisons of the percentage of individuals eligible for screening in the United States under the 2013 USPSTF-recommended strategy vs. the percentage for selected 20 pack-year strategies by sex and race/ethnicity (non-Hispanic whites, non-Hispanic blacks, Hispanics, Asians, and American Indian/Alaska Natives) are presented in Appendix C Tables 29 and 30. These numbers are based on the nationally representative 2015 National Health Interview Survey, updating those in Pinsky et al.^20^ The National Health Interview Survey data suggest that the relative increase in eligibility from reducing the pack-year criterion to 20 pack-years vs. that of the current criteria would be larger for women vs. men and for non-Hispanic blacks, Hispanics, and American Indian/Alaska Natives vs. non-Hispanic whites and Asians. For example, the percentage of eligible women would increase in the A-50-80-20-15 strategy vs. the 2013 USPSTF-recommended criteria from 2.8 percent to 5.5 percent (a 96% increase), whereas the percentage of eligible men would increase the from 4.2 percent to 7.6 percent (a 81% increase). The tables also show the distribution of 100,000 LDCT screens to the population according to the proportion of eligible ever smokers in each sex or in each racial/ethnic group. These tables suggest that the 20 pack-year strategies would distribute these LDCT screens in a more equitable manner across sex and racial/ethnic groups. In all, our findings suggest that expanding eligibility to include individuals with 20 to 29 pack-years results in considerably more benefits, but also in more harms.

Joint consideration of strategies with eligibility based on cumulative smoking exposure and time since quitting (risk factor–based strategies) and strategies with eligibility based on multivariate risk prediction models (risk model–based strategies) provided insights into the potential of more detailed risk model–based screening. In general, although restricted here to only age, smoking history, and sex covariates and thus ignoring other relevant lung cancer risk factors, risk model–based screening strategies based on multivariate models tended to result in higher numbers of lung cancer deaths averted than risk factor–based strategies for programs with a similar number of total LDCT screens. This result was also the case for LYG, although risk model–based and risk factor–based strategies were closer for this metric. This finding is consistent with other recent studies in the literature.^28,^ ^30^ The DA compared the performance of risk model–based programs relying on three different lung cancer risk prediction models: MPLCOm2012, MLCDRAT, and Bach. The analysis suggests that although the specific risk model used might be an important consideration, an even more critical aspect is to determine eligibility risk thresholds specific to the corresponding risk model.

A comparison of risk factor–based criteria with comparable risk model–based screening scenarios with the same age criteria and frequency shows that risk model–based screening strategies tend to shift the ages of screening to older ages when lung cancer risk is highest. This explains their superior performance in reducing lung cancer deaths but the more similar performance with risk factor–based strategies when considering LYG. This finding is consistent with previous analyses in ten Haaf et al.^30^ In rough terms, risk factor–based (age/pack-year/time since quitting) criteria in general tend to screen people at younger ages when lung cancer risk is lower but when there are more potential life-years to be gained if a lung cancer death is prevented. In contrast, risk model–based screening strategies tend to screen older individuals when lung cancer risk is highest, preventing more lung cancer deaths but resulting in fewer LYG per lung cancer death averted. By screening older individuals, risk model–based screening strategies also result in higher numbers of overdiagnosed cases. In contrast, they result in fewer radiation-related lung cancer deaths because their numbers of LDCT screens per screened individual are lower and thus result in fewer and later-in-life radiation exposures. The life-expectancy sensitivity analysis suggests that restricting screening to only those with reasonable life expectancy and minimal comorbid conditions (i.e., to only those eligible for curative treatment) could reduce the harms and overdiagnosis rates while keeping most of the benefits from screening,^34,^ ^35^ consistently also with the previous analyses by ten Haaf et al.^30^

Our findings must be put in context relative to the NLST and other lung cancer screening trials. Here we extrapolated trial results to the general U.S. population rather than focusing only on eligible individuals, and we simulated the impact of multiple rounds of screening with an almost lifetime followup (up to age 90 years or death), rather than considering a fixed number of screens with a short-term followup as is usually done in LDCT trials (e.g., three screens as in NLST with 6 or 7 years of followup). Moreover, for each screening scenario we are estimating impact per 100,000 individuals in the overall population rather than restricting the analysis to only those eligible for screening because the proportion and risk distribution of the population eligible vary greatly across the strategies evaluated. Thus, restricting the analysis to only screen-eligible individuals would lead to noncomparable results between strategies. As such, the predicted mortality reductions per 100,000 population for all scenarios, including the 2013 USPSTF-recommended strategy, are lower than the observed mortality reduction in the NLST,^4–6^ which was restricted to only those meeting the trial eligibility criteria. As discussed above, this is consistent with the results of the 2013 lung screening DA.^36,^ ^41,^ ^44^ The estimated NNS to prevent a lung cancer death ranged from 29 to 64 among consensus-efficient risk factor–based strategies (NNS of 37 for the 2013 USPSTF-recommended strategy in the 1960 birth cohort), which is much more favorable than published estimates for only three screens, which range on average between 280 and 320,^4,^ ^55^ although with variations by risk^34^ but consistent also with the 2013 DA estimates^36,^ ^41,^ ^44^ and closer to estimates for other cancer screening programs extrapolated to the U.S. population, such as colon cancer or breast cancer screening.^56,^ ^57^ The lower NNS vs. direct-trial estimates are due to the consideration of multiple rounds of annual or biennial screening and not just three screens. The rate of overdiagnosis per screen-detected lung cancer ranged from 4.5 to 6.3 percent. This rate is lower than estimates based on the NLST with 6 to 7 years of followup^58^ but consistent with more recent estimates with extended followup^6^ and with estimates accounting for lifetime followup^36,^ ^41,^ ^44,^ ^58^ like the 2013 DA.

## Strengths and Limitations of Modeling

The DA used four established lung cancer natural history models that aim to capture the complexity in smoking patterns and lung cancer risk and integrate and synthetize information from lung cancer screening randomized trials, large epidemiological prospective studies, and cancer surveillance data. The models and the CISNET SHG have been shown to reproduce the patterns of smoking and lung cancer incidence and mortality in the United States^2,^ ^36,^ ^41–43^ and thus provide a framework to extrapolate the effects of screening into the entire U.S. population. By following a comparative modeling approach, the collaborative modeling DA was able to assess the impact of varying model structures and assumptions on the results. Although the absolute numbers of projected lung cancer deaths averted and LYG, as well as the resulting harms, such as false-positive LDCT screens and overdiagnosed cases, vary across models, the conclusions about the relative performance of different screening strategies are generally consistent across models. The models differ in structure (e.g., smoking dose-response model or histology groups modeled) in the way they incorporate screening effects and efficacy, in how they account for followup, and in their projections for future lung cancer incidence and mortality (Appendix A).^30,^ ^59,^ ^60^ This results in differences in the absolute number of projected lung cancer deaths prevented and life-years gained and other outcomes between CISNET models. However, the relative performance of different scenarios according to their characteristics (starting and stopping age, minimum pack-years, maximum years since quit, risk threshold) was consistent across the models. This finding cross-validates the results and provides confidence in the conclusions. Moreover, independent DEAs by CISNET model allowed for identification of strategies that were efficient according to at least three of the four CISNET models, independently of the differences in absolute numbers between models. However, like any other modeling study, our analysis is subject to some limitations.

First, our DA assumed an idealized 100 percent screening uptake (i.e., all people eligible for screening would be identified and would choose to undergo screening after a discussion about potential benefits and harms) and 100 percent screening adherence (i.e., all recommended LDCTs would be completed) for eligible individuals. Thus, projections of the benefits and harms of screening should be interpreted as an upper bound of what the actual impact could be. Varying the uptake and adherence levels assuming a random (uniform) uptake and adherence in the population would not change the relative performance of the screening scenarios and thus our main conclusions, only the overall level of estimated benefits and harms.^61^ Nonetheless it is likely that lung cancer screening uptake and adherence may vary by age, sex, race/ethnicity, socioeconomic status, smoking status, and insurance coverage.^17,^ ^62–64^ This variability could affect the relative performance of strategies that favor screening at older vs. younger ages. In addition, uptake and adherence might be likely to vary by screening frequency; for example, if uptake and adherence are greater for biennial than for annual screening strategies, then the relative performance of biennial strategies would be better than our estimates indicate. Given that lung screening implementation is still at an early stage, there is a lack of data on how uptake and adherence might vary by these and other factors. We thus restricted the analysis to a uniform 100 percent uptake and adherence. However, the potential impact of adherence heterogeneity on the relative performance of alternative strategies should be revisited in future analyses as more data on screening rates emerge, taking into account the specific meaning of uptake and adherence in this context given the shared decision-making requirements for lung screening. Relatedly, recent studies have suggested that adopting lung cancer screening has been less than optimal; only a small percentage of those eligible actually get screened.^12–17^ Moreover, it has been reported that some people who do not meet the criteria are getting screened.^13^ These two issues could greatly affect the actual net benefits and harms of screening at the population level. Furthermore, our analysis did not explicitly examine incidental findings, which could affect the overall benefits and harms of screening^3,^ ^65^ nor other potential harms, such as adverse events other than overdiagnosed cases, false-positive results, and radiation-related lung cancer deaths. In addition, our models were calibrated to lung screening trial outcomes; however, the effectiveness of lung cancer screening may be variable and lower in the general population than in trials because of lower accuracy of LDCT scan interpretation, nodule management protocol adherence, or higher surgical mortality. On the other hand, the models were updated to reflect improvements in nodule followup guidelines since the NLST trial was completed, which should result in lower false-positive rates and fewer followup scans than those in NLST.

Second, the DA focused only on age, smoking history, and sex, ignoring other important lung cancer risk factors, such as race/ethnicity, history of COPD, exposure to occupational and environmental carcinogens, and family history of lung cancer. Including such covariates would require joint simulation of all of these at the U.S. population level, accounting for their correlation and time trends. While the CISNET group has extended the SHG to consider other covariates,^66^ including all of these covariates in the DA would require validated lung cancer natural history models incorporating these risk factors. That being said, although restricted to smoking covariates, sex, and age, the DA can shed some light on the differences between risk factor–based and risk model–based screening strategies. Comparisons of representative risk factor–based strategies with risk model–based strategies with the same age range and screening frequency show that a larger proportion of individuals would be eligible by risk model–based criteria, but not by risk factor–based criteria. This difference would likely increase even further if considering other covariates. For instance, African Americans are known to smoke fewer cigarettes per day than other racial groups and thus have lower pack-years on average. Nonetheless, they have a higher risk of lung cancer on average (~1.4 relative risk vs. the risk for whites).^20–22,^ ^27^ Hence, proportionally, more African Americans with considerable lung cancer risk would be excluded by risk factor–based strategies but not by risk model–based strategies.^66^ Thus, risk model–based screening strategies based on risk prediction models accounting for race/ethnicity and other sociodemographic factors could mitigate an increase in existing lung cancer disparities,^67^ assuming that the benefits of screening and early treatment are consistent across race/ethnicity and sociodemographic factors.

Third, our analysis did not consider potential implementation challenges of risk model–based screening nor whether those could vary by setting or among different demographic groups. Several ongoing implementation studies and trials are evaluating the feasibility and potential of risk model–based screening in clinical settings, so far with promising results.^8,^ ^65,^ ^68–71^ Moreover, several online calculators,^34,^ ^46,^ ^47,^ ^57,^ ^58^ some embedded within screening shared decision-making tools,^34,^ ^72^ are available to facilitate the implementation of risk model–based eligibility using the risk prediction models evaluated. Our simulations assumed that the process of assessing an individual’s lung cancer risk annually (or every other year for biennial strategies) using risk prediction models is equivalent and as effective as calculating risk factor exposures, but further studies are needed to determine if this is the case in clinical practice.

Fourth, our projections do not account for future improvements in lung cancer treatment and further changes in smoking trends. Recent developments in lung cancer targeted therapies and immunotherapies could affect future lung cancer death rates. These improvements could act synergistically with screening as the stage distribution of lung cancers shifts to earlier stages. The CISNET SHG projects future rates of smoking under a status quo scenario, which carries smoking initiation and cessation trends by birth cohort into the future and implicitly assumes that tobacco control practices will remain as they are today. Changes in tobacco control or shifts in tobacco use patterns due to the advent of e-cigarettes and other tobacco products could affect future smoking patterns and result in higher or lower smoking rates for the 1950 and 1960 birth cohorts. These changes could affect the screening eligibility rates and thus the population impact of screening. Furthermore, the DA did not consider the potential additional benefits of complementary smoking cessation programs within the context of lung screening.^68,^ ^73–79^

Finally, the DA focused on two U.S. birth cohorts rather than on the whole population. Given the complex relationship between smoking and lung cancer^45,^ ^46,^ ^80^ and the rapidly changing smoking patterns by birth cohort in the United States,^2,^ ^81^ which, as mentioned above, could greatly affect eligibility and thus the impact of screening, restricting the analyses to single cohorts reduced its complexity and dimensionality and facilitated the comparison between scenarios and the interpretation of the results. Moreover, although these two birth cohorts are separated by only 10 years, they are representative of different moments of the tobacco epidemic and provide a snapshot of how smoking rates and screening eligibility are projected to change in the near future. Our analyses show that despite their differences, the main conclusions regarding the most effective risk factor–based programs (most consensus-efficient strategies are annual, have starting age of 50 or 55 years and stopping ages of 80 years) do not vary by birth cohort.

## Summary

In summary, the CISNET Lung Cancer Working Group collaborative modeling analysis identified a set of LDCT screening programs that are efficient for a given level of screening in reducing lung cancer mortality and providing important gains in life-years at the population level. Most consensus-efficient strategies have screening starting at ages 50 or 55 and stopping at the age of 80 years. Among risk factor–based strategies, starting at age 50 or 55 years results in better performance (higher number of lung cancer deaths averted and LYG for a given number of LDCT screens per 100,000 population) than age 45 years. The 2013 USPSTF-recommended criteria are not among the consensus-efficient strategies for the 1960 birth cohort. However annual risk factor–based strategies with a smoking history of at least 20 pack-years, starting ages of 50 or 55 years, and a stopping age of 80 years are consensus efficient and result in considerably more lung cancer deaths prevented and LYG than the 2013 USPSTF-recommended strategy with limited additional harms. Among risk model–based screening strategies, the net benefits and harms of screening strongly depend on the risk model’s specific risk thresholds. Overall, risk model–based screening strategies result in higher numbers of lung cancer deaths prevented, modest increases in LYG and lower radiation-related lung cancer deaths than risk factor–based strategies; however, they result in higher numbers of overdiagnosed cases. But the analyses did not consider issues of implementation and other potential challenges of risk model–based strategies. Nor did they consider issues of uptake and adherence of the various modeled lung cancer screening strategies.