# Chapter 3 Results

We focus here on the results for the 1960 birth cohort because it will reach age 60 in 2020 and is more representative of current patterns of smoking and future lung cancer risk across the lung cancer screening-eligible population than the 1950 birth cohort. Results for the 1950 birth cohort are presented in the Appendices B and C and the Sensitivity Analysis section. Unless otherwise indicated, results presented here are for men and women combined. Sex-specific results are presented in the Appendices B and C.

## Benefits and Harms

### Efficient Frontiers for Risk Factor–Based Strategies

Figure 1 shows the number of LDCT screens and lung cancer deaths averted relative to no screening for each of the risk factor–based strategies and the 1960 birth cohort. Each panel corresponds to one of the four CISNET models, and the points in each panel represent different screening scenarios. Strategies are colored by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). The solid line represents the efficient frontier for the corresponding model. In general, scenarios on the frontier have a screening stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. Although the absolute range of predicted lung cancer deaths averted varies by CISNET model, the general patterns are consistent across models. Model 1, which predicts the largest lung cancer deaths prevented, is the model that uses false-positive tests, sensitivities, and screening result rates based fully on the NLST, allowing for comparison of alternative protocols and assumptions. Model 2, which predicts the lowest lung cancer deaths averted, uses a different smoking dose-response module (Table 1) and projects lower future lung cancer incidence and mortality than the other three models^51^ and thus fewer lung cancer deaths that could be averted. The results for the 2013 USPSTF-recommended strategy are indicated with an ⊗. This scenario is on or among the closest to the frontier for three out of the four models.

Figure 2 shows the corresponding efficient frontier curves using LYG as the benefit metric and the 1960 birth cohort. The patterns are similar but show less variability among strategies than for lung cancer deaths averted. Although the absolute range of predicted LYG varies by CISNET model, the general patterns are consistent across models. Like with lung cancer deaths prevented, Model 1 predicts the largest LYG, while Model 2 predicts the lowest. In this case, the 2013 USPSTF-recommended strategy is only on (or among the closest to) the efficient frontier for one of the four models.

Appendix B Figures 1 through 4 show the corresponding efficient frontiers for men and women separately, and Appendix B Figures 5 and 6 show the corresponding efficiency frontiers for the 1950 birth cohort (men and women combined). These figures demonstrate that the general patterns observed for the 1960 birth cohort for men and women combined hold for each sex and for the 1950 birth cohort. Appendix B Figures 7 through 12 show the efficient frontiers for the 1960 birth cohort, highlighting screening scenarios by starting age, pack-years, and years since quitting.

### Efficient Frontiers for Risk Factor–Based and Risk Model–Based Strategies

Figure 3 shows the simulated number of LDCT screens and the lung cancer deaths averted for all risk factor–based and risk model–based screening strategies. Strategies are colored by periodicity (annual, biennial) and type of eligibility criteria (risk factor based, risk model based). In general, risk model–based strategies tend to result in larger numbers (than risk factor–based strategies) of lung cancer deaths averted for a given number of LDCT screens (across the whole range of LDCT screens). Thus, most of the scenarios in each efficient frontier are risk model–based screening strategies. Among the scenarios considered, risk model–based screening strategies result in a wider range of LDCT screens than the risk factor–based strategies. The 2013 USPSTF-recommended strategy, marked with an ⊗, is strictly dominated by risk model–based strategies (i.e., it prevented fewer lung cancer deaths than risk model–based strategies requiring a similar number of LDCT screens) according to all the models.

Figure 4 shows the corresponding efficient frontier plots but for LYG. As when considering only risk factor–based strategies, we see less variability when using LYG as a benefit metric than when using lung cancer deaths averted. However, in this case, some of the risk factor–based strategies, particularly biennial with fewer LDCT screens, do jump to (or get close to) the frontier for some of the models. Here, the 2013 USPSTF-recommended strategy, marked with an ⊗, is strictly dominated by risk model–based strategies according to three out of the four models.

Appendix B Figures 13 through 16 show the corresponding efficient frontiers for men and women separately and demonstrate that the general patterns observed for men and women combined hold for each specific sex. Appendix B Figures 17 and 18 show the efficient frontiers for the 1960 birth cohort highlighting the eligibility risk prediction model for each scenario.

## Consensus-Efficient Scenarios

### Risk Factor–Based Consensus-Efficient Scenarios

We identified 57 consensus-efficient scenarios using the DEA for the 1960 birth cohort with both outcome metrics: lung cancer deaths averted and LYG. Of these, 80.7 percent have screening stopping age of 80 years, with 61.4 percent being biennial and 38.6 percent annual strategies. The large majority of these have starting age 50 years (45.6%) or 55 years (49.1%). With regard to minimum pack-years, 26.3 percent have 20 pack-years, 26.3 percent have 25 pack-years, 12.3 percent have 30 pack-years, and 35.1 percent have 40 pack-years. The average number of minimum pack-years across consensus-efficient scenarios is 29.6, and the average maximum years since quitting is 18.9 years, both close to the 2013 USPSTF-recommended strategy. The 2013 USPSTF-recommended scenario is not one of the 57 consensus-efficient scenarios. The average number (across models) of LDCT screens per 100,000 population among the consensus scenarios ranges from 64,607 to 594,973, with the percentage of the population ever screened ranging from 9.0 to 24.1 percent. The number of lung cancer deaths averted per 100,000 population ranges from 173 to 578, corresponding to a population-level lung cancer mortality reduction ranging from 4.5 to 14.9 percent. The LYG ranges from 2,405 to 8,186 per 100,000, and the NNS (persons ever screened per lung cancer death averted) ranges from 29 to 64. Figure 5 shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for all risk factor–based strategies, highlighting the consensus-efficient scenarios (solid color). Each panel shows the corresponding average model efficient frontier. Most of the consensus-efficient scenarios are on the frontier or among the closest to the frontier for both benefit metrics. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of the frontier, whereas annual consensus-efficient scenarios are located on the upper right side of the frontier. The no-screening (black dot), the 2013 USPSTF-recommended (“⊗” mark), and six selected consensus-efficient 20 pack-year annual strategies (see 20 Pack-Year Scenarios section below) are highlighted.

In terms of harms, the average number of false-positive results per screened individual ranges from 1.1 to 2.8, the number of biopsies from 241 to 922 per 100,000, and the average number of LDCT examinations per screened individual from 7.2 to 24.9. The number of overdiagnosed cancers ranges from 27 to 95 per 100,000 population, and the rate of overdiagnosis per screen-detected lung cancer varies from 4.5 to 6.3 percent. Finally, the number of radiation-related lung cancer deaths ranges from 6.8 to 55.0, increasing as a function of the number of screens and the percentage of persons screened. Figure 6 shows the distribution of the overdiagnosis rate for all risk factor–based strategies considered by the model, gender, and stopping age, indicating that across models the proportion of overdiagnosed cases among screen-detected lung cancers increases with stopping age.

Figure 6 Overdiagnosis Rate per Screen-Detected Lung Cancer Cases by Age at Stopping Screening and Sex for Each of the Four CISNET Models—1960 Birth Cohort

Note: Violin plots represent the distribution of the overdiagnosis rate across all the risk factor–based strategies evaluated. The boxplot inside each “violin” shows the overdiagnosis rate median, interquartile range, and 1.5 times the interquartile range across scenarios. The violin body shows the full probability density (reproduced on each side of the boxplot). For all models, the overdiagnosis rate increases as a function of age at stopping.

Abbreviation: CISNET=Cancer Intervention and Surveillance Modeling Network.

Overdiagnosis Rate per Screen-Detected Lung Cancer Cases by Age at Stopping Screening and Sex for Each of the Four CISNET Models—1960 Birth Cohort. Figure 6 shows the range across scenarios of overdiagnosis rates per screen-detected lung cancer cases for each of the four CISNET models. These are shown for three stopping ages (75, 77 and 80) and for males and females separately. Across all models and sex, the range of overdiagnosis rates increases with stopping age. For three of the four models (Models 1, 3, and 4), the overdiagnosis rates for all scenarios are below 10 percent, and for two models, Models 3 and 4, almost all below 5 percent. Model 2 has higher estimates that range from 7 to 15 percent for males and 5 to 12 percent for females.

Table 6 shows the benefits of the consensus-efficient scenarios plus the 2013 USPSTF-recommended scenario restricted to those leading to at least a 9 percent lung cancer mortality reduction (a total of 26 scenarios). We concentrate on these because they provide a lung cancer mortality reduction close to or greater than that of the 2013 USPSTF-recommended strategy (9.8%). Figure 5 shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for these selected consensus-efficient scenarios plus the 2013 USPSTF-recommended strategy. Of these, five are biennial and 21 annual; all have 80 years as the stopping age and range from 14.1 to 24.1 percent eligible individuals. In terms of minimum pack-years, 13 (50.0%) have 20 pack-years, 9 (34.6%) have 25 pack-years, 4 (15.4%) have 30 pack-years, and none has 40 pack-years. The corresponding lung cancer mortality reductions range from 9.0 to 14.9 percent and the LYG from 4,490 to 8,186. Six selected consensus-efficient 20 pack-year annual strategies are highlighted in Figure 5 (see 20 Pack-Year Scenarios section below). Appendix C Table 1 shows the range of benefits estimates across the four CISNET models.

Table 6 Benefits of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC Deaths Averted | NNS
B-55-80-20-20 | 22.0 | 189,587 | 1,134 | 9.0 | 348 | 4,490 | 12.9 | 42 | 545 | 63
B-55-80-20-25 | 22.7 | 207,010 | 1,189 | 9.5 | 366 | 4,701 | 12.8 | 44 | 566 | 62
B-50-80-25-25 | 19.0 | 208,753 | 1,169 | 9.4 | 363 | 4,859 | 13.4 | 43 | 575 | 52
A-55-80-30-15 | 14.1 | 227,443 | 1,102 | 9.8 | 381 | 4,882 | 12.8 | 47 | 597 | 37
A-55-80-25-10 | 16.0 | 234,030 | 1,131 | 10.1 | 392 | 4,969 | 12.7 | 47 | 597 | 41
B-50-80-20-20 | 23.3 | 239,223 | 1,226 | 9.9 | 384 | 5,194 | 13.5 | 46 | 623 | 61
A-55-80-30-20 | 14.5 | 250,592 | 1,169 | 10.5 | 406 | 5,170 | 12.7 | 48 | 617 | 36
B-50-80-20-25 | 23.6 | 258,024 | 1,288 | 10.4 | 404 | 5,436 | 13.5 | 47 | 639 | 58
A-55-80-25-15 | 17.2 | 267,471 | 1,219 | 11.0 | 425 | 5,387 | 12.7 | 50 | 629 | 40
A-55-80-30-25 | 14.8 | 269,096 | 1,218 | 10.9 | 422 | 5,333 | 12.6 | 50 | 638 | 35
A-55-80-25-20 | 18.0 | 298,016 | 1,295 | 11.6 | 450 | 5,690 | 12.6 | 52 | 662 | 40
A-55-80-25-25 | 18.3 | 324,008 | 1,354 | 12.2 | 471 | 5,930 | 12.6 | 55 | 688 | 39
A-55-80-20-15 | 20.6 | 330,095 | 1,334 | 12.1 | 469 | 6,018 | 12.8 | 55 | 704 | 44
A-50-80-30-25 | 15.3 | 334,396 | 1,273 | 11.5 | 447 | 6,066 | 13.6 | 55 | 748 | 34
A-50-80-25-15 | 18.5 | 344,294 | 1,282 | 11.7 | 454 | 6,187 | 13.6 | 56 | 758 | 41
A-55-80-20-20 | 22.0 | 369,610 | 1,423 | 12.9 | 500 | 6,379 | 12.8 | 58 | 739 | 44
A-50-80-20-10 | 21.2 | 369,742 | 1,295 | 12.0 | 464 | 6,435 | 13.9 | 57 | 797 | 46
A-50-80-25-20 | 18.9 | 377,405 | 1,357 | 12.5 | 482 | 6,542 | 13.6 | 58 | 783 | 39
A-50-80-25-25 | 19.0 | 404,469 | 1,417 | 13.0 | 502 | 6,764 | 13.5 | 60 | 806 | 38
A-55-80-20-25 | 22.7 | 404,596 | 1,492 | 13.5 | 523 | 6,654 | 12.7 | 61 | 774 | 43
A-50-80-20-15 | 22.6 | 419,030 | 1,401 | 13.0 | 503 | 6,918 | 13.8 | 61 | 833 | 45
A-50-80-20-20 | 23.3 | 463,457 | 1,487 | 13.8 | 534 | 7,301 | 13.7 | 63 | 868 | 44
A-45-80-25-25 | 19.4 | 482,601 | 1,448 | 13.5 | 521 | 7,336 | 14.1 | 66 | 926 | 37
A-50-80-20-25 | 23.6 | 500,430 | 1,560 | 14.4 | 558 | 7,596 | 13.6 | 66 | 897 | 42
A-45-80-20-20 | 24.0 | 557,453 | 1,523 | 14.4 | 555 | 7,919 | 14.3 | 70 | 1,004 | 43
A-45-80-20-25 | 24.1 | 594,973 | 1,592 | 14.9 | 578 | 8,186 | 14.2 | 73 | 1,029 | 42

* Strategies with at least 9.0 percent lung cancer mortality reduction.

Numbers are per a 100,000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and six selected consensus-efficient 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Table 7 shows the corresponding harms for the 25 selected consensus-efficient scenarios plus the 2013 USPSTF-recommended scenario. In this case, the average number of false-positive results per screened individual ranges from 1.2 to 2.8, the number of biopsies from 518 to 922 per 100,000 population, the average number of LDCT examinations per screened individual from 8.6 to 24.9, and the overdiagnosis rate per screen-detected lung cancer from 5.6 to 6.3 percent. The number of radiation-related lung cancer deaths ranges from 17.5 to 55.0 per 100,000 population. Appendix C Table 2 shows the range of harm estimates across the four CISNET models.

Table 7 Harms of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-55-80-20-20 | 189,587 | 209,334 | 8.6 | 1.2 | 526 | 64 | 1.3 | 5.6 | 17.5
B-55-80-20-25 | 207,010 | 227,740 | 9.1 | 1.3 | 557 | 67 | 1.4 | 5.6 | 18.2
B-50-80-25-25 | 208,753 | 228,965 | 11.0 | 1.5 | 546 | 68 | 1.4 | 5.8 | 19.3
A-55-80-30-15 | 227,443 | 247,644 | 16.1 | 1.9 | 518 | 69 | 1.4 | 6.3 | 20.6
A-55-80-25-10 | 234,030 | 254,870 | 14.6 | 1.8 | 536 | 71 | 1.4 | 6.3 | 21.5
B-50-80-20-20 | 239,223 | 261,627 | 10.3 | 1.4 | 593 | 70 | 1.4 | 5.7 | 22.8
A-55-80-30-20 | 250,592 | 272,008 | 17.3 | 2.0 | 554 | 73 | 1.5 | 6.2 | 21.5
B-50-80-20-25 | 258,024 | 281,421 | 10.9 | 1.5 | 626 | 74 | 1.5 | 5.7 | 23.6
A-55-80-25-15 | 267,471 | 290,163 | 15.6 | 1.9 | 586 | 77 | 1.5 | 6.3 | 23.4
A-55-80-30-25 | 269,096 | 291,461 | 18.2 | 2.1 | 580 | 76 | 1.5 | 6.2 | 22.1
A-55-80-25-20 | 298,016 | 322,330 | 16.6 | 2.0 | 630 | 82 | 1.6 | 6.3 | 24.7
A-55-80-25-25 | 324,008 | 349,657 | 17.7 | 2.1 | 664 | 84 | 1.7 | 6.2 | 25.6
A-55-80-20-15 | 330,095 | 356,390 | 16.0 | 1.9 | 667 | 83 | 1.7 | 6.2 | 29.0
A-50-80-30-25 | 334,396 | 359,972 | 21.9 | 2.5 | 639 | 76 | 1.5 | 6.0 | 29.9
A-50-80-25-15 | 344,294 | 370,892 | 18.6 | 2.2 | 658 | 77 | 1.6 | 6.0 | 32.1
A-55-80-20-20 | 369,610 | 398,094 | 16.8 | 2.0 | 722 | 89 | 1.8 | 6.3 | 30.6
A-50-80-20-10 | 369,742 | 397,994 | 17.4 | 2.1 | 684 | 77 | 1.5 | 5.9 | 36.5
A-50-80-25-20 | 377,405 | 405,682 | 20.0 | 2.3 | 701 | 82 | 1.6 | 6.0 | 33.5
A-50-80-25-25 | 404,469 | 434,104 | 21.3 | 2.5 | 735 | 85 | 1.7 | 6.0 | 34.9
A-55-80-20-25 | 404,596 | 434,892 | 17.8 | 2.1 | 765 | 94 | 1.9 | 6.3 | 31.9
A-50-80-20-15 | 419,030 | 449,947 | 18.5 | 2.2 | 750 | 84 | 1.7 | 6.0 | 38.6
A-50-80-20-20 | 463,457 | 496,698 | 19.9 | 2.3 | 804 | 89 | 1.8 | 6.0 | 40.6
A-45-80-25-25 | 482,601 | 515,967 | 24.9 | 2.8 | 797 | 86 | 1.7 | 5.9 | 45.8
A-50-80-20-25 | 500,430 | 535,519 | 21.2 | 2.5 | 849 | 94 | 1.9 | 6.0 | 42.5
A-45-80-20-20 | 557,453 | 595,203 | 23.2 | 2.7 | 879 | 91 | 1.8 | 6.0 | 53.1
A-45-80-20-25 | 594,973 | 634,568 | 24.7 | 2.8 | 922 | 95 | 1.9 | 6.0 | 55.0

* Strategies with at least 9.0 percent lung cancer mortality reduction.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100,000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected consensus-efficient 20-pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; USPSTF=U.S. Preventive Services Task Force.

Results for all the 57 consensus-efficient plus the 2013 USPSTF-recommended scenarios are shown in Appendix C (Appendix C Tables 3 and 4). Results stratified by sex for the selected consensus-efficient scenarios are also shown in Appendix C (Appendix C Tables 5 and 6 for men and Appendix C Tables 7 and 8 for women). Appendix B Figures 19 and 20 show efficient frontiers for men and women, highlighting the consensus-efficient scenarios when considering risk factor–based screening strategies only.

### 20 Pack-Year Scenarios

Among the consensus-efficient scenarios with at least a 9 percent lung cancer mortality reduction (selected consensus-efficient scenarios), a majority (52%) have 20 pack-years as a minimum criterion for eligibility. This is in contrast with the distribution of minimum pack-years of consensus-efficient scenarios for the 1950 birth cohort in which most selected consensus scenarios have either 25 pack-years (32%) or 30 pack-years (37%) (see Sensitivity Analysis section) and is due in part to the lower levels of smoking in the more recent 1960 birth cohort. Various observational and modeling studies have suggested that reducing the minimum pack-year criterion for lung cancer screening to 20 pack-years would increase the number of lung cancer deaths that would be preventable by screening and also reduce sex and racial disparities in eligibility.^20,^ ^22,^ ^52^ The recently published NELSON trial included ever smokers of ages 50 to 74 years, with a lower smoking exposure criterion than NLST (ever smokers with no more than 10 years since quitting who had smoked more than 15 cigarettes a day for more than 25 years or more than 10 cigarettes a day for more than 30 years), suggesting that expanding eligibility criteria to include smokers with fewer pack-years and starting screening at age 50 years could be beneficial.^9^ Motivated by this, we further analyzed risk factor–based strategies with 20 pack-years as the minimum pack-year criterion. In particular, we focused on consensus-efficient annual 20 pack-year strategies for the 1960 birth cohort with annual frequency and stopping age of 80 years as the 2013 USPSTF-recommended strategy (A-55-80-30-15), with starting ages of 50 or 55 years, and with at least 15 years since quitting smoking. There are six such strategies: A-55-80-20-15, A-55-80-20-20, A-55-80-20-25, A-50-80-20-15, A-50-80-20-20, and A-50-80-20-25 (Tables 6 and 7).

Table 8 shows a comparison of the 2013 USPSTF-recommended screening eligibility criteria with these selected 20 pack-year consensus-efficient strategies. Although these 20 pack-year strategies are consensus efficient under the two-outcome metric, the 2013 USPSTF-recommended strategy is not. The table shows that expanding current screening eligibility to include individuals with 20 to 29 pack-years of exposure would result in an increase in the percentage of the population ever screened from 14.1 percent to 20.6 to 23.6 percent. The average number (across models) of LDCT screens per 100,000 population for these 20 pack-year scenarios ranges from 330,095 to 500,430, in comparison with 227,443 for the 2013 USPSTF-recommended strategy. The average age at last screen ranges from 69.0 to 72.5 years compared with 71.3 years for the 2013 USPSTF-recommended strategy. The average age at first screen ranges from 51.5 years (for all strategies with starting age of 50 years) to 55.7 years, vs. 56.2 years for the 2013 USPSTF-recommended strategy.

Table 8 Comparison of 2013 USPSTF-Recommended (A-55-80-30-15) and Selected Risk Factor–Based Screening (20 Pack-Year Consensus-Efficient) Scenarios—1960 Birth Cohort

| A-55-80-30-15 | A-55-80-20-15 | A-55-80-20-20 | A-55-80-20-25 | A-50-80-20-15 | A-50-80-20-20 | A-50-80-20-25
% eligible | 14.1% | 20.6% | 22.0% | 22.7% | 22.6% | 23.3% | 23.6%
# LDCT screens^*^ | 227,443 | 330,095 | 369,610 | 404,596 | 419,030 | 463,457 | 500,430
Avg. # of LDCT screens per person screened | 16.1 | 16.0 | 16.8 | 17.8 | 18.5 | 19.9 | 21.2
Avg. age at first screen | 56.2 | 55.7 | 55.6 | 55.6 | 51.5 | 51.5 | 51.5
Avg. age at last screen | 71.3 | 70.7 | 71.4 | 72.5 | 69.0 | 70.3 | 71.6
Avg. age at screening | 65.1 | 65.1 | 65.3 | 65.5 | 59.0 | 59.4 | 59.9
LC deaths averted^*^ | 381 | 469 | 500 | 523 | 503 | 534 | 558
Mortality reduction | 9.8% | 12.1% | 12.9% | 13.5% | 13.0% | 13.8% | 14.4%
Difference in LC deaths averted vs. USPSTF strategy | NA | 23.1% | 31.2% | 37.3% | 32.0% | 40.2% | 46.5%
Avg. # screens per LC death averted | 597 | 704 | 739 | 774 | 833 | 868 | 897
LYG^*^ | 4,882 | 6,018 | 6,379 | 6,654 | 6,918 | 7,301 | 7,596
Difference in LYG vs. USPSTF strategy | NA | 23.3% | 30.7% | 36.3% | 41.7% | 49.5% | 55.6%
Avg. # screens per LYG | 47 | 55 | 58 | 61 | 61 | 63 | 66
NNS | 37 | 44 | 44 | 43 | 45 | 44 | 42
False-positive screens per person screened | 1.9 | 1.9 | 2.0 | 2.1 | 2.2 | 2.3 | 2.5
Biopsies | 518 | 667 | 722 | 765 | 750 | 804 | 849
Overdiagnosed cases^*^ | 69 | 83 | 89 | 94 | 84 | 89 | 94
Overdiagnosis rate per screen-detected cancers | 6.3% | 6.2% | 6.3% | 6.3% | 6.0% | 6.0% | 6.0%
Radiation-related lung cancer deaths^*^ | 20.6 | 29.0 | 30.6 | 31.9 | 38.6 | 40.6 | 42.5

* Per 100,000 individuals. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

In terms of benefits, these are higher for risk factor–based strategies with 20 pack-years vs. the 2013 USPSTF-recommended strategy. For instance, the number of lung cancer deaths averted per 100,000 population for the 20 pack-year strategies ranges from 469 to 558, corresponding to a population lung cancer mortality reduction ranging from 12.1 to 14.4 percent. In comparison, the 2013 USPSTF-recommended strategy results in 381 lung cancer deaths averted and a 9.8 percent mortality reduction. The LYG of the selected 20 pack-year strategies ranges from 6,018 to 7,596 per 100,000, and the NNS from 42 to 45. The 2013 USPSTF-recommended strategy would result in 4,882 LYG and has an NNS of 37.

In terms of harms, these are higher in general for the 20 pack-year strategies vs. the 2013 USPSTF-recommended strategy, particularly for strategies with higher maximum years since quitting criterion or younger starting age because these result in a higher average number of LDCT screens per screened individual. The average number of false-positive results per screened individual ranges from 1.9 to 2.5 for the selected 20 pack-year strategies vs. 1.9 for the 2013 USPSTF-recommended strategy. The number of biopsies ranges from 667 to 849 per 100,000 vs. 518 per 100,000 for the 2013 USPSTF-recommended strategy. The average number of LDCT examinations per screened individual ranges from 16.0 to 21.2 vs. 16.1 for the 2013 USPSTF-recommended strategy. The number of overdiagnosed cancers ranges from 83 to 94 per 100,000 population vs. 69 per 100,000 for the 2013 USPSTF-recommended strategy. The rate of overdiagnosis per screen-detected lung cancer ranges from 6.0 to 6.3 percent vs. 6.3 for the 2013 USPSTF-recommended strategy. Finally, the number of radiation-related lung cancer deaths for the selected 20 pack-year strategies ranges from 29.0 to 42.5 per 100,000 population vs. 20.6 per 100,000 population for the 2013 USPSTF-recommended strategy.

Appendix C Tables 9 and 10 show comparisons of the 20 pack-year consensus-efficient strategies with the 2013 USPSTF-recommended strategy by sex. These show similar patterns as for the whole population, but with higher increases in eligibility and lung cancer deaths prevented and LYG for women than men. For instance, women’s eligibility increases from 12.4 percent for the 2013 USPSTF-recommended strategy to 19.3 to 21.5 percent in the 20 pack-year strategies (a 56 to 73% increase), while men’s eligibility increases from 15.7 percent to 21.8 to 25.6 percent (a 39 to 63% increase). In terms of lung cancer deaths prevented, these increase in women from 362 per 100,000 for the USPSTF criteria to 463 to 551 per 100,000 for the 20 pack-year strategies (a 28 to 52% increase), while in men these increase from 400 to 475 to 565 per 100,000 (a 19 to 41% increase). In terms of LYG, these increase in women from 4,685 per 100,000 for the 2013 USPSTF-recommended strategy to 6,014 to 7,496 per 100,000 for the 20 pack-year strategies (a 28 to 60% increase), while in men these increase from 5,078 to 6,022 to 7,696 per 100,000 (a 19 to 52% increase). Similarly, the increase in harms is higher in women than in men. For instance, in women the number of overdiagnosed cancers increases from 64 to 80 to 91 per 100,000 population (a 25 to 42% increase), while in men it increases from 74 to 85 to 97 per 100,000 population (a 15 to 31% increase).

In summary, expanding eligibility to include individuals with 20 to 29 pack-years results in more benefits but also in more harms and higher increases in eligibility and lung cancer deaths prevented and LYG for women than men. We thus include the selected six 20 pack-year strategies as reference scenarios from this point forward and in Figure 5.

### Risk Factor–Based and Risk Model–Based Consensus-Efficient Scenarios

When considering all risk factor–based and risk model–based screening scenarios together, the DEA with both outcome metrics (lung cancer deaths averted and LYG) identified 267 consensus-efficient scenarios. Of these, 6.7 percent (n=18) are risk factor–based strategies, and 93.3 percent (n=249) are risk model–based strategies. Neither the 2013 USPSTF-recommended strategy nor the six selected 20 pack-year strategies are among the 267 consensus-efficient scenarios. All consensus-efficient risk factor–based strategies are biennial (n=18), all with less than 10 percent of the population eligible, whereas 48.2 percent of the risk model–based screening strategies are annual and 51.8 percent biennial. Among 267 scenarios, 59.5 and 40.5 percent have age 50 years and age 55 years as the starting age, respectively. Regarding stopping age, 74.2 percent consensus-efficient strategies stop at age 80 years, 16.9 percent at age 77 years, and only 9.0 percent at age 75 years. All 18 risk factor–based strategies have 40 minimum pack-years and, as mentioned above, are biennial. Among these strategies there are about an equal number of scenarios with 10 and 15 maximum years since quitting (about 33.3% each), but fewer with 20 and 25 maximum years since quitting (22.2% and 11.1%, respectively). Among the 249 risk model–based strategies, 43.8 percent are based on the MPLCOm2012 model, 16.1 percent on the MLCDRAT model, and 40.2 percent on the Bach model. Figure 7 shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for all risk factor–based and risk model–based screening scenarios, highlighting the 267 consensus-efficient scenarios (solid color) and the 2013 USPSTF-recommended scenario (A-55-80-30-15). Each panel shows the corresponding efficient frontier for the average model. Most of the consensus-efficient scenarios are on the frontier or among the closest to the frontier for both benefit metrics.

Figure 7 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based and Risk Model–Based Eligibility Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort

Note: Risk factor–based screening scenarios are represented with triangle points and risk model–based screening scenarios with round points. The curve represents the estimated overall efficient frontier for the average model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting smoking (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted. Panels show all considered strategies but highlight (solid color points) those identified as consensus efficient (listed in Appendix C Tables 11 and 12). The vertical line represents 600,000 LDCT screens, and the horizontal line divides strategies with less than or at least a 9 percent lung cancer mortality reduction. The shaded region includes those scenarios with fewer than 600,000 LDCT screens per 100,000 population and providing at least a 9 percent lung cancer mortality reduction (listed in Tables 9 and 10).

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based and Risk Model–Based Eligibility Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort. Figure 7 shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for all risk factor–based and risk model–based screening scenarios, highlighting the 267 consensus-efficient scenarios and the 2013 USPSTF-recommended scenario (A-55-80-30-15). The consensus-efficient scenarios are those resulting in the most lung cancer deaths averted or life years gained for a given level of LDCT screens. Annual and biennial strategies are also highlighted. Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 800 per 100,000 and life years gained from 0 to 10,000. Most consensus-efficient strategies are risk model–based. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of each panel, whereas annual consensus-efficient scenarios are located on the upper right side of each panel. The 2013 USPSTF-recommended scenario is not among the scenarios that result in the most lung cancer deaths averted nor life years gained for its corresponding level of screening. Thus it is not consensus-efficient for either metric, although it is closer to the most efficient scenarios for life-years gained.

The average number (across models) of LDCT screens per 100,000 population among the consensus-efficient scenarios ranges from 64,607 to 790,911, with the percentage of individuals ever screened ranging from 9.0 to 44.0 percent. Most consensus-efficient strategies with relatively lower number of LDCT screens (less than 175,000 screens) are biennial risk factor–based or risk model–based strategies because these are the least intensive strategies, whereas all strategies with a higher number of LDCT screens are annual risk-based strategies. The number of lung cancer deaths averted ranges from 173 to 728 per 100,000 population, corresponding to lung cancer mortality reductions ranging from 4.5 to 18.8 percent. The LYG ranges from 2,405 to 9,318 per 100,000, and the NNS (persons ever screened per lung cancer death averted) ranges from 37 to 73.

With regard to harms, the average number of false-positive screens per screened individual ranges from 0.8 to 2.4, the number of biopsies from 241 to 1,203 per 100,000, and the average number of LDCT examinations per screened individual from 5.0 to 20.7. The number of overdiagnosed cancers ranges from 26 to 125 per 100,000 population, and the overdiagnosis rate per screen-detected lung cancer varies from 4.5 to 7.1 percent. Finally, the number of radiation-related lung cancer deaths ranges from 5.7 to 52.3, also increasing monotonically as a function of the number of screens and the percentage of people screened.

Table 9 shows the benefits of the consensus-efficient scenarios restricted to those leading to at least 9 percent lung cancer mortality reduction per 100,000 population, as with the selected risk factor–based strategies, and requiring fewer than 600,000 LDCT screens per 100,000 (a total of 144 strategies). We concentrated on strategies resulting in fewer than 600,000 LDCT screens because all risk factor–based strategies are within this limit and one of the main goals is to assess the relative performance of risk factor–based and risk model–based screening strategies at similar levels of screening. For reference, the table also includes the reference 2013 USPSTF-recommended and the six selected 20 pack-year strategies. Figure 7 shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for the 144 selected consensus-efficient scenarios plus the 2013 USPSTF-recommended criteria. Of these, all of the consensus-efficient scenarios are risk model–based screening with 14.3 to 39.0 percent of individuals being eligible for screening at some point during their lifetime. The corresponding mortality reduction ranges from 9.0 to 17.1 percent and the LYG from 3,940 to 8,387 per 100,000 population. Table 10 shows the corresponding harms. In this case, the average number of false-positive screens per screened individual ranges from 1.0 to 2.2, the number of biopsies from 506 to 1,015, the average number of LDCT examinations per screened individual from 7.0 to 19.2, and the overdiagnosis rate per screen-detected lung cancer from 5.6 to 7.1 percent. The number of radiation-related lung cancer deaths ranges from 10.9 to 43.3 per 100,000 population. Results for all the 267 consensus-efficient plus the 2013 USPSTF-recommended and the six selected 20 pack-year scenarios are shown in Appendix C (Appendix C Tables 11 and 12). Results stratified by sex for the selected consensus-efficient scenarios are also shown in Appendix C (Appendix C Tables 13 and 14 for men and Appendix C Tables 15 and 16 for women). Appendix B Figures 21 and 22 show efficient frontiers for men’s and women’s outcomes, highlighting the consensus-efficient scenarios when considering both risk factor–based and risk model–based screening strategies.

Table 9 Benefits of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC Death Averted | NNS
B-50-80-MLCDRAT-0.015 | 20.7 | 148,360 | 1,174 | 9.0 | 348 | 3,940 | 11.3 | 38 | 426 | 59
B-50-80-Bach-0.025 | 21.6 | 150,601 | 1,197 | 9.2 | 355 | 4,017 | 11.3 | 37 | 424 | 61
B-50-80-MPLCOm2012-0.014 | 19.7 | 153,324 | 1,187 | 9.2 | 356 | 4,147 | 11.6 | 37 | 431 | 55
B-55-80-Bach-0.024 | 22.0 | 154,299 | 1,190 | 9.1 | 354 | 4,056 | 11.5 | 38 | 436 | 62
B-50-80-Bach-0.024 | 22.2 | 157,520 | 1,222 | 9.4 | 362 | 4,125 | 11.4 | 38 | 435 | 61
B-55-80-MPLCOm2012-0.013 | 20.4 | 158,123 | 1,181 | 9.1 | 354 | 4,177 | 11.8 | 38 | 447 | 58
B-50-80-MLCDRAT-0.014 | 21.6 | 158,658 | 1,206 | 9.3 | 361 | 4,106 | 11.4 | 39 | 439 | 60
B-50-80-MPLCOm2012-0.013 | 20.6 | 164,259 | 1,218 | 9.5 | 367 | 4,348 | 11.8 | 38 | 448 | 56
B-50-80-Bach-0.023 | 22.7 | 164,603 | 1,242 | 9.5 | 370 | 4,239 | 11.5 | 39 | 445 | 61
B-50-80-Bach-0.022 | 23.3 | 172,049 | 1,262 | 9.7 | 377 | 4,365 | 11.6 | 39 | 456 | 62
A-55-80-MPLCOm2012-0.023 | 14.3 | 174,860 | 1,177 | 10.0 | 388 | 4,161 | 10.7 | 42 | 451 | 37
A-50-80-MPLCOm2012-0.023 | 14.3 | 174,911 | 1,178 | 10.0 | 388 | 4,187 | 10.8 | 42 | 451 | 37
B-55-80-Bach-0.021 | 23.8 | 175,310 | 1,245 | 9.6 | 372 | 4,325 | 11.6 | 41 | 471 | 64
B-50-80-MPLCOm2012-0.012 | 21.6 | 176,755 | 1,253 | 9.7 | 378 | 4,527 | 12.0 | 39 | 468 | 57
A-55-80-MLCDRAT-0.023 | 15.6 | 179,310 | 1,178 | 10.0 | 388 | 4,087 | 10.5 | 44 | 462 | 40
B-50-80-Bach-0.021 | 23.9 | 180,105 | 1,280 | 9.9 | 384 | 4,457 | 11.6 | 40 | 469 | 62
B-55-80-Bach-0.02 | 24.4 | 182,833 | 1,264 | 9.8 | 381 | 4,439 | 11.7 | 41 | 480 | 64
A-55-80-MPLCOm2012-0.022 | 14.7 | 184,176 | 1,204 | 10.3 | 400 | 4,334 | 10.8 | 42 | 460 | 37
A-50-80-MPLCOm2012-0.022 | 14.7 | 184,284 | 1,205 | 10.3 | 399 | 4,336 | 10.9 | 43 | 462 | 37
B-50-80-Bach-0.02 | 24.6 | 188,573 | 1,301 | 10.2 | 394 | 4,596 | 11.7 | 41 | 479 | 62
B-55-80-Bach-0.019 | 25.0 | 190,612 | 1,282 | 10.0 | 387 | 4,547 | 11.7 | 42 | 493 | 65
B-50-80-MPLCOm2012-0.011 | 22.7 | 191,379 | 1,290 | 10.1 | 393 | 4,766 | 12.1 | 40 | 487 | 58
A-55-80-MPLCOm2012-0.021 | 15.3 | 193,965 | 1,232 | 10.6 | 411 | 4,515 | 11.0 | 43 | 472 | 37
A-55-80-Bach-0.034 | 17.1 | 194,099 | 1,247 | 10.6 | 409 | 4,404 | 10.8 | 44 | 475 | 42
A-50-80-MPLCOm2012-0.021 | 15.3 | 194,193 | 1,235 | 10.6 | 410 | 4,502 | 11.0 | 43 | 474 | 37
A-50-80-Bach-0.034 | 17.1 | 194,261 | 1,248 | 10.6 | 411 | 4,417 | 10.7 | 44 | 473 | 42
B-50-80-Bach-0.019 | 25.2 | 197,209 | 1,323 | 10.3 | 400 | 4,727 | 11.8 | 42 | 493 | 63
A-55-80-Bach-0.033 | 17.5 | 202,943 | 1,272 | 10.8 | 420 | 4,539 | 10.8 | 45 | 483 | 42
A-50-80-Bach-0.033 | 17.5 | 203,167 | 1,271 | 10.8 | 419 | 4,526 | 10.8 | 45 | 485 | 42
A-55-80-MPLCOm2012-0.02 | 15.8 | 204,612 | 1,262 | 10.9 | 421 | 4,645 | 11.0 | 44 | 486 | 38
A-50-80-MPLCOm2012-0.02 | 15.8 | 205,020 | 1,262 | 10.8 | 419 | 4,662 | 11.1 | 44 | 489 | 38
B-50-80-Bach-0.018 | 25.8 | 206,581 | 1,343 | 10.5 | 408 | 4,830 | 11.8 | 43 | 506 | 63
B-50-80-MPLCOm2012-0.01 | 23.8 | 206,957 | 1,323 | 10.4 | 404 | 4,967 | 12.3 | 42 | 512 | 59
A-50-80-MLCDRAT-0.02 | 17.4 | 210,560 | 1,273 | 10.9 | 423 | 4,566 | 10.8 | 46 | 498 | 41
A-55-80-Bach-0.032 | 18.0 | 212,181 | 1,296 | 11.1 | 431 | 4,655 | 10.8 | 46 | 492 | 42
A-50-80-Bach-0.032 | 18.0 | 212,490 | 1,298 | 11.1 | 430 | 4,668 | 10.9 | 46 | 494 | 42
A-55-80-MPLCOm2012-0.019 | 16.3 | 216,291 | 1,293 | 11.2 | 434 | 4,833 | 11.1 | 45 | 498 | 38
A-50-80-MPLCOm2012-0.019 | 16.4 | 217,030 | 1,293 | 11.2 | 435 | 4,859 | 11.2 | 45 | 499 | 38
A-55-80-Bach-0.031 | 18.5 | 221,421 | 1,321 | 11.3 | 439 | 4,791 | 10.9 | 46 | 504 | 42
A-50-80-Bach-0.031 | 18.5 | 221,847 | 1,321 | 11.4 | 441 | 4,831 | 11.0 | 46 | 503 | 42
B-50-80-MPLCOm2012-0.009 | 25.0 | 225,054 | 1,357 | 10.8 | 417 | 5,169 | 12.4 | 44 | 540 | 60
A-50-80-MLCDRAT-0.019 | 18.1 | 225,292 | 1,310 | 11.3 | 437 | 4,774 | 10.9 | 47 | 516 | 41
B-50-80-Bach-0.016 | 27.3 | 227,395 | 1,388 | 10.9 | 423 | 5,099 | 12.1 | 45 | 538 | 65
A-55-80-30-15 | 14.1 | 227,443 | 1,102 | 9.8 | 381 | 4,882 | 12.8 | 47 | 597 | 37
A-55-80-MPLCOm2012-0.018 | 17.0 | 228,676 | 1,320 | 11.5 | 444 | 4,982 | 11.2 | 46 | 515 | 38
A-50-80-MPLCOm2012-0.018 | 17.0 | 229,944 | 1,327 | 11.5 | 445 | 5,021 | 11.3 | 46 | 517 | 38
A-55-80-Bach-0.03 | 19.0 | 231,518 | 1,347 | 11.6 | 450 | 4,936 | 11.0 | 47 | 514 | 42
A-50-80-Bach-0.03 | 19.0 | 232,092 | 1,350 | 11.6 | 450 | 4,969 | 11.0 | 47 | 516 | 42
A-50-80-MLCDRAT-0.018 | 18.6 | 236,479 | 1,339 | 11.6 | 450 | 4,942 | 11.0 | 48 | 526 | 41
A-55-80-MLCDRAT-0.018 | 18.6 | 236,483 | 1,340 | 11.5 | 448 | 4,916 | 11.0 | 48 | 528 | 42
A-55-80-Bach-0.029 | 19.5 | 241,484 | 1,370 | 11.8 | 459 | 5,063 | 11.0 | 48 | 526 | 42
A-50-80-Bach-0.029 | 19.5 | 242,278 | 1,374 | 11.8 | 459 | 5,084 | 11.1 | 48 | 528 | 42
A-55-80-MPLCOm2012-0.017 | 17.6 | 242,329 | 1,352 | 11.8 | 455 | 5,163 | 11.3 | 47 | 533 | 39
A-50-80-MPLCOm2012-0.017 | 17.6 | 244,349 | 1,359 | 11.8 | 457 | 5,227 | 11.4 | 47 | 535 | 39
B-50-80-MPLCOm2012-0.008 | 26.5 | 245,777 | 1,399 | 11.2 | 432 | 5,407 | 12.5 | 45 | 569 | 61
B-50-80-Bach-0.014 | 28.8 | 250,390 | 1,430 | 11.3 | 438 | 5,358 | 12.2 | 47 | 572 | 66
A-55-80-Bach-0.028 | 20.0 | 252,590 | 1,396 | 12.1 | 468 | 5,199 | 11.1 | 49 | 540 | 43
A-50-80-Bach-0.028 | 20.0 | 253,613 | 1,399 | 12.1 | 471 | 5,225 | 11.1 | 49 | 538 | 42
A-50-80-MLCDRAT-0.017 | 19.3 | 253,620 | 1,376 | 12.0 | 463 | 5,153 | 11.1 | 49 | 548 | 42
A-55-80-MPLCOm2012-0.016 | 18.3 | 256,724 | 1,383 | 12.1 | 468 | 5,341 | 11.4 | 48 | 549 | 39
A-50-80-MPLCOm2012-0.016 | 18.3 | 259,832 | 1,394 | 12.3 | 475 | 5,502 | 11.6 | 47 | 547 | 39
B-50-80-Bach-0.013 | 29.6 | 263,135 | 1,451 | 11.5 | 445 | 5,498 | 12.4 | 48 | 591 | 67
A-55-80-Bach-0.027 | 20.6 | 263,986 | 1,420 | 12.3 | 478 | 5,328 | 11.1 | 50 | 552 | 43
A-50-80-Bach-0.027 | 20.6 | 265,411 | 1,424 | 12.3 | 478 | 5,353 | 11.2 | 50 | 555 | 43
A-50-80-MLCDRAT-0.016 | 20.0 | 267,426 | 1,409 | 12.3 | 478 | 5,355 | 11.2 | 50 | 559 | 42
B-50-80-MPLCOm2012-0.007 | 28.1 | 270,148 | 1,442 | 11.6 | 449 | 5,644 | 12.6 | 48 | 602 | 63
A-55-80-MPLCOm2012-0.015 | 19.0 | 272,809 | 1,415 | 12.4 | 481 | 5,533 | 11.5 | 49 | 567 | 40
A-55-80-Bach-0.026 | 21.1 | 275,329 | 1,444 | 12.6 | 489 | 5,463 | 11.2 | 50 | 563 | 43
B-50-80-Bach-0.012 | 30.5 | 277,033 | 1,476 | 11.8 | 456 | 5,639 | 12.4 | 49 | 608 | 67
A-50-80-Bach-0.026 | 21.1 | 277,066 | 1,447 | 12.6 | 489 | 5,495 | 11.2 | 50 | 567 | 43
A-50-80-MPLCOm2012-0.015 | 19.0 | 277,426 | 1,429 | 12.6 | 488 | 5,685 | 11.6 | 49 | 568 | 39
A-50-77-MPLCOm2012-0.013 | 19.7 | 280,113 | 1,260 | 11.4 | 441 | 5,712 | 13.0 | 49 | 635 | 45
A-50-80-MLCDRAT-0.015 | 20.8 | 286,154 | 1,451 | 12.7 | 491 | 5,562 | 11.3 | 51 | 583 | 42
A-55-80-Bach-0.025 | 21.7 | 287,935 | 1,470 | 12.8 | 495 | 5,572 | 11.3 | 52 | 582 | 44
A-50-80-Bach-0.025 | 21.7 | 290,340 | 1,475 | 12.9 | 498 | 5,657 | 11.4 | 51 | 583 | 44
A-55-80-MPLCOm2012-0.014 | 19.8 | 290,431 | 1,452 | 12.7 | 494 | 5,717 | 11.6 | 51 | 588 | 40
B-50-80-Bach-0.011 | 31.5 | 292,128 | 1,499 | 12.0 | 465 | 5,800 | 12.5 | 50 | 628 | 68
B-50-80-MPLCOm2012-0.006 | 29.9 | 296,680 | 1,482 | 11.9 | 461 | 5,867 | 12.7 | 51 | 644 | 65
A-50-80-MPLCOm2012-0.014 | 19.8 | 297,009 | 1,466 | 13.0 | 503 | 5,925 | 11.8 | 50 | 590 | 39
A-55-80-Bach-0.024 | 22.2 | 300,842 | 1,494 | 13.1 | 507 | 5,735 | 11.3 | 52 | 593 | 44
A-50-77-MPLCOm2012-0.012 | 20.6 | 303,023 | 1,296 | 11.7 | 455 | 5,960 | 13.1 | 51 | 666 | 45
A-55-80-MLCDRAT-0.014 | 21.7 | 303,286 | 1,480 | 13.0 | 504 | 5,722 | 11.4 | 53 | 602 | 43
A-50-80-Bach-0.024 | 22.3 | 303,778 | 1,502 | 13.2 | 510 | 5,840 | 11.5 | 52 | 596 | 44
A-50-80-MLCDRAT-0.014 | 21.7 | 306,138 | 1,487 | 13.1 | 507 | 5,808 | 11.5 | 53 | 604 | 43
B-50-80-Bach-0.01 | 32.6 | 308,091 | 1,527 | 12.2 | 472 | 5,924 | 12.6 | 52 | 653 | 69
A-55-80-MPLCOm2012-0.013 | 20.6 | 309,284 | 1,482 | 13.1 | 508 | 5,933 | 11.7 | 52 | 609 | 41
A-55-80-Bach-0.023 | 22.8 | 313,914 | 1,520 | 13.4 | 518 | 5,898 | 11.4 | 53 | 606 | 44
A-50-80-Bach-0.023 | 22.9 | 317,678 | 1,530 | 13.4 | 521 | 5,999 | 11.5 | 53 | 610 | 44
A-50-80-MPLCOm2012-0.013 | 20.7 | 318,502 | 1,502 | 13.3 | 514 | 6,136 | 11.9 | 52 | 620 | 40
A-55-80-MLCDRAT-0.013 | 22.6 | 320,862 | 1,516 | 13.4 | 520 | 5,935 | 11.4 | 54 | 617 | 43
A-50-80-MLCDRAT-0.013 | 22.7 | 325,175 | 1,524 | 13.5 | 522 | 6,033 | 11.6 | 54 | 623 | 43
B-50-80-Bach-0.009 | 33.8 | 325,901 | 1,554 | 12.5 | 484 | 6,136 | 12.7 | 53 | 673 | 70
B-50-80-MPLCOm2012-0.005 | 31.9 | 327,272 | 1,522 | 12.3 | 477 | 6,149 | 12.9 | 53 | 686 | 67
A-55-80-Bach-0.022 | 23.4 | 327,719 | 1,542 | 13.6 | 527 | 6,024 | 11.4 | 54 | 622 | 44
A-50-77-MPLCOm2012-0.011 | 21.6 | 328,622 | 1,331 | 12.1 | 469 | 6,212 | 13.2 | 53 | 701 | 46
A-55-80-20-15 | 20.6 | 330,095 | 1,334 | 12.1 | 469 | 6,018 | 12.8 | 55 | 704 | 44
A-55-80-MPLCOm2012-0.012 | 21.6 | 330,347 | 1,519 | 13.4 | 520 | 6,146 | 11.8 | 54 | 635 | 42
A-50-80-Bach-0.022 | 23.4 | 332,451 | 1,550 | 13.7 | 531 | 6,167 | 11.6 | 54 | 626 | 44
A-55-80-Bach-0.021 | 24.0 | 342,337 | 1,566 | 13.9 | 538 | 6,197 | 11.5 | 55 | 636 | 45
A-50-80-MPLCOm2012-0.012 | 21.7 | 343,293 | 1,543 | 13.7 | 532 | 6,409 | 12.0 | 54 | 645 | 41
A-55-80-MLCDRAT-0.012 | 23.8 | 343,713 | 1,551 | 13.7 | 532 | 6,126 | 11.5 | 56 | 646 | 45
A-50-80-Bach-0.021 | 24.1 | 348,282 | 1,577 | 14.0 | 541 | 6,340 | 11.7 | 55 | 644 | 45
A-50-80-MLCDRAT-0.012 | 23.9 | 350,286 | 1,564 | 13.9 | 537 | 6,271 | 11.7 | 56 | 652 | 45
A-55-80-MPLCOm2012-0.011 | 22.6 | 352,002 | 1,552 | 13.8 | 535 | 6,348 | 11.9 | 55 | 658 | 42
A-55-80-Bach-0.02 | 24.6 | 357,203 | 1,586 | 14.1 | 545 | 6,319 | 11.6 | 57 | 655 | 45
A-50-77-MPLCOm2012-0.01 | 22.7 | 357,345 | 1,369 | 12.6 | 488 | 6,529 | 13.4 | 55 | 732 | 47
A-50-80-Bach-0.02 | 24.7 | 364,767 | 1,603 | 14.3 | 555 | 6,545 | 11.8 | 56 | 657 | 45
A-55-80-MLCDRAT-0.011 | 25.5 | 369,025 | 1,595 | 14.2 | 549 | 6,384 | 11.6 | 58 | 672 | 46
A-55-80-20-20 | 22.0 | 369,610 | 1,423 | 12.9 | 500 | 6,379 | 12.8 | 58 | 739 | 44
A-50-80-MPLCOm2012-0.011 | 22.8 | 370,909 | 1,582 | 14.2 | 550 | 6,686 | 12.2 | 55 | 674 | 41
A-55-80-Bach-0.019 | 25.2 | 372,598 | 1,611 | 14.3 | 554 | 6,458 | 11.7 | 58 | 673 | 45
A-55-80-MPLCOm2012-0.01 | 23.7 | 375,484 | 1,586 | 14.1 | 548 | 6,519 | 11.9 | 58 | 685 | 43
A-50-80-MLCDRAT-0.011 | 25.5 | 377,864 | 1,613 | 14.4 | 558 | 6,607 | 11.8 | 57 | 677 | 46
A-50-80-Bach-0.019 | 25.3 | 381,778 | 1,624 | 14.4 | 559 | 6,652 | 11.9 | 57 | 683 | 45
A-55-80-Bach-0.018 | 25.8 | 389,243 | 1,632 | 14.5 | 563 | 6,589 | 11.7 | 59 | 691 | 46
A-55-80-MLCDRAT-0.01 | 27.7 | 398,180 | 1,641 | 14.6 | 564 | 6,605 | 11.7 | 60 | 706 | 49
A-50-80-Bach-0.018 | 26.0 | 400,457 | 1,653 | 14.8 | 572 | 6,846 | 12.0 | 58 | 700 | 45
A-50-80-MPLCOm2012-0.01 | 23.9 | 401,856 | 1,622 | 14.6 | 564 | 6,957 | 12.3 | 58 | 713 | 42
A-55-80-20-25 | 22.7 | 404,596 | 1,492 | 13.5 | 523 | 6,654 | 12.7 | 61 | 774 | 43
A-55-80-Bach-0.017 | 26.5 | 406,323 | 1,657 | 14.9 | 575 | 6,774 | 11.8 | 60 | 707 | 46
A-50-80-MLCDRAT-0.01 | 27.9 | 409,804 | 1,662 | 14.8 | 575 | 6,871 | 11.9 | 60 | 713 | 49
A-50-80-20-15 | 22.6 | 419,030 | 1,401 | 13.0 | 503 | 6,918 | 13.8 | 61 | 833 | 45
A-50-80-Bach-0.017 | 26.6 | 420,352 | 1,678 | 15.1 | 586 | 7,039 | 12.0 | 60 | 717 | 45
A-55-80-Bach-0.016 | 27.2 | 423,929 | 1,677 | 15.0 | 582 | 6,908 | 11.9 | 61 | 728 | 47
A-55-80-MPLCOm2012-0.008 | 26.2 | 432,557 | 1,662 | 14.9 | 579 | 6,975 | 12.0 | 62 | 747 | 45
A-55-80-MLCDRAT-0.009 | 30.4 | 433,597 | 1,696 | 15.0 | 583 | 6,869 | 11.8 | 63 | 744 | 52
A-50-80-MPLCOm2012-0.009 | 25.1 | 437,273 | 1,665 | 15.0 | 582 | 7,291 | 12.5 | 60 | 751 | 43
A-50-80-Bach-0.016 | 27.4 | 441,294 | 1,704 | 15.4 | 595 | 7,190 | 12.1 | 61 | 742 | 46
A-55-80-Bach-0.015 | 27.9 | 442,384 | 1,700 | 15.3 | 592 | 7,034 | 11.9 | 63 | 747 | 47
A-50-80-MLCDRAT-0.009 | 30.6 | 449,030 | 1,717 | 15.4 | 596 | 7,168 | 12.0 | 63 | 753 | 51
A-55-80-Bach-0.014 | 28.7 | 461,609 | 1,723 | 15.5 | 602 | 7,179 | 11.9 | 64 | 767 | 48
A-50-80-Bach-0.015 | 28.1 | 463,301 | 1,727 | 15.6 | 605 | 7,391 | 12.2 | 63 | 766 | 46
A-50-80-20-20 | 23.3 | 463,457 | 1,487 | 13.8 | 534 | 7,301 | 13.7 | 63 | 868 | 44
A-55-80-MLCDRAT-0.008 | 33.3 | 474,060 | 1,749 | 15.6 | 606 | 7,147 | 11.8 | 66 | 782 | 55
A-50-80-MPLCOm2012-0.008 | 26.6 | 478,349 | 1,710 | 15.5 | 601 | 7,564 | 12.6 | 63 | 796 | 44
A-55-80-Bach-0.013 | 29.5 | 482,093 | 1,744 | 15.8 | 610 | 7,330 | 12.0 | 66 | 790 | 48
A-50-80-Bach-0.014 | 28.9 | 486,484 | 1,752 | 15.9 | 616 | 7,582 | 12.3 | 64 | 790 | 47
A-50-80-MLCDRAT-0.008 | 33.5 | 495,424 | 1,779 | 16.0 | 619 | 7,508 | 12.1 | 66 | 800 | 54
A-50-80-20-25 | 23.6 | 500,430 | 1,560 | 14.4 | 558 | 7,596 | 13.6 | 66 | 897 | 42
A-55-80-Bach-0.012 | 30.3 | 503,871 | 1,768 | 16.0 | 617 | 7,467 | 12.1 | 67 | 817 | 49
A-50-80-Bach-0.013 | 29.7 | 511,462 | 1,778 | 16.2 | 627 | 7,746 | 12.4 | 66 | 816 | 47
A-55-80-MLCDRAT-0.007 | 36.3 | 520,869 | 1,805 | 16.2 | 629 | 7,496 | 11.9 | 69 | 828 | 58
A-50-80-MPLCOm2012-0.007 | 28.2 | 524,392 | 1,754 | 16.0 | 620 | 7,904 | 12.7 | 66 | 846 | 45
A-55-80-Bach-0.011 | 31.3 | 527,263 | 1,793 | 16.2 | 628 | 7,606 | 12.1 | 69 | 840 | 50
A-50-80-Bach-0.012 | 30.6 | 538,488 | 1,806 | 16.4 | 635 | 7,914 | 12.5 | 68 | 848 | 48
A-50-80-MLCDRAT-0.007 | 36.5 | 550,777 | 1,843 | 16.7 | 647 | 7,943 | 12.3 | 69 | 851 | 56
A-55-80-Bach-0.01 | 32.3 | 551,762 | 1,816 | 16.5 | 639 | 7,773 | 12.2 | 71 | 863 | 51
A-50-80-Bach-0.011 | 31.6 | 568,005 | 1,834 | 16.7 | 648 | 8,156 | 12.6 | 70 | 877 | 49
A-50-80-MPLCOm2012-0.006 | 30.0 | 575,496 | 1,797 | 16.4 | 635 | 8,164 | 12.9 | 70 | 906 | 47
A-55-80-MLCDRAT-0.006 | 39.0 | 577,420 | 1,865 | 16.9 | 655 | 7,830 | 12.0 | 74 | 882 | 60
A-50-80-Bach-0.01 | 32.7 | 599,143 | 1,862 | 17.1 | 662 | 8,387 | 12.7 | 71 | 905 | 49

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

Numbers are per a 100,000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The risk model–based screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The risk factor–based screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force

Table 10 Harms of 144 Selected^*^ Consensus Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-50-80-MLCDRAT-0.015 | 148,360 | 165,827 | 7.2 | 1.0 | 506 | 76 | 1.5 | 6.5 | 11.1
B-50-80-Bach-0.025 | 150,601 | 168,292 | 7.0 | 1.0 | 516 | 76 | 1.5 | 6.3 | 11.0
B-50-80-MPLCOm2012-0.014 | 153,324 | 170,855 | 7.8 | 1.1 | 512 | 73 | 1.5 | 6.1 | 11.9
B-55-80-Bach-0.024 | 154,299 | 172,167 | 7.0 | 1.0 | 516 | 74 | 1.5 | 6.2 | 11.5
B-50-80-Bach-0.024 | 157,520 | 175,651 | 7.1 | 1.0 | 529 | 77 | 1.5 | 6.3 | 11.8
B-55-80-MPLCOm2012-0.013 | 158,123 | 175,963 | 7.8 | 1.1 | 514 | 71 | 1.4 | 6.0 | 12.5
B-50-80-MLCDRAT-0.014 | 158,658 | 176,788 | 7.3 | 1.0 | 524 | 77 | 1.6 | 6.4 | 12.0
B-50-80-MPLCOm2012-0.013 | 164,259 | 182,478 | 8.0 | 1.1 | 531 | 74 | 1.5 | 6.1 | 13.4
B-50-80-Bach-0.023 | 164,603 | 183,169 | 7.3 | 1.0 | 541 | 78 | 1.6 | 6.3 | 12.3
B-50-80-Bach-0.022 | 172,049 | 191,083 | 7.4 | 1.0 | 553 | 79 | 1.6 | 6.3 | 12.8
A-55-80-MPLCOm2012-0.023 | 174,860 | 192,554 | 12.2 | 1.5 | 508 | 80 | 1.6 | 6.8 | 11.2
A-50-80-MPLCOm2012-0.023 | 174,911 | 192,601 | 12.2 | 1.5 | 508 | 80 | 1.6 | 6.8 | 11.2
B-55-80-Bach-0.021 | 175,310 | 194,510 | 7.4 | 1.0 | 550 | 75 | 1.5 | 6.0 | 13.1
B-50-80-MPLCOm2012-0.012 | 176,755 | 195,746 | 8.2 | 1.1 | 552 | 76 | 1.5 | 6.1 | 13.7
A-55-80-MLCDRAT-0.023 | 179,310 | 197,439 | 11.5 | 1.4 | 513 | 84 | 1.7 | 7.1 | 10.9
B-50-80-Bach-0.021 | 180,105 | 199,649 | 7.5 | 1.1 | 565 | 79 | 1.6 | 6.2 | 13.7
B-55-80-Bach-0.02 | 182,833 | 202,516 | 7.5 | 1.1 | 562 | 76 | 1.5 | 6.0 | 13.9
A-55-80-MPLCOm2012-0.022 | 184,176 | 202,396 | 12.5 | 1.5 | 523 | 82 | 1.6 | 6.8 | 12.1
A-50-80-MPLCOm2012-0.022 | 184,284 | 202,513 | 12.5 | 1.5 | 523 | 82 | 1.6 | 6.8 | 12.1
B-50-80-Bach-0.02 | 188,573 | 208,640 | 7.7 | 1.1 | 579 | 80 | 1.6 | 6.1 | 14.6
B-55-80-Bach-0.019 | 190,612 | 210,780 | 7.6 | 1.1 | 574 | 77 | 1.5 | 6.0 | 14.5
B-50-80-MPLCOm2012-0.011 | 191,379 | 211,271 | 8.4 | 1.2 | 575 | 77 | 1.6 | 6.0 | 15.3
A-55-80-MPLCOm2012-0.021 | 193,965 | 212,755 | 12.7 | 1.5 | 539 | 84 | 1.7 | 6.8 | 13.2
A-55-80-Bach-0.034 | 194,099 | 213,177 | 11.4 | 1.4 | 546 | 88 | 1.8 | 7.1 | 12.8
A-50-80-MPLCOm2012-0.021 | 194,193 | 212,990 | 12.7 | 1.5 | 540 | 84 | 1.7 | 6.8 | 13.2
A-50-80-Bach-0.034 | 194,261 | 213,338 | 11.4 | 1.4 | 546 | 87 | 1.7 | 7.0 | 12.8
B-50-80-Bach-0.019 | 197,209 | 217,812 | 7.8 | 1.1 | 593 | 81 | 1.6 | 6.1 | 15.2
A-55-80-Bach-0.033 | 202,943 | 222,529 | 11.6 | 1.4 | 560 | 88 | 1.8 | 6.9 | 13.5
A-50-80-Bach-0.033 | 203,167 | 222,759 | 11.6 | 1.4 | 560 | 88 | 1.8 | 6.9 | 13.6
A-55-80-MPLCOm2012-0.02 | 204,612 | 224,001 | 13.0 | 1.6 | 555 | 86 | 1.7 | 6.8 | 14.1
A-50-80-MPLCOm2012-0.02 | 205,020 | 224,420 | 13.0 | 1.6 | 555 | 85 | 1.7 | 6.7 | 14.2
B-50-80-Bach-0.018 | 206,581 | 227,744 | 8.0 | 1.1 | 606 | 82 | 1.7 | 6.1 | 16.0
B-50-80-MPLCOm2012-0.01 | 206,957 | 227,804 | 8.7 | 1.2 | 598 | 79 | 1.6 | 6.0 | 16.9
A-50-80-MLCDRAT-0.02 | 210,560 | 230,513 | 12.1 | 1.5 | 565 | 89 | 1.8 | 7.0 | 13.3
A-55-80-Bach-0.032 | 212,181 | 232,294 | 11.8 | 1.4 | 574 | 90 | 1.8 | 6.9 | 14.1
A-50-80-Bach-0.032 | 212,490 | 232,621 | 11.8 | 1.4 | 575 | 89 | 1.8 | 6.9 | 14.1
A-55-80-MPLCOm2012-0.019 | 216,291 | 236,355 | 13.3 | 1.6 | 573 | 87 | 1.7 | 6.7 | 15.1
A-50-80-MPLCOm2012-0.019 | 217,030 | 237,128 | 13.2 | 1.6 | 574 | 87 | 1.7 | 6.7 | 15.2
A-55-80-Bach-0.031 | 221,421 | 242,072 | 12.0 | 1.5 | 589 | 91 | 1.8 | 6.9 | 14.8
A-50-80-Bach-0.031 | 221,847 | 242,513 | 12.0 | 1.5 | 589 | 90 | 1.8 | 6.8 | 14.9
B-50-80-MPLCOm2012-0.009 | 225,054 | 247,007 | 9.0 | 1.2 | 623 | 80 | 1.6 | 5.9 | 18.5
A-50-80-MLCDRAT-0.019 | 225,292 | 246,094 | 12.4 | 1.5 | 587 | 91 | 1.8 | 6.9 | 14.6
B-50-80-Bach-0.016 | 227,395 | 249,832 | 8.3 | 1.2 | 637 | 84 | 1.7 | 6.1 | 18.2
A-55-80-30-15 | 227,443 | 247,644 | 16.1 | 1.9 | 518 | 69 | 1.4 | 6.3 | 20.6
A-55-80-MPLCOm2012-0.018 | 228,676 | 249,442 | 13.5 | 1.6 | 591 | 89 | 1.8 | 6.7 | 15.8
A-50-80-MPLCOm2012-0.018 | 229,944 | 250,782 | 13.5 | 1.6 | 594 | 90 | 1.8 | 6.8 | 15.9
A-55-80-Bach-0.03 | 231,518 | 252,744 | 12.2 | 1.5 | 604 | 93 | 1.9 | 6.9 | 15.5
A-50-80-Bach-0.03 | 232,092 | 253,350 | 12.2 | 1.5 | 605 | 93 | 1.9 | 6.9 | 15.6
A-50-80-MLCDRAT-0.018 | 236,479 | 257,928 | 12.7 | 1.5 | 604 | 92 | 1.8 | 6.9 | 15.6
A-55-80-MLCDRAT-0.018 | 236,483 | 257,918 | 12.7 | 1.5 | 604 | 92 | 1.8 | 6.9 | 15.6
A-55-80-Bach-0.029 | 241,484 | 263,290 | 12.4 | 1.5 | 618 | 94 | 1.9 | 6.9 | 16.2
A-50-80-Bach-0.029 | 242,278 | 264,120 | 12.4 | 1.5 | 620 | 94 | 1.9 | 6.8 | 16.3
A-55-80-MPLCOm2012-0.017 | 242,329 | 263,878 | 13.8 | 1.6 | 610 | 90 | 1.8 | 6.7 | 17.1
A-50-80-MPLCOm2012-0.017 | 244,349 | 265,995 | 13.9 | 1.7 | 614 | 92 | 1.8 | 6.8 | 17.4
B-50-80-MPLCOm2012-0.008 | 245,777 | 268,980 | 9.3 | 1.3 | 653 | 83 | 1.7 | 5.9 | 20.0
B-50-80-Bach-0.014 | 250,390 | 274,208 | 8.7 | 1.2 | 668 | 86 | 1.7 | 6.0 | 19.6
A-55-80-Bach-0.028 | 252,590 | 275,022 | 12.6 | 1.5 | 634 | 96 | 1.9 | 6.9 | 16.8
A-50-80-Bach-0.028 | 253,613 | 276,110 | 12.7 | 1.5 | 636 | 95 | 1.9 | 6.8 | 17.0
A-50-80-MLCDRAT-0.017 | 253,620 | 276,030 | 13.1 | 1.6 | 628 | 95 | 1.9 | 6.9 | 17.0
A-55-80-MPLCOm2012-0.016 | 256,724 | 279,088 | 14.0 | 1.7 | 630 | 92 | 1.8 | 6.7 | 18.3
A-50-80-MPLCOm2012-0.016 | 259,832 | 282,347 | 14.2 | 1.7 | 635 | 94 | 1.9 | 6.7 | 18.9
B-50-80-Bach-0.013 | 263,135 | 287,720 | 8.9 | 1.2 | 685 | 86 | 1.7 | 5.9 | 20.8
A-55-80-Bach-0.027 | 263,986 | 287,083 | 12.8 | 1.5 | 650 | 97 | 1.9 | 6.8 | 17.9
A-50-80-Bach-0.027 | 265,411 | 288,573 | 12.9 | 1.6 | 652 | 97 | 1.9 | 6.8 | 18.1
A-50-80-MLCDRAT-0.016 | 267,426 | 290,613 | 13.4 | 1.6 | 648 | 97 | 1.9 | 6.9 | 18.1
B-50-80-MPLCOm2012-0.007 | 270,148 | 294,837 | 9.6 | 1.3 | 685 | 85 | 1.7 | 5.9 | 21.9
A-55-80-MPLCOm2012-0.015 | 272,809 | 296,092 | 14.4 | 1.7 | 651 | 93 | 1.9 | 6.6 | 19.5
A-55-80-Bach-0.026 | 275,329 | 299,073 | 13.0 | 1.6 | 665 | 99 | 2.0 | 6.9 | 18.7
B-50-80-Bach-0.012 | 277,033 | 302,448 | 9.1 | 1.2 | 704 | 87 | 1.8 | 5.9 | 22.1
A-50-80-Bach-0.026 | 277,066 | 300,897 | 13.1 | 1.6 | 667 | 98 | 2.0 | 6.8 | 18.9
A-50-80-MPLCOm2012-0.015 | 277,426 | 300,937 | 14.6 | 1.7 | 659 | 94 | 1.9 | 6.6 | 20.2
A-50-77-MPLCOm2012-0.013 | 280,113 | 303,848 | 14.2 | 1.7 | 609 | 72 | 1.4 | 5.7 | 22.0
A-50-80-MLCDRAT-0.015 | 286,154 | 310,413 | 13.8 | 1.6 | 674 | 99 | 2.0 | 6.8 | 19.2
A-55-80-Bach-0.025 | 287,935 | 312,383 | 13.3 | 1.6 | 682 | 99 | 2.0 | 6.7 | 19.6
A-50-80-Bach-0.025 | 290,340 | 314,916 | 13.4 | 1.6 | 685 | 99 | 2.0 | 6.7 | 20.0
A-55-80-MPLCOm2012-0.014 | 290,431 | 314,704 | 14.7 | 1.7 | 675 | 95 | 1.9 | 6.5 | 20.5
B-50-80-Bach-0.011 | 292,128 | 318,447 | 9.3 | 1.3 | 723 | 89 | 1.8 | 5.9 | 23.0
B-50-80-MPLCOm2012-0.006 | 296,680 | 322,996 | 9.9 | 1.3 | 719 | 88 | 1.8 | 5.9 | 23.8
A-50-80-MPLCOm2012-0.014 | 297,009 | 321,624 | 15.0 | 1.8 | 684 | 96 | 1.9 | 6.5 | 21.3
A-55-80-Bach-0.024 | 300,842 | 326,030 | 13.6 | 1.6 | 698 | 101 | 2.0 | 6.8 | 20.3
A-50-77-MPLCOm2012-0.012 | 303,023 | 328,035 | 14.7 | 1.8 | 637 | 73 | 1.5 | 5.6 | 24.1
A-55-80-MLCDRAT-0.014 | 303,286 | 328,536 | 14.0 | 1.7 | 695 | 100 | 2.0 | 6.8 | 20.4
A-50-80-Bach-0.024 | 303,778 | 329,091 | 13.6 | 1.6 | 703 | 100 | 2.0 | 6.7 | 20.6
A-50-80-MLCDRAT-0.014 | 306,138 | 331,531 | 14.1 | 1.7 | 699 | 100 | 2.0 | 6.7 | 20.7
B-50-80-Bach-0.01 | 308,091 | 335,373 | 9.5 | 1.3 | 744 | 90 | 1.8 | 5.9 | 24.4
A-55-80-MPLCOm2012-0.013 | 309,284 | 334,629 | 15.0 | 1.8 | 697 | 96 | 1.9 | 6.5 | 21.8
A-55-80-Bach-0.023 | 313,914 | 339,831 | 13.8 | 1.6 | 716 | 102 | 2.0 | 6.7 | 21.0
A-50-80-Bach-0.023 | 317,678 | 343,778 | 13.9 | 1.7 | 721 | 101 | 2.0 | 6.6 | 21.5
A-50-80-MPLCOm2012-0.013 | 318,502 | 344,299 | 15.4 | 1.8 | 709 | 98 | 2.0 | 6.5 | 23.1
A-55-80-MLCDRAT-0.013 | 320,862 | 347,108 | 14.2 | 1.7 | 718 | 102 | 2.0 | 6.7 | 21.3
A-50-80-MLCDRAT-0.013 | 325,175 | 351,637 | 14.3 | 1.7 | 724 | 102 | 2.0 | 6.7 | 21.9
B-50-80-Bach-0.009 | 325,901 | 354,263 | 9.6 | 1.3 | 767 | 91 | 1.8 | 5.9 | 25.7
B-50-80-MPLCOm2012-0.005 | 327,272 | 355,416 | 10.3 | 1.4 | 756 | 89 | 1.8 | 5.8 | 25.3
A-55-80-Bach-0.022 | 327,719 | 354,413 | 14.0 | 1.7 | 732 | 103 | 2.1 | 6.7 | 22.3
A-50-77-MPLCOm2012-0.011 | 328,622 | 355,052 | 15.2 | 1.8 | 665 | 74 | 1.5 | 5.6 | 26.0
A-55-80-20-15 | 330,095 | 356,390 | 16.0 | 1.9 | 667 | 83 | 1.7 | 6.2 | 29.0
A-55-80-MPLCOm2012-0.012 | 330,347 | 356,878 | 15.3 | 1.8 | 723 | 98 | 2.0 | 6.5 | 23.3
A-50-80-Bach-0.022 | 332,451 | 359,385 | 14.2 | 1.7 | 738 | 103 | 2.1 | 6.6 | 22.9
A-55-80-Bach-0.021 | 342,337 | 369,858 | 14.3 | 1.7 | 750 | 105 | 2.1 | 6.7 | 23.1
A-50-80-MPLCOm2012-0.012 | 343,293 | 370,477 | 15.8 | 1.9 | 740 | 99 | 2.0 | 6.4 | 25.2
A-55-80-MLCDRAT-0.012 | 343,713 | 371,269 | 14.4 | 1.7 | 745 | 104 | 2.1 | 6.7 | 23.0
A-50-80-Bach-0.021 | 348,282 | 376,097 | 14.5 | 1.7 | 757 | 104 | 2.1 | 6.6 | 24.0
A-50-80-MLCDRAT-0.012 | 350,286 | 378,187 | 14.7 | 1.7 | 754 | 103 | 2.1 | 6.6 | 23.9
A-55-80-MPLCOm2012-0.011 | 352,002 | 379,754 | 15.6 | 1.8 | 749 | 100 | 2.0 | 6.4 | 24.7
A-55-80-Bach-0.02 | 357,203 | 385,566 | 14.5 | 1.7 | 766 | 105 | 2.1 | 6.6 | 24.1
A-50-77-MPLCOm2012-0.01 | 357,345 | 385,345 | 15.7 | 1.9 | 697 | 76 | 1.5 | 5.6 | 28.7
A-50-80-Bach-0.02 | 364,767 | 393,511 | 14.8 | 1.7 | 776 | 105 | 2.1 | 6.6 | 25.1
A-55-80-MLCDRAT-0.011 | 369,025 | 398,078 | 14.5 | 1.7 | 777 | 105 | 2.1 | 6.6 | 24.6
A-55-80-20-20 | 369,610 | 398,094 | 16.8 | 2.0 | 722 | 89 | 1.8 | 6.3 | 30.6
A-50-80-MPLCOm2012-0.011 | 370,909 | 399,603 | 16.3 | 1.9 | 770 | 101 | 2.0 | 6.4 | 27.2
A-55-80-Bach-0.019 | 372,598 | 401,805 | 14.8 | 1.7 | 784 | 106 | 2.1 | 6.6 | 25.2
A-55-80-MPLCOm2012-0.01 | 375,484 | 404,571 | 15.8 | 1.9 | 776 | 102 | 2.0 | 6.4 | 26.5
A-50-80-MLCDRAT-0.011 | 377,864 | 407,366 | 14.8 | 1.7 | 789 | 105 | 2.1 | 6.5 | 25.8
A-50-80-Bach-0.019 | 381,778 | 411,439 | 15.1 | 1.8 | 794 | 106 | 2.1 | 6.5 | 26.4
A-55-80-Bach-0.018 | 389,243 | 419,367 | 15.1 | 1.8 | 802 | 107 | 2.2 | 6.6 | 26.5
A-55-80-MLCDRAT-0.01 | 398,180 | 429,019 | 14.4 | 1.7 | 813 | 108 | 2.2 | 6.6 | 26.5
A-50-80-Bach-0.018 | 400,457 | 431,163 | 15.4 | 1.8 | 816 | 107 | 2.1 | 6.5 | 28.0
A-50-80-MPLCOm2012-0.01 | 401,856 | 432,251 | 16.8 | 2.0 | 804 | 104 | 2.1 | 6.4 | 29.8
A-55-80-20-25 | 404,596 | 434,892 | 17.8 | 2.1 | 765 | 94 | 1.9 | 6.3 | 31.9
A-55-80-Bach-0.017 | 406,323 | 437,409 | 15.3 | 1.8 | 822 | 109 | 2.2 | 6.6 | 28.0
A-50-80-MLCDRAT-0.01 | 409,804 | 441,216 | 14.7 | 1.7 | 827 | 108 | 2.2 | 6.5 | 28.2
A-50-80-20-15 | 419,030 | 449,947 | 18.5 | 2.2 | 750 | 84 | 1.7 | 6.0 | 38.6
A-50-80-Bach-0.017 | 420,352 | 452,129 | 15.8 | 1.8 | 837 | 108 | 2.2 | 6.4 | 30.1
A-55-80-Bach-0.016 | 423,929 | 455,993 | 15.6 | 1.8 | 840 | 110 | 2.2 | 6.6 | 29.2
A-55-80-MPLCOm2012-0.008 | 432,557 | 464,850 | 16.5 | 1.9 | 839 | 106 | 2.1 | 6.4 | 30.0
A-55-80-MLCDRAT-0.009 | 433,597 | 466,571 | 14.3 | 1.7 | 856 | 112 | 2.2 | 6.6 | 29.3
A-50-80-MPLCOm2012-0.009 | 437,273 | 469,612 | 17.4 | 2.0 | 841 | 105 | 2.1 | 6.3 | 32.3
A-50-80-Bach-0.016 | 441,294 | 474,232 | 16.1 | 1.9 | 860 | 110 | 2.2 | 6.5 | 31.6
A-55-80-Bach-0.015 | 442,384 | 475,479 | 15.9 | 1.9 | 860 | 111 | 2.2 | 6.5 | 30.4
A-50-80-MLCDRAT-0.009 | 449,030 | 482,762 | 14.7 | 1.7 | 872 | 111 | 2.2 | 6.5 | 31.4
A-55-80-Bach-0.014 | 461,609 | 495,768 | 16.1 | 1.9 | 880 | 112 | 2.2 | 6.5 | 31.8
A-50-80-Bach-0.015 | 463,301 | 497,449 | 16.5 | 1.9 | 882 | 110 | 2.2 | 6.4 | 33.3
A-50-80-20-20 | 463,457 | 496,698 | 19.9 | 2.3 | 804 | 89 | 1.8 | 6.0 | 40.6
A-55-80-MLCDRAT-0.008 | 474,060 | 509,474 | 14.2 | 1.7 | 902 | 114 | 2.3 | 6.5 | 31.5
A-50-80-MPLCOm2012-0.008 | 478,349 | 512,920 | 18.0 | 2.1 | 883 | 108 | 2.2 | 6.3 | 35.4
A-55-80-Bach-0.013 | 482,093 | 517,364 | 16.3 | 1.9 | 900 | 113 | 2.3 | 6.5 | 33.3
A-50-80-Bach-0.014 | 486,484 | 521,881 | 16.8 | 2.0 | 905 | 111 | 2.2 | 6.3 | 35.0
A-50-80-MLCDRAT-0.008 | 495,424 | 531,893 | 14.8 | 1.7 | 925 | 114 | 2.3 | 6.4 | 34.2
A-50-80-20-25 | 500,430 | 535,519 | 21.2 | 2.5 | 849 | 94 | 1.9 | 6.0 | 42.5
A-55-80-Bach-0.012 | 503,871 | 540,363 | 16.6 | 1.9 | 922 | 114 | 2.3 | 6.4 | 34.6
A-50-80-Bach-0.013 | 511,462 | 548,218 | 17.2 | 2.0 | 930 | 112 | 2.2 | 6.3 | 37.1
A-55-80-MLCDRAT-0.007 | 520,869 | 559,024 | 14.3 | 1.7 | 953 | 117 | 2.3 | 6.5 | 34.0
A-50-80-MPLCOm2012-0.007 | 524,392 | 561,495 | 18.6 | 2.1 | 928 | 110 | 2.2 | 6.3 | 38.6
A-55-80-Bach-0.011 | 527,263 | 565,051 | 16.8 | 2.0 | 946 | 115 | 2.3 | 6.4 | 36.0
A-50-80-Bach-0.012 | 538,488 | 576,709 | 17.6 | 2.0 | 957 | 113 | 2.3 | 6.3 | 39.1
A-50-80-MLCDRAT-0.007 | 550,777 | 590,414 | 15.1 | 1.8 | 984 | 117 | 2.3 | 6.3 | 37.6
A-55-80-Bach-0.01 | 551,762 | 590,917 | 17.1 | 2.0 | 970 | 116 | 2.3 | 6.4 | 37.5
A-50-80-Bach-0.011 | 568,005 | 607,834 | 18.0 | 2.1 | 985 | 115 | 2.3 | 6.3 | 41.1
A-50-80-MPLCOm2012-0.006 | 575,496 | 615,371 | 19.2 | 2.2 | 976 | 112 | 2.2 | 6.2 | 42.0
A-55-80-MLCDRAT-0.006 | 577,420 | 618,778 | 14.8 | 1.7 | 1,011 | 120 | 2.4 | 6.4 | 37.3
A-50-80-Bach-0.01 | 599,143 | 640,649 | 18.3 | 2.1 | 1,015 | 117 | 2.3 | 6.3 | 43.3

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100,000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

### USPSTF and USPSTF-Like Risk Model–Based Scenarios

As an example and to further understand the differences between risk factor–based and risk model–based screening strategies, Table 11 shows a comparison of the 2013 USPSTF-recommended screening eligibility criteria (A-55-80-30-15) with three risk model–based consensus-efficient scenarios with the same screening starting and stopping ages and frequency and that result in a similar number of LDCT screens as the 2013 USPSTF-recommended strategy: A-55-80-MPLCOm2012-0.018 (i.e., with a 1.8% MPLCOm2012 risk threshold), A-55-80-MLCDRAT-0.018 (i.e., with a 1.8% MLCDRAT risk threshold) and A-55-80-Bach-0.03 (i.e., with a 3.0% Bach risk threshold). The table shows that the percentage of eligible individuals is higher for the risk model–based screening strategies (17.0%, 18.6% and 19.0%) than for the 2013 USPSTF-recommended criteria (14.1%). In contrast, the corresponding number of screens per person screened is lower for the risk model–based strategies (13.5, 12.7, and 12.2, respectively, vs. 16.1). Together these result in 227,443 LDCT screens per 100,000 population for the 2013 USPSTF-recommended strategy vs. 228,676 and 236,483 and 231,518 for the risk model–based screening strategies, respectively.

Table 11 Comparison of the 2013 USPSTF-Recommended (A-55-80-30-15) and Risk Model–Based USPSTF-Like Scenarios

| A-55-80-30-15 | A-55-80-MPLCOm2012-0.018 | A-55-80-MLCDRAT-0.018 | A-55-80-Bach-0.03
% eligible | 14.1% | 17.0% | 18.6% | 19.0%
# LDCT screens^*^ | 227,443 | 228,676 | 236,483 | 231,518
Avg. # of LDCT screens per person screened | 16.1 | 13.5 | 12.7 | 12.2
Avg. age at first screen | 56.2 | 64.0 | 64.5 | 65.4
Avg. age at last screen | 71.3 | 76.5 | 76.5 | 76.8
Avg. age at screening | 65.1 | 69.6 | 70.1 | 70.3
LC deaths averted^*^ | 381 | 444 | 448 | 450
Mortality reduction | 9.8% | 11.5% | 11.5% | 11.6%
Difference in LC deaths averted vs. USPSTF strategy | NA | 16.5% | 17.6% | 18.1%
Avg. # screens per LC death averted | 597 | 515 | 528 | 514
LYG^*^ | 4,882 | 4,982 | 4,916 | 4,936
Difference in LYG vs. USPSTF strategy | NA | 2.0% | 0.7% | 1.1%
Avg. # screens per LYG | 47 | 46 | 48 | 47
NNS | 37 | 38 | 42 | 42
False-positive screens per person screened | 1.9 | 1.6 | 1.5 | 1.5
Biopsies | 518 | 591 | 604 | 604
Overdiagnosed cases^*^ | 69 | 89 | 92 | 93
Overdiagnosis rate per screen-detected cancers | 6.3% | 6.7% | 6.9% | 6.9%
Radiation-related lung cancer deaths^*^ | 20.6 | 15.8 | 15.6 | 15.5

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

The table shows that the ages of screening shift to older ages for the risk model–based screening strategies in comparison to the 2013 USPSTF-recommended criteria; the average ages at first screen for the risk model–based strategies are 64.0, 64.5, and 65.4 years vs. 56.2 years for the 2013 USPSTF-recommended criteria. Similarly, the average age of the last screen is 76.5 or 76.8 years for risk model–based screening strategies vs. 71.3 years for the 2013 USPSTF-recommended criteria. This results in the lower number of screens per person screened for the risk model–based screening strategies.

In terms of benefits, the risk model–based strategies led to a higher number of lung cancer deaths averted (MPLCOm2012: 444; MLCDRAT: 448; Bach: 450 vs. USPSTF: 381 deaths averted per 100,000) and lung cancer mortality reduction (MPLCOm2012: 11.5%; MLCDRAT: 11.5%; Bach: 11.6% vs. USPSTF: 9.8%). These figures correspond to a 16.5, 17.6, and 18.1 percent increase in lung cancer deaths averted by risk model–based strategies, respectively, compared with the 2013 USPSTF-recommended scenario and translate to an average number of screens per lung cancer death averted of 515 (MPLCOm2012), 528 (MLCDRAT), 514 (Bach), and 597 (USPSTF). With regard to LYG, risk model–based screening scenarios led to 2.0, 0.7, and 1.1 percent higher LYG than the 2013 USPSTF-recommended strategy, respectively (MPLCOm2012: 4,982; MLCDRAT: 4,916; and Bach: 4,936 vs. USPSTF: 4,882 LYG per 100,000). The average number of screens per LYG is about the same for all scenarios. Finally, the overdiagnosis rate per screen-detected lung cancer is slightly higher for the risk model–based screening scenarios (MPLCOm2012: 6.7%; MLCDRAT: 6.9%; and Bach: 6.9% vs. USPSTF: 6.3%). However, the number of radiation-related lung cancer deaths per 100,000 is lower for the risk model–based screening strategies (MPLCOm2012: 15.8; MLCDRAT: 15.6; and Bach: 15.5 vs. USPSTF: 20.6).

Lastly, Table 12 shows the percentage of individuals who would ever be eligible for screening or not by the 2013 USPSTF-recommended criteria and by each of the risk model–based screening criteria. In general, more individuals are eligible by the risk model–based criteria but not by the 2013 USPSTF-recommended criteria (MPLCOm2012: 3.9%, MLCDRAT: 5.8%, and Bach: 6.4%) than those eligible by the 2013 USPSTF-recommended criteria but not by the risk model–based criteria (MPLCOm2012: 1.1%, MLCDRAT: 1.3%, and Bach: 1.6%). For example, when considering the MPLCOm2012 criteria, 3.9 percent of individuals would be eligible but not by the 2013 USPSTF-recommended criteria, but only 1.1 percent would be eligible by the 2013 USPSTF-recommended criteria but not by the MPLCOm2012 criteria. When considering the MLCDRAT criteria, 5.8 percent of individuals would be eligible but not by the 2013 USPSTF-recommended criteria, but only 1.3 percent would be eligible by the 2013 USPSTF-recommended criteria but not by the MLCDRAT criteria. Similarly, for the Bach criteria, 6.4 percent of individuals would be eligible but not by the 2013 USPSTF-recommended criteria, but only 1.6 percent would be eligible by the 2013 USPSTF-recommended criteria but not by the Bach criteria.

Table 12 Cross-Screening Eligibility of the 2013 USPSTF-Recommended (A-55-80-30-15) and Risk Model–Based USPSTF-Like Scenarios

| vs. MPLCOm2012-0.018 | | vs. MLCDRAT-0.018 | | vs. Bach-0.03
| Noneligible | Eligible | Noneligible | Eligible | Noneligible | Eligible
2013 USPSTF Noneligible | 81.8% | 3.9% | 79.9% | 5.8% | 79.3% | 6.4%
2013 USPSTF Eligible | 1.1% | 13.2% | 1.3% | 13.0% | 1.6% | 12.7%

Abbreviations: MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Similar comparisons between the six selected 20 pack-year strategies and corresponding risk model–based strategies with the same age eligibility criteria and similar number of LDCT screens are presented in the Appendix C Tables 17 through 22.

## Sensitivity Analysis

### Consensus-Efficient Scenarios and DEA Using Single Metrics and Analyses for the 1950 Birth Cohort

#### Risk Factor–Based Screening Scenarios

We replicated the process to identify consensus-efficient scenarios (i.e., scenarios that have efficiency scores within the top 30% for 3 out of the 4 CISNET models) using single-outcome metrics: lung cancer deaths averted or LYG. We also replicated the risk factor–based DEA using the 1950 birth cohort. In general, the DEA with lung cancer deaths averted selected a larger number of scenarios than with LYG. For example, when considering the 1960 birth cohort, the DEA identified 80 consensus-efficient risk factor–based scenarios when using lung cancer deaths averted only, 50 when using LYG only, and 57 when using both metrics simultaneously (main results). When considering the 1950 birth cohort, the DEA identified 79 consensus-efficient risk factor–based scenarios when using lung cancer deaths averted only, 58 when using LYG only, and 69 when using both metrics simultaneously.

The general features of risk factor–based consensus-efficient strategies when using both outcome metrics simultaneously remain when using a single metric, independently of the birth cohort considered, but with some minor variations. A large majority of strategies have a stopping age of 80 years independently of the metric, and very few have age 45 years as a starting age. However, most consensus-efficient strategies when using lung cancer deaths averted have a starting age of 55 years (57.5%), while most have a starting age of 50 years when using LYG (64.0%). When using both outcomes, there are about an equal number of strategies starting at age 50 or 55 years. About 61 percent of strategies are biennial when using lung cancer deaths averted, increasing to about 68 percent when using LYG. In terms of minimum pack-years, 22.5 percent have 20 pack-years, 22.5 percent have 25 pack-years, 18.7 percent 30 pack-years, and 36.3 percent have 40 pack-years when using deaths averted. When using LYG, 28.0 percent have 20 pack-years, 24.0 percent have 25 pack-years, 10.0 percent have 30 pack-years, and 38.0 percent have 40 pack-years.

Appendix C Tables 23 and 24 show the benefits and harms of the consensus-efficient scenarios when considering both benefit metrics simultaneously for the 1950 birth cohort, restricted to those strategies leading to at least a 9 percent lung cancer mortality reduction and requiring fewer than 600,000 LDCT screens per 100,000 population (a total of 41 scenarios). In this case, the 2013 USPSTF-recommended scenario and the six selected 20 pack-year strategies, except A-55-80-20-15, are among the consensus-efficient scenarios. In general, the percentage of individuals eligible for screening is higher than when considering the 1960 birth cohort (corresponding results shown in Tables 6 and 7), resulting in higher benefits (lung cancer deaths averted and LYG) but also in higher harms (numbers of LDCT screens and followup LDCT scans, overdiagnosed cases, and LDCT radiation-related lung cancers deaths). For example, for the 1950 birth cohort under the 2013 USPSTF-recommended strategy, 20.8 percent would be eligible, resulting in 333,300 LDCT screens, a 12.2 percent mortality reduction, 7,956 LYG, 117 overdiagnosed cases, and 28.9 radiation-related lung cancer deaths. In contrast, for the 1960 birth cohort, the 2013 USPSTF-recommended strategy would screen 14.1 percent of the population, resulting in 227,443 LDCT screens, a 9.8 percent mortality reduction, 4,882 LYG, 69 overdiagnosed cases, and 20.6 radiation-related lung cancer deaths. The selected consensus-efficient scenarios show consistent patterns with those obtained when using the 1960 birth cohort. Specifically, most are annual (61.0%) and have age 80 years as a stopping age (87.8%, the rest have 77 years as a stopping age). However, likely due to cohort differences in smoking patterns and life expectancy, the distribution of minimum pack-years differs; when using the 1950 birth cohort, 19.5 percent have 20 pack-years, 31.7 percent have 25 pack-years, 36.6 percent have 30 pack-years, and 12.2 percent have 40 pack-years, whereas the large majority of consensus-efficient scenarios have 20 pack-years (52.0%) or 25 pack-years (36.0%) when using the 1960 birth cohort, and only 12.0 percent have 30 pack-years and none have 40 pack-years. In terms of outcomes, the consensus-efficient scenarios when using the 1950 birth cohort range from 14.6 to 31.8 percent eligible individuals, from 9.0 to 15.9 percent lung cancer mortality reduction, and the LYG from 5,891 to 10,785.

#### Risk Factor–Based and Risk Model–Based Screening Scenarios

We replicated the process to identify risk factor–based and risk model–based consensus-efficient scenarios using single-outcome metrics in the DEA for the 1960 birth cohort. As with risk factor–based strategies only, the DEA with lung cancer deaths averted selected a larger number of scenarios than with LYG. Specifically, the DEA identified 316 consensus-efficient risk factor–based and risk model–based scenarios when using lung cancer deaths averted only vs. 211 when using LYG only and 267 when using both metrics simultaneously (main analysis). The general features of risk factor–based and risk model–based consensus-efficient strategies when using both outcome metrics simultaneously remain when using a single metric. Most consensus-efficient scenarios are risk model–based strategies, although relatively more risk factor–based scenarios make it to the consensus-efficient list when using LYG (96.8% are risk model based when using lung cancer deaths averted, 87.7% when using LYG, and 93.3% when using both metrics), and most have age 80 years as a stopping age (78.5% with lung cancer deaths averted and 48.3% with LYG, 74.2% when using both metrics). In terms of the risk prediction model, when using lung cancer deaths averted, 29.4 percent of consensus-efficient strategies are based on the MPLCO2012 model, 29.1 percent on the MLCDRAT model, and 38.3 percent on the Bach model. When using LYG, 49.8 percent are based on the MPLCOm2012 model, 4.7 percent on the MLCDRAT model, and 33.2 percent on the Bach model.

#### The 2013 USPSTF-Recommended Strategy and the Selected 20 Pack-Year Strategies as Consensus Efficient

The 2013 USPSTF-recommended criterion is a consensus-efficient scenario when considering risk factor–based strategies only and using lung cancer deaths averted as a metric in the DEA for both the 1950 and the 1960 birth cohorts. This is consistent with the 2013 DA, whose DEA was based on lung cancer deaths averted in the 1950 birth cohort and identified this scenario as one of the top strategies.^36,^ ^44^ However, when considering LYG as the DEA metric, the 2013 USPSTF-recommended criterion is not identified as consensus efficient because it is not among the closest scenarios to the efficient frontier of at least three out of the four models (see Figure 2). When considering both metrics, the 2013 USPSTF-recommended strategy is identified as consensus efficient for the 1950 birth cohort but not for the 1960 birth cohort. In contrast, all six selected 20 pack-year strategies are consensus efficient for the 1950 birth cohort when using the lung cancer deaths averted metric only, two are so when considering LYG only, and all but one are consensus efficient when considering both metrics combined. All six selected 20 pack-year strategies are consensus efficient for the 1960 birth cohort when using either one of the metrics (lung cancer deaths averted or LYG) or combined. Finally, very few risk factor–based strategies are identified as consensus efficient when considering both risk factor–based and risk model–based strategies simultaneously. Most of these are in the lower end of the number of LDCT screens; thus, neither the 2013 USPSTF-recommended criterion nor the six selected 20 pack-year strategies are identified as consensus efficient in this case. Table 13 shows a summary of the DEA results and the inclusion or not of the 2013 USPSTF-recommended criterion and the six selected 20 pack-year strategies as consensus efficient.

Table 13 2013 USPSTF-Recommended Criteria (A-55-80-30-15) and Six Selected Risk Factor–Based Scenarios With 20 Pack-Year Criterion as Consensus Efficient

Group Analysis | LC Deaths Averted^*^ | LYG^*^ | LC Deaths Averted and LYG^*^
1950 Birth Cohort: Risk Factor–Based Strategies Only
Number of consensus-efficient scenarios | 79 | 58 | 69
2013 USPSTF criteria as consensus efficient | Yes | No | Yes
A-55-80-20-15 scenario as consensus efficient | Yes | No | No
A-55-80-20-20 scenario as consensus efficient | Yes | No | Yes
A-55-80-20-25 scenario as consensus efficient | Yes | No | Yes
A-50-80-20-15 scenario as consensus efficient | Yes | No | Yes
A-50-80-20-20 scenario as consensus efficient | Yes | Yes | Yes
A-50-80-20-25 scenario as consensus efficient | Yes | Yes | Yes
1960 Birth Cohort: Risk Factor–Based Strategies Only
Number of consensus-efficient scenarios | 80 | 50 | 57
2013 USPSTF criteria as consensus efficient | Yes | No | No
A-55-80-20-15 scenario as consensus efficient | Yes | Yes | Yes
A-55-80-20-20 scenario as consensus efficient | Yes | Yes | Yes
A-55-80-20-25 scenario as consensus efficient | Yes | Yes | Yes
A-50-80-20-15 scenario as consensus efficient | Yes | Yes | Yes
A-50-80-20-20 scenario as consensus efficient | Yes | Yes | Yes
A-50-80-20-25 scenario as consensus efficient | Yes | Yes | Yes
1960 Birth Cohort: Risk Factor–Based and Risk Model–Based Strategies
Number of consensus-efficient scenarios | 316 | 211 | 267
2013 USPSTF criteria as consensus efficient | No | No | No
A-55-80-20-15 scenario as consensus efficient | No | No | No
A-55-80-20-20 scenario as consensus efficient | No | No | No
A-55-80-20-25 scenario as consensus efficient | No | No | No
A-50-80-20-15 scenario as consensus efficient | No | No | No
A-50-80-20-20 scenario as consensus efficient | No | No | No
A-50-80-20-25 scenario as consensus efficient | No | No | No

* DEA metric.

Abbreviations: LC=lung cancer; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force.

### Life Expectancy Sensitivity Analysis

Appendix C Tables 25 through 26 show the benefits and harms of the selected consensus-efficient strategies when limiting screening to only those with more than 5 years of life expectancy under the assumption of perfect assessment of life expectancy. These tables show the benefits and harms of selected consensus-efficient strategies when considering risk factor–based strategies only, restricted to those strategies resulting in at least a 9 percent lung cancer mortality reduction and requiring fewer than 600,000 LDCT screens in the main analysis. Appendix C Tables 27 and 28 show the benefits and harms of selected consensus-efficient strategies when considering risk factor–based and risk model–based screening strategies jointly, restricted to those strategies resulting in at least a 9 percent lung cancer mortality reduction and requiring fewer than 600,000 LDCT screens in the main analysis.

The tables show that, in general, limiting screening to only those with more than 5 years of life expectancy, assuming a hypothetical perfect assessment of life expectancy, would not greatly affect the resulting benefits (lung cancer mortality reduction or LYG). In contrast, excluding individuals with less than 5 years of life expectancy from screening would result in fewer harms, particularly in considerably fewer overdiagnosed cases. This is particularly true for strategies screening at older ages. For example, for the 2013 USPSTF-recommended strategy, restricting screening to those with at least 5 years of life expectancy would reduce the percentage eligible by 3.5 percent, the total number of LDCT screens by 7.2 percent, the lung cancer mortality reduction by 4.5 percent, and the number of overdiagnosed cancers by 66.7 percent. In comparison, restricting screening to those with at least 5 years of life expectancy for the “USPSTF-like” risk model–based scenario A-55-80-MPLCOm2012-0.018 would reduce the percentage eligible by 5.3 percent, the total number of LDCT screens by 10.4 percent, the lung cancer mortality reduction by 5.0 percent, and the number of overdiagnosed cancers by 68.5 percent.