# Chapter 2 Methods

## Key Questions

The investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions (KQs). Three KQs were developed for this collaborative modeling study:

1. How do the benefits and harms of screening for lung cancer with LDCT vary by (a) age to start screening; (b) age to stop screening; (c) pack-year criterion (d) years since quitting smoking; and (e) screening frequency when using screening, workup, and management protocols that are being implemented in current clinical practice?
2. What are the expected population effects of screening for lung cancer with LDCT for older vs. more recent birth cohorts of the U.S. population?
3. What are the relative benefits and harms of lung cancer screening strategies with eligibility based on individual lung cancer risk (risk model–based) vs. strategies with eligibility based on age, pack-years, and years since quitting smoking (risk factor–based)?

## Lung Cancer Natural History Models

The DA was conducted by investigators of the Cancer Intervention and Surveillance Modeling Network (CISNET) Lung Group. Four CISNET lung cancer screening simulation models from different institutions were used for the analysis: the Microsimulation Screening Analysis (MISCAN)-Lung Model from Erasmus University Medical Center (Model 1), Massachusetts General Hospital–Harvard Medical School (MGH-HMS, Model 2), the Lung Cancer Outcomes Simulation (LCOS) from Stanford University (Model 3), and University of Michigan (Model 4). All of these models were part of the previous lung cancer screening DA conducted for the USPSTF.^3,^ ^36,^ ^41^

### Overview of Decision Models

CISNET’s comparative modeling approach uses multiple decision models to address common research questions. Because the models differ in terms of parameters, assumptions, model structure, and approach, comparison of results across models serves as a gauge of model specification uncertainty. Similarity of results provides greater confidence in the conclusions, whereas variation can indicate areas where more information is needed.

Although the models share common inputs, each modeling team developed its own model based on mathematical descriptions of lung cancer risk as it relates to smoking behaviors. The models explicitly consider individual factors associated with the risk of lung cancer, including the number of cigarettes smoked per day at any given age, the age of smoking initiation, duration of smoking, and the number of years since quitting.

Table 1 shows a comparison of the model characteristics. All models share the same overall structure. The central component of each model is a dose-response module that provides a quantitative description of the age-specific lung cancer incidence and mortality by detailed history of smoking. This module is used to predict age- and sex-specific lung cancer incidence and mortality risk as a function of individual smoking histories.

Table 1 Characteristics of the Four CISNET Lung Group Models Used in the Collaborative Modeling

Model Components | Erasmus-MISCAN; Model 1 | MGH-HMS; Model 2 | Stanford-LCOS; Model 3 | University of Michigan; Model 4
Type of smoking dose-response model | 2-stage clonal expansion model | Probabilistic by histology | 2-stage clonal expansion model | 2-stage clonal expansion model
Datasets used for dose-response parameter calibration | NHS/HPFS, SEER, NLST, PLCO by sex | SEER, NLST, PLCO by sex | NHS/HPFS, U.S. mortality by sex | NHS/HPFS, U.S. mortality by sex
Histological types | Adenocarcinoma+BAC+ large cell, squamous, SCLC, ONSCLC; Distribution of histologies differs by sex | Adenocarcinoma, AIS, large cell, squamous, SCLC, and other | Adenocarcinoma, large cell, squamous, SCLC, BAC; Distribution of histologies differs by sex | Adenocarcinoma+BAC, squamous, SCLC, other as a function of sex, smoking status, cigarettes per day, smoking duration, and years since quitting
Lung cancer stages | IA, IB, II, IIIA, IIIB, IV | IA1, IA2, IB, II, IIIA, IIIB, IV | Early (I-II), advanced (III-IV) | IA, IB, II, IIIA, IIIB, IV
Stage progression | Markov state-transition by histology and sex | Based on tumor volume and metastatic burden | Based on tumor volume and metastatic burden | Markov state-transition by histology and sex
Lung cancer survival | By sex, histology, and stage; based on SEER 18 2004–2010 | Calibrated to SEER 18 2004–2013 survival | Based on SEER 17 1988–2003 survival differentiated by sex | By sex, histology, stage, and age at diagnosis; based on SEER 18 2005–2012
Other-cause mortality | U.S. rates (NCI Smoking History Generator) by sex | Cox model of OC mortality calibrated to NLST/PLCO | Gompertz model of OC mortality based on NLST calibrated model by sex | Gompertz model of OC mortality calibrated to each trial by sex
Screening sensitivity model | By stage and histology | By size (mm) and location in lung (central/peripheral) | By size (mm), histology, and sex | By stage, histology and sex
Screening effectiveness | Cure model^*^ | Stage-shift model^†^ | Cure model^*^ | Stage-shift model^†^
Positive nodule followup algorithm | Implicit based on the NLST | Explicitly modeled using Fleischner and Lung-RADS guidelines; lung cancers diagnosed on followup are categorized as “non-screened-detected” | Explicit model of Lung-RADS guidelines | Implicit based on Lung-RADS

* The benefit of screening is based on a stage-specific cure rate.

† The benefit of screening is based on an earlier stage at detection relative to clinical detection.

Abbreviations: AIS=adenocarcinoma in situ; BAC=bronchioloalveolar carcinoma; CISNET=Cancer Intervention and Surveillance Modeling Network; LCOS=Lung Cancer Outcomes Simulator; Lung-RADS=Lung Imaging Reporting and Data System; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; MISCAN=Microsimulation Screening Analysis; NCI=National Cancer Institute; NHS/HPFS=Nurses’ Health Study/Health Professionals’ Followup Study; NLST=National Lung Screening Trial; OC=other-cause; ONSCLC=other non-small cell lung cancers; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCLC=small-cell lung cancer; SEER=Surveillance, Epidemiology, and End Results.

The models can be used to simulate the natural history of lung cancer given an individual’s sex, birth year, and smoking history. A key component to all models is the Smoking History Generator (SHG), a microsimulator developed by the CISNET Lung Group that generates detailed individual smoking histories for the U.S. population.^2,^ ^42,^ ^43^ These smoking histories serve as the main inputs for the model simulations. Multiple data sources, including the National Health Interview Survey, the Cancer Prevention Studies I and II, and the Human Mortality Database, were used to construct the input parameters for the SHG: rates of smoking initiation; cessation; cigarettes per day consumption; and other causes or all causes of death by age, birth cohort, sex, smoking status, smoking intensity, and years since quit. The SHG was used to simulate smoking and life histories of individuals from the 1950 and 1960 U.S. birth cohorts, which the four models used as inputs.

Each model can simulate the effects of lung cancer screening given an individual’s smoking and lung cancer natural history. The models were calibrated to both the NLST and the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial to produce outcomes that are consistent with both trials.^41^ Specifically, the models were shown to reproduce the observed annual lung cancer incidence and mortality by arm and mode of detection (screening and otherwise) in both trials, the histology and stage distributions, and the estimated benefit of three rounds of LDCT screening in NLST. Three of the models were updated to reflect current practice and nodule evaluation and management according to the Lung-RADS guidelines, modeling the Lung-RADS protocols explicitly or indirectly via the associated rates of false-positive tests (Table 1 and appendix) and adjusting the models to reflect the expected reduction in sensitivity relative to NLST.^8^ The other model uses false-positive tests, sensitivities, and screening result rates based fully on the NLST, allowing for comparison of alternative protocols and assumptions.

The models and the SHG were used to simulate the effect of different lung cancer screening scenarios for the U.S. population. Simulated outcomes included the number and percentage of persons screened given an eligibility criterion, number of lung cancer cases and deaths, number of other-cause deaths, life-years gained (LYG) relative to a no-screening scenario, number of false-positive screens, number of biopsies, overdiagnosed cases, and radiation-related lung cancer deaths. Details for each of the four models are provided in Appendix A.

## Screening Strategies

### Risk Factor–Based Strategies

The DA assessed the relative benefits and harms of alternative LDCT screening strategies. The analysis focused first on strategies using eligibility criteria similar to the prior USPSTF recommendation from 2013, which determines screening eligibility as a function of age and smoking exposure (i.e., scenarios where eligibility assessment is based on age range, pack-years, and years since quitting, henceforth called risk factor–based strategies). This primary analysis also assessed the relative performance of annual vs. biennial screening frequency. Table 2 summarizes the LDCT screening attributes and values considered in the primary risk factor–based strategies DA. A total of 289 scenarios were considered, including a no-screening scenario as reference.

Table 2 Risk Factor–Based Eligibility Screening Strategies

Screening/Modeling Parameter | Values/Ranges | Number of Options
Eligibility starting age | 45, 50, 55 | 3
Eligibility stopping age | 75, 77, 80 | 3
Screening frequency | annual, biennial | 2
Minimum pack-years criterion | 20, 25, 30, 40 | 4
Maximum years since quitting | 10, 15, 20, 25 | 4
Followup protocol | Lung-RADS or NLST | 1
Birth cohort | 1950, 1960 | 2
Horizon | Lifetime
Total # of strategies per cohort^*^ | 289

* Reference scenario: No screening.

† Models 2, 3 and 4 use Lung-RADS protocol/rates while Model 1 uses NLST protocol/rates.

Abbreviation: Lung-RADS=Lung Imaging Reporting and Data System.

We used the four CISNET natural history models to project the benefits and harms of each strategy in the U.S. 1950 and 1960 birth cohorts. We selected these birth cohorts because they are now in the middle of their screening eligibility according to current guidelines (70 years old for 1950 and 60 years old for 1960) and are representative of different moments of the tobacco epidemic (higher smoking prevalence and average smoking intensity for the 1950 birth cohort vs. decreased smoking prevalence and lower average smoking intensity for the 1960 birth cohort) and for comparability with the 2013 DA, which focused on the 1950 birth cohort.^36,^ ^44^ Strategies also varied by starting age (45, 50, 55 years), stopping age (75, 77, 80 years), frequency (annual, biennial), minimum pack-years (20, 25, 30, 40 years), and maximum years since quitting smoking (10, 15, 20, 25 years).

### Risk Model–Based Strategies

The DA also evaluated the potential population impacts of selected lung screening scenarios with eligibility criteria based on multivariate risk models that use smoking duration and intensity, sex, and age to estimate lung cancer risk (i.e., strategies where risk assessment is based on a multivariate model considering age, smoking, and sex information, henceforth called risk model–based screening strategies). For these scenarios, we focused on 6-year lung cancer risk (probability of lung cancer incidence or mortality within the next 6 years) because this was the duration of followup in the NLST trial, and one of the multivariate risk models considered has a fixed 6-year risk prediction horizon. The lung cancer risk calculation for screening eligibility considered an individual’s age, sex, and more detailed smoking history than risk factor–based strategies (i.e., smoking duration, smoking intensity, years since cessation). This “unpacking” of pack-years into its components has been shown to be important because each metric has independent predictive value, and collapsing these into a single measure of cumulative exposure, such as pack-years, potentially reduces the precision to determine those most likely to be diagnosed with or die from lung cancer.^27,^ ^45,^ ^46^ No other established risk factors for lung cancer, such as race/ethnicity, COPD, or individual and family history of lung cancer, were considered in this collaborative modeling DA. This is because it would require the joint simulation of these risk factors with smoking, sex, and age at the population level and the availability of well-calibrated and validated lung cancer natural history models incorporating all covariates. For each simulated individual, the assessment of eligibility was performed annually (or every other year for biennial strategies), from the starting age of eligibility until the stopping age or death.

Three lung cancer risk prediction models were considered to generate individual eligibility based on lung cancer risk: 1) a modified PLCOm2012 model (MPLCOm2012), 2) a modified version of the Lung Cancer Death Risk Assessment Tool (LCDRAT) model (MLCDRAT), and 3) the Bach model. The MPLCOm2012 model is a simplified version of the 6-year lung cancer incidence risk PLCOm2012^25,^ ^27,^ ^29^ model restricted to age and smoking covariates (i.e., setting race/ethnicity, education, body mass index, COPD, personal history of cancer, and family history of lung cancer, which are in the full model, at its reference value). The MPLCOm2012 has an area under the curve (AUC) of 0.784 in the PLCO control arm compared with an AUC of 0.795 for the full model.^29^ Analogously, the MLCDRAT model is a simplified version of the LCDRAT lung cancer mortality model restricted to age, sex, and smoking covariates (i.e., excluding race/ethnicity, education, COPD, and family history of lung cancer, which are in the full model).^47^ The model’s developer, Dr. Hormuzd Katki of the National Cancer Institute, provided the model to the DA team. The MLCDRAT model has an AUC of 0.78 in the PLCO control arm. We used the model to compute 6-year lung cancer mortality risk. The Bach model,^48^ which predicts 1-year lung cancer incidence risk, was used as published but compounded to produce a 6-year incidence risk estimate. This model considers age, sex, smoking covariates, and occupational asbestos exposure. We used the model assuming no asbestos exposure (i.e., set asbestos exposure=0 in the model) because this is how it has been recently validated.^29,^ ^47^ The Bach model, with asbestos set to 0, has an AUC of 0.78 in the PLCO control arm.^29^

These three risk prediction models were selected based on two independent analyses of the performance of several risk prediction models in identifying lung cancer incidence and mortality cases in the PLCO and NLST trials and other U.S. cohorts,^29,^ ^47^ their practicality and ease of implementation, and their use as risk prediction models in current lung screening recommendations/implementations.^49^ Of the risk prediction models evaluated in ten Haaf et al,^29^ the PLCOm2012, Bach, and Two-Stage Clonal Expansion (TSCE) models outperformed other risk prediction models. However, the TSCE model is less straightforward to implement and is used as a dose-response model in some of the CISNET lung cancer natural history models. Hence, we did not use the TSCE model to determine screening eligibility in our risk model–based screening analyses. A recent analysis by Katki et al^47^ demonstrated that the Lung Cancer Risk Assessment Tool (LCRAT) (a model that predicts lung cancer incidence) and the LCDRAT (a model that predicts lung cancer mortality) models have similar performance to the PLCOm2012 and Bach models; thus, we included the LCDRAT lung cancer mortality model to complement the two incidence models. It is worth noting, however, that currently the incidence risk prediction models are effective in identifying individuals at high risk for both lung cancer incidence and lung cancer mortality (Figures 2 through 5 in ten Haaf et al.^29^).

Figure 1 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting smoking (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. Figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 800 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. For all four models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. The 2013 USPSTF-recommended strategy is among the most efficient for 3 out of the 4 models (Models 1, 3 and 4).

Figure 2 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting smoking (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. Figure 2 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 10,000 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. For all four models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. The 2013 USPSTF-recommended strategy is among the most efficient for one of the four models (Model 1).

Figure 3 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort

Note: Risk factor–based screening scenarios (n=288) are represented with triangle points and risk model–based screening scenarios (n=804) with round points. The line represents the estimated overall efficient frontier per model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting smoking (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. Figure 3 shows the simulated number of LDCT screens and the lung cancer deaths averted per 100,000 for all risk factor–based and risk model–based screening strategies for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and by type of eligibility criteria (risk factor–based or risk model–based). Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 1,100 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. The figure shows that across all CISNET models, risk model–based strategies result in larger numbers of lung cancer deaths averted for a given number of LDCT screens than risk factor–based strategies. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. Like other risk factor–based strategies, the 2013 USPSTF-recommended strategy is not among the most efficient for any of the four CISNET models presented.

Figure 4 Number of LDCT Screening Examinations vs. the LYG in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort

Note: Risk factor–based screening scenarios (n=288) are represented with triangle points and risk model–based screening scenarios (n=804) with round points. The line represents the estimated overall efficient frontier per model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting smoking (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force.

Number of LDCT Screening Examinations vs. the Life Years Gained in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. Figure 4 shows the simulated number of LDCT screens and the life years gained per 100,000 for all risk factor–based and risk model–based screening strategies for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and by type of eligibility criteria (risk factor–based or risk model–based). Number of LDCTs range from 0 to 800,000. Life years gained range from 0 to 12,500 per 100,000. The most efficient strategies are those resulting in the most life years gained for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. The figure shows that across all CISNET models, risk model–based strategies tend to result in slightly larger numbers of life years gained for a given number of LDCT screens than risk factor–based strategies. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. Like other risk factor–based strategies, the 2013 USPSTF-recommended strategy is not among the most efficient for any of the four CISNET models presented.

Figure 5 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort

Note: Each point represents a different scenario, and the curve represents the estimated efficient frontier for the average model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting smoking (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot), the 2013 USPSTF-recommended (“⊗” mark), and six selected consensus-efficient 20 pack-year scenarios are highlighted. The panels show all 288 risk factor–based strategies but highlight (solid color points) those identified as consensus efficient (listed in Appendix C Tables 3 and 4). The horizontal line divides strategies with less than or at least a 9 percent lung cancer mortality reduction. The shaded region includes those scenarios with at least a 9 percent lung cancer mortality reduction (listed in Tables 6 and 7).

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panels) and LYG (Right Panels) in Risk Factor–Based Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort. Figure 5 shows the average, across the four CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left panel) and LYG (right panel) for all risk factor–based strategies, highlighting the consensus-efficient scenarios. The consensus-efficient scenarios are those resulting in the most lung cancer deaths averted or life years gained for a given level of LDCT screens. Annual and biennial strategies are also highlighted. Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 600 per 100,000 and life years gained from 0 to 8,000. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of each panel, whereas annual consensus-efficient scenarios are located on the upper right side of each panel. The 2013 USPSTF-recommended scenario, and six selected consensus-efficient 20 pack-year annual strategies are highlighted. These are all consensus-efficient, thus result in the most lung cancer deaths averted for their corresponding level of screening.

The evaluated risk model–based screening strategies varied then by risk prediction model (Bach, MLCDRAT, MPLCOm2012), model-specific risk threshold (i.e., the minimum level of risk required for eligibility), and lower (50, 55 years) and upper (75, 77, 80 years) age limits. We considered age limits of eligibility for two reasons: 1) to limit the extrapolation of the risk calculation to younger ages because the risk models were developed using data restricted to ages equal to or older than 50 (Bach) or 55 years (MPLCOm2012 and MLCDRAT) and 2) to avoid having people getting screened in the simulation during their 90s, more than 10 years beyond the age range for which LDCT screening has been evaluated and because of the shorter life expectancy at those ages. Model-specific risk thresholds (Table 3) were determined based on a previous analysis that identified threshold ranges per risk model resulting in similar percentages of screen-eligible people in the 1960 birth cohort as in the risk factor–based strategies considered in the DA.^30^ Previous simulation analyses of the performance of the PLCOm2012 and Bach models to identify individuals at high risk of lung cancer in the PLCO and NLST trials suggest that using thresholds within these ranges would yield a positive net benefit from risk model–based screening relative to the NLST criteria.^29^ For each risk model, we evaluated risk thresholds within the model-specific ranges at 0.1 percent increments. Table 3 shows a summary of the resulting 804 risk model–based screening strategies evaluated. To limit the scenarios and comparisons in the risk model–based screening analysis, we focused only on the 1960 birth cohort, which, as mentioned above, is now at the beginning of its eligibility and more representative of current smoking patterns in the United States.

Table 3 Risk Model–Based Eligibility Screening Strategies (1960 Birth Cohort)

Parameter | Values | Number of Options
Risk model | MPLCOm2012, MLCDRAT, Bach | 3
MPLCOm2012 risk model thresholds * | 0.4%, 0.5%, 0.6%, 0.7%, 0.8%, 0.9%, 1.0%, 1.1%, 1.2%, 1.3%, 1.4%, 1.5%, 1.6%, 1.7%, 1.8%, 1.9%, 2.0%, 2.1%, 2.2%, 2.3% | 20
MLCDRAT risk model thresholds * | 0.4%, 0.5%, 0.6%, 0.7%, 0.8%, 0.9%, 1.0%, 1.1%, 1.2%, 1.3%, 1.4%,1.5%, 1.6%, 1.7%, 1.8%, 1.9 %, 2.0%, 2.1%, 2.2%, 2.3% | 20
Bach risk model thresholds * | 0.8%, 0.9%, 1.0%, 1.1%, 1.2%, 1.3%, 1.4%, 1.5%, 1.6%, 1.7%, 1.8%, 1.9%, 2.0%, 2.1%, 2.2%, 2.3%, 2.4%, 2.5%, 2.6%, 2.7%, 2.8%, 2.9%, 3.0%, 3.1 %, 3.2%, 3.3%, 3.4% | 27
Screening frequency | annual, biennial | 2
Lower age limit | 50, 55 | 2
Upper age limit | 75,77, 80 | 3
Birth cohort | 1960 | 1
Total # of strategies | 804

* Because the risk models produce different absolute risks, we considered a range of model-specific risk thresholds based on sensitivity in the PLCO control arm and the percentage eligible for screening under each threshold in the 1960 birth cohort.

Abbreviations: MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; PLCO=Prostate, Lung, Colorectal, and Ovarian.

## Scenario Simulation and Analysis

We used the SHG to simulate individual smoking and life histories of 1 million men and 1 million women from the U.S. 1950 and the 1960 birth cohorts from ages 45 to 90 years or death. The simulated individual histories were used as input by all four CISNET simulation models. Models then simulated the lung cancer screening outcomes for each individual under the different screening scenarios described above. All simulations were performed assuming that all screen-eligible individuals would choose to undergo lung cancer screening and would also adhere to ongoing screening (annual or biennial) for the duration of their screening eligibility. Smoking cessation and the risk of competing causes of disease and death were assumed to be unaffected by screening results.

## Outcomes

Each model aggregated individual simulation results into counts of screening examinations and health outcomes separately for men and women. Most measures are reported as “per person in the population” rather than “per person screened” because programs defining eligibility based on smoking history may screen similar proportions of the population but screen dissimilar people, even for identical starting and stopping ages. False-positive screens, however, are reported as “per person screened.”

Table 4 lists the specific outcomes evaluated for each screening scenario by each model. These outcomes include measures of benefit such as lung cancer deaths averted, lung cancer mortality reduction and LYG vs. no-screening scenario, and measures of harm or burden such as the percentage of individuals eligible for screening, the number of LDCT screens and followup scans, the false-positive rates, biopsies following positive screens, and the rate of cancer overdiagnosis. Two models (Models 2 and 4) were used to estimate radiation-related lung cancer deaths.

Table 4 Modeled Outcomes

Outcomes per Screening Scenario | Value
Eligible persons | Number per 100,000 and percentage
LDCT screens and followup scans | Number per 100,000
False-positive screens | Per person screened
Biopsies^*^ | Number per 100,000
Lung cancer incidence | Cases and rate per 100,000
Lung cancer mortality | Deaths, deaths averted and rate per 100,000
LYG vs. no screening | Per 100,000
Overdiagnosed cases | Number per 100,000 and percentage per screen detected cancers
Radiation-related lung cancer deaths^†^ | Number per 100,000

* Based on the number of screen-detected lung cancers and false-positive LDCT screens.

† Only two models (Models 2 and 4) estimate radiation-related lung cancer deaths. For this reason, these are reported as a separate column and not included in the average lung cancer deaths and deaths averted counts in the result tables.

Abbreviations: LDCT=low-dose computed tomography; LYG=life-years gained.

We represented the trade-off between maximizing the benefits (here, lung cancer deaths averted, or LYG) due to a specific screening program and simultaneously minimizing the corresponding burden or harms (here, number of screening exams under each program) by plotting benefit vs. burden for each scenario and generating a corresponding “efficient frontier.” The efficient frontier is the line connecting the strategies that provide the largest benefit (lung cancer deaths averted or LYG) for a given number of LDCT screens. We used LDCT screens as the burden or harms metric because it is independent of other assumptions and it is measured consistently across models. However, we calculated additional measures of harm for each scenario as described above. Each model generated efficient frontiers that connected the screening programs that prevented the most lung cancer deaths or generated the most LYG for each possible value of the number of LDCT screens. Separate efficient frontiers by model were generated for both benefit measures (lung cancer deaths averted and LYG) by sex and both sexes combined and for each birth cohort (1950 and 1960).

## Selection of Consensus-Efficient Scenarios

To identify efficient scenarios providing the most lung cancer deaths averted and/or LYG for a given level of screening (measured here as the number of LDCT screens per 100,000 population), we conducted a data envelopment analysis (DEA).^36,^ ^41,^ ^50^ The DEA allows for identification of efficient scenarios accounting for a harms or burden metric (here, the number of LDCT screens) and one or several gain or benefits metrics (here, the number of lung cancer deaths averted, LYG, or both metrics simultaneously). In simple terms, for a single-benefit DEA, the approach finds programs that are near the efficient frontier of LDCT screens vs. lung cancer deaths averted or LDCT screens vs. LYG. For a two-benefit DEA, the method identifies strategies that are near the two-dimensional efficiency curve defined by the outer envelope of lung cancer deaths averted per number of LDCT screens vs. LYG per number of LDCT screens. We conducted independent DEAs for each CISNET model to identify model-specific efficient scenarios and then selected those that were efficient for at least three of the four models. This approach ensured an equal weighting of the CISNET models, preventing us from giving preference to models with higher levels of predicted benefits in the identification of efficient scenarios. Specifically, for each model’s results, using the DEA we generated a rank score (decile of distance from the model’s efficient frontier [or curve] for each scenario not on the frontier [or curve]). We then identified scenarios on (score 0) or closest to (first 3 deciles) the frontier of at least three CISNET models (i.e., scenarios that have efficiency scores within the top 30% for at least 3 out of the 4 models).

We performed three separate DEAs, using either lung cancer deaths averted alone, LYG alone, or both benefit metrics simultaneously (i.e., a 2-outcome metric). Main DEAs were based on the two-outcome metric with the single-metric DEAs used as sensitivity analyses.

For each consensus-efficient program, we aggregated sex-specific results to derive average (across the 4 CISNET models) predicted counts of lung cancer cases, lung cancer deaths, life years, and screening LDCT exams performed and other outcomes. We calculated the percentage of the cohort receiving at least one screening exam and the number of persons ever screened per lung cancer death averted (number needed to screen, NNS). We provide results per 100,000 individuals alive at age 45 years. As mentioned above, because the proportion and characteristics of screen-eligible individuals vary by scenario and birth cohort, the results were calculated “per 100,000 population” (including both screened and unscreened individuals) rather than “per screened population” so that outcomes are comparable across scenarios.

## Sensitivity Analyses

In addition to the KQs above, additional sensitivity analyses assessed the effectiveness of different LDCT screening strategies for the effect of limiting screening to only those with more than 5 years of life expectancy assuming a perfect assessment of life expectancy. Life expectancy here is not considered an eligibility criterion. Instead, it is used as a way to operationalize in the simulation the fact that persons with significant comorbidities and short life expectancy would not be recommended for screening because they would not be eligible for curative treatment (e.g., lung resection). Table 5 summarizes the sensitivity analyses.

Table 5 Parameters Varied in Main Sensitivity Analyses^*^

Sensitivity Analyses | Description
Life expectancy | Evaluate the impact of limiting screening to only those with more than 5 years of life expectancy (assuming a perfect assessment of life expectancy)
DEA metric | Lung cancer deaths averted, LYG

* Restricted to scenarios of interest identified in the primary DAs.

Abbreviations: DA=decision analysis; DEA=data envelope analysis; LYG=life-years gained.