# Chapter 1 Introduction

Lung cancer remains the most common cause of cancer mortality in the United States, despite the considerable decrease in smoking and the resulting decrease in smoking-related lung cancer incidence and mortality.^1,^ ^2^ In an effort to further reduce the burden of lung cancer in the United States, in 2013 the U.S. Preventive Services Task Force (USPSTF) recommended annual screening for lung cancer with low-dose computed tomography (LDCT) in adults ages 55 through 80 years who have at least a 30 pack-year smoking history and currently smoke or have quit within the past 15 years.^3^ The recommendations further stated that screening should be discontinued once a person has not smoked for 15 years or develops a health condition that substantially limits life expectancy or the ability or willingness to have curative lung surgery (Grade: B recommendation).

Important questions remain regarding the benefits and harms of lung cancer screening, particularly as it is being implemented in clinical practice in the United States. The 2013 USPSTF lung cancer screening recommendations were largely based on the results of the National Lung Screening Trial (NLST),^4–6^ which found a 16 to 20 percent lung cancer mortality relative reduction for LDCT screening vs. screening with chest radiographs. Since then, lung cancer screening programs have been established across the United States, and new clinical guidelines have emerged for classifying and managing screen-detected pulmonary nodules, updating the protocols used in NLST. In particular, the American College of Radiology released the Lung Imaging Reporting and Data System (Lung-RADS™) with the goal of improving the interpretation of screening results, reducing the rate of false-positive findings, and supporting the uniform implementation of lung cancer screening across the United States.^7,^ ^8^ In addition, other randomized trials, including the Dutch–Belgian lung-cancer screening trial (NELSON) that showed a 24 percent lung cancer mortality relative reduction in men at 10 years after four rounds of LDCT screening vs. a no screening arm,^9^ reported their findings.^9,^ ^10^ Nonetheless, early reports of lung cancer screening practices in different health systems have suggested that the implementation of screening with LDCT has been far from optimal. These reports have found that few eligible persons have accessed or opted for screening, while some ineligible persons with less smoking exposure than required by current guidelines and some with severe comorbidities are being screened.^11–19^

Most current LDCT screening recommendations are based on age, cumulative smoking exposure (30 pack-years), and years since quitting smoking alone and do not consider additional risk factors. However, some population groups, such as African American men or those with a family history of lung cancer, might be at high risk of lung cancer even when not meeting the 30 pack-year or other criteria.^20–22^ It has been suggested that less than 45 percent of patients with lung cancer would meet the USPSTF screening eligibility criteria.^23^ For these reasons, proposed alternatives are to reduce the minimum pack-year criterion or to use multivariate risk prediction models to select eligible individuals based on their estimated individual probability of being diagnosed with or dying from lung cancer.^24–27^ In fact, the most recent National Comprehensive Cancer Network lung cancer screening guidelines recommend screening also for persons older than 50 years with 20 pack-years or more of smoking exposure who have additional risk factors (such as chronic obstructive pulmonary disease [COPD] or family history of lung cancer) that would increase their probability of getting lung cancer within the next 6 years (i.e., 6-year lung cancer risk) to 1.3 percent or higher according to the PLCOm2012 multivariate lung cancer risk model (level 2 recommendation, category 2a).^27^ These recommendations are largely based on expert opinion, given the scarcity of studies evaluating the efficacy of screening strategies based on risk; however, evidence is starting to emerge on the potential benefits and challenges of implementing programs based on risk calculation.^25–30^ Nonetheless, although much attention has been focused on evaluating the use of risk assessment to maximize the efficiency of screening, less attention has been paid to quantifying the potential resulting harms related to screening patients with comorbidities and short life expectancy who also tend to be those at the highest levels of lung cancer risk.^31–35^

This report describes a collaborative simulation modeling study or decision analysis (DA) performed for the USPSTF. The USPSTF will use this analysis to inform its updated lung cancer screening recommendations. Recognizing that simulation models provide a way to extrapolate available evidence and predict long-term outcomes,^36–39^ the USPSTF commissioned this simulation modeling effort to assess the benefits and harms of various approaches to screening with LDCT. This analysis accompanies the corresponding systematic review to update the evidence on the benefits and harms of lung cancer screening.^40^

The collaborative modeling study provides an assessment of the potential benefits and harms of lung cancer screening at the population level reflecting current U.S. nodule management and followup guidelines (i.e., using Lung-RADS). The analysis evaluates the impact of screening on the lung cancer outcomes for two U.S. birth cohorts, 1950 and 1960, which are representative of the target population. In addition, this analysis, together with the systematic evidence review, provides an evaluation of screening strategies based on individual lung cancer risk (probability of incidence or death within a given period) and evaluates how strategies based on risk prediction models, termed risk model–based strategies, compare with strategies based on age, cumulative smoking exposure (pack-years), and years since quitting smoking, termed risk factor–based strategies.