# Appendix C Supplemental Tables

Appendix C Table 1 Benefits of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Average and Range Across CISNET Models.

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC Deaths Averted | NNS
B-55-80-20-20 | 22; (21.6, 22.4) | 189,587; (187,469, 193,002) | 1,134; (350, 1,634) | 9; (4.8, 14.1) | 348; (177, 516) | 4,490; (2,649, 6,032) | 12.9; (11.7, 14.9) | 42; (31, 72) | 545; (365, 1,068) | 63; (42, 123)
B-55-80-20-25 | 22.7; (22.2, 23.1) | 207,010; (204,167, 210,769) | 1,189; (370, 1,722) | 9.5; (5.1, 14.7) | 366; (188, 536) | 4,701; (2,829, 6,222) | 12.8; (11.6, 15) | 44; (33, 73) | 566; (383, 1,092) | 62; (42, 119)
B-50-80-25-25 | 19; (18.6, 19.4) | 208,753; (205,300, 212,339) | 1,169; (324, 1,701) | 9.4; (5.1, 14.5) | 363; (189, 529) | 4,859; (3,009, 6,362) | 13.4; (12, 15.9) | 43; (32, 69) | 575; (391, 1,086) | 52; (36, 98)
A-55-80-30-15 | 14.1; (13.8, 14.4) | 227,443; (225,768, 230,480) | 1,102; (258, 1,454) | 9.8; (5.1, 16) | 381; (188, 584) | 4,882; (2,788, 6,899) | 12.8; (11.8, 14.8) | 47; (33, 82) | 597; (387, 1,207) | 37; (24, 73)
A-55-80-25-10 | 16; (15.7, 16.3) | 234,030; (231,840, 237,539) | 1,131; (280, 1,490) | 10.1; (5.3, 16.4) | 392; (196, 600) | 4,969; (2,836, 7,039) | 12.7; (11.7, 14.5) | 47; (33, 83) | 597; (390, 1,194) | 41; (27, 80)
B-50-80-20-20 | 23.3; (22.8, 23.8) | 239,223; (235,387, 243,378) | 1,226; (366, 1,770) | 9.9; (5.7, 15.3) | 384; (211, 559) | 5,194; (3,390, 6,814) | 13.5; (12.2, 16.1) | 46; (35, 70) | 623; (425, 1,122) | 61; (41, 109)
A-55-80-30-20 | 14.5; (14.2, 14.8) | 250,592; (248,922, 254,015) | 1,169; (273, 1,552) | 10.5; (5.5, 16.8) | 406; (203, 614) | 5,170; (3,021, 7,177) | 12.7; (11.7, 14.9) | 48; (35, 83) | 617; (405, 1,226) | 36; (23, 70)
B-50-80-20-25 | 23.6; (23, 24) | 258,024; (253,262, 262,523) | 1,288; (383, 1,869) | 10.4; (6, 15.9) | 404; (222, 581) | 5,436; (3,572, 7,027) | 13.5; (12.1, 16) | 47; (36, 72) | 639; (441, 1,143) | 58; (40, 104)
A-55-80-25-15 | 17.2; (16.9, 17.6) | 267,471; (265,565, 271,399) | 1,219; (304, 1,614) | 11; (5.9, 17.6) | 425; (217, 643) | 5,387; (3,198, 7,487) | 12.7; (11.6, 14.7) | 50; (36, 84) | 629; (414, 1,227) | 40; (27, 78)
A-55-80-30-25 | 14.8; (14.4, 15.1) | 269,096; (266,481, 272,914) | 1,218; (283, 1,630) | 10.9; (5.8, 17.4) | 422; (212, 637) | 5,333; (3,146, 7,379) | 12.6; (11.6, 14.8) | 50; (36, 85) | 638; (418, 1,257) | 35; (23, 68)
A-55-80-25-20 | 18; (17.5, 18.3) | 298,016; (294,992, 302,450) | 1,295; (321, 1,723) | 11.6; (6.4, 18.6) | 450; (235, 679) | 5,690; (3,485, 7,834) | 12.6; (11.5, 14.8) | 52; (38, 85) | 662; (437, 1,259) | 40; (26, 75)
A-55-80-25-25 | 18.3; (17.9, 18.7) | 324,008; (319,778, 328,976) | 1,354; (336, 1,812) | 12.2; (6.7, 19.3) | 471; (247, 706) | 5,930; (3,672, 8,091) | 12.6; (11.5, 14.8) | 55; (40, 88) | 688; (455, 1,297) | 39; (26, 73)
A-55-80-20-15 | 20.6; (20.3, 20.9) | 330,095; (326,746, 335,324) | 1,334; (353, 1,762) | 12.1; (7, 19.2) | 469; (257, 700) | 6,018; (3,843, 8,198) | 12.8; (11.7, 14.9) | 55; (40, 86) | 704; (471, 1,278) | 44; (29, 79)
A-50-80-30-25 | 15.3; (14.9, 15.6) | 334,396; (329,497, 339,808) | 1,273; (284, 1,716) | 11.5; (6.5, 18.2) | 447; (239, 665) | 6,066; (3,867, 8,198) | 13.6; (12.3, 16.2) | 55; (40, 86) | 748; (495, 1,377) | 34; (23, 62)
A-50-80-25-15 | 18.5; (18.1, 18.9) | 344,294; (340,634, 349,670) | 1,282; (311, 1,706) | 11.7; (6.8, 18.5) | 454; (249, 677) | 6,187; (4,000, 8,437) | 13.6; (12.4, 16) | 56; (41, 86) | 758; (506, 1,368) | 41; (27, 73)
A-55-80-20-20 | 22; (21.6, 22.4) | 369,610; (364,985, 375,424) | 1,423; (375, 1,890) | 12.9; (7.5, 20.3) | 500; (278, 740) | 6,379; (4,177, 8,600) | 12.8; (11.6, 15) | 58; (43, 89) | 739; (498, 1,321) | 44; (30, 78)
A-50-80-20-10 | 21.2; (20.9, 21.5) | 369,742; (365,540, 375,831) | 1,295; (335, 1,716) | 12 (7.2, 18.8) | 464; (267, 687) | 6,435; (4,289, 8,674) | 13.9; (12.6, 16.1) | 57; (43, 86) | 797; (538, 1,376) | 46; (31, 79)
A-50-80-25-20 | 18.9; (18.5, 19.3) | 377,405; (372,386, 383,356) | 1,357; (327, 1,816) | 12.5; (7.2, 19.4) | 482; (267, 711) | 6,542; (4,299, 8,787) | 13.6; (12.4, 16.1) | 58; (43, 87) | 783; (527, 1,399) | 39; (26, 69)
A-50-80-25-25 | 19; (18.6, 19.4) | 404,469; (398,087, 411,019) | 1,417; (338, 1,906) | 13; (7.6, 20.2) | 502; (279, 738) | 6,764; (4,490, 9,030) | 13.5; (12.2, 16.1) | 60; (44, 89) | 806; (543, 1,431) | 38; (25, 67)
A-55-80-20-25 | 22.7; (22.2, 23.1) | 404,596; (398,475, 411,071) | 1,492; (394, 1,996) | 13.5; (8, 21.1) | 523; (294, 772) | 6,654; (4,426, 8,907) | 12.7; (11.5, 15) | 61; (45, 91) | 774; (522, 1,362) | 43; (29, 76)
A-50-80-20-15 | 22.6; (22.2, 23) | 419,030; (413,422, 425,782) | 1,401; (362, 1,862) | 13; (8, 20.2) | 503; (294, 738) | 6,918; (4,761, 9,223) | 13.8; (12.5, 16.2) | 61; (45, 88) | 833; (566, 1,411) | 45; (31, 76)
A-50-80-20-20 | 23.3; (22.8, 23.8) | 463,457; (456,067, 470,995) | 1,487; (382, 1,990) | 13.8; (8.5, 21.2) | 534; (315, 776) | 7,301; (5,129, 9,627) | 13.7; (12.4, 16.2) | 63; (48, 90) | 868; (594, 1,453) | 44; (30, 73)
A-45-80-25-25 | 19.4; (19, 19.8) | 482,601; (473,409, 491,032) | 1,448; (340, 1,955) | 13.5; (8.2, 20.8) | 521; (303, 760) | 7,336; (5,164, 9,571) | 14.1; (12.6, 17) | 66; (50, 92) | 926; (627, 1,565) | 37; (25, 63)
A-50-80-20-25 | 23.6; (23, 24) | 500,430; (491,300, 508,669) | 1,560; (396, 2,096) | 14.4; (9, 22.1) | 558; (331, 807) | 7,596; (5,381, 9,920) | 13.6; (12.3, 16.3) | 66; (50, 92) | 897; (616, 1,493) | 42; (29, 70)
A-45-80-20-20 | 24; (23.5, 24.5) | 557,453; (547,674, 566,689) | 1,523; (383, 2,043) | 14.4; (9.3, 21.8) | 555; (345, 797) | 7,919; (5,935, 10,162) | 14.3; (12.7, 17.2) | 70; (55, 93) | 1004; (695, 1,595) | 43; (30, 69)
A-45-80-20-25 | 24.1; (23.5, 24.5) | 594,973; (583,344, 604,931) | 1,592; (397, 2,149) | 14.9; (9.7, 22.7) | 578; (359, 828) | 8,186; (6,165, 10,463) | 14.2; (12.6, 17.1) | 73; (56, 95) | 1029; (713, 1,631) | 42; (29, 66)

* Strategies with at least 9.0 percent lung cancer mortality reduction.

Numbers are per a 100,000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. Each cell shows the average and range (lowest and highest) estimate across the four CISNET models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and six selected consensus-efficient 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 2 Harms of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Average and Range Across CISNET Models.

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-55-80-20-20 | 189,587; (187,469, 193,002) | 209334; (201,862, 220,551) | 8.6; (8.6, 8.7) | 1.2; (0.5, 2.2) | 526; (396, 606) | 64; (31, 85) | 1.3; (0.6, 1.7) | 5.6; (4.4, 8.9) | 17.5; (12.8, 22.2)
B-55-80-20-25 | 207,010; (204,167, 210,769) | 227,740; (220,307, 237,455) | 9.1; (9.1, 9.2) | 1.3; (0.6, 2.3) | 557; (421, 641) | 67; (32, 88) | 1.4; (0.6, 1.8) | 5.6; (4.5, 8.7) | 18.2; (13.9, 22.5)
B-50-80-25-25 | 208,753; (205,300, 212,339) | 228,965; (221,702, 237,530) | 11; (10.9, 11.1) | 1.5; (0.6, 2.6) | 546; (399, 634) | 68; (28, 92) | 1.4; (0.5, 1.9) | 5.8; (4.6, 8.6) | 19.3; (14.4, 24.2)
A-55-80-30-15 | 227,443; (225,768, 230,480) | 247,644; (239,774, 257,540) | 16.1; (15.9, 16.5) | 1.9; (0.9, 3.1) | 518; (336, 658) | 69; (29, 101) | 1.4; (0.6, 2.1) | 6.3; (5, 11.2) | 20.6; (15.3, 25.8)
A-55-80-25-10 | 234,030; (231,840, 237,539) | 254,870; (246,460, 264,329) | 14.6; (14.6, 14.8) | 1.8; (0.8, 2.9) | 536; (360, 677) | 71; (30, 105) | 1.4; (0.6, 2.2) | 6.3; (5, 10.8) | 21.5; (15.7, 27.3)
B-50-80-20-20 | 239,223; (235,387, 243,378) | 261,627; (254,111, 268,764) | 10.3; (10.2, 10.3) | 1.4; (0.6, 2.6) | 593; (467, 689) | 70; (32, 95) | 1.4; (0.6, 2) | 5.7; (4.4, 8.8) | 22.8; (16.6, 29)
A-55-80-30-20 | 250,592; (248,922, 254,015) | 272,008; (264,192, 279,882) | 17.3; (17.1, 17.6) | 2; (1, 3.2) | 554; (357, 701) | 73; (32, 106) | 1.5; (0.6, 2.2) | 6.2; (5.1, 11.5) | 21.5; (16.6, 26.3)
B-50-80-20-25 | 258,024; (253,262, 262,523) | 281,421; (273,995, 287,279) | 10.9; (10.9, 11) | 1.5; (0.7, 2.7) | 626; (490, 724) | 74; (33, 99) | 1.5; (0.6, 2) | 5.7; (4.5, 8.7) | 23.6; (17.7, 29.5)
A-55-80-25-15 | 267,471; (265,565, 271,399) | 290,163; (282,372, 298,333) | 15.6; (15.4, 15.7) | 1.9; (0.9, 3) | 586; (398, 743) | 77; (32, 113) | 1.5; (0.6, 2.3) | 6.3; (5.1, 10.7) | 23.4; (17.8, 29.1)
A-55-80-30-25 | 269,096; (266,481, 272,914) | 291,461; (283,790, 297,939) | 18.2; (18.1, 18.6) | 2.1; (1, 3.3) | 580; (373, 735) | 76; (32, 110) | 1.5; (0.6, 2.3) | 6.2; (5.2, 11.4) | 22.1; (17.6, 26.6)
A-55-80-25-20 | 298,016; (294,992, 302,450) | 322,330; (314,570, 331,529) | 16.6; (16.5, 16.8) | 2; (0.9, 3.1) | 630; (429, 798) | 82; (36, 119) | 1.6; (0.7, 2.4) | 6.3; (5.1, 11.1) | 24.7; (19.6, 29.8)
A-55-80-25-25 | 324,008; (319,778, 328,976) | 349,657; (342,030, 359,416) | 17.7; (17.5, 17.9) | 2.1; (1, 3.2) | 664; (451, 842) | 84; (37, 123) | 1.7; (0.7, 2.5) | 6.2; (4.9, 10.9) | 25.6; (21, 30.2)
A-55-80-20-15 | 330,095; (326,746, 335,324) | 356,390; (348,621, 368,653) | 16; (16, 16.2) | 1.9; (0.9, 3) | 667; (480, 848) | 83; (38, 121) | 1.7; (0.7, 2.5) | 6.2; (4.9, 10.8) | 29; (22, 36)
A-50-80-30-25 | 334,396; (329,497, 339,808) | 359,972; (352,943, 368,506) | 21.9; (21.7, 22.1) | 2.5; (1.2, 3.8) | 639; (433, 817) | 76; (33, 109) | 1.5; (0.6, 2.2) | 6; (4.8, 11.6) | 29.9; (23, 36.8)
A-50-80-25-15 | 344,294; (340,634, 349,670) | 370,892; (363,381, 383,048) | 18.6; (18.4, 18.8) | 2.2; (1.1, 3.5) | 658; (479, 840) | 77; (34, 111) | 1.6; (0.7, 2.3) | 6; (4.9, 10.9) | 32.1; (24.1, 40.2)
A-55-80-20-20 | 369,610; (364,985, 375,424) | 398,094; (390,275, 412,147) | 16.8; (16.8, 17) | 2; (1, 3.1) | 722; (523, 917) | 89; (42, 127) | 1.8; (0.8, 2.6) | 6.3; (5.1, 11.2) | 30.6; (24.3, 37)
A-50-80-20-10 | 369,742; (365,540, 375,831) | 397,994; (390,503, 412,275) | 17.4; (17.4, 17.5) | 2.1; (1, 3.3) | 684; (525, 873) | 77; (37, 111) | 1.5; (0.7, 2.3) | 5.9; (4.8, 11.1) | 36.5; (26.1, 47)
A-50-80-25-20 | 377,405; (372,386, 383,356) | 405,682; (398,226, 418,755) | 20; (19.8, 20.2) | 2.3; (1.1, 3.6) | 701; (508, 897) | 82; (36, 117) | 1.6; (0.7, 2.4) | 6; (4.9, 11.1) | 33.5; (26.1, 40.9)
A-50-80-25-25 | 404,469; (398,087, 411,019) | 434,104; (426,897, 447,570) | 21.3; (21.1, 21.5) | 2.5; (1.2, 3.8) | 735; (527, 942) | 85; (37, 121) | 1.7; (0.7, 2.5) | 6; (4.9, 11) | 34.9; (27.6, 42.1)
A-55-80-20-25 | 404,596; (398,475, 411,071) | 434,892; (427,122, 449,985) | 17.8; (17.8, 18) | 2.1; (1, 3.2) | 765; (556, 973) | 94; (43, 132) | 1.9; (0.8, 2.7) | 6.3; (5.1, 11) | 31.9; (26.2, 37.6)
A-50-80-20-15 | 419,030; (413,422, 425,782) | 449,947; (442,335, 466,558) | 18.5; (18.5, 18.6) | 2.2; (1, 3.5) | 750; (578, 959) | 84; (40, 119) | 1.7; (0.8, 2.4) | 6; (4.8, 11.1) | 38.6; (29.2, 48)
A-50-80-20-20 | 463,457; (456,067, 470,995) | 496,698; (489,237, 514,727) | 19.9; (19.8, 20) | 2.3; (1.1, 3.6) | 804; (619, 1,031) | 89; (43, 125) | 1.8; (0.8, 2.6) | 6; (4.9, 11.3) | 40.6; (31.9, 49.3)
A-45-80-25-25 | 482,601; (473,409, 491,032) | 515,967; (505,095, 531,931) | 24.9; (24.7, 25) | 2.8; (1.4, 4.4) | 797; (610, 1,025) | 86; (39, 123) | 1.7; (0.8, 2.5) | 5.9; (4.7, 11.5) | 45.8; (34.1, 57.6)
A-50-80-20-25 | 500,430; (491,300, 508,669) | 535,519; (524,554, 554,368) | 21.2; (21.2, 21.4) | 2.5; (1.2, 3.8) | 849; (647, 1,088) | 94; (45, 130) | 1.9; (0.9, 2.7) | 6; (4.9, 11.3) | 42.5; (34, 51)
A-45-80-20-20 | 557,453; (547,674, 566,689) | 595,203; (580,476, 617,835) | 23.2; (23.1, 23.4) | 2.7; (1.3, 4.2) | 879; (721, 1,132) | 91; (45, 127) | 1.8; (0.9, 2.6) | 6; (4.8, 11.7) | 53.1; (39.5, 66.8)
A-45-80-20-25 | 594,973; (583,344, 604,931) | 634,568; (616,172, 657,897) | 24.7; (24.6, 24.8) | 2.8; (1.4, 4.4) | 922; (748, 1,189) | 95; (46, 132) | 1.9; (0.9, 2.7) | 6; (4.8, 11.6) | 55; (41.7, 68.4)

* Strategies with at least 9.0 percent lung cancer mortality reduction.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100,000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. Each cell shows the average and range (lowest and highest) estimate across the four CISNET models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected consensus-efficient 20-pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; USPSTF=U.S. Preventive Services Task Force

Appendix C Table 3 Benefits of 57 Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC deaths averted | NNS
B-55-75-40-10 | 9.0 | 64,607 | 569 | 4.5 | 173 | 2,405 | 13.9 | 27 | 373 | 52
B-55-77-40-10 | 9.0 | 67,867 | 627 | 4.9 | 189 | 2,523 | 13.3 | 27 | 359 | 48
B-55-75-40-15 | 9.3 | 70,408 | 601 | 4.7 | 183 | 2,559 | 14.0 | 28 | 385 | 51
B-55-80-40-10 | 9.0 | 70,999 | 681 | 5.3 | 204 | 2,610 | 12.8 | 27 | 348 | 44
B-55-77-40-15 | 9.3 | 74,368 | 663 | 5.2 | 201 | 2,648 | 13.2 | 28 | 370 | 46
B-55-80-40-15 | 9.4 | 78,245 | 729 | 5.6 | 218 | 2,751 | 12.6 | 28 | 359 | 43
B-50-77-40-10 | 9.5 | 79,248 | 634 | 5.0 | 196 | 2,765 | 14.1 | 29 | 404 | 48
B-55-77-40-20 | 9.5 | 79,273 | 689 | 5.3 | 207 | 2,743 | 13.3 | 29 | 383 | 46
B-50-75-40-15 | 9.7 | 81,993 | 606 | 4.9 | 189 | 2,810 | 14.9 | 29 | 434 | 51
B-50-80-40-10 | 9.6 | 83,744 | 722 | 5.6 | 219 | 2,910 | 13.3 | 29 | 382 | 44
B-55-80-40-20 | 9.6 | 83,861 | 761 | 5.9 | 227 | 2,871 | 12.6 | 29 | 369 | 42
B-50-77-40-15 | 9.7 | 86,158 | 673 | 5.3 | 208 | 2,940 | 14.1 | 29 | 414 | 47
B-55-80-40-25 | 9.6 | 87,795 | 782 | 6.0 | 232 | 2,915 | 12.6 | 30 | 378 | 41
B-50-77-40-20 | 9.8 | 91,142 | 695 | 5.6 | 216 | 3,029 | 14.0 | 30 | 422 | 45
B-50-80-40-15 | 9.8 | 91,757 | 769 | 6.0 | 234 | 3,070 | 13.1 | 30 | 392 | 42
B-50-77-40-25 | 9.8 | 94,455 | 710 | 5.7 | 221 | 3,104 | 14.0 | 30 | 427 | 44
B-50-80-40-20 | 9.9 | 97,823 | 806 | 6.3 | 246 | 3,211 | 13.1 | 30 | 398 | 40
B-50-80-40-25 | 9.9 | 101,977 | 829 | 6.5 | 253 | 3,269 | 12.9 | 31 | 403 | 39
B-55-80-30-15 | 14.1 | 116,975 | 876 | 6.9 | 266 | 3,435 | 12.9 | 34 | 440 | 53
B-55-80-25-10 | 16.0 | 120,809 | 900 | 7.1 | 273 | 3,519 | 12.9 | 34 | 443 | 59
B-55-80-30-20 | 14.5 | 128,506 | 929 | 7.3 | 282 | 3,617 | 12.8 | 36 | 456 | 51
B-55-80-25-20 | 18.0 | 152,967 | 1,029 | 8.1 | 313 | 4,008 | 12.8 | 38 | 489 | 58
B-50-80-30-20 | 15.3 | 162,722 | 1,003 | 8.0 | 312 | 4,208 | 13.5 | 39 | 522 | 49
A-55-80-40-20 | 9.6 | 163,476 | 953 | 8.4 | 327 | 4,058 | 12.4 | 40 | 500 | 29
B-55-80-25-25 | 18.3 | 165,874 | 1,080 | 8.4 | 327 | 4,173 | 12.8 | 40 | 507 | 56
B-55-80-20-15 | 20.6 | 169,689 | 1,063 | 8.4 | 326 | 4,215 | 12.9 | 40 | 521 | 63
A-55-80-40-25 | 9.7 | 171,482 | 981 | 8.7 | 336 | 4,171 | 12.4 | 41 | 510 | 29
B-50-80-30-25 | 15.3 | 172,484 | 1,047 | 8.4 | 324 | 4,342 | 13.4 | 40 | 532 | 47
B-50-80-25-15 | 18.5 | 178,078 | 1,051 | 8.4 | 327 | 4,430 | 13.5 | 40 | 545 | 57
B-55-80-20-20 | 22.0 | 189,587 | 1,134 | 9.0 | 348 | 4,490 | 12.9 | 42 | 545 | 63
B-50-80-20-10 | 21.2 | 191,326 | 1,061 | 8.6 | 333 | 4,592 | 13.8 | 42 | 575 | 64
B-50-80-25-20 | 18.9 | 194,975 | 1,115 | 8.9 | 346 | 4,663 | 13.5 | 42 | 564 | 55
B-50-77-25-25 | 19.0 | 195,133 | 987 | 8.1 | 314 | 4,582 | 14.6 | 43 | 621 | 61
B-55-80-20-25 | 22.7 | 207,010 | 1,189 | 9.5 | 366 | 4,701 | 12.8 | 44 | 566 | 62
B-50-80-25-25 | 19.0 | 208,753 | 1,169 | 9.4 | 363 | 4,859 | 13.4 | 43 | 575 | 52
A-55-80-30-15 | 14.1 | 227,443 | 1,102 | 9.8 | 381 | 4,882 | 12.8 | 47 | 597 | 37
A-55-80-25-10 | 16.0 | 234,030 | 1,131 | 10.1 | 392 | 4,969 | 12.7 | 47 | 597 | 41
B-50-80-20-20 | 23.3 | 239,223 | 1,226 | 9.9 | 384 | 5,194 | 13.5 | 46 | 623 | 61
A-55-80-30-20 | 14.5 | 250,592 | 1,169 | 10.5 | 406 | 5,170 | 12.7 | 48 | 617 | 36
B-50-80-20-25 | 23.6 | 258,024 | 1,288 | 10.4 | 404 | 5,436 | 13.5 | 47 | 639 | 58
A-55-80-25-15 | 17.2 | 267,471 | 1,219 | 11.0 | 425 | 5,387 | 12.7 | 50 | 629 | 40
A-55-80-30-25 | 14.8 | 269,096 | 1,218 | 10.9 | 422 | 5,333 | 12.6 | 50 | 638 | 35
A-55-80-25-20 | 18.0 | 298,016 | 1,295 | 11.6 | 450 | 5,690 | 12.6 | 52 | 662 | 40
A-55-80-25-25 | 18.3 | 324,008 | 1,354 | 12.2 | 471 | 5,930 | 12.6 | 55 | 688 | 39
A-55-80-20-15 | 20.6 | 330,095 | 1,334 | 12.1 | 469 | 6,018 | 12.8 | 55 | 704 | 44
A-50-80-30-25 | 15.3 | 334,396 | 1,273 | 11.5 | 447 | 6,066 | 13.6 | 55 | 748 | 34
A-50-80-25-15 | 18.5 | 344,294 | 1,282 | 11.7 | 454 | 6,187 | 13.6 | 56 | 758 | 41
A-55-80-20-20 | 22.0 | 369,610 | 1,423 | 12.9 | 500 | 6,379 | 12.8 | 58 | 739 | 44
A-50-80-20-10 | 21.2 | 369,742 | 1,295 | 12.0 | 464 | 6,435 | 13.9 | 57 | 797 | 46
A-50-80-25-20 | 18.9 | 377,405 | 1,357 | 12.5 | 482 | 6,542 | 13.6 | 58 | 783 | 39
A-50-80-25-25 | 19.0 | 404,469 | 1,417 | 13.0 | 502 | 6,764 | 13.5 | 60 | 806 | 38
A-55-80-20-25 | 22.7 | 404,596 | 1,492 | 13.5 | 523 | 6,654 | 12.7 | 61 | 774 | 43
A-50-80-20-15 | 22.6 | 419,030 | 1,401 | 13.0 | 503 | 6,918 | 13.8 | 61 | 833 | 45
A-50-80-20-20 | 23.3 | 463,457 | 1,487 | 13.8 | 534 | 7,301 | 13.7 | 63 | 868 | 44
A-45-80-25-25 | 19.4 | 482,601 | 1,448 | 13.5 | 521 | 7,336 | 14.1 | 66 | 926 | 37
A-50-80-20-25 | 23.6 | 500,430 | 1,560 | 14.4 | 558 | 7,596 | 13.6 | 66 | 897 | 42
A-45-80-20-20 | 24.0 | 557,453 | 1,523 | 14.4 | 555 | 7,919 | 14.3 | 70 | 1,004 | 43
A-45-80-20-25 | 24.1 | 594,973 | 1,592 | 14.9 | 578 | 8,186 | 14.2 | 73 | 1,029 | 42

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 4 Harms of 57 Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^*^
B-55-75-40-10 | 64,607 | 76,031 | 7.2 | 1.1 | 241 | 27 | 0.5 | 4.7 | 6.8
B-55-77-40-10 | 67,867 | 79,460 | 7.5 | 1.1 | 262 | 32 | 0.6 | 5.1 | 6.8
B-55-75-40-15 | 70,408 | 82,183 | 7.6 | 1.1 | 256 | 28 | 0.6 | 4.7 | 7.3
B-55-80-40-10 | 70,999 | 82,748 | 7.9 | 1.1 | 281 | 38 | 0.8 | 5.6 | 7.0
B-55-77-40-15 | 74,368 | 86,348 | 8.0 | 1.1 | 278 | 34 | 0.7 | 5.1 | 7.3
B-55-80-40-15 | 78,245 | 90,409 | 8.3 | 1.2 | 301 | 41 | 0.8 | 5.6 | 7.4
B-50-77-40-10 | 79,248 | 91,457 | 8.3 | 1.2 | 273 | 30 | 0.6 | 4.7 | 9.0
B-55-77-40-20 | 79,273 | 91,528 | 8.3 | 1.2 | 289 | 35 | 0.7 | 5.1 | 7.5
B-50-75-40-15 | 81,993 | 94,358 | 8.5 | 1.2 | 266 | 27 | 0.5 | 4.5 | 9.3
B-50-80-40-10 | 83,744 | 96,205 | 8.7 | 1.2 | 304 | 40 | 0.8 | 5.5 | 9.1
B-55-80-40-20 | 83,861 | 96,341 | 8.7 | 1.2 | 315 | 44 | 0.9 | 5.8 | 7.7
B-50-77-40-15 | 86,158 | 98,746 | 8.9 | 1.3 | 290 | 32 | 0.7 | 4.8 | 9.4
B-55-80-40-25 | 87,795 | 100,483 | 9.1 | 1.3 | 324 | 44 | 0.9 | 5.6 | 7.7
B-50-77-40-20 | 91,142 | 103,995 | 9.3 | 1.3 | 300 | 34 | 0.7 | 4.9 | 9.6
B-50-80-40-15 | 91,757 | 104,657 | 9.4 | 1.3 | 324 | 43 | 0.9 | 5.6 | 9.5
B-50-77-40-25 | 94,455 | 107,470 | 9.6 | 1.3 | 307 | 34 | 0.7 | 4.8 | 9.7
B-50-80-40-20 | 97,823 | 111,033 | 9.9 | 1.4 | 340 | 46 | 0.9 | 5.7 | 9.7
B-50-80-40-25 | 101,977 | 115,402 | 10.3 | 1.4 | 350 | 47 | 1.0 | 5.7 | 9.8
B-55-80-30-15 | 116,975 | 131,843 | 8.3 | 1.2 | 383 | 50 | 1.0 | 5.7 | 11.6
B-55-80-25-10 | 120,809 | 136,159 | 7.6 | 1.1 | 396 | 52 | 1.0 | 5.8 | 12.2
B-55-80-30-20 | 128,506 | 144,018 | 8.9 | 1.2 | 408 | 53 | 1.1 | 5.7 | 12.1
B-55-80-25-20 | 152,967 | 170,246 | 8.5 | 1.2 | 462 | 59 | 1.2 | 5.7 | 14.2
B-50-80-30-20 | 162,722 | 180,006 | 10.6 | 1.5 | 457 | 58 | 1.2 | 5.8 | 16.2
A-55-80-40-20 | 163,476 | 179,811 | 17.0 | 2.0 | 422 | 60 | 1.2 | 6.3 | 13.8
B-55-80-25-25 | 165,874 | 183,864 | 9.1 | 1.3 | 487 | 62 | 1.3 | 5.7 | 14.6
B-55-80-20-15 | 169,689 | 188,224 | 8.2 | 1.2 | 489 | 60 | 1.2 | 5.6 | 16.7
A-55-80-40-25 | 171,482 | 188,230 | 17.7 | 2.1 | 435 | 61 | 1.2 | 6.2 | 14.0
B-50-80-30-25 | 172,484 | 190,291 | 11.3 | 1.5 | 477 | 60 | 1.2 | 5.7 | 16.5
B-50-80-25-15 | 178,078 | 196,667 | 9.6 | 1.4 | 489 | 60 | 1.2 | 5.7 | 18.1
B-55-80-20-20 | 189,587 | 209,334 | 8.6 | 1.2 | 526 | 64 | 1.3 | 5.6 | 17.5
B-50-80-20-10 | 191,326 | 210,985 | 9.0 | 1.3 | 506 | 61 | 1.2 | 5.7 | 20.7
B-50-80-25-20 | 194,975 | 214,471 | 10.3 | 1.4 | 521 | 65 | 1.3 | 5.8 | 18.7
B-50-77-25-25 | 195,133 | 214,624 | 10.3 | 1.4 | 480 | 48 | 1.0 | 4.9 | 19.0
B-55-80-20-25 | 207,010 | 227,740 | 9.1 | 1.3 | 557 | 67 | 1.4 | 5.6 | 18.2
B-50-80-25-25 | 208,753 | 228,965 | 11.0 | 1.5 | 546 | 68 | 1.4 | 5.8 | 19.3
A-55-80-30-15 | 227,443 | 247,644 | 16.1 | 1.9 | 518 | 69 | 1.4 | 6.3 | 20.6
A-55-80-25-10 | 234,030 | 254,870 | 14.6 | 1.8 | 536 | 71 | 1.4 | 6.3 | 21.5
B-50-80-20-20 | 239,223 | 261,627 | 10.3 | 1.4 | 593 | 70 | 1.4 | 5.7 | 22.8
A-55-80-30-20 | 250,592 | 272,008 | 17.3 | 2.0 | 554 | 73 | 1.5 | 6.2 | 21.5
B-50-80-20-25 | 258,024 | 281,421 | 10.9 | 1.5 | 626 | 74 | 1.5 | 5.7 | 23.6
A-55-80-25-15 | 267,471 | 290,163 | 15.6 | 1.9 | 586 | 77 | 1.5 | 6.3 | 23.4
A-55-80-30-25 | 269,096 | 291,461 | 18.2 | 2.1 | 580 | 76 | 1.5 | 6.2 | 22.1
A-55-80-25-20 | 298,016 | 322,330 | 16.6 | 2.0 | 630 | 82 | 1.6 | 6.3 | 24.7
A-55-80-25-25 | 324,008 | 349,657 | 17.7 | 2.1 | 664 | 84 | 1.7 | 6.2 | 25.6
A-55-80-20-15 | 330,095 | 356,390 | 16.0 | 1.9 | 667 | 83 | 1.7 | 6.2 | 29.0
A-50-80-30-25 | 334,396 | 359,972 | 21.9 | 2.5 | 639 | 76 | 1.5 | 6.0 | 29.9
A-50-80-25-15 | 344,294 | 370,892 | 18.6 | 2.2 | 658 | 77 | 1.6 | 6.0 | 32.1
A-55-80-20-20 | 369,610 | 398,094 | 16.8 | 2.0 | 722 | 89 | 1.8 | 6.3 | 30.6
A-50-80-20-10 | 369,742 | 397,994 | 17.4 | 2.1 | 684 | 77 | 1.5 | 5.9 | 36.5
A-50-80-25-20 | 377,405 | 405,682 | 20.0 | 2.3 | 701 | 82 | 1.6 | 6.0 | 33.5
A-50-80-25-25 | 404,469 | 434,104 | 21.3 | 2.5 | 735 | 85 | 1.7 | 6.0 | 34.9
A-55-80-20-25 | 404,596 | 434,892 | 17.8 | 2.1 | 765 | 94 | 1.9 | 6.3 | 31.9
A-50-80-20-15 | 419,030 | 449,947 | 18.5 | 2.2 | 750 | 84 | 1.7 | 6.0 | 38.6
A-50-80-20-20 | 463,457 | 496,698 | 19.9 | 2.3 | 804 | 89 | 1.8 | 6.0 | 40.6
A-45-80-25-25 | 482,601 | 515,967 | 24.9 | 2.8 | 797 | 86 | 1.7 | 5.9 | 45.8
A-50-80-20-25 | 500,430 | 535,519 | 21.2 | 2.5 | 849 | 94 | 1.9 | 6.0 | 42.5
A-45-80-20-20 | 557,453 | 595,203 | 23.2 | 2.7 | 879 | 91 | 1.8 | 6.0 | 53.1
A-45-80-20-25 | 594,973 | 634,568 | 24.7 | 2.8 | 922 | 95 | 1.9 | 6.0 | 55.0

* Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 5 Benefits of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort Men

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC deaths averted | NNS
B-55-80-20-20 | 23.5 | 195,717 | 1,188 | 8.6 | 346 | 4,446 | 12.8 | 44 | 566 | 68
B-55-80-20-25 | 24.4 | 215,054 | 1,244 | 9.0 | 363 | 4,650 | 12.8 | 46 | 592 | 67
B-50-80-25-25 | 21.1 | 227,415 | 1,248 | 9.1 | 366 | 4,908 | 13.4 | 46 | 621 | 58
A-55-80-25-10 | 17.2 | 249,626 | 1,223 | 10.1 | 406 | 5,116 | 12.6 | 49 | 615 | 42
A-55-80-30-15 | 15.7 | 250,071 | 1,209 | 10.0 | 400 | 5,078 | 12.7 | 49 | 625 | 39
B-50-80-20-20 | 25.3 | 251,271 | 1,290 | 9.5 | 383 | 5,174 | 13.5 | 49 | 656 | 66
B-50-80-20-25 | 25.6 | 272,290 | 1,353 | 10.0 | 402 | 5,427 | 13.5 | 50 | 677 | 64
A-55-80-30-20 | 16.3 | 275,890 | 1,278 | 10.6 | 426 | 5,398 | 12.7 | 51 | 648 | 38
A-55-80-25-15 | 18.8 | 285,370 | 1,310 | 10.9 | 439 | 5,544 | 12.6 | 51 | 650 | 43
A-55-80-30-25 | 16.7 | 297,195 | 1,328 | 11.0 | 442 | 5,561 | 12.6 | 53 | 672 | 38
A-55-80-25-20 | 19.7 | 318,886 | 1,388 | 11.5 | 461 | 5,808 | 12.6 | 55 | 692 | 43
A-55-80-20-15 | 21.8 | 338,814 | 1,415 | 11.8 | 475 | 6,022 | 12.7 | 56 | 713 | 46
A-55-80-25-25 | 20.2 | 348,216 | 1,451 | 12.0 | 484 | 6,080 | 12.6 | 57 | 719 | 42
A-50-80-25-15 | 20.4 | 372,871 | 1,389 | 11.8 | 471 | 6,425 | 13.6 | 58 | 792 | 43
A-50-80-30-25 | 17.4 | 373,581 | 1,399 | 11.7 | 469 | 6,383 | 13.6 | 59 | 797 | 37
A-55-80-20-20 | 23.5 | 380,919 | 1,502 | 12.6 | 505 | 6,396 | 12.7 | 60 | 754 | 47
A-50-80-20-10 | 22.6 | 386,227 | 1,392 | 11.9 | 477 | 6,564 | 13.8 | 59 | 810 | 47
A-50-80-25-20 | 21.0 | 409,766 | 1,467 | 12.4 | 497 | 6,748 | 13.6 | 61 | 824 | 42
A-55-80-20-25 | 24.4 | 419,641 | 1,572 | 13.1 | 526 | 6,664 | 12.7 | 63 | 798 | 46
A-50-80-20-15 | 24.4 | 438,248 | 1,497 | 12.8 | 513 | 7,031 | 13.7 | 62 | 854 | 48
A-50-80-25-25 | 21.1 | 440,553 | 1,529 | 12.9 | 517 | 6,970 | 13.5 | 63 | 852 | 41
A-50-80-20-20 | 25.3 | 486,445 | 1,584 | 13.5 | 542 | 7,397 | 13.6 | 66 | 898 | 47
A-50-80-20-25 | 25.6 | 527,801 | 1,657 | 14.1 | 565 | 7,696 | 13.6 | 69 | 934 | 45
A-45-80-25-25 | 21.7 | 531,572 | 1,569 | 13.5 | 540 | 7,619 | 14.1 | 70 | 984 | 40
A-45-80-20-20 | 26.2 | 594,043 | 1,628 | 14.2 | 566 | 8,087 | 14.3 | 73 | 1,050 | 46
A-45-80-20-25 | 26.3 | 636,177 | 1,698 | 14.7 | 586 | 8,346 | 14.2 | 76 | 1,086 | 45

* Strategies with at least 9.0 percent lung cancer mortality reduction.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 6 Harms of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort Men

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-55-80-20-20 | 195,717 | 215,799 | 8.3 | 1.2 | 550 | 66 | 1.3 | 5.6 | 15.9
B-55-80-20-25 | 215,054 | 236,240 | 8.8 | 1.2 | 582 | 68 | 1.3 | 5.5 | 16.5
B-50-80-25-25 | 227,415 | 248,683 | 10.8 | 1.5 | 588 | 71 | 1.4 | 5.7 | 18.1
A-55-80-25-10 | 249,626 | 271,247 | 14.5 | 1.8 | 577 | 74 | 1.5 | 6.1 | 19.8
A-55-80-30-15 | 250,071 | 271,454 | 15.9 | 1.9 | 569 | 74 | 1.4 | 6.1 | 19.2
B-50-80-20-20 | 251,271 | 274,358 | 9.9 | 1.4 | 626 | 72 | 1.4 | 5.6 | 20.9
B-50-80-20-25 | 272,290 | 296,497 | 10.6 | 1.5 | 660 | 75 | 1.5 | 5.5 | 21.3
A-55-80-30-20 | 275,890 | 298,634 | 16.9 | 2.0 | 608 | 78 | 1.5 | 6.1 | 20.0
A-55-80-25-15 | 285,370 | 309,010 | 15.2 | 1.8 | 630 | 80 | 1.6 | 6.1 | 21.7
A-55-80-30-25 | 297,195 | 321,032 | 17.8 | 2.1 | 636 | 80 | 1.6 | 6.0 | 20.5
A-55-80-25-20 | 318,886 | 344,314 | 16.2 | 1.9 | 676 | 85 | 1.7 | 6.1 | 22.8
A-55-80-20-15 | 338,814 | 365,553 | 15.5 | 1.9 | 701 | 85 | 1.7 | 6.0 | 25.5
A-55-80-25-25 | 348,216 | 375,168 | 17.2 | 2.0 | 713 | 88 | 1.7 | 6.1 | 23.5
A-50-80-25-15 | 372,871 | 400,959 | 18.3 | 2.2 | 714 | 80 | 1.6 | 5.8 | 30.4
A-50-80-30-25 | 373,581 | 401,173 | 21.5 | 2.5 | 708 | 81 | 1.6 | 5.8 | 28.4
A-55-80-20-20 | 380,919 | 409,986 | 16.2 | 1.9 | 757 | 92 | 1.8 | 6.1 | 27.0
A-50-80-20-10 | 386,227 | 415,291 | 17.1 | 2.1 | 728 | 80 | 1.6 | 5.7 | 32.9
A-50-80-25-20 | 409,766 | 439,725 | 19.5 | 2.3 | 761 | 86 | 1.7 | 5.9 | 31.6
A-55-80-20-25 | 419,641 | 450,762 | 17.2 | 2.0 | 804 | 96 | 1.9 | 6.1 | 28.0
A-50-80-20-15 | 438,248 | 470,133 | 18.0 | 2.1 | 796 | 87 | 1.7 | 5.8 | 34.8
A-50-80-25-25 | 440,553 | 472,067 | 20.9 | 2.4 | 798 | 89 | 1.7 | 5.8 | 32.8
A-50-80-20-20 | 486,445 | 520,898 | 19.2 | 2.3 | 854 | 92 | 1.8 | 5.8 | 36.6
A-50-80-20-25 | 527,801 | 564,345 | 20.6 | 2.4 | 902 | 97 | 1.9 | 5.9 | 38.3
A-45-80-25-25 | 531,572 | 567,427 | 24.5 | 2.8 | 871 | 89 | 1.8 | 5.7 | 42.7
A-45-80-20-20 | 594,043 | 633,633 | 22.7 | 2.7 | 941 | 95 | 1.9 | 5.8 | 47.4
A-45-80-20-25 | 636,177 | 677,865 | 24.2 | 2.8 | 987 | 98 | 1.9 | 5.8 | 49.4

* Strategies with at least 9.0 percent lung cancer mortality reduction.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 7 Benefits of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort Women

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC deaths averted | NNS
B-55-80-20-20 | 20.4 | 183,456 | 1,080 | 9.4 | 350 | 4,534 | 13.0 | 40 | 524 | 58
B-50-80-25-25 | 17.0 | 190,090 | 1,089 | 9.7 | 360 | 4,810 | 13.4 | 40 | 528 | 47
B-55-80-20-25 | 20.9 | 198,965 | 1,134 | 9.9 | 369 | 4,751 | 12.9 | 42 | 539 | 57
A-55-80-30-15 | 12.4 | 204,815 | 995 | 9.7 | 362 | 4,685 | 12.9 | 44 | 566 | 34
A-55-80-25-10 | 14.7 | 218,434 | 1,039 | 10.1 | 378 | 4,822 | 12.8 | 45 | 578 | 39
A-55-80-30-20 | 12.7 | 225,294 | 1,060 | 10.4 | 387 | 4,942 | 12.8 | 46 | 582 | 33
B-50-80-20-20 | 21.4 | 227,175 | 1,161 | 10.3 | 384 | 5,214 | 13.6 | 44 | 592 | 56
A-55-80-30-25 | 12.9 | 240,997 | 1,107 | 10.8 | 402 | 5,106 | 12.7 | 47 | 599 | 32
B-50-80-20-25 | 21.5 | 243,757 | 1,222 | 10.8 | 405 | 5,446 | 13.4 | 45 | 602 | 53
A-55-80-25-15 | 15.7 | 249,571 | 1,128 | 11.0 | 411 | 5,229 | 12.7 | 48 | 607 | 38
A-55-80-25-20 | 16.3 | 277,146 | 1,202 | 11.8 | 439 | 5,572 | 12.7 | 50 | 631 | 37
A-50-80-30-25 | 13.2 | 295,210 | 1,147 | 11.4 | 425 | 5,748 | 13.5 | 51 | 695 | 31
A-55-80-25-25 | 16.5 | 299,799 | 1,257 | 12.3 | 459 | 5,781 | 12.6 | 52 | 653 | 36
A-50-80-25-15 | 16.6 | 315,717 | 1,174 | 11.7 | 437 | 5,948 | 13.6 | 53 | 722 | 38
A-55-80-20-15 | 19.3 | 321,376 | 1,253 | 12.4 | 463 | 6,014 | 13.0 | 53 | 694 | 42
A-50-80-25-20 | 16.9 | 345,044 | 1,248 | 12.5 | 467 | 6,336 | 13.6 | 54 | 739 | 36
A-50-80-20-10 | 19.7 | 353,258 | 1,198 | 12.1 | 452 | 6,306 | 14.0 | 56 | 782 | 44
A-55-80-20-20 | 20.4 | 358,302 | 1,345 | 13.2 | 495 | 6,363 | 12.9 | 56 | 724 | 41
A-50-80-25-25 | 17.0 | 368,385 | 1,304 | 13.0 | 487 | 6,557 | 13.5 | 56 | 756 | 35
A-55-80-20-25 | 20.9 | 389,551 | 1,413 | 13.9 | 520 | 6,645 | 12.8 | 59 | 749 | 40
A-50-80-20-15 | 20.9 | 399,813 | 1,305 | 13.2 | 492 | 6,805 | 13.8 | 59 | 813 | 42
A-45-80-25-25 | 17.2 | 433,630 | 1,327 | 13.5 | 503 | 7,052 | 14.0 | 61 | 862 | 34
A-50-80-20-20 | 21.4 | 440,469 | 1,391 | 14.1 | 526 | 7,205 | 13.7 | 61 | 837 | 41
A-50-80-20-25 | 21.5 | 473,059 | 1,463 | 14.7 | 551 | 7,496 | 13.6 | 63 | 859 | 39
A-45-80-20-20 | 21.9 | 520,864 | 1,419 | 14.6 | 545 | 7,750 | 14.2 | 67 | 956 | 40
A-45-80-20-25 | 21.9 | 553,768 | 1,486 | 15.2 | 569 | 8,025 | 14.1 | 69 | 973 | 38

* Strategies with at least 9.0 percent lung cancer mortality reduction.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 8 Harms of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort Women

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-55-80-20-20 | 183,456 | 202,870 | 9.0 | 1.3 | 502 | 62 | 1.3 | 5.7 | 19.2
B-50-80-25-25 | 190,090 | 209,246 | 11.2 | 1.5 | 505 | 66 | 1.4 | 6.1 | 20.5
B-55-80-20-25 | 198,965 | 219,240 | 9.5 | 1.3 | 531 | 67 | 1.4 | 5.9 | 19.8
A-55-80-30-15 | 204,815 | 223,834 | 16.5 | 2.0 | 467 | 64 | 1.3 | 6.4 | 22.0
A-55-80-25-10 | 218,434 | 238,493 | 14.9 | 1.8 | 495 | 68 | 1.4 | 6.5 | 23.2
A-55-80-30-20 | 225,294 | 245,381 | 17.7 | 2.1 | 500 | 68 | 1.4 | 6.4 | 22.9
B-50-80-20-20 | 227,175 | 248,896 | 10.6 | 1.5 | 561 | 69 | 1.4 | 5.9 | 24.8
A-55-80-30-25 | 240,997 | 261,890 | 18.7 | 2.2 | 524 | 73 | 1.5 | 6.6 | 23.7
B-50-80-20-25 | 243,757 | 266,344 | 11.3 | 1.5 | 591 | 73 | 1.5 | 6.0 | 25.8
A-55-80-25-15 | 249,571 | 271,315 | 15.9 | 1.9 | 543 | 74 | 1.5 | 6.6 | 25.2
A-55-80-25-20 | 277,146 | 300,346 | 17.0 | 2.0 | 584 | 78 | 1.6 | 6.5 | 26.6
A-50-80-30-25 | 295,210 | 318,771 | 22.4 | 2.5 | 571 | 71 | 1.5 | 6.2 | 31.4
A-55-80-25-25 | 299,799 | 324,146 | 18.2 | 2.1 | 614 | 81 | 1.7 | 6.4 | 27.8
A-50-80-25-15 | 315,717 | 340,825 | 19.0 | 2.2 | 602 | 74 | 1.5 | 6.3 | 33.9
A-55-80-20-15 | 321,376 | 347,227 | 16.7 | 2.0 | 633 | 80 | 1.6 | 6.4 | 32.4
A-50-80-25-20 | 345,044 | 371,638 | 20.4 | 2.4 | 642 | 77 | 1.6 | 6.2 | 35.4
A-50-80-20-10 | 353,258 | 380,696 | 17.9 | 2.1 | 639 | 74 | 1.5 | 6.2 | 40.1
A-55-80-20-20 | 358,302 | 386,201 | 17.6 | 2.1 | 686 | 87 | 1.8 | 6.5 | 34.2
A-50-80-25-25 | 368,385 | 396,142 | 21.7 | 2.5 | 673 | 81 | 1.7 | 6.2 | 36.9
A-55-80-20-25 | 389,551 | 419,022 | 18.6 | 2.2 | 726 | 91 | 1.9 | 6.4 | 35.8
A-50-80-20-15 | 399,813 | 429,762 | 19.1 | 2.3 | 703 | 82 | 1.7 | 6.3 | 42.4
A-45-80-25-25 | 433,630 | 464,507 | 25.2 | 2.9 | 723 | 82 | 1.7 | 6.2 | 49.0
A-50-80-20-20 | 440,469 | 472,498 | 20.6 | 2.4 | 754 | 86 | 1.8 | 6.2 | 44.6
A-50-80-20-25 | 473,059 | 506,693 | 22.0 | 2.5 | 796 | 90 | 1.9 | 6.2 | 46.7
A-45-80-20-20 | 520,864 | 556,773 | 23.8 | 2.8 | 817 | 86 | 1.8 | 6.1 | 58.9
A-45-80-20-25 | 553,768 | 591,272 | 25.3 | 2.9 | 857 | 92 | 1.9 | 6.2 | 60.7

* Strategies with at least 9.0 percent lung cancer mortality reduction.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 9 Comparison of 2013 USPSTF-Recommended (A-55-80-30-15) and Selected Risk Factor–Based Screening (20 Pack-Year Consensus-Efficient) Scenarios—1960 Birth Cohort Men

Outcome | A-55-80-30-15 | A-55-80-20-15 | A-55-80-20-20 | A-55-80-20-25 | A-50-80-20-15 | A-50-80-20-20 | A-50-80-20-25
% eligible | 15.7% | 21.8% | 23.5% | 24.4% | 24.4% | 25.3% | 25.6%
# LDCT screens^*^ | 250,071 | 338,814 | 380,919 | 419,641 | 438,248 | 486,445 | 527,801
Avg. # of LDCT screens per person screened | 15.9 | 15.5 | 16.2 | 17.2 | 18.0 | 19.2 | 20.6
Avg. age at first screen | 55.9 | 55.6 | 55.5 | 55.5 | 51.2 | 51.2 | 51.2
Avg. age at last screen | 70.6 | 70.0 | 70.6 | 71.6 | 68.1 | 69.3 | 70.7
Avg. age at screening | 64.8 | 64.9 | 65.0 | 65.2 | 58.5 | 58.9 | 59.4
LC deaths averted^*^ | 400 | 475 | 505 | 526 | 513 | 542 | 565
Mortality reduction | 10.0% | 11.8% | 12.6% | 13.1% | 12.8% | 13.5% | 14.1%
Difference in LC deaths averted vs. USPSTF strategy | NA | 18.8% | 26.2% | 31.5% | 28.2% | 35.5% | 41.2%
Avg. # screens per LC deaths averted | 625 | 713 | 754 | 798 | 854 | 898 | 934
LYG^*^ | 5,078 | 6,022 | 6,396 | 6,664 | 7,031 | 7,397 | 7,696
Difference in LYG vs. USPSTF strategy | NA | 18.6% | 26.0% | 31.2% | 38.5% | 45.7% | 51.6%
Avg. # screens per LYG | 49 | 56 | 60 | 63 | 62 | 66 | 69
NNS | 39 | 46 | 47 | 46 | 48 | 47 | 45
False-positive screens per person screened | 1.9 | 1.9 | 1.9 | 2.0 | 2.1 | 2.3 | 2.4
Biopsies | 569 | 701 | 757 | 804 | 796 | 854 | 902
Overdiagnosed cases^*^ | 74 | 85 | 92 | 96 | 87 | 92 | 97
Overdiagnosis rate per screen-detected cancers | 6.1% | 6.0% | 6.1% | 6.1% | 5.8% | 5.8% | 5.9%
Radiation-related lung cancer deaths^*^ | 19.2 | 25.5 | 27.0 | 28.0 | 34.8 | 36.6 | 38.3

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 10 Comparison of 2013 USPSTF-Recommended (A-55-80-30-15) and Selected Risk Factor–Based Screening (20 Pack-Year Consensus-Efficient) Scenarios—1960 Birth Cohort Women

Outcome | A-55-80-30-15 | A-55-80-20-15 | A-55-80-20-20 | A-55-80-20-25 | A-50-80-20-15 | A-50-80-20-20 | A-50-80-20-25
% eligible | 12.4% | 19.3% | 20.4% | 20.9% | 20.9% | 21.4% | 21.5%
# LDCT screens^*^ | 204,815 | 321,376 | 358,302 | 389,551 | 399,813 | 440,469 | 473,059
Avg. # of LDCT screens per person screened | 16.5 | 16.7 | 17.6 | 18.6 | 19.1 | 20.6 | 22.0
Avg. age at first screen | 56.7 | 55.8 | 55.8 | 55.8 | 51.9 | 51.8 | 51.8
Avg. age at last screen | 72.1 | 71.5 | 72.3 | 73.4 | 70.0 | 71.4 | 72.7
Avg. age at screening | 65.4 | 65.4 | 65.6 | 65.9 | 59.5 | 60.0 | 60.5
LC deaths averted^*^ | 362 | 463 | 495 | 520 | 492 | 526 | 551
Mortality reduction | 9.7% | 12.4% | 13.2% | 13.9% | 13.2% | 14.1% | 14.7%
Difference in LC deaths averted vs. USPSTF strategy | NA | 27.9% | 36.7% | 43.6% | 35.9% | 45.3% | 52.2%
Avg. # screens per LC deaths averted | 566 | 694 | 724 | 749 | 813 | 837 | 859
LYG^*^ | 4,685 | 6,014 | 6,363 | 6,645 | 6,805 | 7,205 | 7,496
Difference in LYG vs. USPSTF strategy | NA | 28.4% | 35.8% | 41.8% | 45.3% | 53.8% | 60.0%
Avg. # screens per LYG | 44 | 53 | 56 | 59 | 59 | 61 | 63
NNS | 34 | 42 | 41 | 40 | 42 | 41 | 39
False-positive screens per person screened | 2.0 | 2.0 | 2.1 | 2.2 | 2.3 | 2.4 | 2.5
Biopsies | 467 | 633 | 686 | 726 | 703 | 754 | 796
Overdiagnosed cases^*^ | 64 | 80 | 87 | 91 | 82 | 86 | 90
Overdiagnosis rate per screen-detected cancers | 6.4% | 6.4% | 6.5% | 6.4% | 6.3% | 6.2% | 6.2%
Radiation-related lung cancer deaths^*^ | 22.0 | 32.4 | 34.2 | 35.8 | 42.4 | 44.6 | 46.7

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 11 Benefits of 267 Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC deaths averted | NNS
B-55-75-40-10 | 9.0 | 64,607 | 569 | 4.5 | 173 | 2,405 | 13.9 | 27 | 373 | 52
B-50-75-MPLCOm2012-0.023 | 12.6 | 67,076 | 654 | 4.9 | 192 | 2,436 | 12.7 | 28 | 349 | 66
B-55-77-40-10 | 9.0 | 67,867 | 627 | 4.9 | 189 | 2,523 | 13.3 | 27 | 359 | 48
B-55-75-MPLCOm2012-0.023 | 12.7 | 68,309 | 671 | 5.1 | 196 | 2,471 | 12.6 | 28 | 349 | 65
B-55-75-40-15 | 9.3 | 70,408 | 601 | 4.7 | 183 | 2,559 | 14.0 | 28 | 385 | 51
B-55-80-40-10 | 9.0 | 70,999 | 681 | 5.3 | 204 | 2,610 | 12.8 | 27 | 348 | 44
B-50-75-MPLCOm2012-0.022 | 13.1 | 71,120 | 672 | 5.1 | 199 | 2,546 | 12.8 | 28 | 357 | 66
B-55-75-MPLCOm2012-0.022 | 13.1 | 72,215 | 688 | 5.3 | 206 | 2,602 | 12.6 | 28 | 351 | 64
B-50-75-Bach-0.034 | 14.6 | 72,902 | 685 | 5.2 | 203 | 2,577 | 12.7 | 28 | 359 | 72
B-55-75-Bach-0.034 | 14.7 | 74,244 | 698 | 5.4 | 207 | 2,599 | 12.6 | 29 | 359 | 71
B-55-77-40-15 | 9.3 | 74,368 | 663 | 5.2 | 201 | 2,648 | 13.2 | 28 | 370 | 46
B-50-75-MPLCOm2012-0.021 | 13.5 | 75,334 | 693 | 5.3 | 206 | 2,665 | 12.9 | 28 | 366 | 66
B-50-75-40-10 | 9.5 | 75,796 | 578 | 4.6 | 179 | 2,666 | 14.9 | 28 | 423 | 53
B-55-75-MPLCOm2012-0.021 | 13.6 | 76,427 | 706 | 5.4 | 210 | 2,670 | 12.7 | 29 | 364 | 65
B-50-77-MPLCOm2012-0.023 | 13.2 | 76,449 | 767 | 5.8 | 224 | 2,673 | 11.9 | 29 | 341 | 59
B-50-75-Bach-0.033 | 15.1 | 76,596 | 700 | 5.3 | 207 | 2,648 | 12.8 | 29 | 370 | 73
B-55-77-MPLCOm2012-0.023 | 13.3 | 77,651 | 781 | 5.9 | 230 | 2,705 | 11.8 | 29 | 338 | 58
B-55-75-Bach-0.033 | 15.2 | 77,925 | 713 | 5.5 | 214 | 2,685 | 12.5 | 29 | 364 | 71
B-55-80-40-15 | 9.4 | 78,245 | 729 | 5.6 | 218 | 2,751 | 12.6 | 28 | 359 | 43
B-50-77-MLCDRAT-0.023 | 14.8 | 78,818 | 767 | 5.7 | 223 | 2,608 | 11.7 | 30 | 353 | 66
B-50-77-40-10 | 9.5 | 79,248 | 634 | 5.0 | 196 | 2,765 | 14.1 | 29 | 404 | 48
B-55-77-40-20 | 9.5 | 79,273 | 689 | 5.3 | 207 | 2,743 | 13.3 | 29 | 383 | 46
B-55-77-MLCDRAT-0.023 | 14.9 | 80,013 | 782 | 5.8 | 227 | 2,618 | 11.5 | 31 | 352 | 66
B-50-75-MPLCOm2012-0.02 | 14.0 | 80,036 | 714 | 5.4 | 211 | 2,755 | 13.1 | 29 | 379 | 66
B-50-77-MPLCOm2012-0.022 | 13.7 | 80,825 | 786 | 5.9 | 230 | 2,782 | 12.1 | 29 | 351 | 60
B-55-75-MPLCOm2012-0.02 | 14.1 | 81,162 | 725 | 5.6 | 217 | 2,787 | 12.8 | 29 | 374 | 65
B-55-77-MPLCOm2012-0.022 | 13.8 | 81,893 | 799 | 6.1 | 236 | 2,809 | 11.9 | 29 | 347 | 58
B-50-75-40-15 | 9.7 | 81,993 | 606 | 4.9 | 189 | 2,810 | 14.9 | 29 | 434 | 51
B-50-80-40-10 | 9.6 | 83,744 | 722 | 5.6 | 219 | 2,910 | 13.3 | 29 | 382 | 44
B-55-80-40-20 | 9.6 | 83,861 | 761 | 5.9 | 227 | 2,871 | 12.6 | 29 | 369 | 42
B-50-77-Bach-0.034 | 15.5 | 83,925 | 804 | 6.1 | 237 | 2,821 | 11.9 | 30 | 354 | 65
B-55-77-Bach-0.034 | 15.7 | 85,280 | 816 | 6.3 | 243 | 2,868 | 11.8 | 30 | 351 | 65
B-50-75-MPLCOm2012-0.019 | 14.6 | 85,284 | 735 | 5.7 | 220 | 2,887 | 13.1 | 30 | 388 | 66
B-50-77-MPLCOm2012-0.021 | 14.2 | 85,344 | 808 | 6.1 | 236 | 2,870 | 12.2 | 30 | 362 | 60
B-50-77-40-15 | 9.7 | 86,158 | 673 | 5.3 | 208 | 2,940 | 14.1 | 29 | 414 | 47
B-55-77-MPLCOm2012-0.021 | 14.2 | 86,395 | 821 | 6.3 | 244 | 2,910 | 11.9 | 30 | 354 | 58
B-55-75-MPLCOm2012-0.019 | 14.7 | 86,605 | 748 | 5.8 | 225 | 2,907 | 12.9 | 30 | 385 | 65
B-50-77-Bach-0.033 | 16.0 | 87,952 | 821 | 6.3 | 244 | 2,930 | 12.0 | 30 | 360 | 66
B-55-77-Bach-0.033 | 16.1 | 89,277 | 836 | 6.4 | 247 | 2,935 | 11.9 | 30 | 361 | 65
B-55-80-MPLCOm2012-0.023 | 14.1 | 89,961 | 934 | 6.9 | 269 | 2,938 | 10.9 | 31 | 334 | 52
B-50-77-MPLCOm2012-0.02 | 14.7 | 90,392 | 830 | 6.3 | 246 | 3,006 | 12.2 | 30 | 367 | 60
B-50-80-MPLCOm2012-0.023 | 14.2 | 90,966 | 951 | 7.1 | 275 | 2,970 | 10.8 | 31 | 331 | 52
B-50-77-40-20 | 9.8 | 91,142 | 695 | 5.6 | 216 | 3,029 | 14.0 | 30 | 422 | 45
B-55-77-MPLCOm2012-0.02 | 14.8 | 91,484 | 841 | 6.5 | 250 | 3,012 | 12.0 | 30 | 366 | 59
B-50-80-40-15 | 9.8 | 91,757 | 769 | 6.0 | 234 | 3,070 | 13.1 | 30 | 392 | 42
B-50-77-Bach-0.032 | 16.5 | 92,216 | 840 | 6.4 | 248 | 2,990 | 12.1 | 31 | 372 | 67
B-55-80-MLCDRAT-0.023 | 15.5 | 92,514 | 933 | 6.8 | 265 | 2,838 | 10.7 | 33 | 349 | 58
B-50-80-MLCDRAT-0.023 | 15.5 | 93,592 | 951 | 7.1 | 274 | 2,881 | 10.5 | 32 | 342 | 57
B-50-77-40-25 | 9.8 | 94,455 | 710 | 5.7 | 221 | 3,104 | 14.0 | 30 | 427 | 44
B-55-80-MPLCOm2012-0.022 | 14.6 | 94,628 | 957 | 7.2 | 278 | 3,062 | 11.0 | 31 | 340 | 53
B-50-80-MPLCOm2012-0.022 | 14.7 | 95,837 | 974 | 7.3 | 283 | 3,074 | 10.9 | 31 | 339 | 52
B-50-77-MPLCOm2012-0.019 | 15.2 | 95,987 | 853 | 6.6 | 254 | 3,131 | 12.3 | 31 | 378 | 60
B-50-77-Bach-0.031 | 17.0 | 96,543 | 862 | 6.6 | 254 | 3,069 | 12.1 | 31 | 380 | 67
B-50-75-MPLCOm2012-0.017 | 15.7 | 97,041 | 776 | 6.0 | 232 | 3,117 | 13.4 | 31 | 418 | 68
B-55-77-MPLCOm2012-0.019 | 15.3 | 97,287 | 865 | 6.7 | 260 | 3,154 | 12.1 | 31 | 374 | 59
B-50-80-40-20 | 9.9 | 97,823 | 806 | 6.3 | 246 | 3,211 | 13.1 | 30 | 398 | 40
B-55-77-Bach-0.031 | 17.1 | 97,940 | 874 | 6.7 | 262 | 3,111 | 11.9 | 31 | 374 | 65
B-55-80-MPLCOm2012-0.021 | 15.1 | 99,674 | 984 | 7.3 | 285 | 3,161 | 11.1 | 32 | 350 | 53
B-50-80-MPLCOm2012-0.021 | 15.2 | 101,031 | 1,001 | 7.5 | 292 | 3,203 | 11.0 | 32 | 346 | 52
B-50-77-Bach-0.03 | 17.5 | 101,222 | 880 | 6.8 | 262 | 3,180 | 12.1 | 32 | 386 | 67
B-50-80-Bach-0.034 | 16.9 | 101,409 | 1,009 | 7.5 | 292 | 3,137 | 10.7 | 32 | 347 | 58
B-55-80-Bach-0.034 | 16.9 | 101,612 | 1,013 | 7.3 | 284 | 3,100 | 10.9 | 33 | 358 | 60
B-50-77-MPLCOm2012-0.018 | 15.8 | 101,924 | 876 | 6.8 | 263 | 3,268 | 12.4 | 31 | 388 | 60
B-50-80-40-25 | 9.9 | 101,977 | 829 | 6.5 | 253 | 3,269 | 12.9 | 31 | 403 | 39
B-55-77-MPLCOm2012-0.018 | 15.9 | 102,872 | 888 | 6.8 | 264 | 3,226 | 12.2 | 32 | 390 | 60
B-55-80-MLCDRAT-0.021 | 16.6 | 103,248 | 984 | 7.4 | 287 | 3,097 | 10.8 | 33 | 360 | 58
B-50-75-MPLCOm2012-0.016 | 16.4 | 103,782 | 799 | 6.2 | 242 | 3,274 | 13.5 | 32 | 429 | 68
B-55-75-MPLCOm2012-0.016 | 16.4 | 103,925 | 812 | 6.4 | 247 | 3,254 | 13.2 | 32 | 421 | 66
B-55-80-MPLCOm2012-0.02 | 15.6 | 105,030 | 1,001 | 7.5 | 292 | 3,268 | 11.2 | 32 | 360 | 53
B-50-80-Bach-0.033 | 17.4 | 106,067 | 1,027 | 7.7 | 300 | 3,239 | 10.8 | 33 | 354 | 58
B-55-80-Bach-0.033 | 17.4 | 106,108 | 1,034 | 7.5 | 289 | 3,177 | 11.0 | 33 | 367 | 60
B-50-80-MPLCOm2012-0.02 | 15.7 | 106,418 | 1,023 | 7.7 | 300 | 3,322 | 11.1 | 32 | 355 | 52
B-50-77-MPLCOm2012-0.017 | 16.4 | 108,577 | 901 | 6.9 | 269 | 3,370 | 12.5 | 32 | 404 | 61
B-55-77-MPLCOm2012-0.017 | 16.5 | 109,070 | 912 | 7.0 | 272 | 3,352 | 12.3 | 33 | 401 | 61
B-55-80-Bach-0.032 | 17.9 | 110,822 | 1,054 | 7.6 | 295 | 3,266 | 11.1 | 34 | 376 | 61
B-50-80-Bach-0.032 | 17.9 | 110,827 | 1,049 | 7.8 | 304 | 3,299 | 10.9 | 34 | 365 | 59
B-55-80-MPLCOm2012-0.019 | 16.2 | 110,978 | 1,022 | 7.7 | 301 | 3,398 | 11.3 | 33 | 369 | 54
B-50-75-MPLCOm2012-0.015 | 17.1 | 111,552 | 824 | 6.4 | 250 | 3,410 | 13.6 | 33 | 446 | 68
B-50-80-MPLCOm2012-0.019 | 16.3 | 112,284 | 1,046 | 7.9 | 307 | 3,423 | 11.1 | 33 | 366 | 53
B-55-80-Bach-0.031 | 18.3 | 115,487 | 1,074 | 7.8 | 302 | 3,345 | 11.1 | 35 | 382 | 61
B-50-80-Bach-0.031 | 18.4 | 115,564 | 1,068 | 8.1 | 313 | 3,412 | 10.9 | 34 | 369 | 59
B-50-77-MPLCOm2012-0.016 | 17.1 | 115,780 | 924 | 7.2 | 278 | 3,529 | 12.7 | 33 | 416 | 62
B-55-77-MPLCOm2012-0.016 | 17.2 | 115,846 | 938 | 7.3 | 283 | 3,519 | 12.4 | 33 | 409 | 61
B-50-80-MLCDRAT-0.019 | 18.0 | 117,231 | 1,058 | 8.0 | 311 | 3,402 | 10.9 | 34 | 377 | 58
B-55-80-MPLCOm2012-0.018 | 16.8 | 117,313 | 1,047 | 7.9 | 306 | 3,476 | 11.4 | 34 | 383 | 55
B-55-80-Bach-0.03 | 18.8 | 119,154 | 1,069 | 8.0 | 312 | 3,473 | 11.1 | 34 | 382 | 60
B-50-80-MPLCOm2012-0.018 | 16.9 | 119,159 | 1,073 | 8.1 | 314 | 3,554 | 11.3 | 34 | 379 | 54
B-50-75-MPLCOm2012-0.014 | 17.9 | 120,192 | 847 | 6.6 | 258 | 3,542 | 13.7 | 34 | 466 | 69
B-50-80-Bach-0.03 | 18.9 | 120,957 | 1,090 | 8.3 | 321 | 3,518 | 11.0 | 34 | 377 | 59
B-55-80-MLCDRAT-0.018 | 18.4 | 121,586 | 1,066 | 8.0 | 310 | 3,446 | 11.1 | 35 | 392 | 59
B-50-80-MLCDRAT-0.018 | 18.5 | 123,032 | 1,084 | 8.2 | 318 | 3,497 | 11.0 | 35 | 387 | 58
B-55-77-MPLCOm2012-0.015 | 17.9 | 123,731 | 963 | 7.5 | 292 | 3,641 | 12.5 | 34 | 424 | 61
B-50-77-MPLCOm2012-0.015 | 17.8 | 124,014 | 951 | 7.4 | 286 | 3,654 | 12.8 | 34 | 434 | 62
B-55-80-Bach-0.029 | 19.3 | 124,216 | 1,090 | 8.2 | 318 | 3,537 | 11.1 | 35 | 391 | 61
B-55-80-MPLCOm2012-0.017 | 17.4 | 124,249 | 1,078 | 8.1 | 315 | 3,591 | 11.4 | 35 | 394 | 55
B-50-80-Bach-0.029 | 19.4 | 126,151 | 1,112 | 8.4 | 327 | 3,606 | 11.0 | 35 | 386 | 59
B-50-80-MPLCOm2012-0.017 | 17.5 | 126,738 | 1,105 | 8.4 | 326 | 3,699 | 11.3 | 34 | 389 | 54
B-50-75-MPLCOm2012-0.013 | 18.7 | 129,678 | 873 | 6.9 | 269 | 3,718 | 13.8 | 35 | 482 | 70
B-55-80-Bach-0.028 | 19.8 | 129,813 | 1,108 | 8.4 | 326 | 3,634 | 11.1 | 36 | 398 | 61
B-55-80-MPLCOm2012-0.016 | 18.1 | 131,558 | 1,102 | 8.4 | 325 | 3,761 | 11.6 | 35 | 405 | 56
B-50-80-Bach-0.028 | 19.9 | 131,788 | 1,131 | 8.6 | 333 | 3,696 | 11.1 | 36 | 396 | 60
B-55-77-MPLCOm2012-0.014 | 18.7 | 132,093 | 988 | 7.8 | 303 | 3,797 | 12.5 | 35 | 436 | 62
B-50-77-MPLCOm2012-0.014 | 18.6 | 133,200 | 976 | 7.7 | 297 | 3,834 | 12.9 | 35 | 448 | 63
B-50-80-MPLCOm2012-0.016 | 18.2 | 134,642 | 1,130 | 8.6 | 335 | 3,873 | 11.6 | 35 | 402 | 54
B-50-80-Bach-0.027 | 20.5 | 137,862 | 1,152 | 8.7 | 339 | 3,799 | 11.2 | 36 | 407 | 60
B-50-80-MLCDRAT-0.016 | 19.9 | 138,763 | 1,141 | 8.7 | 337 | 3,774 | 11.2 | 37 | 412 | 59
B-55-80-MPLCOm2012-0.015 | 18.8 | 139,739 | 1,128 | 8.6 | 335 | 3,901 | 11.6 | 36 | 417 | 56
B-50-77-MPLCOm2012-0.013 | 19.5 | 143,278 | 1,004 | 7.9 | 307 | 4,005 | 13.0 | 36 | 467 | 64
B-50-80-MPLCOm2012-0.015 | 18.9 | 143,399 | 1,158 | 8.9 | 346 | 4,021 | 11.6 | 36 | 414 | 55
B-50-80-Bach-0.026 | 21.0 | 143,828 | 1,174 | 8.9 | 347 | 3,912 | 11.3 | 37 | 414 | 61
B-55-80-Bach-0.025 | 21.5 | 147,758 | 1,169 | 8.9 | 346 | 3,948 | 11.4 | 37 | 427 | 62
B-50-80-MLCDRAT-0.015 | 20.7 | 148,360 | 1,174 | 9.0 | 348 | 3,940 | 11.3 | 38 | 426 | 59
B-55-80-MPLCOm2012-0.014 | 19.6 | 148,615 | 1,155 | 8.9 | 344 | 4,049 | 11.8 | 37 | 432 | 57
B-50-80-Bach-0.025 | 21.6 | 150,601 | 1,197 | 9.2 | 355 | 4,017 | 11.3 | 37 | 424 | 61
B-50-80-MPLCOm2012-0.014 | 19.7 | 153,324 | 1,187 | 9.2 | 356 | 4,147 | 11.6 | 37 | 431 | 55
B-55-80-Bach-0.024 | 22.0 | 154,299 | 1,190 | 9.1 | 354 | 4,056 | 11.5 | 38 | 436 | 62
B-50-77-MPLCOm2012-0.012 | 20.4 | 154,882 | 1,035 | 8.2 | 317 | 4,152 | 13.1 | 37 | 489 | 64
B-50-80-Bach-0.024 | 22.2 | 157,520 | 1,222 | 9.4 | 362 | 4,125 | 11.4 | 38 | 435 | 61
B-55-80-MPLCOm2012-0.013 | 20.4 | 158,123 | 1,181 | 9.1 | 354 | 4,177 | 11.8 | 38 | 447 | 58
B-50-80-MLCDRAT-0.014 | 21.6 | 158,658 | 1,206 | 9.3 | 361 | 4,106 | 11.4 | 39 | 439 | 60
B-50-80-MPLCOm2012-0.013 | 20.6 | 164,259 | 1,218 | 9.5 | 367 | 4,348 | 11.8 | 38 | 448 | 56
B-50-80-Bach-0.023 | 22.7 | 164,603 | 1,242 | 9.5 | 370 | 4,239 | 11.5 | 39 | 445 | 61
B-50-77-MPLCOm2012-0.011 | 21.4 | 167,727 | 1,059 | 8.4 | 325 | 4,336 | 13.3 | 39 | 516 | 66
B-50-80-Bach-0.022 | 23.3 | 172,049 | 1,262 | 9.7 | 377 | 4,365 | 11.6 | 39 | 456 | 62
A-55-80-MPLCOm2012-0.023 | 14.3 | 174,860 | 1,177 | 10.0 | 388 | 4,161 | 10.7 | 42 | 451 | 37
A-50-80-MPLCOm2012-0.023 | 14.3 | 174,911 | 1,178 | 10.0 | 388 | 4,187 | 10.8 | 42 | 451 | 37
B-55-80-Bach-0.021 | 23.8 | 175,310 | 1,245 | 9.6 | 372 | 4,325 | 11.6 | 41 | 471 | 64
B-50-80-MPLCOm2012-0.012 | 21.6 | 176,755 | 1,253 | 9.7 | 378 | 4,527 | 12.0 | 39 | 468 | 57
A-55-80-MLCDRAT-0.023 | 15.6 | 179,310 | 1,178 | 10.0 | 388 | 4,087 | 10.5 | 44 | 462 | 40
B-50-80-Bach-0.021 | 23.9 | 180,105 | 1,280 | 9.9 | 384 | 4,457 | 11.6 | 40 | 469 | 62
B-50-77-MPLCOm2012-0.01 | 22.6 | 182,246 | 1,092 | 8.8 | 340 | 4,598 | 13.5 | 40 | 536 | 66
B-55-80-Bach-0.02 | 24.4 | 182,833 | 1,264 | 9.8 | 381 | 4,439 | 11.7 | 41 | 480 | 64
A-55-80-MPLCOm2012-0.022 | 14.7 | 184,176 | 1,204 | 10.3 | 400 | 4,334 | 10.8 | 42 | 460 | 37
A-50-80-MPLCOm2012-0.022 | 14.7 | 184,284 | 1,205 | 10.3 | 399 | 4,336 | 10.9 | 43 | 462 | 37
B-50-80-Bach-0.02 | 24.6 | 188,573 | 1,301 | 10.2 | 394 | 4,596 | 11.7 | 41 | 479 | 62
B-55-80-Bach-0.019 | 25.0 | 190,612 | 1,282 | 10.0 | 387 | 4,547 | 11.7 | 42 | 493 | 65
B-50-80-MPLCOm2012-0.011 | 22.7 | 191,379 | 1,290 | 10.1 | 393 | 4,766 | 12.1 | 40 | 487 | 58
A-55-80-MPLCOm2012-0.021 | 15.3 | 193,965 | 1,232 | 10.6 | 411 | 4,515 | 11.0 | 43 | 472 | 37
A-55-80-Bach-0.034 | 17.1 | 194,099 | 1,247 | 10.6 | 409 | 4,404 | 10.8 | 44 | 475 | 42
A-50-80-MPLCOm2012-0.021 | 15.3 | 194,193 | 1,235 | 10.6 | 410 | 4,502 | 11.0 | 43 | 474 | 37
A-50-80-Bach-0.034 | 17.1 | 194,261 | 1,248 | 10.6 | 411 | 4,417 | 10.7 | 44 | 473 | 42
B-50-80-Bach-0.019 | 25.2 | 197,209 | 1,323 | 10.3 | 400 | 4,727 | 11.8 | 42 | 493 | 63
A-55-80-Bach-0.033 | 17.5 | 202,943 | 1,272 | 10.8 | 420 | 4,539 | 10.8 | 45 | 483 | 42
A-50-80-Bach-0.033 | 17.5 | 203,167 | 1,271 | 10.8 | 419 | 4,526 | 10.8 | 45 | 485 | 42
A-55-80-MPLCOm2012-0.02 | 15.8 | 204,612 | 1,262 | 10.9 | 421 | 4,645 | 11.0 | 44 | 486 | 38
A-50-80-MPLCOm2012-0.02 | 15.8 | 205,020 | 1,262 | 10.8 | 419 | 4,662 | 11.1 | 44 | 489 | 38
B-50-80-Bach-0.018 | 25.8 | 206,581 | 1,343 | 10.5 | 408 | 4,830 | 11.8 | 43 | 506 | 63
B-50-80-MPLCOm2012-0.01 | 23.8 | 206,957 | 1,323 | 10.4 | 404 | 4,967 | 12.3 | 42 | 512 | 59
A-50-80-MLCDRAT-0.02 | 17.4 | 210,560 | 1,273 | 10.9 | 423 | 4,566 | 10.8 | 46 | 498 | 41
A-55-80-Bach-0.032 | 18.0 | 212,181 | 1,296 | 11.1 | 431 | 4,655 | 10.8 | 46 | 492 | 42
A-50-80-Bach-0.032 | 18.0 | 212,490 | 1,298 | 11.1 | 430 | 4,668 | 10.9 | 46 | 494 | 42
A-55-80-MPLCOm2012-0.019 | 16.3 | 216,291 | 1,293 | 11.2 | 434 | 4,833 | 11.1 | 45 | 498 | 38
A-50-80-MPLCOm2012-0.019 | 16.4 | 217,030 | 1,293 | 11.2 | 435 | 4,859 | 11.2 | 45 | 499 | 38
A-55-80-Bach-0.031 | 18.5 | 221,421 | 1,321 | 11.3 | 439 | 4,791 | 10.9 | 46 | 504 | 42
A-50-80-Bach-0.031 | 18.5 | 221,847 | 1,321 | 11.4 | 441 | 4,831 | 11.0 | 46 | 503 | 42
B-50-80-MPLCOm2012-0.009 | 25.0 | 225,054 | 1,357 | 10.8 | 417 | 5,169 | 12.4 | 44 | 540 | 60
A-50-80-MLCDRAT-0.019 | 18.1 | 225,292 | 1,310 | 11.3 | 437 | 4,774 | 10.9 | 47 | 516 | 41
B-50-80-Bach-0.016 | 27.3 | 227,395 | 1,388 | 10.9 | 423 | 5,099 | 12.1 | 45 | 538 | 65
A-55-80-30-15 | 14.1 | 227,443 | 1,102 | 9.8 | 381 | 4,882 | 12.8 | 47 | 597 | 37
A-55-80-MPLCOm2012-0.018 | 17.0 | 228,676 | 1,320 | 11.5 | 444 | 4,982 | 11.2 | 46 | 515 | 38
A-50-80-MPLCOm2012-0.018 | 17.0 | 229,944 | 1,327 | 11.5 | 445 | 5,021 | 11.3 | 46 | 517 | 38
A-55-80-Bach-0.03 | 19.0 | 231,518 | 1,347 | 11.6 | 450 | 4,936 | 11.0 | 47 | 514 | 42
A-50-80-Bach-0.03 | 19.0 | 232,092 | 1,350 | 11.6 | 450 | 4,969 | 11.0 | 47 | 516 | 42
A-50-80-MLCDRAT-0.018 | 18.6 | 236,479 | 1,339 | 11.6 | 450 | 4,942 | 11.0 | 48 | 526 | 41
A-55-80-MLCDRAT-0.018 | 18.6 | 236,483 | 1,340 | 11.5 | 448 | 4,916 | 11.0 | 48 | 528 | 42
A-55-80-Bach-0.029 | 19.5 | 241,484 | 1,370 | 11.8 | 459 | 5,063 | 11.0 | 48 | 526 | 42
A-50-80-Bach-0.029 | 19.5 | 242,278 | 1,374 | 11.8 | 459 | 5,084 | 11.1 | 48 | 528 | 42
A-55-80-MPLCOm2012-0.017 | 17.6 | 242,329 | 1,352 | 11.8 | 455 | 5,163 | 11.3 | 47 | 533 | 39
A-50-80-MPLCOm2012-0.017 | 17.6 | 244,349 | 1,359 | 11.8 | 457 | 5,227 | 11.4 | 47 | 535 | 39
B-50-80-MPLCOm2012-0.008 | 26.5 | 245,777 | 1,399 | 11.2 | 432 | 5,407 | 12.5 | 45 | 569 | 61
B-50-80-Bach-0.014 | 28.8 | 250,390 | 1,430 | 11.3 | 438 | 5,358 | 12.2 | 47 | 572 | 66
A-55-80-Bach-0.028 | 20.0 | 252,590 | 1,396 | 12.1 | 468 | 5,199 | 11.1 | 49 | 540 | 43
A-50-80-Bach-0.028 | 20.0 | 253,613 | 1,399 | 12.1 | 471 | 5,225 | 11.1 | 49 | 538 | 42
A-50-80-MLCDRAT-0.017 | 19.3 | 253,620 | 1,376 | 12.0 | 463 | 5,153 | 11.1 | 49 | 548 | 42
A-55-80-MPLCOm2012-0.016 | 18.3 | 256,724 | 1,383 | 12.1 | 468 | 5,341 | 11.4 | 48 | 549 | 39
A-50-80-MPLCOm2012-0.016 | 18.3 | 259,832 | 1,394 | 12.3 | 475 | 5,502 | 11.6 | 47 | 547 | 39
B-50-80-Bach-0.013 | 29.6 | 263,135 | 1,451 | 11.5 | 445 | 5,498 | 12.4 | 48 | 591 | 67
A-55-80-Bach-0.027 | 20.6 | 263,986 | 1,420 | 12.3 | 478 | 5,328 | 11.1 | 50 | 552 | 43
A-50-80-Bach-0.027 | 20.6 | 265,411 | 1,424 | 12.3 | 478 | 5,353 | 11.2 | 50 | 555 | 43
A-50-80-MLCDRAT-0.016 | 20.0 | 267,426 | 1,409 | 12.3 | 478 | 5,355 | 11.2 | 50 | 559 | 42
B-50-80-MPLCOm2012-0.007 | 28.1 | 270,148 | 1,442 | 11.6 | 449 | 5,644 | 12.6 | 48 | 602 | 63
A-55-80-MPLCOm2012-0.015 | 19.0 | 272,809 | 1,415 | 12.4 | 481 | 5,533 | 11.5 | 49 | 567 | 40
A-55-80-Bach-0.026 | 21.1 | 275,329 | 1,444 | 12.6 | 489 | 5,463 | 11.2 | 50 | 563 | 43
B-50-80-Bach-0.012 | 30.5 | 277,033 | 1,476 | 11.8 | 456 | 5,639 | 12.4 | 49 | 608 | 67
A-50-80-Bach-0.026 | 21.1 | 277,066 | 1,447 | 12.6 | 489 | 5,495 | 11.2 | 50 | 567 | 43
A-50-80-MPLCOm2012-0.015 | 19.0 | 277,426 | 1,429 | 12.6 | 488 | 5,685 | 11.6 | 49 | 568 | 39
A-50-77-MPLCOm2012-0.013 | 19.7 | 280,113 | 1,260 | 11.4 | 441 | 5,712 | 13.0 | 49 | 635 | 45
A-50-80-MLCDRAT-0.015 | 20.8 | 286,154 | 1,451 | 12.7 | 491 | 5,562 | 11.3 | 51 | 583 | 42
A-55-80-Bach-0.025 | 21.7 | 287,935 | 1,470 | 12.8 | 495 | 5,572 | 11.3 | 52 | 582 | 44
A-50-80-Bach-0.025 | 21.7 | 290,340 | 1,475 | 12.9 | 498 | 5,657 | 11.4 | 51 | 583 | 44
A-55-80-MPLCOm2012-0.014 | 19.8 | 290,431 | 1,452 | 12.7 | 494 | 5,717 | 11.6 | 51 | 588 | 40
B-50-80-Bach-0.011 | 31.5 | 292,128 | 1,499 | 12.0 | 465 | 5,800 | 12.5 | 50 | 628 | 68
B-50-80-MPLCOm2012-0.006 | 29.9 | 296,680 | 1,482 | 11.9 | 461 | 5,867 | 12.7 | 51 | 644 | 65
A-50-80-MPLCOm2012-0.014 | 19.8 | 297,009 | 1,466 | 13.0 | 503 | 5,925 | 11.8 | 50 | 590 | 39
A-55-80-Bach-0.024 | 22.2 | 300,842 | 1,494 | 13.1 | 507 | 5,735 | 11.3 | 52 | 593 | 44
A-50-77-MPLCOm2012-0.012 | 20.6 | 303,023 | 1,296 | 11.7 | 455 | 5,960 | 13.1 | 51 | 666 | 45
A-55-80-MLCDRAT-0.014 | 21.7 | 303,286 | 1,480 | 13.0 | 504 | 5,722 | 11.4 | 53 | 602 | 43
A-50-80-Bach-0.024 | 22.3 | 303,778 | 1,502 | 13.2 | 510 | 5,840 | 11.5 | 52 | 596 | 44
A-50-80-MLCDRAT-0.014 | 21.7 | 306,138 | 1,487 | 13.1 | 507 | 5,808 | 11.5 | 53 | 604 | 43
B-50-80-Bach-0.01 | 32.6 | 308,091 | 1,527 | 12.2 | 472 | 5,924 | 12.6 | 52 | 653 | 69
A-55-80-MPLCOm2012-0.013 | 20.6 | 309,284 | 1,482 | 13.1 | 508 | 5,933 | 11.7 | 52 | 609 | 41
A-55-80-Bach-0.023 | 22.8 | 313,914 | 1,520 | 13.4 | 518 | 5,898 | 11.4 | 53 | 606 | 44
A-50-80-Bach-0.023 | 22.9 | 317,678 | 1,530 | 13.4 | 521 | 5,999 | 11.5 | 53 | 610 | 44
A-50-80-MPLCOm2012-0.013 | 20.7 | 318,502 | 1,502 | 13.3 | 514 | 6,136 | 11.9 | 52 | 620 | 40
A-55-80-MLCDRAT-0.013 | 22.6 | 320,862 | 1,516 | 13.4 | 520 | 5,935 | 11.4 | 54 | 617 | 43
A-50-80-MLCDRAT-0.013 | 22.7 | 325,175 | 1,524 | 13.5 | 522 | 6,033 | 11.6 | 54 | 623 | 43
B-50-80-Bach-0.009 | 33.8 | 325,901 | 1,554 | 12.5 | 484 | 6,136 | 12.7 | 53 | 673 | 70
B-50-80-MPLCOm2012-0.005 | 31.9 | 327,272 | 1,522 | 12.3 | 477 | 6,149 | 12.9 | 53 | 686 | 67
A-55-80-Bach-0.022 | 23.4 | 327,719 | 1,542 | 13.6 | 527 | 6,024 | 11.4 | 54 | 622 | 44
A-50-77-MPLCOm2012-0.011 | 21.6 | 328,622 | 1,331 | 12.1 | 469 | 6,212 | 13.2 | 53 | 701 | 46
A-55-80-20-15 | 20.6 | 330,095 | 1,334 | 12.1 | 469 | 6,018 | 12.8 | 55 | 704 | 44
A-55-80-MPLCOm2012-0.012 | 21.6 | 330,347 | 1,519 | 13.4 | 520 | 6,146 | 11.8 | 54 | 635 | 42
A-50-80-Bach-0.022 | 23.4 | 332,451 | 1,550 | 13.7 | 531 | 6,167 | 11.6 | 54 | 626 | 44
A-55-80-Bach-0.021 | 24.0 | 342,337 | 1,566 | 13.9 | 538 | 6,197 | 11.5 | 55 | 636 | 45
A-50-80-MPLCOm2012-0.012 | 21.7 | 343,293 | 1,543 | 13.7 | 532 | 6,409 | 12.0 | 54 | 645 | 41
A-55-80-MLCDRAT-0.012 | 23.8 | 343,713 | 1,551 | 13.7 | 532 | 6,126 | 11.5 | 56 | 646 | 45
A-50-80-Bach-0.021 | 24.1 | 348,282 | 1,577 | 14.0 | 541 | 6,340 | 11.7 | 55 | 644 | 45
A-50-80-MLCDRAT-0.012 | 23.9 | 350,286 | 1,564 | 13.9 | 537 | 6,271 | 11.7 | 56 | 652 | 45
A-55-80-MPLCOm2012-0.011 | 22.6 | 352,002 | 1,552 | 13.8 | 535 | 6,348 | 11.9 | 55 | 658 | 42
A-55-80-Bach-0.02 | 24.6 | 357,203 | 1,586 | 14.1 | 545 | 6,319 | 11.6 | 57 | 655 | 45
A-50-77-MPLCOm2012-0.01 | 22.7 | 357,345 | 1,369 | 12.6 | 488 | 6,529 | 13.4 | 55 | 732 | 47
A-50-80-Bach-0.02 | 24.7 | 364,767 | 1,603 | 14.3 | 555 | 6,545 | 11.8 | 56 | 657 | 45
A-55-80-MLCDRAT-0.011 | 25.5 | 369,025 | 1,595 | 14.2 | 549 | 6,384 | 11.6 | 58 | 672 | 46
A-55-80-20-20 | 22.0 | 369,610 | 1,423 | 12.9 | 500 | 6,379 | 12.8 | 58 | 739 | 44
A-50-80-MPLCOm2012-0.011 | 22.8 | 370,909 | 1,582 | 14.2 | 550 | 6,686 | 12.2 | 55 | 674 | 41
A-55-80-Bach-0.019 | 25.2 | 372,598 | 1,611 | 14.3 | 554 | 6,458 | 11.7 | 58 | 673 | 45
A-55-80-MPLCOm2012-0.01 | 23.7 | 375,484 | 1,586 | 14.1 | 548 | 6,519 | 11.9 | 58 | 685 | 43
A-50-80-MLCDRAT-0.011 | 25.5 | 377,864 | 1,613 | 14.4 | 558 | 6,607 | 11.8 | 57 | 677 | 46
A-50-80-Bach-0.019 | 25.3 | 381,778 | 1,624 | 14.4 | 559 | 6,652 | 11.9 | 57 | 683 | 45
A-55-80-Bach-0.018 | 25.8 | 389,243 | 1,632 | 14.5 | 563 | 6,589 | 11.7 | 59 | 691 | 46
A-55-80-MLCDRAT-0.01 | 27.7 | 398,180 | 1,641 | 14.6 | 564 | 6,605 | 11.7 | 60 | 706 | 49
A-50-80-Bach-0.018 | 26.0 | 400,457 | 1,653 | 14.8 | 572 | 6,846 | 12.0 | 58 | 700 | 45
A-50-80-MPLCOm2012-0.01 | 23.9 | 401,856 | 1,622 | 14.6 | 564 | 6,957 | 12.3 | 58 | 713 | 42
A-55-80-20-25 | 22.7 | 404,596 | 1,492 | 13.5 | 523 | 6,654 | 12.7 | 61 | 774 | 43
A-55-80-Bach-0.017 | 26.5 | 406,323 | 1,657 | 14.9 | 575 | 6,774 | 11.8 | 60 | 707 | 46
A-50-80-MLCDRAT-0.01 | 27.9 | 409,804 | 1,662 | 14.8 | 575 | 6,871 | 11.9 | 60 | 713 | 49
A-50-80-20-15 | 22.6 | 419,030 | 1,401 | 13.0 | 503 | 6,918 | 13.8 | 61 | 833 | 45
A-50-80-Bach-0.017 | 26.6 | 420,352 | 1,678 | 15.1 | 586 | 7,039 | 12.0 | 60 | 717 | 45
A-55-80-Bach-0.016 | 27.2 | 423,929 | 1,677 | 15.0 | 582 | 6,908 | 11.9 | 61 | 728 | 47
A-55-80-MPLCOm2012-0.008 | 26.2 | 432,557 | 1,662 | 14.9 | 579 | 6,975 | 12.0 | 62 | 747 | 45
A-55-80-MLCDRAT-0.009 | 30.4 | 433,597 | 1,696 | 15.0 | 583 | 6,869 | 11.8 | 63 | 744 | 52
A-50-80-MPLCOm2012-0.009 | 25.1 | 437,273 | 1,665 | 15.0 | 582 | 7,291 | 12.5 | 60 | 751 | 43
A-50-80-Bach-0.016 | 27.4 | 441,294 | 1,704 | 15.4 | 595 | 7,190 | 12.1 | 61 | 742 | 46
A-55-80-Bach-0.015 | 27.9 | 442,384 | 1,700 | 15.3 | 592 | 7,034 | 11.9 | 63 | 747 | 47
A-50-80-MLCDRAT-0.009 | 30.6 | 449,030 | 1,717 | 15.4 | 596 | 7,168 | 12.0 | 63 | 753 | 51
A-55-80-Bach-0.014 | 28.7 | 461,609 | 1,723 | 15.5 | 602 | 7,179 | 11.9 | 64 | 767 | 48
A-50-80-Bach-0.015 | 28.1 | 463,301 | 1,727 | 15.6 | 605 | 7,391 | 12.2 | 63 | 766 | 46
A-50-80-20-20 | 23.3 | 463,457 | 1,487 | 13.8 | 534 | 7,301 | 13.7 | 63 | 868 | 44
A-55-80-MLCDRAT-0.008 | 33.3 | 474,060 | 1,749 | 15.6 | 606 | 7,147 | 11.8 | 66 | 782 | 55
A-50-80-MPLCOm2012-0.008 | 26.6 | 478,349 | 1,710 | 15.5 | 601 | 7,564 | 12.6 | 63 | 796 | 44
A-55-80-Bach-0.013 | 29.5 | 482,093 | 1,744 | 15.8 | 610 | 7,330 | 12.0 | 66 | 790 | 48
A-50-80-Bach-0.014 | 28.9 | 486,484 | 1,752 | 15.9 | 616 | 7,582 | 12.3 | 64 | 790 | 47
A-50-80-MLCDRAT-0.008 | 33.5 | 495,424 | 1,779 | 16.0 | 619 | 7,508 | 12.1 | 66 | 800 | 54
A-50-80-20-25 | 23.6 | 500,430 | 1,560 | 14.4 | 558 | 7,596 | 13.6 | 66 | 897 | 42
A-55-80-Bach-0.012 | 30.3 | 503,871 | 1,768 | 16.0 | 617 | 7,467 | 12.1 | 67 | 817 | 49
A-50-80-Bach-0.013 | 29.7 | 511,462 | 1,778 | 16.2 | 627 | 7,746 | 12.4 | 66 | 816 | 47
A-55-80-MLCDRAT-0.007 | 36.3 | 520,869 | 1,805 | 16.2 | 629 | 7,496 | 11.9 | 69 | 828 | 58
A-50-80-MPLCOm2012-0.007 | 28.2 | 524,392 | 1,754 | 16.0 | 620 | 7,904 | 12.7 | 66 | 846 | 45
A-55-80-Bach-0.011 | 31.3 | 527,263 | 1,793 | 16.2 | 628 | 7,606 | 12.1 | 69 | 840 | 50
A-50-80-Bach-0.012 | 30.6 | 538,488 | 1,806 | 16.4 | 635 | 7,914 | 12.5 | 68 | 848 | 48
A-50-80-MLCDRAT-0.007 | 36.5 | 550,777 | 1,843 | 16.7 | 647 | 7,943 | 12.3 | 69 | 851 | 56
A-55-80-Bach-0.01 | 32.3 | 551,762 | 1,816 | 16.5 | 639 | 7,773 | 12.2 | 71 | 863 | 51
A-50-80-Bach-0.011 | 31.6 | 568,005 | 1,834 | 16.7 | 648 | 8,156 | 12.6 | 70 | 877 | 49
A-50-80-MPLCOm2012-0.006 | 30.0 | 575,496 | 1,797 | 16.4 | 635 | 8,164 | 12.9 | 70 | 906 | 47
A-55-80-MLCDRAT-0.006 | 39.0 | 577,420 | 1,865 | 16.9 | 655 | 7,830 | 12.0 | 74 | 882 | 60
A-50-80-Bach-0.01 | 32.7 | 599,143 | 1,862 | 17.1 | 662 | 8,387 | 12.7 | 71 | 905 | 49
A-50-80-MLCDRAT-0.006 | 39.3 | 616,864 | 1,908 | 17.4 | 674 | 8,383 | 12.4 | 74 | 915 | 58
A-50-80-Bach-0.009 | 33.9 | 633,671 | 1,888 | 17.5 | 676 | 8,600 | 12.7 | 74 | 937 | 50
A-50-80-MPLCOm2012-0.005 | 32.0 | 635,352 | 1,848 | 17.1 | 660 | 8,585 | 13.0 | 74 | 963 | 48
A-50-80-Bach-0.008 | 35.1 | 671,522 | 1,920 | 17.8 | 688 | 8,822 | 12.8 | 76 | 976 | 51
A-50-80-MLCDRAT-0.005 | 41.9 | 700,139 | 1,969 | 18.1 | 700 | 8,805 | 12.6 | 80 | 1,000 | 60
A-50-80-MPLCOm2012-0.004 | 34.2 | 708,806 | 1,894 | 17.6 | 681 | 8,944 | 13.1 | 79 | 1,041 | 50
A-55-80-MLCDRAT-0.004 | 43.4 | 714,694 | 1,967 | 18.1 | 700 | 8,509 | 12.2 | 84 | 1,021 | 62
A-50-80-MLCDRAT-0.004 | 44.0 | 790,911 | 2,027 | 18.8 | 728 | 9,318 | 12.8 | 85 | 1,086 | 60

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 12 Harms of 267 Consensus-Efficient Risk Model-Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^*^
B-55-75-40-10 | 64,607 | 76,031 | 7.2 | 1.1 | 241 | 27 | 0.5 | 4.7 | 6.8
B-50-75-MPLCOm2012-0.023 | 67,076 | 79,108 | 5.3 | 0.8 | 274 | 33 | 0.7 | 5.0 | 5.7
B-55-77-40-10 | 67,867 | 79,460 | 7.5 | 1.1 | 262 | 32 | 0.6 | 5.1 | 6.8
B-55-75-MPLCOm2012-0.023 | 68,309 | 80,492 | 5.4 | 0.8 | 280 | 35 | 0.7 | 5.2 | 5.7
B-55-75-40-15 | 70,408 | 82,183 | 7.6 | 1.1 | 256 | 28 | 0.6 | 4.7 | 7.3
B-55-80-40-10 | 70,999 | 82,748 | 7.9 | 1.1 | 281 | 38 | 0.8 | 5.6 | 7.0
B-50-75-MPLCOm2012-0.022 | 71,120 | 83,443 | 5.4 | 0.8 | 283 | 34 | 0.7 | 5.1 | 6.1
B-55-75-MPLCOm2012-0.022 | 72,215 | 84,666 | 5.5 | 0.9 | 289 | 36 | 0.7 | 5.2 | 6.1
B-50-75-Bach-0.034 | 72,902 | 85,518 | 5.0 | 0.8 | 290 | 35 | 0.7 | 5.1 | 6.5
B-55-75-Bach-0.034 | 74,244 | 87,029 | 5.1 | 0.8 | 295 | 35 | 0.7 | 5.0 | 6.4
B-55-77-40-15 | 74,368 | 86,348 | 8.0 | 1.1 | 278 | 34 | 0.7 | 5.1 | 7.3
B-50-75-MPLCOm2012-0.021 | 75,334 | 87,933 | 5.6 | 0.9 | 293 | 35 | 0.7 | 5.1 | 6.7
B-50-75-40-10 | 75,796 | 87,827 | 8.0 | 1.2 | 253 | 26 | 0.5 | 4.5 | 8.9
B-55-75-MPLCOm2012-0.021 | 76,427 | 89,164 | 5.6 | 0.9 | 299 | 37 | 0.7 | 5.2 | 6.6
B-50-77-MPLCOm2012-0.023 | 76,449 | 89,055 | 5.8 | 0.9 | 317 | 43 | 0.9 | 5.6 | 6.1
B-50-75-Bach-0.033 | 76,596 | 89,468 | 5.1 | 0.8 | 298 | 35 | 0.7 | 5.0 | 7.0
B-55-77-MPLCOm2012-0.023 | 77,651 | 90,393 | 5.8 | 0.9 | 322 | 44 | 0.9 | 5.6 | 6.1
B-55-75-Bach-0.033 | 77,925 | 90,958 | 5.1 | 0.8 | 304 | 36 | 0.7 | 5.0 | 6.9
B-55-80-40-15 | 78,245 | 90,409 | 8.3 | 1.2 | 301 | 41 | 0.8 | 5.6 | 7.4
B-50-77-MLCDRAT-0.023 | 78,818 | 91,788 | 5.3 | 0.8 | 320 | 44 | 0.9 | 5.7 | 5.8
B-50-77-40-10 | 79,248 | 91,457 | 8.3 | 1.2 | 273 | 30 | 0.6 | 4.7 | 9.0
B-55-77-40-20 | 79,273 | 91,528 | 8.3 | 1.2 | 289 | 35 | 0.7 | 5.1 | 7.5
B-55-77-MLCDRAT-0.023 | 80,013 | 93,128 | 5.4 | 0.8 | 326 | 46 | 0.9 | 5.9 | 5.8
B-50-75-MPLCOm2012-0.02 | 80,036 | 92,949 | 5.7 | 0.9 | 304 | 36 | 0.7 | 5.0 | 7.2
B-50-77-MPLCOm2012-0.022 | 80,825 | 93,729 | 5.9 | 0.9 | 327 | 44 | 0.9 | 5.6 | 6.5
B-55-75-MPLCOm2012-0.02 | 81,162 | 94,209 | 5.8 | 0.9 | 309 | 37 | 0.8 | 5.1 | 7.1
B-55-77-MPLCOm2012-0.022 | 81,893 | 94,926 | 5.9 | 0.9 | 332 | 45 | 0.9 | 5.6 | 6.5
B-50-75-40-15 | 81,993 | 94,358 | 8.5 | 1.2 | 266 | 27 | 0.5 | 4.5 | 9.3
B-50-80-40-10 | 83,744 | 96,205 | 8.7 | 1.2 | 304 | 40 | 0.8 | 5.5 | 9.1
B-55-80-40-20 | 83,861 | 96,341 | 8.7 | 1.2 | 315 | 44 | 0.9 | 5.8 | 7.7
B-50-77-Bach-0.034 | 83,925 | 97,234 | 5.4 | 0.8 | 336 | 45 | 0.9 | 5.6 | 6.8
B-55-77-Bach-0.034 | 85,280 | 98,765 | 5.4 | 0.8 | 342 | 46 | 0.9 | 5.6 | 6.8
B-50-75-MPLCOm2012-0.019 | 85,284 | 98,517 | 5.8 | 0.9 | 315 | 36 | 0.7 | 4.9 | 7.9
B-50-77-MPLCOm2012-0.021 | 85,344 | 98,554 | 6.0 | 0.9 | 337 | 45 | 0.9 | 5.6 | 7.0
B-50-77-40-15 | 86,158 | 98,746 | 8.9 | 1.3 | 290 | 32 | 0.7 | 4.8 | 9.4
B-55-77-MPLCOm2012-0.021 | 86,395 | 99,720 | 6.1 | 0.9 | 343 | 46 | 0.9 | 5.6 | 7.0
B-55-75-MPLCOm2012-0.019 | 86,605 | 100,021 | 5.9 | 0.9 | 321 | 38 | 0.8 | 5.1 | 7.7
B-50-77-Bach-0.033 | 87,952 | 101,542 | 5.5 | 0.8 | 345 | 45 | 0.9 | 5.5 | 7.4
B-55-77-Bach-0.033 | 89,277 | 103,030 | 5.5 | 0.8 | 351 | 47 | 1.0 | 5.6 | 7.3
B-55-80-MPLCOm2012-0.023 | 89,961 | 103,385 | 6.4 | 0.9 | 380 | 60 | 1.2 | 6.4 | 6.4
B-50-77-MPLCOm2012-0.02 | 90,392 | 103,922 | 6.1 | 0.9 | 348 | 46 | 0.9 | 5.5 | 7.5
B-50-80-MPLCOm2012-0.023 | 90,966 | 104,505 | 6.4 | 0.9 | 386 | 62 | 1.3 | 6.5 | 6.4
B-50-77-40-20 | 91,142 | 103,995 | 9.3 | 1.3 | 300 | 34 | 0.7 | 4.9 | 9.6
B-55-77-MPLCOm2012-0.02 | 91,484 | 105,148 | 6.2 | 0.9 | 353 | 47 | 0.9 | 5.6 | 7.4
B-50-80-40-15 | 91,757 | 104,657 | 9.4 | 1.3 | 324 | 43 | 0.9 | 5.6 | 9.5
B-50-77-Bach-0.032 | 92,216 | 106,093 | 5.6 | 0.8 | 355 | 47 | 0.9 | 5.6 | 7.6
B-55-80-MLCDRAT-0.023 | 92,514 | 106,280 | 6.0 | 0.9 | 383 | 62 | 1.2 | 6.6 | 6.2
B-50-80-MLCDRAT-0.023 | 93,592 | 107,488 | 6.0 | 0.9 | 390 | 63 | 1.3 | 6.6 | 6.2
B-50-77-40-25 | 94,455 | 107,470 | 9.6 | 1.3 | 307 | 34 | 0.7 | 4.8 | 9.7
B-55-80-MPLCOm2012-0.022 | 94,628 | 108,355 | 6.5 | 0.9 | 391 | 61 | 1.2 | 6.4 | 6.7
B-50-80-MPLCOm2012-0.022 | 95,837 | 109,701 | 6.5 | 0.9 | 397 | 64 | 1.3 | 6.6 | 6.7
B-50-77-MPLCOm2012-0.019 | 95,987 | 109,867 | 6.3 | 0.9 | 361 | 47 | 0.9 | 5.5 | 8.3
B-50-77-Bach-0.031 | 96,543 | 110,714 | 5.7 | 0.9 | 366 | 48 | 1.0 | 5.6 | 7.8
B-50-75-MPLCOm2012-0.017 | 97,041 | 111,072 | 6.2 | 0.9 | 338 | 38 | 0.8 | 4.9 | 9.0
B-55-77-MPLCOm2012-0.019 | 97,287 | 111,339 | 6.4 | 0.9 | 366 | 48 | 1.0 | 5.5 | 8.1
B-50-80-40-20 | 97,823 | 111,033 | 9.9 | 1.4 | 340 | 46 | 0.9 | 5.7 | 9.7
B-55-77-Bach-0.031 | 97,940 | 112,294 | 5.7 | 0.9 | 371 | 49 | 1.0 | 5.6 | 7.7
B-55-80-MPLCOm2012-0.021 | 99,674 | 113,735 | 6.6 | 1.0 | 404 | 63 | 1.3 | 6.4 | 7.3
B-50-80-MPLCOm2012-0.021 | 101,031 | 115,245 | 6.6 | 1.0 | 411 | 66 | 1.3 | 6.6 | 7.3
B-50-77-Bach-0.03 | 101,222 | 115,720 | 5.8 | 0.9 | 376 | 49 | 1.0 | 5.6 | 8.3
B-50-80-Bach-0.034 | 101,409 | 115,892 | 6.0 | 0.9 | 415 | 67 | 1.3 | 6.6 | 7.0
B-55-80-Bach-0.034 | 101,612 | 116,031 | 6.0 | 0.9 | 416 | 65 | 1.3 | 6.4 | 7.0
B-50-77-MPLCOm2012-0.018 | 101,924 | 116,201 | 6.5 | 1.0 | 373 | 49 | 1.0 | 5.6 | 8.5
B-50-80-40-25 | 101,977 | 115,402 | 10.3 | 1.4 | 350 | 47 | 1.0 | 5.7 | 9.8
B-55-77-MPLCOm2012-0.018 | 102,872 | 117,290 | 6.5 | 1.0 | 378 | 50 | 1.0 | 5.6 | 8.3
B-55-80-MLCDRAT-0.021 | 103,248 | 117,727 | 6.2 | 0.9 | 408 | 64 | 1.3 | 6.5 | 7.3
B-50-75-MPLCOm2012-0.016 | 103,782 | 118,247 | 6.3 | 1.0 | 351 | 39 | 0.8 | 4.9 | 9.8
B-55-75-MPLCOm2012-0.016 | 103,925 | 118,497 | 6.3 | 1.0 | 356 | 41 | 0.8 | 5.0 | 9.4
B-55-80-MPLCOm2012-0.02 | 105,030 | 119,440 | 6.7 | 1.0 | 413 | 63 | 1.3 | 6.3 | 7.7
B-50-80-Bach-0.033 | 106,067 | 120,862 | 6.1 | 0.9 | 425 | 67 | 1.4 | 6.5 | 7.7
B-55-80-Bach-0.033 | 106,108 | 120,822 | 6.1 | 0.9 | 426 | 67 | 1.3 | 6.5 | 7.6
B-50-80-MPLCOm2012-0.02 | 106,418 | 120,972 | 6.8 | 1.0 | 422 | 66 | 1.3 | 6.5 | 7.8
B-50-77-MPLCOm2012-0.017 | 108,577 | 123,290 | 6.6 | 1.0 | 386 | 50 | 1.0 | 5.5 | 9.4
B-55-77-MPLCOm2012-0.017 | 109,070 | 123,890 | 6.6 | 1.0 | 391 | 50 | 1.0 | 5.5 | 9.0
B-55-80-Bach-0.032 | 110,822 | 125,850 | 6.2 | 0.9 | 436 | 67 | 1.4 | 6.4 | 7.9
B-50-80-Bach-0.032 | 110,827 | 125,935 | 6.2 | 0.9 | 436 | 69 | 1.4 | 6.6 | 7.9
B-55-80-MPLCOm2012-0.019 | 110,978 | 125,778 | 6.9 | 1.0 | 425 | 64 | 1.3 | 6.3 | 8.5
B-50-75-MPLCOm2012-0.015 | 111,552 | 126,508 | 6.5 | 1.0 | 366 | 40 | 0.8 | 4.9 | 10.0
B-50-80-MPLCOm2012-0.019 | 112,284 | 127,214 | 6.9 | 1.0 | 434 | 66 | 1.3 | 6.3 | 8.7
B-55-80-Bach-0.031 | 115,487 | 130,820 | 6.3 | 0.9 | 446 | 68 | 1.4 | 6.3 | 8.1
B-50-80-Bach-0.031 | 115,564 | 130,987 | 6.3 | 0.9 | 446 | 69 | 1.4 | 6.5 | 8.2
B-50-77-MPLCOm2012-0.016 | 115,780 | 130,964 | 6.8 | 1.0 | 400 | 50 | 1.0 | 5.4 | 10.3
B-55-77-MPLCOm2012-0.016 | 115,846 | 131,117 | 6.7 | 1.0 | 405 | 52 | 1.0 | 5.5 | 9.7
B-50-80-MLCDRAT-0.019 | 117,231 | 132,697 | 6.5 | 0.9 | 443 | 70 | 1.4 | 6.6 | 8.3
B-55-80-MPLCOm2012-0.018 | 117,313 | 132,517 | 7.0 | 1.0 | 438 | 65 | 1.3 | 6.2 | 8.7
B-55-80-Bach-0.03 | 119,154 | 134,726 | 6.3 | 0.9 | 448 | 67 | 1.4 | 6.3 | 8.6
B-50-80-MPLCOm2012-0.018 | 119,159 | 134,536 | 7.1 | 1.0 | 448 | 68 | 1.4 | 6.3 | 9.0
B-50-75-MPLCOm2012-0.014 | 120,192 | 135,706 | 6.7 | 1.0 | 380 | 41 | 0.8 | 4.8 | 11.0
B-50-80-Bach-0.03 | 120,957 | 136,726 | 6.4 | 0.9 | 457 | 70 | 1.4 | 6.4 | 8.7
B-55-80-MLCDRAT-0.018 | 121,586 | 137,265 | 6.6 | 0.9 | 449 | 68 | 1.4 | 6.4 | 8.9
B-50-80-MLCDRAT-0.018 | 123,032 | 138,877 | 6.7 | 1.0 | 457 | 71 | 1.4 | 6.5 | 8.9
B-55-77-MPLCOm2012-0.015 | 123,731 | 139,522 | 6.9 | 1.0 | 419 | 53 | 1.1 | 5.5 | 10.0
B-50-77-MPLCOm2012-0.015 | 124,014 | 139,709 | 7.0 | 1.0 | 415 | 51 | 1.0 | 5.4 | 10.4
B-55-80-Bach-0.029 | 124,216 | 140,132 | 6.4 | 0.9 | 459 | 69 | 1.4 | 6.3 | 9.3
B-55-80-MPLCOm2012-0.017 | 124,249 | 139,896 | 7.1 | 1.0 | 454 | 67 | 1.3 | 6.2 | 9.5
B-50-80-Bach-0.029 | 126,151 | 142,261 | 6.5 | 0.9 | 468 | 72 | 1.4 | 6.5 | 9.4
B-50-80-MPLCOm2012-0.017 | 126,738 | 142,603 | 7.2 | 1.0 | 465 | 70 | 1.4 | 6.3 | 9.8
B-50-75-MPLCOm2012-0.013 | 129,678 | 145,797 | 6.9 | 1.0 | 396 | 41 | 0.8 | 4.7 | 12.4
B-55-80-Bach-0.028 | 129,813 | 146,107 | 6.6 | 0.9 | 470 | 70 | 1.4 | 6.3 | 9.7
B-55-80-MPLCOm2012-0.016 | 131,558 | 147,676 | 7.3 | 1.0 | 467 | 68 | 1.4 | 6.2 | 10.3
B-50-80-Bach-0.028 | 131,788 | 148,269 | 6.6 | 1.0 | 479 | 73 | 1.5 | 6.5 | 10.0
B-55-77-MPLCOm2012-0.014 | 132,093 | 148,432 | 7.1 | 1.0 | 434 | 53 | 1.1 | 5.4 | 10.8
B-50-77-MPLCOm2012-0.014 | 133,200 | 149,468 | 7.2 | 1.0 | 430 | 52 | 1.0 | 5.3 | 11.3
B-50-80-MPLCOm2012-0.016 | 134,642 | 151,004 | 7.4 | 1.0 | 479 | 71 | 1.4 | 6.3 | 10.8
B-50-80-Bach-0.027 | 137,862 | 154,728 | 6.7 | 1.0 | 490 | 74 | 1.5 | 6.4 | 10.3
B-50-80-MLCDRAT-0.016 | 138,763 | 155,616 | 7.0 | 1.0 | 487 | 74 | 1.5 | 6.5 | 10.3
B-55-80-MPLCOm2012-0.015 | 139,739 | 156,391 | 7.4 | 1.0 | 482 | 69 | 1.4 | 6.1 | 10.5
B-50-77-MPLCOm2012-0.013 | 143,278 | 160,195 | 7.3 | 1.1 | 448 | 52 | 1.1 | 5.2 | 13.0
B-50-80-MPLCOm2012-0.015 | 143,399 | 160,323 | 7.6 | 1.1 | 495 | 73 | 1.5 | 6.3 | 10.9
B-50-80-Bach-0.026 | 143,828 | 161,083 | 6.8 | 1.0 | 503 | 75 | 1.5 | 6.4 | 10.3
B-55-80-Bach-0.025 | 147,758 | 165,203 | 6.9 | 1.0 | 504 | 72 | 1.5 | 6.2 | 10.6
B-50-80-MLCDRAT-0.015 | 148,360 | 165,827 | 7.2 | 1.0 | 506 | 76 | 1.5 | 6.5 | 11.1
B-55-80-MPLCOm2012-0.014 | 148,615 | 165,839 | 7.6 | 1.1 | 498 | 69 | 1.4 | 6.0 | 11.4
B-50-80-Bach-0.025 | 150,601 | 168,292 | 7.0 | 1.0 | 516 | 76 | 1.5 | 6.3 | 11.0
B-50-80-MPLCOm2012-0.014 | 153,324 | 170,855 | 7.8 | 1.1 | 512 | 73 | 1.5 | 6.1 | 11.9
B-55-80-Bach-0.024 | 154,299 | 172,167 | 7.0 | 1.0 | 516 | 74 | 1.5 | 6.2 | 11.5
B-50-77-MPLCOm2012-0.012 | 154,882 | 172,502 | 7.6 | 1.1 | 467 | 54 | 1.1 | 5.2 | 13.3
B-50-80-Bach-0.024 | 157,520 | 175,651 | 7.1 | 1.0 | 529 | 77 | 1.5 | 6.3 | 11.8
B-55-80-MPLCOm2012-0.013 | 158,123 | 175,963 | 7.8 | 1.1 | 514 | 71 | 1.4 | 6.0 | 12.5
B-50-80-MLCDRAT-0.014 | 158,658 | 176,788 | 7.3 | 1.0 | 524 | 77 | 1.6 | 6.4 | 12.0
B-50-80-MPLCOm2012-0.013 | 164,259 | 182,478 | 8.0 | 1.1 | 531 | 74 | 1.5 | 6.1 | 13.4
B-50-80-Bach-0.023 | 164,603 | 183,169 | 7.3 | 1.0 | 541 | 78 | 1.6 | 6.3 | 12.3
B-50-77-MPLCOm2012-0.011 | 167,727 | 186,154 | 7.8 | 1.1 | 485 | 55 | 1.1 | 5.2 | 14.9
B-50-80-Bach-0.022 | 172,049 | 191,083 | 7.4 | 1.0 | 553 | 79 | 1.6 | 6.3 | 12.8
A-55-80-MPLCOm2012-0.023 | 174,860 | 192,554 | 12.2 | 1.5 | 508 | 80 | 1.6 | 6.8 | 11.2
A-50-80-MPLCOm2012-0.023 | 174,911 | 192,601 | 12.2 | 1.5 | 508 | 80 | 1.6 | 6.8 | 11.2
B-55-80-Bach-0.021 | 175,310 | 194,510 | 7.4 | 1.0 | 550 | 75 | 1.5 | 6.0 | 13.1
B-50-80-MPLCOm2012-0.012 | 176,755 | 195,746 | 8.2 | 1.1 | 552 | 76 | 1.5 | 6.1 | 13.7
A-55-80-MLCDRAT-0.023 | 179,310 | 197,439 | 11.5 | 1.4 | 513 | 84 | 1.7 | 7.1 | 10.9
B-50-80-Bach-0.021 | 180,105 | 199,649 | 7.5 | 1.1 | 565 | 79 | 1.6 | 6.2 | 13.7
B-50-77-MPLCOm2012-0.01 | 182,246 | 201,560 | 8.1 | 1.1 | 507 | 56 | 1.1 | 5.1 | 16.3
B-55-80-Bach-0.02 | 182,833 | 202,516 | 7.5 | 1.1 | 562 | 76 | 1.5 | 6.0 | 13.9
A-55-80-MPLCOm2012-0.022 | 184,176 | 202,396 | 12.5 | 1.5 | 523 | 82 | 1.6 | 6.8 | 12.1
A-50-80-MPLCOm2012-0.022 | 184,284 | 202,513 | 12.5 | 1.5 | 523 | 82 | 1.6 | 6.8 | 12.1
B-50-80-Bach-0.02 | 188,573 | 208,640 | 7.7 | 1.1 | 579 | 80 | 1.6 | 6.1 | 14.6
B-55-80-Bach-0.019 | 190,612 | 210,780 | 7.6 | 1.1 | 574 | 77 | 1.5 | 6.0 | 14.5
B-50-80-MPLCOm2012-0.011 | 191,379 | 211,271 | 8.4 | 1.2 | 575 | 77 | 1.6 | 6.0 | 15.3
A-55-80-MPLCOm2012-0.021 | 193,965 | 212,755 | 12.7 | 1.5 | 539 | 84 | 1.7 | 6.8 | 13.2
A-55-80-Bach-0.034 | 194,099 | 213,177 | 11.4 | 1.4 | 546 | 88 | 1.8 | 7.1 | 12.8
A-50-80-MPLCOm2012-0.021 | 194,193 | 212,990 | 12.7 | 1.5 | 540 | 84 | 1.7 | 6.8 | 13.2
A-50-80-Bach-0.034 | 194,261 | 213,338 | 11.4 | 1.4 | 546 | 87 | 1.7 | 7.0 | 12.8
B-50-80-Bach-0.019 | 197,209 | 217,812 | 7.8 | 1.1 | 593 | 81 | 1.6 | 6.1 | 15.2
A-55-80-Bach-0.033 | 202,943 | 222,529 | 11.6 | 1.4 | 560 | 88 | 1.8 | 6.9 | 13.5
A-50-80-Bach-0.033 | 203,167 | 222,759 | 11.6 | 1.4 | 560 | 88 | 1.8 | 6.9 | 13.6
A-55-80-MPLCOm2012-0.02 | 204,612 | 224,001 | 13.0 | 1.6 | 555 | 86 | 1.7 | 6.8 | 14.1
A-50-80-MPLCOm2012-0.02 | 205,020 | 224,420 | 13.0 | 1.6 | 555 | 85 | 1.7 | 6.7 | 14.2
B-50-80-Bach-0.018 | 206,581 | 227,744 | 8.0 | 1.1 | 606 | 82 | 1.7 | 6.1 | 16.0
B-50-80-MPLCOm2012-0.01 | 206,957 | 227,804 | 8.7 | 1.2 | 598 | 79 | 1.6 | 6.0 | 16.9
A-50-80-MLCDRAT-0.02 | 210,560 | 230,513 | 12.1 | 1.5 | 565 | 89 | 1.8 | 7.0 | 13.3
A-55-80-Bach-0.032 | 212,181 | 232,294 | 11.8 | 1.4 | 574 | 90 | 1.8 | 6.9 | 14.1
A-50-80-Bach-0.032 | 212,490 | 232,621 | 11.8 | 1.4 | 575 | 89 | 1.8 | 6.9 | 14.1
A-55-80-MPLCOm2012-0.019 | 216,291 | 236,355 | 13.3 | 1.6 | 573 | 87 | 1.7 | 6.7 | 15.1
A-50-80-MPLCOm2012-0.019 | 217,030 | 237,128 | 13.2 | 1.6 | 574 | 87 | 1.7 | 6.7 | 15.2
A-55-80-Bach-0.031 | 221,421 | 242,072 | 12.0 | 1.5 | 589 | 91 | 1.8 | 6.9 | 14.8
A-50-80-Bach-0.031 | 221,847 | 242,513 | 12.0 | 1.5 | 589 | 90 | 1.8 | 6.8 | 14.9
B-50-80-MPLCOm2012-0.009 | 225,054 | 247,007 | 9.0 | 1.2 | 623 | 80 | 1.6 | 5.9 | 18.5
A-50-80-MLCDRAT-0.019 | 225,292 | 246,094 | 12.4 | 1.5 | 587 | 91 | 1.8 | 6.9 | 14.6
B-50-80-Bach-0.016 | 227,395 | 249,832 | 8.3 | 1.2 | 637 | 84 | 1.7 | 6.1 | 18.2
A-55-80-30-15 | 227,443 | 247,644 | 16.1 | 1.9 | 518 | 69 | 1.4 | 6.3 | 20.6
A-55-80-MPLCOm2012-0.018 | 228,676 | 249,442 | 13.5 | 1.6 | 591 | 89 | 1.8 | 6.7 | 15.8
A-50-80-MPLCOm2012-0.018 | 229,944 | 250,782 | 13.5 | 1.6 | 594 | 90 | 1.8 | 6.8 | 15.9
A-55-80-Bach-0.03 | 231,518 | 252,744 | 12.2 | 1.5 | 604 | 93 | 1.9 | 6.9 | 15.5
A-50-80-Bach-0.03 | 232,092 | 253,350 | 12.2 | 1.5 | 605 | 93 | 1.9 | 6.9 | 15.6
A-50-80-MLCDRAT-0.018 | 236,479 | 257,928 | 12.7 | 1.5 | 604 | 92 | 1.8 | 6.9 | 15.6
A-55-80-MLCDRAT-0.018 | 236,483 | 257,918 | 12.7 | 1.5 | 604 | 92 | 1.8 | 6.9 | 15.6
A-55-80-Bach-0.029 | 241,484 | 263,290 | 12.4 | 1.5 | 618 | 94 | 1.9 | 6.9 | 16.2
A-50-80-Bach-0.029 | 242,278 | 264,120 | 12.4 | 1.5 | 620 | 94 | 1.9 | 6.8 | 16.3
A-55-80-MPLCOm2012-0.017 | 242,329 | 263,878 | 13.8 | 1.6 | 610 | 90 | 1.8 | 6.7 | 17.1
A-50-80-MPLCOm2012-0.017 | 244,349 | 265,995 | 13.9 | 1.7 | 614 | 92 | 1.8 | 6.8 | 17.4
B-50-80-MPLCOm2012-0.008 | 245,777 | 268,980 | 9.3 | 1.3 | 653 | 83 | 1.7 | 5.9 | 20.0
B-50-80-Bach-0.014 | 250,390 | 274,208 | 8.7 | 1.2 | 668 | 86 | 1.7 | 6.0 | 19.6
A-55-80-Bach-0.028 | 252,590 | 275,022 | 12.6 | 1.5 | 634 | 96 | 1.9 | 6.9 | 16.8
A-50-80-Bach-0.028 | 253,613 | 276,110 | 12.7 | 1.5 | 636 | 95 | 1.9 | 6.8 | 17.0
A-50-80-MLCDRAT-0.017 | 253,620 | 276,030 | 13.1 | 1.6 | 628 | 95 | 1.9 | 6.9 | 17.0
A-55-80-MPLCOm2012-0.016 | 256,724 | 279,088 | 14.0 | 1.7 | 630 | 92 | 1.8 | 6.7 | 18.3
A-50-80-MPLCOm2012-0.016 | 259,832 | 282,347 | 14.2 | 1.7 | 635 | 94 | 1.9 | 6.7 | 18.9
B-50-80-Bach-0.013 | 263,135 | 287,720 | 8.9 | 1.2 | 685 | 86 | 1.7 | 5.9 | 20.8
A-55-80-Bach-0.027 | 263,986 | 287,083 | 12.8 | 1.5 | 650 | 97 | 1.9 | 6.8 | 17.9
A-50-80-Bach-0.027 | 265,411 | 288,573 | 12.9 | 1.6 | 652 | 97 | 1.9 | 6.8 | 18.1
A-50-80-MLCDRAT-0.016 | 267,426 | 290,613 | 13.4 | 1.6 | 648 | 97 | 1.9 | 6.9 | 18.1
B-50-80-MPLCOm2012-0.007 | 270,148 | 294,837 | 9.6 | 1.3 | 685 | 85 | 1.7 | 5.9 | 21.9
A-55-80-MPLCOm2012-0.015 | 272,809 | 296,092 | 14.4 | 1.7 | 651 | 93 | 1.9 | 6.6 | 19.5
A-55-80-Bach-0.026 | 275,329 | 299,073 | 13.0 | 1.6 | 665 | 99 | 2.0 | 6.9 | 18.7
B-50-80-Bach-0.012 | 277,033 | 302,448 | 9.1 | 1.2 | 704 | 87 | 1.8 | 5.9 | 22.1
A-50-80-Bach-0.026 | 277,066 | 300,897 | 13.1 | 1.6 | 667 | 98 | 2.0 | 6.8 | 18.9
A-50-80-MPLCOm2012-0.015 | 277,426 | 300,937 | 14.6 | 1.7 | 659 | 94 | 1.9 | 6.6 | 20.2
A-50-77-MPLCOm2012-0.013 | 280,113 | 303,848 | 14.2 | 1.7 | 609 | 72 | 1.4 | 5.7 | 22.0
A-50-80-MLCDRAT-0.015 | 286,154 | 310,413 | 13.8 | 1.6 | 674 | 99 | 2.0 | 6.8 | 19.2
A-55-80-Bach-0.025 | 287,935 | 312,383 | 13.3 | 1.6 | 682 | 99 | 2.0 | 6.7 | 19.6
A-50-80-Bach-0.025 | 290,340 | 314,916 | 13.4 | 1.6 | 685 | 99 | 2.0 | 6.7 | 20.0
A-55-80-MPLCOm2012-0.014 | 290,431 | 314,704 | 14.7 | 1.7 | 675 | 95 | 1.9 | 6.5 | 20.5
B-50-80-Bach-0.011 | 292,128 | 318,447 | 9.3 | 1.3 | 723 | 89 | 1.8 | 5.9 | 23.0
B-50-80-MPLCOm2012-0.006 | 296,680 | 322,996 | 9.9 | 1.3 | 719 | 88 | 1.8 | 5.9 | 23.8
A-50-80-MPLCOm2012-0.014 | 297,009 | 321,624 | 15.0 | 1.8 | 684 | 96 | 1.9 | 6.5 | 21.3
A-55-80-Bach-0.024 | 300,842 | 326,030 | 13.6 | 1.6 | 698 | 101 | 2.0 | 6.8 | 20.3
A-50-77-MPLCOm2012-0.012 | 303,023 | 328,035 | 14.7 | 1.8 | 637 | 73 | 1.5 | 5.6 | 24.1
A-55-80-MLCDRAT-0.014 | 303,286 | 328,536 | 14.0 | 1.7 | 695 | 100 | 2.0 | 6.8 | 20.4
A-50-80-Bach-0.024 | 303,778 | 329,091 | 13.6 | 1.6 | 703 | 100 | 2.0 | 6.7 | 20.6
A-50-80-MLCDRAT-0.014 | 306,138 | 331,531 | 14.1 | 1.7 | 699 | 100 | 2.0 | 6.7 | 20.7
B-50-80-Bach-0.01 | 308,091 | 335,373 | 9.5 | 1.3 | 744 | 90 | 1.8 | 5.9 | 24.4
A-55-80-MPLCOm2012-0.013 | 309,284 | 334,629 | 15.0 | 1.8 | 697 | 96 | 1.9 | 6.5 | 21.8
A-55-80-Bach-0.023 | 313,914 | 339,831 | 13.8 | 1.6 | 716 | 102 | 2.0 | 6.7 | 21.0
A-50-80-Bach-0.023 | 317,678 | 343,778 | 13.9 | 1.7 | 721 | 101 | 2.0 | 6.6 | 21.5
A-50-80-MPLCOm2012-0.013 | 318,502 | 344,299 | 15.4 | 1.8 | 709 | 98 | 2.0 | 6.5 | 23.1
A-55-80-MLCDRAT-0.013 | 320,862 | 347,108 | 14.2 | 1.7 | 718 | 102 | 2.0 | 6.7 | 21.3
A-50-80-MLCDRAT-0.013 | 325,175 | 351,637 | 14.3 | 1.7 | 724 | 102 | 2.0 | 6.7 | 21.9
B-50-80-Bach-0.009 | 325,901 | 354,263 | 9.6 | 1.3 | 767 | 91 | 1.8 | 5.9 | 25.7
B-50-80-MPLCOm2012-0.005 | 327,272 | 355,416 | 10.3 | 1.4 | 756 | 89 | 1.8 | 5.8 | 25.3
A-55-80-Bach-0.022 | 327,719 | 354,413 | 14.0 | 1.7 | 732 | 103 | 2.1 | 6.7 | 22.3
A-50-77-MPLCOm2012-0.011 | 328,622 | 355,052 | 15.2 | 1.8 | 665 | 74 | 1.5 | 5.6 | 26.0
A-55-80-20-15 | 330,095 | 356,390 | 16.0 | 1.9 | 667 | 83 | 1.7 | 6.2 | 29.0
A-55-80-MPLCOm2012-0.012 | 330,347 | 356,878 | 15.3 | 1.8 | 723 | 98 | 2.0 | 6.5 | 23.3
A-50-80-Bach-0.022 | 332,451 | 359,385 | 14.2 | 1.7 | 738 | 103 | 2.1 | 6.6 | 22.9
A-55-80-Bach-0.021 | 342,337 | 369,858 | 14.3 | 1.7 | 750 | 105 | 2.1 | 6.7 | 23.1
A-50-80-MPLCOm2012-0.012 | 343,293 | 370,477 | 15.8 | 1.9 | 740 | 99 | 2.0 | 6.4 | 25.2
A-55-80-MLCDRAT-0.012 | 343,713 | 371,269 | 14.4 | 1.7 | 745 | 104 | 2.1 | 6.7 | 23.0
A-50-80-Bach-0.021 | 348,282 | 376,097 | 14.5 | 1.7 | 757 | 104 | 2.1 | 6.6 | 24.0
A-50-80-MLCDRAT-0.012 | 350,286 | 378,187 | 14.7 | 1.7 | 754 | 103 | 2.1 | 6.6 | 23.9
A-55-80-MPLCOm2012-0.011 | 352,002 | 379,754 | 15.6 | 1.8 | 749 | 100 | 2.0 | 6.4 | 24.7
A-55-80-Bach-0.02 | 357,203 | 385,566 | 14.5 | 1.7 | 766 | 105 | 2.1 | 6.6 | 24.1
A-50-77-MPLCOm2012-0.01 | 357,345 | 385,345 | 15.7 | 1.9 | 697 | 76 | 1.5 | 5.6 | 28.7
A-50-80-Bach-0.02 | 364,767 | 393,511 | 14.8 | 1.7 | 776 | 105 | 2.1 | 6.6 | 25.1
A-55-80-MLCDRAT-0.011 | 369,025 | 398,078 | 14.5 | 1.7 | 777 | 105 | 2.1 | 6.6 | 24.6
A-55-80-20-20 | 369,610 | 398,094 | 16.8 | 2.0 | 722 | 89 | 1.8 | 6.3 | 30.6
A-50-80-MPLCOm2012-0.011 | 370,909 | 399,603 | 16.3 | 1.9 | 770 | 101 | 2.0 | 6.4 | 27.2
A-55-80-Bach-0.019 | 372,598 | 401,805 | 14.8 | 1.7 | 784 | 106 | 2.1 | 6.6 | 25.2
A-55-80-MPLCOm2012-0.01 | 375,484 | 404,571 | 15.8 | 1.9 | 776 | 102 | 2.0 | 6.4 | 26.5
A-50-80-MLCDRAT-0.011 | 377,864 | 407,366 | 14.8 | 1.7 | 789 | 105 | 2.1 | 6.5 | 25.8
A-50-80-Bach-0.019 | 381,778 | 411,439 | 15.1 | 1.8 | 794 | 106 | 2.1 | 6.5 | 26.4
A-55-80-Bach-0.018 | 389,243 | 419,367 | 15.1 | 1.8 | 802 | 107 | 2.2 | 6.6 | 26.5
A-55-80-MLCDRAT-0.01 | 398,180 | 429,019 | 14.4 | 1.7 | 813 | 108 | 2.2 | 6.6 | 26.5
A-50-80-Bach-0.018 | 400,457 | 431,163 | 15.4 | 1.8 | 816 | 107 | 2.1 | 6.5 | 28.0
A-50-80-MPLCOm2012-0.01 | 401,856 | 432,251 | 16.8 | 2.0 | 804 | 104 | 2.1 | 6.4 | 29.8
A-55-80-20-25 | 404,596 | 434,892 | 17.8 | 2.1 | 765 | 94 | 1.9 | 6.3 | 31.9
A-55-80-Bach-0.017 | 406,323 | 437,409 | 15.3 | 1.8 | 822 | 109 | 2.2 | 6.6 | 28.0
A-50-80-MLCDRAT-0.01 | 409,804 | 441,216 | 14.7 | 1.7 | 827 | 108 | 2.2 | 6.5 | 28.2
A-50-80-20-15 | 419,030 | 449,947 | 18.5 | 2.2 | 750 | 84 | 1.7 | 6.0 | 38.6
A-50-80-Bach-0.017 | 420,352 | 452,129 | 15.8 | 1.8 | 837 | 108 | 2.2 | 6.4 | 30.1
A-55-80-Bach-0.016 | 423,929 | 455,993 | 15.6 | 1.8 | 840 | 110 | 2.2 | 6.6 | 29.2
A-55-80-MPLCOm2012-0.008 | 432,557 | 464,850 | 16.5 | 1.9 | 839 | 106 | 2.1 | 6.4 | 30.0
A-55-80-MLCDRAT-0.009 | 433,597 | 466,571 | 14.3 | 1.7 | 856 | 112 | 2.2 | 6.6 | 29.3
A-50-80-MPLCOm2012-0.009 | 437,273 | 469,612 | 17.4 | 2.0 | 841 | 105 | 2.1 | 6.3 | 32.3
A-50-80-Bach-0.016 | 441,294 | 474,232 | 16.1 | 1.9 | 860 | 110 | 2.2 | 6.5 | 31.6
A-55-80-Bach-0.015 | 442,384 | 475,479 | 15.9 | 1.9 | 860 | 111 | 2.2 | 6.5 | 30.4
A-50-80-MLCDRAT-0.009 | 449,030 | 482,762 | 14.7 | 1.7 | 872 | 111 | 2.2 | 6.5 | 31.4
A-55-80-Bach-0.014 | 461,609 | 495,768 | 16.1 | 1.9 | 880 | 112 | 2.2 | 6.5 | 31.8
A-50-80-Bach-0.015 | 463,301 | 497,449 | 16.5 | 1.9 | 882 | 110 | 2.2 | 6.4 | 33.3
A-50-80-20-20 | 463,457 | 496,698 | 19.9 | 2.3 | 804 | 89 | 1.8 | 6.0 | 40.6
A-55-80-MLCDRAT-0.008 | 474,060 | 509,474 | 14.2 | 1.7 | 902 | 114 | 2.3 | 6.5 | 31.5
A-50-80-MPLCOm2012-0.008 | 478,349 | 512,920 | 18.0 | 2.1 | 883 | 108 | 2.2 | 6.3 | 35.4
A-55-80-Bach-0.013 | 482,093 | 517,364 | 16.3 | 1.9 | 900 | 113 | 2.3 | 6.5 | 33.3
A-50-80-Bach-0.014 | 486,484 | 521,881 | 16.8 | 2.0 | 905 | 111 | 2.2 | 6.3 | 35.0
A-50-80-MLCDRAT-0.008 | 495,424 | 531,893 | 14.8 | 1.7 | 925 | 114 | 2.3 | 6.4 | 34.2
A-50-80-20-25 | 500,430 | 535,519 | 21.2 | 2.5 | 849 | 94 | 1.9 | 6.0 | 42.5
A-55-80-Bach-0.012 | 503,871 | 540,363 | 16.6 | 1.9 | 922 | 114 | 2.3 | 6.4 | 34.6
A-50-80-Bach-0.013 | 511,462 | 548,218 | 17.2 | 2.0 | 930 | 112 | 2.2 | 6.3 | 37.1
A-55-80-MLCDRAT-0.007 | 520,869 | 559,024 | 14.3 | 1.7 | 953 | 117 | 2.3 | 6.5 | 34.0
A-50-80-MPLCOm2012-0.007 | 524,392 | 561,495 | 18.6 | 2.1 | 928 | 110 | 2.2 | 6.3 | 38.6
A-55-80-Bach-0.011 | 527,263 | 565,051 | 16.8 | 2.0 | 946 | 115 | 2.3 | 6.4 | 36.0
A-50-80-Bach-0.012 | 538,488 | 576,709 | 17.6 | 2.0 | 957 | 113 | 2.3 | 6.3 | 39.1
A-50-80-MLCDRAT-0.007 | 550,777 | 590,414 | 15.1 | 1.8 | 984 | 117 | 2.3 | 6.3 | 37.6
A-55-80-Bach-0.01 | 551,762 | 590,917 | 17.1 | 2.0 | 970 | 116 | 2.3 | 6.4 | 37.5
A-50-80-Bach-0.011 | 568,005 | 607,834 | 18.0 | 2.1 | 985 | 115 | 2.3 | 6.3 | 41.1
A-50-80-MPLCOm2012-0.006 | 575,496 | 615,371 | 19.2 | 2.2 | 976 | 112 | 2.2 | 6.2 | 42.0
A-55-80-MLCDRAT-0.006 | 577,420 | 618,778 | 14.8 | 1.7 | 1,011 | 120 | 2.4 | 6.4 | 37.3
A-50-80-Bach-0.01 | 599,143 | 640,649 | 18.3 | 2.1 | 1,015 | 117 | 2.3 | 6.3 | 43.3
A-50-80-MLCDRAT-0.006 | 616,864 | 660,217 | 15.7 | 1.8 | 1,050 | 120 | 2.4 | 6.3 | 42.3
A-50-80-Bach-0.009 | 633,671 | 677,053 | 18.7 | 2.1 | 1,046 | 118 | 2.3 | 6.2 | 45.6
A-50-80-MPLCOm2012-0.005 | 635,352 | 678,491 | 19.9 | 2.3 | 1,032 | 114 | 2.3 | 6.2 | 45.7
A-50-80-Bach-0.008 | 671,522 | 716,944 | 19.1 | 2.2 | 1,081 | 119 | 2.4 | 6.2 | 48.3
A-50-80-MLCDRAT-0.005 | 700,139 | 747,972 | 16.7 | 1.9 | 1,125 | 123 | 2.5 | 6.2 | 47.2
A-50-80-MPLCOm2012-0.004 | 708,806 | 755,847 | 20.7 | 2.4 | 1,094 | 115 | 2.3 | 6.1 | 49.6
A-55-80-MLCDRAT-0.004 | 714,694 | 763,529 | 16.5 | 1.9 | 1,135 | 125 | 2.5 | 6.4 | 43.4
A-50-80-MLCDRAT-0.004 | 790,911 | 843,539 | 18.0 | 2.1 | 1,203 | 125 | 2.5 | 6.2 | 52.3

* Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 13 Benefits of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort Men

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC deaths averted | NNS
B-50-80-Bach-0.025 | 22.3 | 159,773 | 1,255 | 8.8 | 354 | 4,056 | 11.5 | 39 | 451 | 63
B-50-80-MLCDRAT-0.015 | 22.0 | 161,822 | 1,253 | 8.8 | 355 | 4,064 | 11.4 | 40 | 456 | 62
B-50-80-MPLCOm2012-0.014 | 20.9 | 162,809 | 1,246 | 8.8 | 356 | 4,167 | 11.7 | 39 | 457 | 59
B-55-80-Bach-0.024 | 22.7 | 162,817 | 1,245 | 8.7 | 352 | 4,078 | 11.6 | 40 | 463 | 64
B-50-80-Bach-0.024 | 22.9 | 166,596 | 1,278 | 9.0 | 361 | 4,139 | 11.5 | 40 | 461 | 63
B-55-80-MPLCOm2012-0.013 | 21.6 | 166,735 | 1,241 | 8.7 | 353 | 4,176 | 11.8 | 40 | 472 | 61
B-50-80-MLCDRAT-0.014 | 22.8 | 170,783 | 1,274 | 9.0 | 361 | 4,135 | 11.5 | 41 | 473 | 63
B-50-80-Bach-0.023 | 23.4 | 173,502 | 1,297 | 9.1 | 367 | 4,241 | 11.6 | 41 | 473 | 64
B-50-80-MPLCOm2012-0.013 | 21.8 | 174,275 | 1,276 | 9.0 | 364 | 4,359 | 12.0 | 40 | 479 | 60
B-50-80-Bach-0.022 | 24.0 | 181,151 | 1,318 | 9.3 | 375 | 4,376 | 11.7 | 41 | 483 | 64
B-55-80-Bach-0.021 | 24.5 | 183,290 | 1,299 | 9.1 | 367 | 4,272 | 11.6 | 43 | 499 | 67
B-50-80-MPLCOm2012-0.012 | 22.8 | 187,331 | 1,317 | 9.3 | 375 | 4,524 | 12.1 | 41 | 500 | 61
A-55-80-MPLCOm2012-0.023 | 15.1 | 187,833 | 1,258 | 9.9 | 398 | 4,295 | 10.8 | 44 | 472 | 38
A-50-80-MPLCOm2012-0.023 | 15.1 | 187,903 | 1,262 | 9.8 | 397 | 4,309 | 10.9 | 44 | 473 | 38
B-50-80-Bach-0.021 | 24.7 | 189,239 | 1,336 | 9.5 | 381 | 4,441 | 11.7 | 43 | 497 | 65
B-55-80-Bach-0.02 | 25.1 | 190,476 | 1,317 | 9.3 | 377 | 4,397 | 11.7 | 43 | 505 | 67
A-55-80-MPLCOm2012-0.022 | 15.6 | 197,533 | 1,286 | 10.1 | 409 | 4,455 | 10.9 | 44 | 483 | 38
B-50-80-Bach-0.02 | 25.3 | 197,676 | 1,356 | 9.7 | 390 | 4,566 | 11.7 | 43 | 507 | 65
A-50-80-MPLCOm2012-0.022 | 15.6 | 197,695 | 1,288 | 10.1 | 407 | 4,440 | 10.9 | 45 | 486 | 38
B-55-80-Bach-0.019 | 25.8 | 198,153 | 1,337 | 9.5 | 384 | 4,553 | 11.9 | 44 | 516 | 67
A-55-80-MLCDRAT-0.023 | 16.8 | 198,541 | 1,285 | 10.0 | 404 | 4,292 | 10.6 | 46 | 491 | 42
B-50-80-MPLCOm2012-0.011 | 24.0 | 202,477 | 1,356 | 9.7 | 393 | 4,787 | 12.2 | 42 | 515 | 61
B-50-80-Bach-0.019 | 26.0 | 206,172 | 1,379 | 9.8 | 394 | 4,701 | 11.9 | 44 | 523 | 66
A-55-80-MPLCOm2012-0.021 | 16.1 | 207,708 | 1,316 | 10.4 | 419 | 4,630 | 11.1 | 45 | 496 | 38
A-50-80-MPLCOm2012-0.021 | 16.1 | 208,036 | 1,321 | 10.4 | 418 | 4,642 | 11.1 | 45 | 498 | 39
A-55-80-Bach-0.034 | 17.8 | 210,852 | 1,337 | 10.5 | 423 | 4,603 | 10.9 | 46 | 498 | 42
A-50-80-Bach-0.034 | 17.8 | 211,124 | 1,341 | 10.5 | 425 | 4,630 | 10.9 | 46 | 497 | 42
B-50-80-Bach-0.018 | 26.6 | 215,660 | 1,395 | 9.9 | 400 | 4,775 | 11.9 | 45 | 539 | 66
B-50-80-MPLCOm2012-0.01 | 25.2 | 218,734 | 1,390 | 10.0 | 403 | 4,959 | 12.3 | 44 | 543 | 63
A-55-80-MPLCOm2012-0.02 | 16.7 | 218,788 | 1,348 | 10.7 | 429 | 4,758 | 11.1 | 46 | 510 | 39
A-50-80-MPLCOm2012-0.02 | 16.7 | 219,385 | 1,347 | 10.6 | 427 | 4,783 | 11.2 | 46 | 514 | 39
A-55-80-Bach-0.033 | 18.2 | 219,722 | 1,362 | 10.7 | 432 | 4,725 | 10.9 | 47 | 509 | 42
A-50-80-Bach-0.033 | 18.2 | 220,098 | 1,360 | 10.7 | 430 | 4,702 | 10.9 | 47 | 512 | 42
A-55-80-Bach-0.032 | 18.7 | 229,326 | 1,388 | 11.0 | 442 | 4,843 | 11.0 | 47 | 519 | 42
A-50-80-Bach-0.032 | 18.7 | 229,844 | 1,389 | 11.0 | 443 | 4,877 | 11.0 | 47 | 519 | 42
A-55-80-MPLCOm2012-0.019 | 17.3 | 230,831 | 1,380 | 10.9 | 441 | 4,959 | 11.2 | 47 | 523 | 39
A-50-80-MPLCOm2012-0.019 | 17.3 | 231,879 | 1,381 | 11.0 | 442 | 4,982 | 11.3 | 47 | 525 | 39
A-50-80-MLCDRAT-0.02 | 18.8 | 232,308 | 1,386 | 10.9 | 440 | 4,801 | 10.9 | 48 | 528 | 43
B-50-80-Bach-0.016 | 28.1 | 236,644 | 1,447 | 10.5 | 421 | 5,101 | 12.1 | 46 | 562 | 67
B-50-80-MPLCOm2012-0.009 | 26.5 | 237,535 | 1,424 | 10.3 | 416 | 5,184 | 12.5 | 46 | 571 | 64
A-55-80-Bach-0.031 | 19.2 | 238,433 | 1,410 | 11.2 | 452 | 4,968 | 11.0 | 48 | 528 | 42
A-50-80-Bach-0.031 | 19.2 | 239,121 | 1,411 | 11.2 | 451 | 5,010 | 11.1 | 48 | 530 | 43
A-55-80-MPLCOm2012-0.018 | 17.9 | 243,611 | 1,409 | 11.2 | 451 | 5,091 | 11.3 | 48 | 540 | 40
A-50-80-MPLCOm2012-0.018 | 17.9 | 245,376 | 1,418 | 11.2 | 451 | 5,131 | 11.4 | 48 | 544 | 40
A-50-80-MLCDRAT-0.019 | 19.5 | 247,829 | 1,422 | 11.3 | 455 | 5,027 | 11.0 | 49 | 545 | 43
A-55-80-Bach-0.03 | 19.7 | 248,734 | 1,435 | 11.4 | 459 | 5,089 | 11.1 | 49 | 542 | 43
A-50-80-Bach-0.03 | 19.7 | 249,665 | 1,442 | 11.4 | 460 | 5,152 | 11.2 | 48 | 543 | 43
A-55-80-30-15 | 15.7 | 250,071 | 1,209 | 10.0 | 400 | 5,078 | 12.7 | 49 | 625 | 39
A-55-80-MPLCOm2012-0.017 | 18.6 | 257,599 | 1,439 | 11.5 | 462 | 5,266 | 11.4 | 49 | 558 | 40
A-55-80-Bach-0.029 | 20.2 | 258,471 | 1,457 | 11.7 | 469 | 5,239 | 11.2 | 49 | 551 | 43
B-50-80-MPLCOm2012-0.008 | 28.0 | 258,855 | 1,466 | 10.7 | 431 | 5,397 | 12.5 | 48 | 601 | 65
A-50-80-MLCDRAT-0.018 | 20.0 | 259,222 | 1,449 | 11.6 | 467 | 5,184 | 11.1 | 50 | 555 | 43
A-55-80-MLCDRAT-0.018 | 20.0 | 259,229 | 1,451 | 11.6 | 467 | 5,182 | 11.1 | 50 | 555 | 43
A-50-80-Bach-0.029 | 20.2 | 259,707 | 1,465 | 11.7 | 469 | 5,270 | 11.2 | 49 | 554 | 43
B-50-80-Bach-0.014 | 29.7 | 259,722 | 1,486 | 10.8 | 433 | 5,332 | 12.3 | 49 | 600 | 69
A-50-80-MPLCOm2012-0.017 | 18.6 | 260,376 | 1,449 | 11.6 | 467 | 5,366 | 11.5 | 49 | 558 | 40
A-55-80-Bach-0.028 | 20.7 | 269,770 | 1,481 | 11.9 | 477 | 5,348 | 11.2 | 50 | 566 | 43
A-50-80-Bach-0.028 | 20.7 | 271,389 | 1,488 | 12.0 | 482 | 5,405 | 11.2 | 50 | 563 | 43
A-55-80-MPLCOm2012-0.016 | 19.3 | 272,384 | 1,470 | 11.8 | 475 | 5,427 | 11.4 | 50 | 573 | 41
B-50-80-Bach-0.013 | 30.6 | 272,403 | 1,507 | 10.9 | 438 | 5,417 | 12.4 | 50 | 622 | 70
A-50-80-MPLCOm2012-0.016 | 19.3 | 276,601 | 1,485 | 12.1 | 485 | 5,637 | 11.6 | 49 | 570 | 40
A-50-80-MLCDRAT-0.017 | 20.7 | 277,443 | 1,488 | 12.0 | 482 | 5,412 | 11.2 | 51 | 576 | 43
A-55-80-Bach-0.027 | 21.2 | 280,992 | 1,505 | 12.1 | 488 | 5,486 | 11.2 | 51 | 576 | 43
A-50-80-Bach-0.027 | 21.3 | 283,167 | 1,516 | 12.1 | 488 | 5,552 | 11.4 | 51 | 580 | 44
B-50-80-MPLCOm2012-0.007 | 29.7 | 283,776 | 1,505 | 11.0 | 444 | 5,619 | 12.7 | 51 | 639 | 67
B-50-80-Bach-0.012 | 31.5 | 285,918 | 1,538 | 11.2 | 448 | 5,560 | 12.4 | 51 | 638 | 70
A-55-80-MPLCOm2012-0.015 | 20.0 | 288,785 | 1,501 | 12.2 | 489 | 5,645 | 11.5 | 51 | 591 | 41
A-50-80-MLCDRAT-0.016 | 21.3 | 291,376 | 1,518 | 12.3 | 494 | 5,614 | 11.4 | 52 | 590 | 43
A-55-80-Bach-0.026 | 21.8 | 292,283 | 1,530 | 12.4 | 498 | 5,617 | 11.3 | 52 | 587 | 44
A-50-80-Bach-0.026 | 21.8 | 294,924 | 1,537 | 12.4 | 498 | 5,663 | 11.4 | 52 | 592 | 44
A-50-80-MPLCOm2012-0.015 | 20.1 | 294,962 | 1,520 | 12.4 | 498 | 5,826 | 11.7 | 51 | 592 | 40
A-50-77-MPLCOm2012-0.013 | 20.8 | 299,824 | 1,357 | 11.3 | 453 | 5,876 | 13.0 | 51 | 662 | 46
B-50-80-Bach-0.011 | 32.6 | 301,272 | 1,557 | 11.4 | 458 | 5,734 | 12.5 | 53 | 658 | 71
A-55-80-Bach-0.025 | 22.4 | 304,744 | 1,554 | 12.5 | 504 | 5,698 | 11.3 | 53 | 605 | 44
A-55-80-MPLCOm2012-0.014 | 20.9 | 306,772 | 1,538 | 12.5 | 502 | 5,839 | 11.6 | 53 | 611 | 42
A-50-80-Bach-0.025 | 22.4 | 308,347 | 1,564 | 12.6 | 507 | 5,820 | 11.5 | 53 | 608 | 44
B-50-80-MPLCOm2012-0.006 | 31.5 | 310,648 | 1,547 | 11.4 | 456 | 5,814 | 12.8 | 53 | 681 | 69
A-50-80-MLCDRAT-0.015 | 22.1 | 311,463 | 1,561 | 12.6 | 507 | 5,798 | 11.4 | 54 | 614 | 44
A-50-80-MPLCOm2012-0.014 | 21.0 | 315,485 | 1,559 | 12.8 | 514 | 6,089 | 11.8 | 52 | 614 | 41
B-50-80-Bach-0.01 | 33.7 | 317,492 | 1,583 | 11.6 | 465 | 5,851 | 12.6 | 54 | 683 | 72
A-55-80-Bach-0.024 | 22.9 | 317,493 | 1,578 | 12.9 | 517 | 5,871 | 11.4 | 54 | 614 | 44
A-50-80-Bach-0.024 | 23.0 | 321,715 | 1,591 | 13.0 | 522 | 6,024 | 11.5 | 53 | 616 | 44
A-50-77-MPLCOm2012-0.012 | 21.8 | 323,796 | 1,394 | 11.7 | 468 | 6,118 | 13.1 | 53 | 692 | 47
A-55-80-MPLCOm2012-0.013 | 21.7 | 325,898 | 1,571 | 12.8 | 515 | 6,041 | 11.7 | 54 | 633 | 42
A-55-80-MLCDRAT-0.014 | 22.9 | 326,637 | 1,582 | 12.9 | 518 | 5,915 | 11.4 | 55 | 631 | 44
A-55-80-Bach-0.023 | 23.5 | 329,902 | 1,603 | 13.1 | 525 | 6,003 | 11.4 | 55 | 628 | 45
A-50-80-MLCDRAT-0.014 | 23.0 | 331,138 | 1,593 | 13.0 | 523 | 6,030 | 11.5 | 55 | 633 | 44
B-50-80-Bach-0.009 | 34.9 | 335,044 | 1,612 | 11.9 | 479 | 6,090 | 12.7 | 55 | 699 | 73
A-50-80-Bach-0.023 | 23.6 | 335,415 | 1,618 | 13.2 | 529 | 6,145 | 11.6 | 55 | 634 | 45
A-50-80-MPLCOm2012-0.013 | 21.9 | 337,953 | 1,597 | 13.0 | 523 | 6,272 | 12.0 | 54 | 646 | 42
A-55-80-20-15 | 21.8 | 338,814 | 1,415 | 11.8 | 475 | 6,022 | 12.7 | 56 | 713 | 46
B-50-80-MPLCOm2012-0.005 | 33.6 | 341,618 | 1,587 | 11.7 | 471 | 6,084 | 12.9 | 56 | 725 | 71
A-55-80-Bach-0.022 | 24.0 | 343,709 | 1,621 | 13.3 | 534 | 6,117 | 11.5 | 56 | 644 | 45
A-55-80-MLCDRAT-0.013 | 23.8 | 344,246 | 1,619 | 13.3 | 534 | 6,128 | 11.5 | 56 | 645 | 45
A-55-80-MPLCOm2012-0.012 | 22.7 | 347,253 | 1,604 | 13.1 | 525 | 6,223 | 11.9 | 56 | 661 | 43
A-50-80-Bach-0.022 | 24.1 | 350,428 | 1,639 | 13.5 | 541 | 6,331 | 11.7 | 55 | 648 | 45
A-50-77-MPLCOm2012-0.011 | 22.9 | 350,473 | 1,428 | 12.0 | 480 | 6,343 | 13.2 | 55 | 730 | 48
A-50-80-MLCDRAT-0.013 | 23.8 | 351,020 | 1,633 | 13.4 | 538 | 6,273 | 11.7 | 56 | 652 | 44
A-55-80-Bach-0.021 | 24.7 | 357,845 | 1,649 | 13.5 | 544 | 6,279 | 11.5 | 57 | 658 | 45
A-50-80-MPLCOm2012-0.012 | 22.9 | 363,819 | 1,640 | 13.4 | 540 | 6,542 | 12.1 | 56 | 674 | 42
A-50-80-Bach-0.021 | 24.8 | 366,256 | 1,668 | 13.7 | 548 | 6,453 | 11.8 | 57 | 668 | 45
A-55-80-MLCDRAT-0.012 | 24.9 | 367,142 | 1,648 | 13.5 | 543 | 6,291 | 11.6 | 58 | 676 | 46
A-55-80-MPLCOm2012-0.011 | 23.8 | 368,985 | 1,639 | 13.5 | 541 | 6,414 | 11.9 | 58 | 682 | 44
A-55-80-Bach-0.02 | 25.3 | 372,015 | 1,667 | 13.7 | 549 | 6,382 | 11.6 | 58 | 678 | 46
A-50-80-MLCDRAT-0.012 | 25.0 | 376,831 | 1,669 | 13.7 | 551 | 6,489 | 11.8 | 58 | 684 | 45
A-50-77-MPLCOm2012-0.01 | 24.1 | 380,379 | 1,468 | 12.5 | 500 | 6,660 | 13.3 | 57 | 761 | 48
A-55-80-20-20 | 23.5 | 380,919 | 1,502 | 12.6 | 505 | 6,396 | 12.7 | 60 | 754 | 47
A-50-80-Bach-0.02 | 25.4 | 382,555 | 1,695 | 14.0 | 561 | 6,640 | 11.8 | 58 | 682 | 45
A-55-80-Bach-0.019 | 25.9 | 387,182 | 1,691 | 13.9 | 558 | 6,489 | 11.6 | 60 | 694 | 46
A-55-80-MLCDRAT-0.011 | 26.6 | 391,357 | 1,691 | 14.0 | 560 | 6,543 | 11.7 | 60 | 699 | 48
A-50-80-MPLCOm2012-0.011 | 24.0 | 392,507 | 1,680 | 13.9 | 557 | 6,813 | 12.2 | 58 | 705 | 43
A-55-80-MPLCOm2012-0.01 | 24.9 | 392,619 | 1,675 | 13.8 | 555 | 6,599 | 11.9 | 59 | 707 | 45
A-50-80-Bach-0.019 | 26.1 | 399,519 | 1,714 | 14.1 | 565 | 6,745 | 11.9 | 59 | 707 | 46
A-55-80-Bach-0.018 | 26.6 | 402,967 | 1,712 | 14.1 | 564 | 6,621 | 11.7 | 61 | 714 | 47
A-50-80-MLCDRAT-0.011 | 26.7 | 403,985 | 1,718 | 14.2 | 570 | 6,794 | 11.9 | 59 | 709 | 47
A-50-80-Bach-0.018 | 26.7 | 418,219 | 1,742 | 14.4 | 576 | 6,951 | 12.1 | 60 | 726 | 46
A-55-80-Bach-0.017 | 27.2 | 419,571 | 1,739 | 14.4 | 576 | 6,799 | 11.8 | 62 | 728 | 47
A-55-80-20-25 | 24.4 | 419,641 | 1,572 | 13.1 | 526 | 6,664 | 12.7 | 63 | 798 | 46
A-55-80-MLCDRAT-0.01 | 29.0 | 420,681 | 1,736 | 14.3 | 573 | 6,718 | 11.7 | 63 | 734 | 51
A-50-80-MPLCOm2012-0.01 | 25.3 | 424,646 | 1,718 | 14.3 | 572 | 7,082 | 12.4 | 60 | 742 | 44
A-55-80-Bach-0.016 | 28.0 | 436,416 | 1,758 | 14.6 | 585 | 6,938 | 11.9 | 63 | 746 | 48
A-50-80-MLCDRAT-0.01 | 29.2 | 437,146 | 1,763 | 14.6 | 585 | 7,060 | 12.1 | 62 | 747 | 50
A-50-80-20-15 | 24.4 | 438,248 | 1,497 | 12.8 | 513 | 7,031 | 13.7 | 62 | 854 | 48
A-50-80-Bach-0.017 | 27.5 | 438,368 | 1,766 | 14.6 | 587 | 7,103 | 12.1 | 62 | 747 | 47
A-55-80-MPLCOm2012-0.008 | 27.6 | 450,041 | 1,748 | 14.5 | 583 | 7,015 | 12.0 | 64 | 772 | 47
A-55-80-Bach-0.015 | 28.7 | 454,682 | 1,778 | 14.8 | 592 | 7,053 | 11.9 | 64 | 768 | 48
A-55-80-MLCDRAT-0.009 | 31.7 | 455,814 | 1,791 | 14.7 | 591 | 6,971 | 11.8 | 65 | 771 | 54
A-50-80-Bach-0.016 | 28.2 | 459,189 | 1,792 | 14.9 | 599 | 7,278 | 12.2 | 63 | 767 | 47
A-50-80-MPLCOm2012-0.009 | 26.6 | 461,261 | 1,763 | 14.7 | 590 | 7,435 | 12.6 | 62 | 782 | 45
A-55-80-Bach-0.014 | 29.5 | 473,162 | 1,802 | 15.0 | 600 | 7,171 | 12.0 | 66 | 789 | 49
A-50-80-MLCDRAT-0.009 | 31.9 | 477,198 | 1,821 | 15.1 | 605 | 7,322 | 12.1 | 65 | 789 | 53
A-50-80-Bach-0.015 | 29.0 | 481,441 | 1,819 | 15.2 | 610 | 7,477 | 12.3 | 64 | 789 | 48
A-50-80-20-20 | 25.3 | 486,445 | 1,584 | 13.5 | 542 | 7,397 | 13.6 | 66 | 898 | 47
A-55-80-Bach-0.013 | 30.3 | 493,124 | 1,820 | 15.1 | 607 | 7,300 | 12.0 | 68 | 812 | 50
A-55-80-MLCDRAT-0.008 | 34.6 | 493,984 | 1,836 | 15.2 | 609 | 7,214 | 11.8 | 68 | 811 | 57
A-50-80-MPLCOm2012-0.008 | 28.1 | 503,446 | 1,808 | 15.2 | 608 | 7,666 | 12.6 | 66 | 828 | 46
A-50-80-Bach-0.014 | 29.8 | 504,514 | 1,844 | 15.5 | 620 | 7,645 | 12.3 | 66 | 814 | 48
A-55-80-Bach-0.012 | 31.2 | 513,666 | 1,846 | 15.3 | 615 | 7,431 | 12.1 | 69 | 835 | 51
A-50-80-MLCDRAT-0.008 | 34.9 | 523,694 | 1,881 | 15.7 | 628 | 7,668 | 12.2 | 68 | 834 | 56
A-50-80-20-25 | 25.6 | 527,801 | 1,657 | 14.1 | 565 | 7,696 | 13.6 | 69 | 934 | 45
A-50-80-Bach-0.013 | 30.7 | 529,448 | 1,869 | 15.7 | 630 | 7,800 | 12.4 | 68 | 840 | 49
A-55-80-Bach-0.011 | 32.2 | 536,628 | 1,870 | 15.6 | 627 | 7,564 | 12.1 | 71 | 856 | 51
A-55-80-MLCDRAT-0.007 | 37.4 | 540,710 | 1,892 | 15.8 | 632 | 7,554 | 12.0 | 72 | 856 | 59
A-50-80-MPLCOm2012-0.007 | 29.7 | 550,625 | 1,854 | 15.6 | 626 | 8,004 | 12.8 | 69 | 880 | 47
A-50-80-Bach-0.012 | 31.6 | 555,908 | 1,897 | 15.9 | 636 | 7,966 | 12.5 | 70 | 874 | 50
A-55-80-Bach-0.01 | 33.2 | 560,821 | 1,892 | 15.9 | 637 | 7,716 | 12.1 | 73 | 880 | 52
A-50-80-MLCDRAT-0.007 | 37.8 | 579,320 | 1,942 | 16.3 | 652 | 8,064 | 12.4 | 72 | 889 | 58
A-50-80-Bach-0.011 | 32.7 | 585,729 | 1,922 | 16.2 | 649 | 8,180 | 12.6 | 72 | 903 | 50
A-55-80-MLCDRAT-0.006 | 40.0 | 596,266 | 1,947 | 16.4 | 656 | 7,843 | 12.0 | 76 | 909 | 61
A-50-80-MPLCOm2012-0.006 | 31.6 | 602,353 | 1,895 | 16.0 | 641 | 8,249 | 12.9 | 73 | 940 | 49
A-50-80-Bach-0.01 | 33.8 | 617,099 | 1,950 | 16.5 | 662 | 8,378 | 12.7 | 74 | 932 | 51

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 14 Harms of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort Men

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-50-80-Bach-0.025 | 159,773 | 177,817 | 7.2 | 1.0 | 541 | 76 | 1.5 | 6.1 | 10.3
B-50-80-MLCDRAT-0.015 | 161,822 | 179,943 | 7.4 | 1.0 | 542 | 78 | 1.5 | 6.2 | 10.7
B-50-80-MPLCOm2012-0.014 | 162,809 | 180,756 | 7.8 | 1.1 | 539 | 75 | 1.5 | 6.0 | 11.1
B-55-80-Bach-0.024 | 162,817 | 181,009 | 7.2 | 1.0 | 540 | 76 | 1.5 | 6.1 | 10.7
B-50-80-Bach-0.024 | 166,596 | 185,070 | 7.3 | 1.0 | 554 | 78 | 1.5 | 6.1 | 11.0
B-55-80-MPLCOm2012-0.013 | 166,735 | 184,962 | 7.7 | 1.1 | 540 | 72 | 1.4 | 5.8 | 11.6
B-50-80-MLCDRAT-0.014 | 170,783 | 189,472 | 7.5 | 1.1 | 556 | 78 | 1.5 | 6.1 | 11.4
B-50-80-Bach-0.023 | 173,502 | 192,402 | 7.4 | 1.0 | 566 | 78 | 1.5 | 6.0 | 11.7
B-50-80-MPLCOm2012-0.013 | 174,275 | 192,952 | 8.0 | 1.1 | 558 | 75 | 1.5 | 5.9 | 12.2
B-50-80-Bach-0.022 | 181,151 | 200,524 | 7.5 | 1.1 | 578 | 79 | 1.5 | 6.0 | 11.8
B-55-80-Bach-0.021 | 183,290 | 202,795 | 7.5 | 1.1 | 574 | 77 | 1.5 | 5.9 | 12.3
B-50-80-MPLCOm2012-0.012 | 187,331 | 206,816 | 8.2 | 1.1 | 581 | 77 | 1.5 | 5.8 | 12.7
A-55-80-MPLCOm2012-0.023 | 187,833 | 206,087 | 12.4 | 1.5 | 543 | 83 | 1.6 | 6.6 | 10.6
A-50-80-MPLCOm2012-0.023 | 187,903 | 206,149 | 12.4 | 1.5 | 544 | 84 | 1.6 | 6.7 | 10.6
B-50-80-Bach-0.021 | 189,239 | 209,132 | 7.7 | 1.1 | 591 | 80 | 1.6 | 6.0 | 13.0
B-55-80-Bach-0.02 | 190,476 | 210,430 | 7.6 | 1.1 | 586 | 77 | 1.5 | 5.8 | 13.0
A-55-80-MPLCOm2012-0.022 | 197,533 | 216,343 | 12.7 | 1.5 | 559 | 85 | 1.7 | 6.6 | 11.1
B-50-80-Bach-0.02 | 197,676 | 218,094 | 7.8 | 1.1 | 604 | 80 | 1.6 | 5.9 | 13.7
A-50-80-MPLCOm2012-0.022 | 197,695 | 216,505 | 12.7 | 1.5 | 559 | 85 | 1.7 | 6.6 | 11.1
B-55-80-Bach-0.019 | 198,153 | 218,611 | 7.7 | 1.1 | 598 | 78 | 1.5 | 5.8 | 13.3
A-55-80-MLCDRAT-0.023 | 198,541 | 217,591 | 11.8 | 1.4 | 561 | 90 | 1.8 | 7.0 | 10.3
B-50-80-MPLCOm2012-0.011 | 202,477 | 222,890 | 8.4 | 1.2 | 605 | 78 | 1.5 | 5.8 | 14.4
B-50-80-Bach-0.019 | 206,172 | 227,110 | 7.9 | 1.1 | 618 | 80 | 1.6 | 5.8 | 14.2
A-55-80-MPLCOm2012-0.021 | 207,708 | 227,097 | 12.9 | 1.5 | 575 | 87 | 1.7 | 6.6 | 12.4
A-50-80-MPLCOm2012-0.021 | 208,036 | 227,444 | 12.9 | 1.6 | 577 | 88 | 1.7 | 6.7 | 12.4
A-55-80-Bach-0.034 | 210,852 | 230,654 | 11.8 | 1.4 | 586 | 91 | 1.8 | 6.8 | 12.4
A-50-80-Bach-0.034 | 211,124 | 230,939 | 11.9 | 1.4 | 587 | 91 | 1.8 | 6.8 | 12.4
B-50-80-Bach-0.018 | 215,660 | 237,177 | 8.1 | 1.1 | 630 | 81 | 1.6 | 5.8 | 15.0
B-50-80-MPLCOm2012-0.01 | 218,734 | 240,164 | 8.7 | 1.2 | 629 | 79 | 1.6 | 5.7 | 15.2
A-55-80-MPLCOm2012-0.02 | 218,788 | 238,809 | 13.1 | 1.6 | 593 | 88 | 1.7 | 6.5 | 13.2
A-50-80-MPLCOm2012-0.02 | 219,385 | 239,424 | 13.1 | 1.6 | 593 | 89 | 1.7 | 6.6 | 13.3
A-55-80-Bach-0.033 | 219,722 | 240,035 | 12.1 | 1.5 | 600 | 92 | 1.8 | 6.8 | 12.9
A-50-80-Bach-0.033 | 220,098 | 240,422 | 12.1 | 1.5 | 600 | 93 | 1.8 | 6.8 | 13.0
A-55-80-Bach-0.032 | 229,326 | 250,179 | 12.3 | 1.5 | 615 | 93 | 1.8 | 6.7 | 13.5
A-50-80-Bach-0.032 | 229,844 | 250,737 | 12.3 | 1.5 | 616 | 93 | 1.8 | 6.7 | 13.6
A-55-80-MPLCOm2012-0.019 | 230,831 | 251,544 | 13.3 | 1.6 | 611 | 90 | 1.8 | 6.5 | 13.9
A-50-80-MPLCOm2012-0.019 | 231,879 | 252,644 | 13.4 | 1.6 | 613 | 91 | 1.8 | 6.6 | 14.0
A-50-80-MLCDRAT-0.02 | 232,308 | 253,318 | 12.4 | 1.5 | 617 | 95 | 1.9 | 6.9 | 12.6
B-50-80-Bach-0.016 | 236,644 | 259,440 | 8.4 | 1.2 | 664 | 83 | 1.6 | 5.7 | 16.7
B-50-80-MPLCOm2012-0.009 | 237,535 | 260,113 | 9.0 | 1.2 | 655 | 80 | 1.6 | 5.6 | 16.8
A-55-80-Bach-0.031 | 238,433 | 259,818 | 12.4 | 1.5 | 629 | 94 | 1.8 | 6.7 | 14.3
A-50-80-Bach-0.031 | 239,121 | 260,536 | 12.5 | 1.5 | 629 | 94 | 1.8 | 6.7 | 14.4
A-55-80-MPLCOm2012-0.018 | 243,611 | 265,042 | 13.6 | 1.6 | 629 | 93 | 1.8 | 6.6 | 14.6
A-50-80-MPLCOm2012-0.018 | 245,376 | 266,914 | 13.7 | 1.6 | 634 | 94 | 1.8 | 6.6 | 14.6
A-50-80-MLCDRAT-0.019 | 247,829 | 269,732 | 12.7 | 1.5 | 639 | 95 | 1.9 | 6.7 | 13.9
A-55-80-Bach-0.03 | 248,734 | 270,709 | 12.6 | 1.5 | 644 | 96 | 1.9 | 6.7 | 15.0
A-50-80-Bach-0.03 | 249,665 | 271,690 | 12.7 | 1.5 | 647 | 98 | 1.9 | 6.8 | 15.0
A-55-80-30-15 | 250,071 | 271,454 | 15.9 | 1.9 | 569 | 74 | 1.4 | 6.1 | 19.2
A-55-80-MPLCOm2012-0.017 | 257,599 | 279,846 | 13.8 | 1.7 | 649 | 94 | 1.8 | 6.5 | 15.8
A-55-80-Bach-0.029 | 258,471 | 281,008 | 12.8 | 1.5 | 658 | 97 | 1.9 | 6.7 | 15.5
B-50-80-MPLCOm2012-0.008 | 258,855 | 282,714 | 9.2 | 1.3 | 685 | 83 | 1.6 | 5.7 | 18.4
A-50-80-MLCDRAT-0.018 | 259,222 | 281,781 | 13.0 | 1.6 | 655 | 97 | 1.9 | 6.7 | 14.6
A-55-80-MLCDRAT-0.018 | 259,229 | 281,781 | 13.0 | 1.6 | 656 | 96 | 1.9 | 6.6 | 14.6
A-50-80-Bach-0.029 | 259,707 | 282,302 | 12.9 | 1.5 | 661 | 99 | 1.9 | 6.8 | 15.6
B-50-80-Bach-0.014 | 259,722 | 283,917 | 8.7 | 1.2 | 694 | 85 | 1.7 | 5.7 | 18.0
A-50-80-MPLCOm2012-0.017 | 260,376 | 282,753 | 14.0 | 1.7 | 654 | 96 | 1.9 | 6.6 | 16.1
A-55-80-Bach-0.028 | 269,770 | 292,932 | 13.0 | 1.6 | 673 | 99 | 1.9 | 6.7 | 16.0
A-50-80-Bach-0.028 | 271,389 | 294,655 | 13.1 | 1.6 | 676 | 100 | 2.0 | 6.7 | 16.0
A-55-80-MPLCOm2012-0.016 | 272,384 | 295,471 | 14.1 | 1.7 | 669 | 97 | 1.9 | 6.6 | 16.9
B-50-80-Bach-0.013 | 272,403 | 297,367 | 8.9 | 1.2 | 710 | 85 | 1.7 | 5.6 | 18.6
A-50-80-MPLCOm2012-0.016 | 276,601 | 299,891 | 14.3 | 1.7 | 676 | 98 | 1.9 | 6.6 | 17.5
A-50-80-MLCDRAT-0.017 | 277,443 | 301,020 | 13.4 | 1.6 | 680 | 99 | 1.9 | 6.7 | 15.9
A-55-80-Bach-0.027 | 280,992 | 304,828 | 13.3 | 1.6 | 688 | 100 | 2.0 | 6.6 | 16.8
A-50-80-Bach-0.027 | 283,167 | 307,107 | 13.3 | 1.6 | 693 | 102 | 2.0 | 6.7 | 16.9
B-50-80-MPLCOm2012-0.007 | 283,776 | 309,157 | 9.6 | 1.3 | 717 | 85 | 1.7 | 5.6 | 19.6
B-50-80-Bach-0.012 | 285,918 | 311,687 | 9.1 | 1.2 | 731 | 87 | 1.7 | 5.7 | 19.5
A-55-80-MPLCOm2012-0.015 | 288,785 | 312,806 | 14.4 | 1.7 | 690 | 97 | 1.9 | 6.5 | 17.8
A-50-80-MLCDRAT-0.016 | 291,376 | 315,736 | 13.7 | 1.6 | 699 | 100 | 2.0 | 6.6 | 17.0
A-55-80-Bach-0.026 | 292,283 | 316,751 | 13.4 | 1.6 | 704 | 101 | 2.0 | 6.6 | 17.5
A-50-80-Bach-0.026 | 294,924 | 319,534 | 13.5 | 1.6 | 708 | 102 | 2.0 | 6.6 | 17.5
A-50-80-MPLCOm2012-0.015 | 294,962 | 319,290 | 14.7 | 1.7 | 700 | 98 | 1.9 | 6.4 | 18.5
A-50-77-MPLCOm2012-0.013 | 299,824 | 324,503 | 14.4 | 1.7 | 655 | 76 | 1.5 | 5.6 | 20.0
B-50-80-Bach-0.011 | 301,272 | 327,971 | 9.2 | 1.3 | 749 | 89 | 1.7 | 5.7 | 20.4
A-55-80-Bach-0.025 | 304,744 | 329,910 | 13.6 | 1.6 | 720 | 102 | 2.0 | 6.6 | 18.2
A-55-80-MPLCOm2012-0.014 | 306,772 | 331,792 | 14.7 | 1.7 | 714 | 98 | 1.9 | 6.4 | 18.6
A-50-80-Bach-0.025 | 308,347 | 333,700 | 13.8 | 1.6 | 726 | 103 | 2.0 | 6.6 | 18.5
B-50-80-MPLCOm2012-0.006 | 310,648 | 337,686 | 9.9 | 1.3 | 751 | 89 | 1.7 | 5.8 | 21.1
A-50-80-MLCDRAT-0.015 | 311,463 | 336,952 | 14.1 | 1.7 | 727 | 103 | 2.0 | 6.6 | 17.8
A-50-80-MPLCOm2012-0.014 | 315,485 | 340,961 | 15.0 | 1.8 | 727 | 99 | 1.9 | 6.4 | 19.6
B-50-80-Bach-0.01 | 317,492 | 345,173 | 9.4 | 1.3 | 770 | 90 | 1.8 | 5.7 | 21.1
A-55-80-Bach-0.024 | 317,493 | 343,389 | 13.9 | 1.6 | 736 | 103 | 2.0 | 6.5 | 18.6
A-50-80-Bach-0.024 | 321,715 | 347,798 | 14.0 | 1.7 | 743 | 104 | 2.0 | 6.5 | 18.9
A-50-77-MPLCOm2012-0.012 | 323,796 | 349,800 | 14.9 | 1.8 | 683 | 76 | 1.5 | 5.5 | 22.3
A-55-80-MPLCOm2012-0.013 | 325,898 | 352,028 | 15.0 | 1.8 | 738 | 100 | 2.0 | 6.4 | 19.7
A-55-80-MLCDRAT-0.014 | 326,637 | 353,017 | 14.3 | 1.7 | 744 | 103 | 2.0 | 6.5 | 19.0
A-55-80-Bach-0.023 | 329,902 | 356,492 | 14.0 | 1.7 | 753 | 104 | 2.0 | 6.5 | 19.2
A-50-80-MLCDRAT-0.014 | 331,138 | 357,743 | 14.4 | 1.7 | 750 | 104 | 2.0 | 6.5 | 19.2
B-50-80-Bach-0.009 | 335,044 | 363,803 | 9.6 | 1.3 | 793 | 91 | 1.8 | 5.6 | 22.1
A-50-80-Bach-0.023 | 335,415 | 362,284 | 14.2 | 1.7 | 761 | 105 | 2.1 | 6.5 | 19.7
A-50-80-MPLCOm2012-0.013 | 337,953 | 364,676 | 15.4 | 1.8 | 754 | 102 | 2.0 | 6.4 | 20.9
A-55-80-20-15 | 338,814 | 365,553 | 15.5 | 1.9 | 701 | 85 | 1.7 | 6.0 | 25.5
B-50-80-MPLCOm2012-0.005 | 341,618 | 370,499 | 10.2 | 1.4 | 788 | 89 | 1.7 | 5.6 | 22.4
A-55-80-Bach-0.022 | 343,709 | 371,077 | 14.3 | 1.7 | 768 | 105 | 2.0 | 6.5 | 20.1
A-55-80-MLCDRAT-0.013 | 344,246 | 371,602 | 14.5 | 1.7 | 768 | 104 | 2.0 | 6.4 | 19.6
A-55-80-MPLCOm2012-0.012 | 347,253 | 374,586 | 15.3 | 1.8 | 763 | 101 | 2.0 | 6.3 | 21.2
A-50-80-Bach-0.022 | 350,428 | 378,144 | 14.5 | 1.7 | 778 | 106 | 2.1 | 6.5 | 20.8
A-50-77-MPLCOm2012-0.011 | 350,473 | 377,955 | 15.3 | 1.8 | 712 | 78 | 1.5 | 5.5 | 24.0
A-50-80-MLCDRAT-0.013 | 351,020 | 378,721 | 14.7 | 1.7 | 777 | 105 | 2.1 | 6.4 | 20.2
A-55-80-Bach-0.021 | 357,845 | 386,027 | 14.5 | 1.7 | 787 | 107 | 2.1 | 6.5 | 20.7
A-50-80-MPLCOm2012-0.012 | 363,819 | 391,987 | 15.9 | 1.9 | 785 | 103 | 2.0 | 6.3 | 23.2
A-50-80-Bach-0.021 | 366,256 | 394,849 | 14.8 | 1.7 | 798 | 107 | 2.1 | 6.4 | 21.8
A-55-80-MLCDRAT-0.012 | 367,142 | 395,803 | 14.7 | 1.7 | 792 | 106 | 2.1 | 6.4 | 20.8
A-55-80-MPLCOm2012-0.011 | 368,985 | 397,533 | 15.5 | 1.8 | 789 | 103 | 2.0 | 6.3 | 22.3
A-55-80-Bach-0.02 | 372,015 | 400,988 | 14.7 | 1.7 | 802 | 108 | 2.1 | 6.5 | 21.4
A-50-80-MLCDRAT-0.012 | 376,831 | 406,001 | 15.1 | 1.8 | 805 | 106 | 2.1 | 6.4 | 21.9
A-50-77-MPLCOm2012-0.01 | 380,379 | 409,508 | 15.8 | 1.9 | 745 | 80 | 1.6 | 5.4 | 26.2
A-55-80-20-20 | 380,919 | 409,986 | 16.2 | 1.9 | 757 | 92 | 1.8 | 6.1 | 27.0
A-50-80-Bach-0.02 | 382,555 | 412,078 | 15.1 | 1.8 | 818 | 109 | 2.1 | 6.4 | 22.4
A-55-80-Bach-0.019 | 387,182 | 417,016 | 14.9 | 1.8 | 820 | 109 | 2.1 | 6.4 | 22.4
A-55-80-MLCDRAT-0.011 | 391,357 | 421,465 | 14.7 | 1.7 | 823 | 107 | 2.1 | 6.3 | 21.7
A-50-80-MPLCOm2012-0.011 | 392,507 | 422,240 | 16.4 | 1.9 | 817 | 105 | 2.0 | 6.2 | 25.0
A-55-80-MPLCOm2012-0.01 | 392,619 | 422,531 | 15.8 | 1.8 | 817 | 106 | 2.1 | 6.3 | 23.7
A-50-80-Bach-0.019 | 399,519 | 429,959 | 15.3 | 1.8 | 835 | 110 | 2.1 | 6.4 | 23.5
A-55-80-Bach-0.018 | 402,967 | 433,679 | 15.1 | 1.8 | 837 | 109 | 2.1 | 6.4 | 23.4
A-50-80-MLCDRAT-0.011 | 403,985 | 434,727 | 15.1 | 1.8 | 840 | 108 | 2.1 | 6.3 | 23.0
A-50-80-Bach-0.018 | 418,219 | 449,707 | 15.7 | 1.8 | 857 | 111 | 2.2 | 6.4 | 25.0
A-55-80-Bach-0.017 | 419,571 | 451,223 | 15.4 | 1.8 | 857 | 110 | 2.2 | 6.3 | 25.0
A-55-80-20-25 | 419,641 | 450,762 | 17.2 | 2.0 | 804 | 96 | 1.9 | 6.1 | 28.0
A-55-80-MLCDRAT-0.01 | 420,681 | 452,612 | 14.5 | 1.7 | 859 | 110 | 2.1 | 6.3 | 23.3
A-50-80-MPLCOm2012-0.01 | 424,646 | 456,160 | 16.8 | 2.0 | 851 | 108 | 2.1 | 6.3 | 27.2
A-55-80-Bach-0.016 | 436,416 | 468,989 | 15.6 | 1.8 | 875 | 111 | 2.2 | 6.3 | 26.0
A-50-80-MLCDRAT-0.01 | 437,146 | 469,895 | 15.0 | 1.8 | 878 | 109 | 2.1 | 6.2 | 25.4
A-50-80-20-15 | 438,248 | 470,133 | 18.0 | 2.1 | 796 | 87 | 1.7 | 5.8 | 34.8
A-50-80-Bach-0.017 | 438,368 | 470,946 | 15.9 | 1.9 | 878 | 112 | 2.2 | 6.3 | 27.3
A-55-80-MPLCOm2012-0.008 | 450,041 | 483,185 | 16.3 | 1.9 | 879 | 110 | 2.1 | 6.3 | 26.0
A-55-80-Bach-0.015 | 454,682 | 488,283 | 15.8 | 1.9 | 894 | 112 | 2.2 | 6.3 | 26.6
A-55-80-MLCDRAT-0.009 | 455,814 | 489,876 | 14.4 | 1.7 | 902 | 113 | 2.2 | 6.3 | 26.5
A-50-80-Bach-0.016 | 459,189 | 492,919 | 16.3 | 1.9 | 901 | 114 | 2.2 | 6.4 | 28.7
A-50-80-MPLCOm2012-0.009 | 461,261 | 494,773 | 17.3 | 2.0 | 890 | 108 | 2.1 | 6.1 | 29.0
A-55-80-Bach-0.014 | 473,162 | 507,797 | 16.0 | 1.9 | 913 | 112 | 2.2 | 6.2 | 27.5
A-50-80-MLCDRAT-0.009 | 477,198 | 512,305 | 15.0 | 1.8 | 925 | 113 | 2.2 | 6.2 | 29.1
A-50-80-Bach-0.015 | 481,441 | 516,395 | 16.6 | 1.9 | 924 | 113 | 2.2 | 6.2 | 29.8
A-50-80-20-20 | 486,445 | 520,898 | 19.2 | 2.3 | 854 | 92 | 1.8 | 5.8 | 36.6
A-55-80-Bach-0.013 | 493,124 | 528,833 | 16.3 | 1.9 | 932 | 113 | 2.2 | 6.2 | 28.9
A-55-80-MLCDRAT-0.008 | 493,984 | 530,349 | 14.3 | 1.7 | 944 | 115 | 2.3 | 6.3 | 27.8
A-50-80-MPLCOm2012-0.008 | 503,446 | 539,247 | 17.9 | 2.1 | 933 | 112 | 2.2 | 6.2 | 31.9
A-50-80-Bach-0.014 | 504,514 | 540,717 | 16.9 | 2.0 | 947 | 114 | 2.2 | 6.2 | 30.7
A-55-80-Bach-0.012 | 513,666 | 550,548 | 16.5 | 1.9 | 954 | 115 | 2.2 | 6.2 | 29.9
A-50-80-MLCDRAT-0.008 | 523,694 | 561,540 | 15.0 | 1.8 | 977 | 117 | 2.3 | 6.2 | 31.1
A-50-80-20-25 | 527,801 | 564,345 | 20.6 | 2.4 | 902 | 97 | 1.9 | 5.9 | 38.3
A-50-80-Bach-0.013 | 529,448 | 567,018 | 17.2 | 2.0 | 972 | 115 | 2.3 | 6.2 | 32.7
A-55-80-Bach-0.011 | 536,628 | 574,791 | 16.7 | 1.9 | 978 | 116 | 2.3 | 6.2 | 30.7
A-55-80-MLCDRAT-0.007 | 540,710 | 579,802 | 14.5 | 1.7 | 995 | 118 | 2.3 | 6.2 | 29.8
A-50-80-MPLCOm2012-0.007 | 550,625 | 589,036 | 18.5 | 2.1 | 979 | 113 | 2.2 | 6.1 | 34.5
A-50-80-Bach-0.012 | 555,908 | 594,910 | 17.6 | 2.0 | 998 | 116 | 2.3 | 6.1 | 34.6
A-55-80-Bach-0.01 | 560,821 | 600,336 | 16.9 | 2.0 | 1,001 | 117 | 2.3 | 6.2 | 31.8
A-50-80-MLCDRAT-0.007 | 579,320 | 620,339 | 15.3 | 1.8 | 1,036 | 119 | 2.3 | 6.1 | 34.0
A-50-80-Bach-0.011 | 585,729 | 626,353 | 17.9 | 2.1 | 1,027 | 118 | 2.3 | 6.1 | 36.1
A-55-80-MLCDRAT-0.006 | 596,266 | 638,485 | 14.9 | 1.8 | 1,050 | 121 | 2.4 | 6.2 | 32.0
A-50-80-MPLCOm2012-0.006 | 602,353 | 643,586 | 19.1 | 2.2 | 1,027 | 115 | 2.3 | 6.1 | 37.1
A-50-80-Bach-0.01 | 617,099 | 659,415 | 18.3 | 2.1 | 1,056 | 120 | 2.4 | 6.2 | 37.6

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 15 Benefits of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort Women

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC deaths averted | NNS
B-50-80-MLCDRAT-0.015 | 19.4 | 134,898 | 1,095 | 9.2 | 342 | 3,817 | 11.2 | 35 | 394 | 57
B-50-80-Bach-0.025 | 20.9 | 141,428 | 1,140 | 9.5 | 356 | 3,977 | 11.2 | 36 | 397 | 59
B-50-80-MPLCOm2012-0.014 | 18.6 | 143,839 | 1,128 | 9.5 | 355 | 4,127 | 11.6 | 35 | 405 | 52
B-55-80-Bach-0.024 | 21.3 | 145,782 | 1,135 | 9.5 | 355 | 4,034 | 11.4 | 36 | 411 | 60
B-50-80-MLCDRAT-0.014 | 20.4 | 146,532 | 1,139 | 9.7 | 361 | 4,078 | 11.3 | 36 | 406 | 57
B-50-80-Bach-0.024 | 21.5 | 148,445 | 1,165 | 9.7 | 364 | 4,111 | 11.3 | 36 | 408 | 59
B-55-80-MPLCOm2012-0.013 | 19.3 | 149,511 | 1,122 | 9.5 | 355 | 4,179 | 11.8 | 36 | 421 | 54
B-50-80-MPLCOm2012-0.013 | 19.4 | 154,244 | 1,159 | 9.9 | 369 | 4,337 | 11.8 | 36 | 418 | 53
B-50-80-Bach-0.023 | 22.1 | 155,703 | 1,187 | 10.0 | 373 | 4,238 | 11.4 | 37 | 417 | 59
A-55-80-MLCDRAT-0.023 | 14.4 | 160,079 | 1,071 | 10.0 | 372 | 3,881 | 10.4 | 41 | 430 | 39
A-55-80-MPLCOm2012-0.023 | 13.5 | 161,887 | 1,097 | 10.2 | 379 | 4,027 | 10.6 | 40 | 427 | 36
A-50-80-MPLCOm2012-0.023 | 13.5 | 161,919 | 1,094 | 10.2 | 379 | 4,065 | 10.7 | 40 | 427 | 36
B-50-80-Bach-0.022 | 22.6 | 162,947 | 1,205 | 10.2 | 380 | 4,355 | 11.5 | 37 | 429 | 59
B-50-80-MPLCOm2012-0.012 | 20.3 | 166,180 | 1,188 | 10.2 | 380 | 4,531 | 11.9 | 37 | 437 | 53
B-55-80-Bach-0.021 | 23.1 | 167,330 | 1,190 | 10.1 | 378 | 4,378 | 11.6 | 38 | 443 | 61
A-55-80-MPLCOm2012-0.022 | 13.9 | 170,819 | 1,122 | 10.5 | 392 | 4,213 | 10.7 | 41 | 436 | 35
A-50-80-MPLCOm2012-0.022 | 13.9 | 170,873 | 1,122 | 10.5 | 391 | 4,231 | 10.8 | 40 | 437 | 36
B-50-80-Bach-0.021 | 23.2 | 170,970 | 1,224 | 10.3 | 386 | 4,472 | 11.6 | 38 | 443 | 60
B-55-80-Bach-0.02 | 23.7 | 175,191 | 1,210 | 10.3 | 385 | 4,481 | 11.6 | 39 | 455 | 62
A-55-80-Bach-0.034 | 16.4 | 177,346 | 1,158 | 10.6 | 396 | 4,205 | 10.6 | 42 | 448 | 41
A-50-80-Bach-0.034 | 16.4 | 177,398 | 1,156 | 10.6 | 397 | 4,204 | 10.6 | 42 | 447 | 41
B-50-80-Bach-0.02 | 23.8 | 179,470 | 1,245 | 10.6 | 398 | 4,627 | 11.6 | 39 | 451 | 60
A-55-80-MPLCOm2012-0.021 | 14.4 | 180,223 | 1,149 | 10.8 | 403 | 4,399 | 10.9 | 41 | 447 | 36
B-50-80-MPLCOm2012-0.011 | 21.4 | 180,282 | 1,223 | 10.5 | 394 | 4,744 | 12.0 | 38 | 458 | 54
A-50-80-MPLCOm2012-0.021 | 14.4 | 180,349 | 1,149 | 10.8 | 402 | 4,363 | 10.9 | 41 | 449 | 36
B-55-80-Bach-0.019 | 24.3 | 183,071 | 1,227 | 10.4 | 390 | 4,541 | 11.6 | 40 | 469 | 62
A-55-80-Bach-0.033 | 16.8 | 186,164 | 1,182 | 11.0 | 409 | 4,353 | 10.6 | 43 | 455 | 41
A-50-80-Bach-0.033 | 16.8 | 186,235 | 1,181 | 11.0 | 409 | 4,349 | 10.6 | 43 | 455 | 41
B-50-80-Bach-0.019 | 24.4 | 188,246 | 1,268 | 10.9 | 406 | 4,753 | 11.7 | 40 | 464 | 60
A-50-80-MLCDRAT-0.02 | 16.1 | 188,813 | 1,160 | 10.9 | 406 | 4,331 | 10.7 | 44 | 465 | 40
A-55-80-MPLCOm2012-0.02 | 14.9 | 190,436 | 1,176 | 11.1 | 413 | 4,531 | 11.0 | 42 | 461 | 36
A-50-80-MPLCOm2012-0.02 | 14.9 | 190,654 | 1,177 | 11.0 | 411 | 4,541 | 11.0 | 42 | 464 | 36
A-55-80-Bach-0.032 | 17.3 | 195,037 | 1,205 | 11.3 | 420 | 4,466 | 10.6 | 44 | 464 | 41
A-50-80-Bach-0.032 | 17.3 | 195,135 | 1,207 | 11.2 | 418 | 4,459 | 10.7 | 44 | 467 | 41
B-50-80-MPLCOm2012-0.01 | 22.4 | 195,180 | 1,255 | 10.8 | 405 | 4,974 | 12.3 | 39 | 482 | 55
B-50-80-Bach-0.018 | 25.0 | 197,502 | 1,292 | 11.1 | 416 | 4,885 | 11.7 | 40 | 475 | 60
A-55-80-MPLCOm2012-0.019 | 15.4 | 201,751 | 1,206 | 11.5 | 427 | 4,707 | 11.0 | 43 | 472 | 36
A-50-80-MPLCOm2012-0.019 | 15.4 | 202,181 | 1,206 | 11.5 | 428 | 4,737 | 11.1 | 43 | 472 | 36
A-50-80-MLCDRAT-0.019 | 16.8 | 202,754 | 1,198 | 11.2 | 419 | 4,521 | 10.8 | 45 | 484 | 40
A-55-80-Bach-0.031 | 17.8 | 204,408 | 1,232 | 11.5 | 427 | 4,614 | 10.8 | 44 | 479 | 42
A-50-80-Bach-0.031 | 17.8 | 204,573 | 1,231 | 11.6 | 431 | 4,652 | 10.8 | 44 | 475 | 41
A-55-80-30-15 | 12.4 | 204,815 | 995 | 9.7 | 362 | 4,685 | 12.9 | 44 | 566 | 34
B-50-80-MPLCOm2012-0.009 | 23.6 | 212,574 | 1,289 | 11.2 | 418 | 5,154 | 12.3 | 41 | 509 | 56
A-55-80-MLCDRAT-0.018 | 17.3 | 213,736 | 1,229 | 11.5 | 429 | 4,650 | 10.8 | 46 | 498 | 40
A-50-80-MLCDRAT-0.018 | 17.3 | 213,737 | 1,229 | 11.6 | 433 | 4,699 | 10.9 | 45 | 494 | 40
A-55-80-MPLCOm2012-0.018 | 16.0 | 213,742 | 1,232 | 11.8 | 438 | 4,873 | 11.1 | 44 | 488 | 37
A-55-80-Bach-0.03 | 18.3 | 214,301 | 1,259 | 11.8 | 441 | 4,784 | 10.8 | 45 | 486 | 41
A-50-80-MPLCOm2012-0.018 | 16.0 | 214,512 | 1,237 | 11.8 | 440 | 4,911 | 11.2 | 44 | 488 | 36
A-50-80-Bach-0.03 | 18.3 | 214,518 | 1,258 | 11.8 | 439 | 4,787 | 10.9 | 45 | 489 | 42
B-50-80-Bach-0.016 | 26.4 | 218,146 | 1,328 | 11.4 | 425 | 5,097 | 12.0 | 43 | 513 | 62
A-55-80-Bach-0.029 | 18.8 | 224,497 | 1,283 | 12.0 | 449 | 4,886 | 10.9 | 46 | 500 | 42
A-50-80-Bach-0.029 | 18.8 | 224,848 | 1,283 | 12.0 | 449 | 4,897 | 10.9 | 46 | 501 | 42
A-55-80-MPLCOm2012-0.017 | 16.6 | 227,059 | 1,265 | 12.0 | 449 | 5,060 | 11.3 | 45 | 506 | 37
A-50-80-MPLCOm2012-0.017 | 16.6 | 228,322 | 1,269 | 12.0 | 448 | 5,088 | 11.4 | 45 | 510 | 37
A-50-80-MLCDRAT-0.017 | 18.0 | 229,798 | 1,265 | 11.9 | 445 | 4,893 | 11.0 | 47 | 516 | 40
B-50-80-MPLCOm2012-0.008 | 25.0 | 232,698 | 1,331 | 11.6 | 433 | 5,417 | 12.5 | 43 | 537 | 58
A-55-80-Bach-0.028 | 19.3 | 235,410 | 1,311 | 12.3 | 459 | 5,051 | 11.0 | 47 | 513 | 42
A-50-80-Bach-0.028 | 19.3 | 235,837 | 1,309 | 12.3 | 459 | 5,046 | 11.0 | 47 | 514 | 42
B-50-80-Bach-0.014 | 27.9 | 241,059 | 1,374 | 11.8 | 442 | 5,383 | 12.2 | 45 | 545 | 63
A-55-80-MPLCOm2012-0.016 | 17.3 | 241,064 | 1,297 | 12.4 | 461 | 5,255 | 11.4 | 46 | 523 | 38
A-50-80-MPLCOm2012-0.016 | 17.3 | 243,063 | 1,303 | 12.5 | 465 | 5,366 | 11.5 | 45 | 523 | 37
A-50-80-MLCDRAT-0.016 | 18.6 | 243,477 | 1,300 | 12.4 | 461 | 5,097 | 11.1 | 48 | 528 | 40
A-55-80-Bach-0.027 | 19.9 | 246,980 | 1,336 | 12.6 | 469 | 5,170 | 11.0 | 48 | 527 | 42
A-50-80-Bach-0.027 | 19.9 | 247,655 | 1,333 | 12.5 | 468 | 5,154 | 11.0 | 48 | 529 | 43
B-50-80-Bach-0.013 | 28.7 | 253,866 | 1,395 | 12.1 | 453 | 5,579 | 12.3 | 46 | 560 | 63
B-50-80-MPLCOm2012-0.007 | 26.5 | 256,519 | 1,379 | 12.2 | 454 | 5,669 | 12.5 | 45 | 565 | 58
A-55-80-MPLCOm2012-0.015 | 17.9 | 256,832 | 1,328 | 12.7 | 473 | 5,422 | 11.5 | 47 | 543 | 38
A-55-80-Bach-0.026 | 20.4 | 258,376 | 1,358 | 12.9 | 480 | 5,309 | 11.1 | 49 | 538 | 42
A-50-80-Bach-0.026 | 20.5 | 259,208 | 1,357 | 12.9 | 480 | 5,327 | 11.1 | 49 | 540 | 43
A-50-80-MPLCOm2012-0.015 | 18.0 | 259,891 | 1,339 | 12.8 | 478 | 5,544 | 11.6 | 47 | 544 | 38
A-50-77-MPLCOm2012-0.013 | 18.5 | 260,403 | 1,163 | 11.5 | 429 | 5,548 | 12.9 | 47 | 607 | 43
A-50-80-MLCDRAT-0.015 | 19.5 | 260,844 | 1,340 | 12.7 | 474 | 5,326 | 11.2 | 49 | 550 | 41
B-50-80-Bach-0.012 | 29.6 | 268,148 | 1,415 | 12.4 | 463 | 5,717 | 12.3 | 47 | 579 | 64
A-55-80-Bach-0.025 | 21.0 | 271,125 | 1,385 | 13.0 | 486 | 5,446 | 11.2 | 50 | 558 | 43
A-50-80-Bach-0.025 | 21.0 | 272,333 | 1,386 | 13.1 | 489 | 5,494 | 11.2 | 50 | 557 | 43
A-55-80-MPLCOm2012-0.014 | 18.7 | 274,089 | 1,366 | 13.0 | 486 | 5,595 | 11.5 | 49 | 564 | 38
A-50-80-MPLCOm2012-0.014 | 18.7 | 278,533 | 1,372 | 13.2 | 492 | 5,761 | 11.7 | 48 | 566 | 38
A-55-80-MLCDRAT-0.014 | 20.5 | 279,935 | 1,378 | 13.1 | 491 | 5,528 | 11.3 | 51 | 570 | 42
A-50-80-MLCDRAT-0.014 | 20.5 | 281,138 | 1,382 | 13.2 | 492 | 5,585 | 11.4 | 50 | 571 | 42
A-50-77-MPLCOm2012-0.012 | 19.4 | 282,250 | 1,198 | 11.8 | 442 | 5,803 | 13.1 | 49 | 639 | 44
B-50-80-MPLCOm2012-0.006 | 28.3 | 282,713 | 1,418 | 12.5 | 467 | 5,920 | 12.7 | 48 | 605 | 61
B-50-80-Bach-0.011 | 30.5 | 282,984 | 1,441 | 12.6 | 472 | 5,866 | 12.4 | 48 | 600 | 65
A-55-80-Bach-0.024 | 21.6 | 284,191 | 1,411 | 13.3 | 497 | 5,599 | 11.3 | 51 | 572 | 43
A-50-80-Bach-0.024 | 21.6 | 285,840 | 1,413 | 13.3 | 498 | 5,655 | 11.4 | 51 | 574 | 43
A-55-80-MPLCOm2012-0.013 | 19.5 | 292,670 | 1,393 | 13.4 | 500 | 5,824 | 11.6 | 50 | 585 | 39
A-55-80-MLCDRAT-0.013 | 21.5 | 297,479 | 1,412 | 13.6 | 506 | 5,742 | 11.3 | 52 | 588 | 42
A-55-80-Bach-0.023 | 22.1 | 297,926 | 1,437 | 13.7 | 512 | 5,794 | 11.3 | 51 | 582 | 43
B-50-80-Bach-0.01 | 31.5 | 298,689 | 1,472 | 12.8 | 478 | 5,997 | 12.5 | 50 | 625 | 66
A-50-80-MPLCOm2012-0.013 | 19.5 | 299,050 | 1,406 | 13.5 | 506 | 6,000 | 11.9 | 50 | 591 | 39
A-50-80-MLCDRAT-0.013 | 21.5 | 299,330 | 1,414 | 13.6 | 507 | 5,793 | 11.4 | 52 | 590 | 42
A-50-80-Bach-0.023 | 22.2 | 299,941 | 1,442 | 13.7 | 512 | 5,852 | 11.4 | 51 | 586 | 43
A-50-77-MPLCOm2012-0.011 | 20.3 | 306,772 | 1,234 | 12.3 | 458 | 6,081 | 13.3 | 50 | 670 | 44
A-55-80-Bach-0.022 | 22.7 | 311,728 | 1,462 | 13.9 | 521 | 5,931 | 11.4 | 53 | 598 | 44
B-50-80-MPLCOm2012-0.005 | 30.3 | 312,927 | 1,458 | 12.9 | 484 | 6,215 | 12.8 | 50 | 647 | 63
A-55-80-MPLCOm2012-0.012 | 20.4 | 313,442 | 1,433 | 13.8 | 514 | 6,069 | 11.8 | 52 | 610 | 40
A-50-80-Bach-0.022 | 22.7 | 314,475 | 1,462 | 13.9 | 521 | 6,004 | 11.5 | 52 | 604 | 44
B-50-80-Bach-0.009 | 32.6 | 316,758 | 1,496 | 13.1 | 490 | 6,182 | 12.6 | 51 | 646 | 67
A-55-80-MLCDRAT-0.012 | 22.8 | 320,284 | 1,454 | 13.9 | 521 | 5,961 | 11.4 | 54 | 615 | 44
A-55-80-20-15 | 19.3 | 321,376 | 1,253 | 12.4 | 463 | 6,014 | 13.0 | 53 | 694 | 42
A-50-80-MPLCOm2012-0.012 | 20.4 | 322,767 | 1,447 | 14.0 | 524 | 6,276 | 12.0 | 51 | 616 | 39
A-50-80-MLCDRAT-0.012 | 22.8 | 323,741 | 1,460 | 14.0 | 524 | 6,054 | 11.6 | 53 | 618 | 44
A-55-80-Bach-0.021 | 23.3 | 326,829 | 1,483 | 14.2 | 532 | 6,115 | 11.5 | 53 | 614 | 44
A-50-80-Bach-0.021 | 23.3 | 330,309 | 1,487 | 14.3 | 535 | 6,226 | 11.6 | 53 | 617 | 44
A-50-77-MPLCOm2012-0.01 | 21.4 | 334,311 | 1,270 | 12.7 | 476 | 6,397 | 13.4 | 52 | 702 | 45
A-55-80-MPLCOm2012-0.011 | 21.4 | 335,019 | 1,465 | 14.2 | 530 | 6,282 | 11.9 | 53 | 632 | 40
A-55-80-Bach-0.02 | 23.9 | 342,391 | 1,506 | 14.5 | 542 | 6,255 | 11.5 | 55 | 632 | 44
A-55-80-MLCDRAT-0.011 | 24.3 | 346,694 | 1,499 | 14.4 | 537 | 6,226 | 11.6 | 56 | 646 | 45
A-50-80-Bach-0.02 | 23.9 | 346,979 | 1,511 | 14.7 | 549 | 6,451 | 11.8 | 54 | 632 | 44
A-50-80-MPLCOm2012-0.011 | 21.5 | 349,310 | 1,484 | 14.5 | 543 | 6,559 | 12.1 | 53 | 643 | 40
A-50-80-MLCDRAT-0.011 | 24.4 | 351,744 | 1,509 | 14.6 | 547 | 6,420 | 11.7 | 55 | 643 | 45
A-55-80-Bach-0.019 | 24.5 | 358,013 | 1,530 | 14.7 | 551 | 6,428 | 11.7 | 56 | 650 | 44
A-55-80-20-20 | 20.4 | 358,302 | 1,345 | 13.2 | 495 | 6,363 | 12.9 | 56 | 724 | 41
A-55-80-MPLCOm2012-0.01 | 22.4 | 358,348 | 1,497 | 14.5 | 541 | 6,438 | 11.9 | 56 | 662 | 41
A-50-80-Bach-0.019 | 24.5 | 364,037 | 1,534 | 14.8 | 554 | 6,560 | 11.8 | 55 | 657 | 44
A-55-80-Bach-0.018 | 25.1 | 375,520 | 1,553 | 15.0 | 561 | 6,557 | 11.7 | 57 | 669 | 45
A-55-80-MLCDRAT-0.01 | 26.5 | 375,679 | 1,546 | 14.8 | 555 | 6,493 | 11.7 | 58 | 677 | 48
A-50-80-MPLCOm2012-0.01 | 22.5 | 379,066 | 1,525 | 14.9 | 556 | 6,832 | 12.3 | 55 | 682 | 40
A-50-80-MLCDRAT-0.01 | 26.6 | 382,462 | 1,560 | 15.1 | 565 | 6,682 | 11.8 | 57 | 677 | 47
A-50-80-Bach-0.018 | 25.2 | 382,696 | 1,563 | 15.2 | 567 | 6,740 | 11.9 | 57 | 675 | 44
A-55-80-20-25 | 20.9 | 389,551 | 1,413 | 13.9 | 520 | 6,645 | 12.8 | 59 | 749 | 40
A-55-80-Bach-0.017 | 25.7 | 393,075 | 1,576 | 15.4 | 574 | 6,748 | 11.8 | 58 | 685 | 45
A-50-80-20-15 | 20.9 | 399,813 | 1,305 | 13.2 | 492 | 6,805 | 13.8 | 59 | 813 | 42
A-50-80-Bach-0.017 | 25.8 | 402,336 | 1,590 | 15.6 | 584 | 6,974 | 11.9 | 58 | 689 | 44
A-55-80-MLCDRAT-0.009 | 29.1 | 411,379 | 1,600 | 15.3 | 574 | 6,767 | 11.8 | 61 | 717 | 51
A-55-80-Bach-0.016 | 26.4 | 411,443 | 1,596 | 15.5 | 579 | 6,879 | 11.9 | 60 | 711 | 46
A-50-80-MPLCOm2012-0.009 | 23.7 | 413,285 | 1,567 | 15.3 | 574 | 7,148 | 12.5 | 58 | 720 | 41
A-55-80-MPLCOm2012-0.008 | 24.8 | 415,073 | 1,576 | 15.4 | 575 | 6,935 | 12.1 | 60 | 722 | 43
A-50-80-MLCDRAT-0.009 | 29.2 | 420,863 | 1,613 | 15.7 | 587 | 7,014 | 11.9 | 60 | 717 | 50
A-50-80-Bach-0.016 | 26.5 | 423,398 | 1,615 | 15.8 | 590 | 7,101 | 12.0 | 60 | 718 | 45
A-55-80-Bach-0.015 | 27.1 | 430,085 | 1,622 | 15.8 | 591 | 7,014 | 11.9 | 61 | 728 | 46
A-50-80-20-20 | 21.4 | 440,469 | 1,391 | 14.1 | 526 | 7,205 | 13.7 | 61 | 837 | 41
A-50-80-Bach-0.015 | 27.2 | 445,160 | 1,635 | 16.0 | 601 | 7,305 | 12.2 | 61 | 741 | 45
A-55-80-Bach-0.014 | 27.8 | 450,056 | 1,644 | 16.1 | 603 | 7,186 | 11.9 | 63 | 746 | 46
A-50-80-MPLCOm2012-0.008 | 25.1 | 453,251 | 1,612 | 15.9 | 594 | 7,461 | 12.6 | 61 | 763 | 42
A-55-80-MLCDRAT-0.008 | 32.1 | 454,135 | 1,662 | 16.1 | 602 | 7,081 | 11.8 | 64 | 754 | 53
A-50-80-MLCDRAT-0.008 | 32.2 | 467,154 | 1,677 | 16.3 | 611 | 7,349 | 12.0 | 64 | 765 | 53
A-50-80-Bach-0.014 | 28.0 | 468,455 | 1,660 | 16.4 | 612 | 7,520 | 12.3 | 62 | 765 | 46
A-55-80-Bach-0.013 | 28.6 | 471,061 | 1,667 | 16.4 | 613 | 7,361 | 12.0 | 64 | 768 | 47
A-50-80-20-25 | 21.5 | 473,059 | 1,463 | 14.7 | 551 | 7,496 | 13.6 | 63 | 859 | 39
A-50-80-Bach-0.013 | 28.8 | 493,477 | 1,687 | 16.7 | 624 | 7,692 | 12.3 | 64 | 791 | 46
A-55-80-Bach-0.012 | 29.5 | 494,075 | 1,690 | 16.6 | 620 | 7,503 | 12.1 | 66 | 797 | 48
A-50-80-MPLCOm2012-0.007 | 26.6 | 498,159 | 1,655 | 16.4 | 613 | 7,804 | 12.7 | 64 | 813 | 43
A-55-80-MLCDRAT-0.007 | 35.1 | 501,028 | 1,718 | 16.7 | 627 | 7,437 | 11.9 | 67 | 799 | 56
A-55-80-Bach-0.011 | 30.4 | 517,897 | 1,715 | 16.8 | 630 | 7,647 | 12.1 | 68 | 822 | 48
A-50-80-Bach-0.012 | 29.7 | 521,068 | 1,715 | 16.9 | 634 | 7,862 | 12.4 | 66 | 822 | 47
A-50-80-MLCDRAT-0.007 | 35.2 | 522,234 | 1,743 | 17.2 | 643 | 7,823 | 12.2 | 67 | 812 | 55
A-55-80-Bach-0.01 | 31.3 | 542,703 | 1,740 | 17.1 | 642 | 7,829 | 12.2 | 69 | 845 | 49
A-50-80-MPLCOm2012-0.006 | 28.3 | 548,639 | 1,700 | 16.8 | 629 | 8,080 | 12.8 | 68 | 872 | 45
A-50-80-Bach-0.011 | 30.6 | 550,280 | 1,746 | 17.3 | 647 | 8,132 | 12.6 | 68 | 851 | 47
A-55-80-MLCDRAT-0.006 | 38.0 | 558,573 | 1,783 | 17.5 | 654 | 7,817 | 12.0 | 71 | 854 | 58
A-50-80-Bach-0.01 | 31.6 | 581,188 | 1,773 | 17.7 | 663 | 8,395 | 12.7 | 69 | 877 | 48

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 16 Harms of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort Women

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-50-80-MLCDRAT-0.015 | 134,898 | 151,711 | 7.0 | 1.0 | 470 | 74 | 1.5 | 6.8 | 11.4
B-50-80-Bach-0.025 | 141,428 | 158,768 | 6.8 | 1.0 | 490 | 76 | 1.6 | 6.7 | 11.6
B-50-80-MPLCOm2012-0.014 | 143,839 | 160,954 | 7.7 | 1.1 | 485 | 72 | 1.5 | 6.4 | 12.6
B-55-80-Bach-0.024 | 145,782 | 163,326 | 6.8 | 1.0 | 491 | 71 | 1.5 | 6.3 | 12.3
B-50-80-MLCDRAT-0.014 | 146,532 | 164,104 | 7.2 | 1.0 | 493 | 76 | 1.6 | 6.7 | 12.7
B-50-80-Bach-0.024 | 148,445 | 166,232 | 6.9 | 1.0 | 504 | 76 | 1.6 | 6.5 | 12.6
B-55-80-MPLCOm2012-0.013 | 149,511 | 166,964 | 7.7 | 1.1 | 488 | 70 | 1.5 | 6.2 | 13.4
B-50-80-MPLCOm2012-0.013 | 154,244 | 172,003 | 8.0 | 1.1 | 503 | 74 | 1.5 | 6.4 | 14.5
B-50-80-Bach-0.023 | 155,703 | 173,936 | 7.0 | 1.0 | 516 | 78 | 1.6 | 6.6 | 12.9
A-55-80-MLCDRAT-0.023 | 160,079 | 177,286 | 11.1 | 1.4 | 465 | 78 | 1.6 | 7.3 | 11.5
A-55-80-MPLCOm2012-0.023 | 161,887 | 179,022 | 12.0 | 1.5 | 473 | 77 | 1.6 | 7.0 | 11.8
A-50-80-MPLCOm2012-0.023 | 161,919 | 179,054 | 12.0 | 1.5 | 472 | 76 | 1.6 | 6.9 | 11.9
B-50-80-Bach-0.022 | 162,947 | 181,642 | 7.2 | 1.0 | 528 | 79 | 1.6 | 6.6 | 13.7
B-50-80-MPLCOm2012-0.012 | 166,180 | 184,676 | 8.2 | 1.1 | 522 | 75 | 1.6 | 6.3 | 14.7
B-55-80-Bach-0.021 | 167,330 | 186,225 | 7.2 | 1.0 | 526 | 74 | 1.5 | 6.2 | 13.8
A-55-80-MPLCOm2012-0.022 | 170,819 | 188,449 | 12.3 | 1.5 | 487 | 79 | 1.6 | 7.0 | 13.0
A-50-80-MPLCOm2012-0.022 | 170,873 | 188,520 | 12.3 | 1.5 | 487 | 79 | 1.6 | 7.0 | 13.1
B-50-80-Bach-0.021 | 170,970 | 190,166 | 7.4 | 1.0 | 540 | 79 | 1.6 | 6.5 | 14.4
B-55-80-Bach-0.02 | 175,191 | 194,603 | 7.4 | 1.0 | 539 | 75 | 1.5 | 6.2 | 14.9
A-55-80-Bach-0.034 | 177,346 | 195,699 | 10.8 | 1.3 | 506 | 84 | 1.7 | 7.3 | 13.2
A-50-80-Bach-0.034 | 177,398 | 195,737 | 10.8 | 1.3 | 505 | 83 | 1.7 | 7.2 | 13.2
B-50-80-Bach-0.02 | 179,470 | 199,187 | 7.5 | 1.1 | 554 | 80 | 1.7 | 6.4 | 15.4
A-55-80-MPLCOm2012-0.021 | 180,223 | 198,413 | 12.5 | 1.5 | 502 | 81 | 1.7 | 7.0 | 14.0
B-50-80-MPLCOm2012-0.011 | 180,282 | 199,651 | 8.4 | 1.2 | 545 | 76 | 1.6 | 6.2 | 16.3
A-50-80-MPLCOm2012-0.021 | 180,349 | 198,537 | 12.5 | 1.5 | 502 | 81 | 1.7 | 7.0 | 14.1
B-55-80-Bach-0.019 | 183,071 | 202,948 | 7.5 | 1.1 | 551 | 76 | 1.6 | 6.2 | 15.7
A-55-80-Bach-0.033 | 186,164 | 205,023 | 11.1 | 1.4 | 520 | 84 | 1.7 | 7.1 | 14.1
A-50-80-Bach-0.033 | 186,235 | 205,095 | 11.1 | 1.4 | 519 | 84 | 1.7 | 7.1 | 14.1
B-50-80-Bach-0.019 | 188,246 | 208,514 | 7.7 | 1.1 | 568 | 81 | 1.7 | 6.4 | 16.3
A-50-80-MLCDRAT-0.02 | 188,813 | 207,708 | 11.7 | 1.4 | 513 | 83 | 1.7 | 7.2 | 14.1
A-55-80-MPLCOm2012-0.02 | 190,436 | 209,193 | 12.8 | 1.5 | 518 | 83 | 1.7 | 7.1 | 15.0
A-50-80-MPLCOm2012-0.02 | 190,654 | 209,417 | 12.8 | 1.5 | 518 | 82 | 1.7 | 7.0 | 15.1
A-55-80-Bach-0.032 | 195,037 | 214,409 | 11.3 | 1.4 | 533 | 86 | 1.8 | 7.1 | 14.6
A-50-80-Bach-0.032 | 195,135 | 214,505 | 11.3 | 1.4 | 534 | 85 | 1.7 | 7.0 | 14.6
B-50-80-MPLCOm2012-0.01 | 195,180 | 215,443 | 8.7 | 1.2 | 567 | 78 | 1.6 | 6.2 | 18.7
B-50-80-Bach-0.018 | 197,502 | 218,311 | 7.9 | 1.1 | 583 | 83 | 1.7 | 6.4 | 17.0
A-55-80-MPLCOm2012-0.019 | 201,751 | 221,166 | 13.1 | 1.6 | 535 | 84 | 1.7 | 7.0 | 16.3
A-50-80-MPLCOm2012-0.019 | 202,181 | 221,613 | 13.1 | 1.6 | 535 | 83 | 1.7 | 6.9 | 16.5
A-50-80-MLCDRAT-0.019 | 202,754 | 222,456 | 12.1 | 1.5 | 535 | 87 | 1.8 | 7.3 | 15.4
A-55-80-Bach-0.031 | 204,408 | 224,326 | 11.5 | 1.4 | 548 | 88 | 1.8 | 7.1 | 15.3
A-50-80-Bach-0.031 | 204,573 | 224,490 | 11.5 | 1.4 | 548 | 87 | 1.8 | 7.1 | 15.4
A-55-80-30-15 | 204,815 | 223,834 | 16.5 | 2.0 | 467 | 64 | 1.3 | 6.4 | 22.0
B-50-80-MPLCOm2012-0.009 | 212,574 | 233,902 | 9.0 | 1.2 | 591 | 79 | 1.6 | 6.1 | 20.2
A-55-80-MLCDRAT-0.018 | 213,736 | 234,055 | 12.4 | 1.5 | 553 | 88 | 1.8 | 7.2 | 16.6
A-50-80-MLCDRAT-0.018 | 213,737 | 234,074 | 12.4 | 1.5 | 553 | 88 | 1.8 | 7.2 | 16.6
A-55-80-MPLCOm2012-0.018 | 213,742 | 233,843 | 13.4 | 1.6 | 552 | 85 | 1.7 | 6.9 | 16.9
A-55-80-Bach-0.03 | 214,301 | 234,779 | 11.7 | 1.4 | 564 | 90 | 1.8 | 7.1 | 16.0
A-50-80-MPLCOm2012-0.018 | 214,512 | 234,651 | 13.4 | 1.6 | 554 | 86 | 1.8 | 7.0 | 17.3
A-50-80-Bach-0.03 | 214,518 | 235,010 | 11.7 | 1.4 | 564 | 88 | 1.8 | 7.0 | 16.2
B-50-80-Bach-0.016 | 218,146 | 240,223 | 8.3 | 1.1 | 610 | 84 | 1.7 | 6.3 | 19.8
A-55-80-Bach-0.029 | 224,497 | 245,573 | 11.9 | 1.5 | 579 | 91 | 1.9 | 7.1 | 16.9
A-50-80-Bach-0.029 | 224,848 | 245,938 | 12.0 | 1.5 | 579 | 89 | 1.8 | 6.9 | 17.1
A-55-80-MPLCOm2012-0.017 | 227,059 | 247,910 | 13.7 | 1.6 | 571 | 86 | 1.8 | 6.8 | 18.3
A-50-80-MPLCOm2012-0.017 | 228,322 | 249,238 | 13.8 | 1.6 | 574 | 88 | 1.8 | 6.9 | 18.6
A-50-80-MLCDRAT-0.017 | 229,798 | 251,041 | 12.8 | 1.5 | 575 | 90 | 1.9 | 7.1 | 18.1
B-50-80-MPLCOm2012-0.008 | 232,698 | 255,245 | 9.3 | 1.3 | 620 | 83 | 1.7 | 6.2 | 21.6
A-55-80-Bach-0.028 | 235,410 | 257,111 | 12.2 | 1.5 | 595 | 92 | 1.9 | 7.0 | 17.7
A-50-80-Bach-0.028 | 235,837 | 257,565 | 12.2 | 1.5 | 595 | 90 | 1.8 | 6.9 | 18.0
B-50-80-Bach-0.014 | 241,059 | 264,500 | 8.6 | 1.2 | 643 | 87 | 1.8 | 6.3 | 21.1
A-55-80-MPLCOm2012-0.016 | 241,064 | 262,706 | 13.9 | 1.7 | 591 | 87 | 1.8 | 6.7 | 19.6
A-50-80-MPLCOm2012-0.016 | 243,063 | 264,803 | 14.0 | 1.7 | 594 | 89 | 1.8 | 6.8 | 20.2
A-50-80-MLCDRAT-0.016 | 243,477 | 265,489 | 13.1 | 1.6 | 596 | 93 | 1.9 | 7.2 | 19.2
A-55-80-Bach-0.027 | 246,980 | 269,339 | 12.4 | 1.5 | 611 | 94 | 1.9 | 7.0 | 19.0
A-50-80-Bach-0.027 | 247,655 | 270,039 | 12.4 | 1.5 | 611 | 92 | 1.9 | 6.9 | 19.3
B-50-80-Bach-0.013 | 253,866 | 278,073 | 8.8 | 1.2 | 660 | 86 | 1.8 | 6.2 | 23.1
B-50-80-MPLCOm2012-0.007 | 256,519 | 280,518 | 9.7 | 1.3 | 654 | 86 | 1.8 | 6.2 | 24.2
A-55-80-MPLCOm2012-0.015 | 256,832 | 279,377 | 14.3 | 1.7 | 612 | 89 | 1.8 | 6.7 | 21.3
A-55-80-Bach-0.026 | 258,376 | 281,394 | 12.7 | 1.5 | 626 | 96 | 2.0 | 7.1 | 20.0
A-50-80-Bach-0.026 | 259,208 | 282,261 | 12.6 | 1.5 | 626 | 93 | 1.9 | 6.9 | 20.3
A-50-80-MPLCOm2012-0.015 | 259,891 | 282,583 | 14.4 | 1.7 | 617 | 90 | 1.9 | 6.7 | 21.9
A-50-77-MPLCOm2012-0.013 | 260,403 | 283,193 | 14.1 | 1.7 | 564 | 67 | 1.4 | 5.8 | 24.1
A-50-80-MLCDRAT-0.015 | 260,844 | 283,874 | 13.4 | 1.6 | 621 | 95 | 1.9 | 7.1 | 20.5
B-50-80-Bach-0.012 | 268,148 | 293,208 | 9.1 | 1.2 | 677 | 87 | 1.8 | 6.1 | 24.7
A-55-80-Bach-0.025 | 271,125 | 294,855 | 12.9 | 1.6 | 643 | 97 | 2.0 | 7.0 | 21.1
A-50-80-Bach-0.025 | 272,333 | 296,131 | 13.0 | 1.6 | 644 | 95 | 1.9 | 6.9 | 21.5
A-55-80-MPLCOm2012-0.014 | 274,089 | 297,615 | 14.7 | 1.7 | 636 | 91 | 1.9 | 6.7 | 22.3
A-50-80-MPLCOm2012-0.014 | 278,533 | 302,287 | 14.9 | 1.8 | 641 | 93 | 1.9 | 6.8 | 23.1
A-55-80-MLCDRAT-0.014 | 279,935 | 304,056 | 13.7 | 1.6 | 646 | 97 | 2.0 | 7.0 | 21.8
A-50-80-MLCDRAT-0.014 | 281,138 | 305,319 | 13.7 | 1.6 | 648 | 96 | 2.0 | 6.9 | 22.2
A-50-77-MPLCOm2012-0.012 | 282,250 | 306,270 | 14.5 | 1.8 | 591 | 70 | 1.4 | 5.8 | 25.9
B-50-80-MPLCOm2012-0.006 | 282,713 | 308,306 | 10.0 | 1.4 | 687 | 87 | 1.8 | 6.1 | 26.5
B-50-80-Bach-0.011 | 282,984 | 308,924 | 9.3 | 1.3 | 697 | 88 | 1.8 | 6.1 | 25.5
A-55-80-Bach-0.024 | 284,191 | 308,672 | 13.2 | 1.6 | 660 | 99 | 2.0 | 7.0 | 22.0
A-50-80-Bach-0.024 | 285,840 | 310,383 | 13.2 | 1.6 | 662 | 96 | 2.0 | 6.8 | 22.4
A-55-80-MPLCOm2012-0.013 | 292,670 | 317,231 | 15.0 | 1.8 | 657 | 92 | 1.9 | 6.6 | 24.0
A-55-80-MLCDRAT-0.013 | 297,479 | 322,614 | 13.8 | 1.7 | 669 | 99 | 2.0 | 7.0 | 23.0
A-55-80-Bach-0.023 | 297,926 | 323,169 | 13.5 | 1.6 | 678 | 100 | 2.1 | 7.0 | 22.8
B-50-80-Bach-0.01 | 298,689 | 325,572 | 9.5 | 1.3 | 719 | 91 | 1.9 | 6.2 | 27.7
A-50-80-MPLCOm2012-0.013 | 299,050 | 323,922 | 15.3 | 1.8 | 665 | 94 | 1.9 | 6.7 | 25.2
A-50-80-MLCDRAT-0.013 | 299,330 | 324,552 | 13.9 | 1.7 | 671 | 99 | 2.0 | 7.0 | 23.5
A-50-80-Bach-0.023 | 299,941 | 325,273 | 13.5 | 1.6 | 681 | 98 | 2.0 | 6.8 | 23.2
A-50-77-MPLCOm2012-0.011 | 306,772 | 332,150 | 15.1 | 1.8 | 619 | 71 | 1.5 | 5.8 | 28.1
A-55-80-Bach-0.022 | 311,728 | 337,749 | 13.7 | 1.6 | 696 | 101 | 2.1 | 6.9 | 24.4
B-50-80-MPLCOm2012-0.005 | 312,927 | 340,332 | 10.3 | 1.4 | 723 | 88 | 1.8 | 6.0 | 28.3
A-55-80-MPLCOm2012-0.012 | 313,442 | 339,169 | 15.4 | 1.8 | 683 | 95 | 1.9 | 6.6 | 25.5
A-50-80-Bach-0.022 | 314,475 | 340,625 | 13.9 | 1.7 | 697 | 99 | 2.0 | 6.8 | 25.0
B-50-80-Bach-0.009 | 316,758 | 344,723 | 9.7 | 1.3 | 740 | 91 | 1.9 | 6.1 | 29.3
A-55-80-MLCDRAT-0.012 | 320,284 | 346,735 | 14.0 | 1.7 | 698 | 102 | 2.1 | 7.0 | 25.2
A-55-80-20-15 | 321,376 | 347,227 | 16.7 | 2.0 | 633 | 80 | 1.6 | 6.4 | 32.4
A-50-80-MPLCOm2012-0.012 | 322,767 | 348,967 | 15.8 | 1.8 | 694 | 95 | 2.0 | 6.6 | 27.2
A-50-80-MLCDRAT-0.012 | 323,741 | 350,374 | 14.2 | 1.7 | 702 | 101 | 2.1 | 6.9 | 25.9
A-55-80-Bach-0.021 | 326,829 | 353,690 | 14.0 | 1.7 | 712 | 103 | 2.1 | 6.9 | 25.4
A-50-80-Bach-0.021 | 330,309 | 357,346 | 14.2 | 1.7 | 716 | 101 | 2.1 | 6.8 | 26.1
A-50-77-MPLCOm2012-0.01 | 334,311 | 361,183 | 15.6 | 1.9 | 649 | 73 | 1.5 | 5.7 | 31.1
A-55-80-MPLCOm2012-0.011 | 335,019 | 361,976 | 15.7 | 1.8 | 709 | 96 | 2.0 | 6.6 | 27.1
A-55-80-Bach-0.02 | 342,391 | 370,144 | 14.3 | 1.7 | 730 | 103 | 2.1 | 6.8 | 26.8
A-55-80-MLCDRAT-0.011 | 346,694 | 374,691 | 14.3 | 1.7 | 731 | 103 | 2.1 | 6.9 | 27.5
A-50-80-Bach-0.02 | 346,979 | 374,945 | 14.5 | 1.7 | 735 | 101 | 2.1 | 6.7 | 27.7
A-50-80-MPLCOm2012-0.011 | 349,310 | 376,967 | 16.2 | 1.9 | 724 | 98 | 2.0 | 6.6 | 29.4
A-50-80-MLCDRAT-0.011 | 351,744 | 380,005 | 14.4 | 1.7 | 737 | 102 | 2.1 | 6.8 | 28.5
A-55-80-Bach-0.019 | 358,013 | 386,594 | 14.6 | 1.7 | 748 | 104 | 2.1 | 6.8 | 28.0
A-55-80-20-20 | 358,302 | 386,201 | 17.6 | 2.1 | 686 | 87 | 1.8 | 6.5 | 34.2
A-55-80-MPLCOm2012-0.01 | 358,348 | 386,610 | 16.0 | 1.9 | 735 | 98 | 2.0 | 6.5 | 29.3
A-50-80-Bach-0.019 | 364,037 | 392,918 | 14.9 | 1.8 | 753 | 102 | 2.1 | 6.6 | 29.2
A-55-80-Bach-0.018 | 375,520 | 405,056 | 15.0 | 1.8 | 767 | 106 | 2.2 | 6.8 | 29.5
A-55-80-MLCDRAT-0.01 | 375,679 | 405,427 | 14.2 | 1.7 | 767 | 107 | 2.2 | 6.9 | 29.6
A-50-80-MPLCOm2012-0.01 | 379,066 | 408,341 | 16.8 | 2.0 | 757 | 100 | 2.0 | 6.6 | 32.4
A-50-80-MLCDRAT-0.01 | 382,462 | 412,538 | 14.4 | 1.7 | 775 | 106 | 2.2 | 6.8 | 31.0
A-50-80-Bach-0.018 | 382,696 | 412,618 | 15.2 | 1.8 | 775 | 104 | 2.1 | 6.7 | 30.9
A-55-80-20-25 | 389,551 | 419,022 | 18.6 | 2.2 | 726 | 91 | 1.9 | 6.4 | 35.8
A-55-80-Bach-0.017 | 393,075 | 423,595 | 15.3 | 1.8 | 786 | 107 | 2.2 | 6.8 | 31.1
A-50-80-20-15 | 399,813 | 429,762 | 19.1 | 2.3 | 703 | 82 | 1.7 | 6.3 | 42.4
A-50-80-Bach-0.017 | 402,336 | 433,313 | 15.6 | 1.8 | 797 | 104 | 2.1 | 6.5 | 32.9
A-55-80-MLCDRAT-0.009 | 411,379 | 443,267 | 14.1 | 1.7 | 809 | 110 | 2.3 | 6.9 | 32.1
A-55-80-Bach-0.016 | 411,443 | 442,996 | 15.6 | 1.8 | 805 | 108 | 2.2 | 6.8 | 32.4
A-50-80-MPLCOm2012-0.009 | 413,285 | 444,451 | 17.4 | 2.0 | 793 | 101 | 2.1 | 6.4 | 35.7
A-55-80-MPLCOm2012-0.008 | 415,073 | 446,515 | 16.7 | 1.9 | 798 | 102 | 2.1 | 6.5 | 34.0
A-50-80-MLCDRAT-0.009 | 420,863 | 453,220 | 14.4 | 1.7 | 819 | 109 | 2.2 | 6.8 | 33.7
A-50-80-Bach-0.016 | 423,398 | 455,546 | 16.0 | 1.9 | 819 | 106 | 2.2 | 6.6 | 34.5
A-55-80-Bach-0.015 | 430,085 | 462,676 | 15.9 | 1.9 | 826 | 110 | 2.2 | 6.8 | 34.1
A-50-80-20-20 | 440,469 | 472,498 | 20.6 | 2.4 | 754 | 86 | 1.8 | 6.2 | 44.6
A-50-80-Bach-0.015 | 445,160 | 478,502 | 16.4 | 1.9 | 839 | 107 | 2.2 | 6.5 | 36.8
A-55-80-Bach-0.014 | 450,056 | 483,739 | 16.2 | 1.9 | 846 | 111 | 2.3 | 6.8 | 36.0
A-50-80-MPLCOm2012-0.008 | 453,251 | 486,593 | 18.1 | 2.1 | 834 | 104 | 2.1 | 6.5 | 38.9
A-55-80-MLCDRAT-0.008 | 454,135 | 488,599 | 14.1 | 1.7 | 860 | 113 | 2.3 | 6.8 | 35.1
A-50-80-MLCDRAT-0.008 | 467,154 | 502,246 | 14.5 | 1.7 | 873 | 112 | 2.3 | 6.7 | 37.3
A-50-80-Bach-0.014 | 468,455 | 503,045 | 16.7 | 1.9 | 863 | 108 | 2.2 | 6.5 | 39.2
A-55-80-Bach-0.013 | 471,061 | 505,895 | 16.5 | 1.9 | 867 | 112 | 2.3 | 6.7 | 37.8
A-50-80-20-25 | 473,059 | 506,693 | 22.0 | 2.5 | 796 | 90 | 1.9 | 6.2 | 46.7
A-50-80-Bach-0.013 | 493,477 | 529,419 | 17.1 | 2.0 | 888 | 109 | 2.2 | 6.5 | 41.4
A-55-80-Bach-0.012 | 494,075 | 530,177 | 16.7 | 1.9 | 890 | 113 | 2.3 | 6.7 | 39.4
A-50-80-MPLCOm2012-0.007 | 498,159 | 533,954 | 18.7 | 2.1 | 878 | 106 | 2.2 | 6.4 | 42.7
A-55-80-MLCDRAT-0.007 | 501,028 | 538,246 | 14.3 | 1.7 | 911 | 116 | 2.4 | 6.8 | 38.1
A-55-80-Bach-0.011 | 517,897 | 555,310 | 17.0 | 2.0 | 914 | 114 | 2.3 | 6.6 | 41.3
A-50-80-Bach-0.012 | 521,068 | 558,508 | 17.5 | 2.0 | 915 | 111 | 2.3 | 6.5 | 43.7
A-50-80-MLCDRAT-0.007 | 522,234 | 560,489 | 14.8 | 1.7 | 932 | 114 | 2.3 | 6.5 | 41.2
A-55-80-Bach-0.01 | 542,703 | 581,498 | 17.3 | 2.0 | 939 | 115 | 2.4 | 6.6 | 43.2
A-50-80-MPLCOm2012-0.006 | 548,639 | 587,157 | 19.4 | 2.2 | 925 | 108 | 2.2 | 6.4 | 47.0
A-50-80-Bach-0.011 | 550,280 | 589,315 | 18.0 | 2.1 | 944 | 112 | 2.3 | 6.4 | 46.1
A-55-80-MLCDRAT-0.006 | 558,573 | 599,071 | 14.7 | 1.7 | 972 | 119 | 2.4 | 6.7 | 42.6
A-50-80-Bach-0.01 | 581,188 | 621,883 | 18.4 | 2.1 | 973 | 113 | 2.3 | 6.4 | 49.0

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 17 Comparison of the A-55-80-20-15 and Equivalent Risk Model–Based Screening Scenarios

Outcome | A-55-80-20-15 | A-55-80-MPLCOm2012-0.012 | A-55-80-MLCDRAT-0.012 | A-55-80-Bach-0.022
% eligible | 20.6% | 21.6% | 23.8% | 23.4%
# LDCT screens^*^ | 330,095 | 330,347 | 343,713 | 327,719
Avg. # of LDCT screens per person screened | 16.0 | 15.3 | 14.4 | 14.0
Avg. age at first screen | 55.7 | 62.0 | 62.8 | 63.4
Avg. age at last screen | 70.7 | 76.3 | 76.4 | 76.6
Avg. age at screening | 65.1 | 68.5 | 69.1 | 69.3
LC deaths averted^*^ | 469 | 520 | 532 | 527
Mortality reduction | 12.1% | 13.4% | 13.7% | 13.6%
Difference in LC deaths averted vs. A-55-80-20-15 strategy | NA | 10.9% | 13.4% | 12.4%
Avg. # screens per LC deaths averted | 704 | 635 | 646 | 622
LYG^*^ | 6,018 | 6,146 | 6,126 | 6,024
Difference in LYG vs. A-55-80-20-15 strategy | NA | 2.1% | 1.0% | 0.1%
Avg. # screens per LYG | 55 | 54 | 56 | 54
NNS | 44 | 42 | 45 | 44
False-positive screens per person screened | 1.9 | 1.8 | 1.7 | 1.7
Biopsies | 667 | 723 | 745 | 732
Overdiagnosed cases^*^ | 83 | 98 | 104 | 103
Overdiagnosis rate per screen-detected cancers | 6.2% | 6.5% | 6.6% | 6.7%
Radiation-related lung cancer deaths^*^ | 29.0 | 23.3 | 23.0 | 22.3

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 18 Comparison of the A-55-80-20-20 and Equivalent Risk Model–Based Screening Scenarios

Outcome | A-55-80-20-20 | A-55-80-MPLCOm2012-0.010 | A-55-80-MLCDRAT-0.011 | A-55-80-Bach-0.019
% eligible | 22.0% | 23.7% | 25.5% | 25.2%
# LDCT screens^*^ | 369,610 | 375,484 | 369,025 | 372,598
Avg. # of LDCT screens per person screened | 16.8 | 15.8 | 14.5 | 14.8
Avg. age at first screen | 55.6 | 61.5 | 62.8 | 62.6
Avg. age at last screen | 71.4 | 76.3 | 76.5 | 76.5
Avg. age at screening | 65.3 | 68.2 | 68.9 | 68.9
LC deaths averted^*^ | 500 | 548 | 549 | 554
Mortality reduction | 12.9% | 14.1% | 14.2% | 14.3%
Difference in LC deaths averted vs. A-55-80-20-20 strategy | NA | 9.6% | 9.8% | 10.8%
Avg. # screens per LC deaths averted | 739 | 685 | 672 | 673
LYG^*^ | 6,379 | 6,519 | 6,384 | 6,458
Difference in LYG vs. A-55-80-20-20 strategy | NA | 2.2% | 0.1% | 1.2%
Avg. # screens per LYG | 58 | 58 | 58 | 58
NNS | 44 | 43 | 46 | 45
False-positive screens per person screened | 2.0 | 1.9 | 1.7 | 1.7
Biopsies | 722 | 776 | 777 | 784
Overdiagnosed cases^*^ | 89 | 102 | 105 | 106
Overdiagnosis rate per screen-detected cancers | 6.3% | 6.4% | 6.6% | 6.6%
Radiation-related lung cancer deaths^*^ | 30.6 | 26.5 | 24.6 | 25.2

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 19 Comparison of the A-55-80-20-25 and Equivalent Risk Model–Based Screening Scenarios

Outcome | A-55-80-20-25 | A-55-80-MPLCOm2012-0.008 | A-55-80-MLCDRAT-0.010 | A-55-80-Bach-0.017
% eligible | 22.7% | 26.2% | 27.7% | 26.5%
# LDCT screens^*^ | 404,596 | 432,557 | 398,180 | 406,323
Avg. # of LDCT screens per person screened | 17.8 | 16.5 | 14.4 | 15.3
Avg. age at first screen | 55.6 | 60.8 | 63.0 | 62.0
Avg. age at last screen | 72.5 | 76.3 | 76.6 | 76.4
Avg. age at screening | 65.5 | 68.1 | 68.8 | 68.7
LC deaths averted^*^ | 523 | 579 | 564 | 575
Mortality reduction | 13.5% | 14.9% | 14.6% | 14.9%
Difference in LC deaths averted vs. A-55-80-20-25 strategy | NA | 10.7% | 7.8% | 9.9%
Avg. # screens per LC deaths averted | 774 | 747 | 706 | 707
LYG^*^ | 6,654 | 6,975 | 6,605 | 6,774
Difference in LYG vs. A-55-80-20-25 strategy | NA | 4.8% | −0.7% | 1.8%
Avg. # screens per LYG | 61 | 62 | 60 | 60
NNS | 43 | 45 | 49 | 46
False-positive screens per person screened | 2.1 | 1.9 | 1.7 | 1.8
Biopsies | 765 | 839 | 813 | 822
Overdiagnosed cases^*^ | 94 | 106 | 108 | 109
Overdiagnosis rate per screen-detected cancers | 6.3% | 6.4% | 6.6% | 6.6%
Radiation-related lung cancer deaths^*^ | 31.9 | 30.0 | 26.5 | 28.0

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 20 Comparison of the A-50-80-20-15 and Equivalent Risk Model–Based Screening Scenarios

Outcome | A-50-80-20-15 | A-50-80-MPLCOm2012-0.010 | A-50-80-MLCDRAT-0.010 | A-50-80-Bach-0.017
% eligible | 22.6% | 23.9% | 27.9% | 26.6%
# LDCT screens^*^ | 419,030 | 401,856 | 409,804 | 420,352
Avg. # of LDCT screens per person screened | 18.5 | 16.8 | 14.7 | 15.8
Avg. age at first screen | 51.5 | 60.3 | 62.6 | 61.4
Avg. age at last screen | 69.0 | 76.0 | 76.5 | 76.3
Avg. age at screening | 59.0 | 63.3 | 64.0 | 64.0
LC deaths averted^*^ | 503 | 564 | 575 | 586
Mortality reduction | 13.0% | 14.6% | 14.8% | 15.1%
Difference in LC deaths averted vs. A-50-80-20-15 strategy | NA | 12.1% | 14.3% | 16.5%
Avg. # screens per LC deaths averted | 833 | 713 | 713 | 717
LYG^*^ | 6,918 | 6,957 | 6,871 | 7,039
Difference in LYG vs. A-50-80-20-15 strategy | NA | 0.6% | −0.7% | 1.7%
Avg. # screens per LYG | 61 | 58 | 60 | 60
NNS | 45 | 42 | 49 | 45
False-positive screens per person screened | 2.2 | 2.0 | 1.7 | 1.8
Biopsies | 750 | 804 | 827 | 837
Overdiagnosed cases^*^ | 84 | 104 | 108 | 108
Overdiagnosis rate per screen-detected cancers | 6.0% | 6.4% | 6.5% | 6.4%
Radiation-related lung cancer deaths^*^ | 38.6 | 29.8 | 28.2 | 30.1

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 21 Comparison of the A-50-80-20-20 and Equivalent Risk Model–Based Screening Scenarios

Outcome | A-50-80-20-20 | A-50-80-MPLCOm2012-0.008 | A-50-80-MLCDRAT-0.009 | A-50-80-Bach-0.015
% eligible | 23.3% | 26.6% | 30.6% | 28.1%
# LDCT screens^*^ | 463,457 | 478,349 | 449,030 | 463,301
Avg. # of LDCT screens per person screened | 19.9 | 18.0 | 14.7 | 16.5
Avg. age at first screen | 51.5 | 59.0 | 62.7 | 60.6
Avg. age at last screen | 70.3 | 76.0 | 76.6 | 76.2
Avg. age at screening | 59.4 | 62.9 | 63.7 | 63.8
LC deaths averted^*^ | 534 | 601 | 596 | 605
Mortality reduction | 13.8% | 15.5% | 15.4% | 15.6%
Difference in LC deaths averted vs. A-50-80-20-20 strategy | NA | 12.5% | 11.6% | 13.3%
Avg. # screens per LC deaths averted | 868 | 796 | 753 | 766
LYG^*^ | 7,301 | 7,564 | 7,168 | 7,391
Difference in LYG vs. A-50-80-20-20 strategy | NA | 3.6% | −1.8% | 1.2%
Avg. # screens per LYG | 63 | 63 | 63 | 63
NNS | 44 | 44 | 51 | 46
False-positive screens per person screened | 2.3 | 2.1 | 1.7 | 1.9
Biopsies | 804 | 883 | 872 | 882
Overdiagnosed cases^*^ | 89 | 108 | 111 | 110
Overdiagnosis rate per screen-detected cancers | 6.0% | 6.3% | 6.5% | 6.4%
Radiation-related lung cancer deaths^*^ | 40.6 | 35.4 | 31.4 | 33.3

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 22 Comparison of the A-50-80-20-25 and Equivalent Risk Model–Based Screening Scenarios

Outcome | A-50-80-20-25 | A-50-80-MPLCOm2012-0.008 | A-50-80-MLCDRAT-0.008 | A-50-80-Bach-0.013
% eligible | 23.6% | 26.6% | 33.5% | 29.7%
# LDCT screens^*^ | 500,430 | 478,349 | 495,424 | 511,462
Avg. # of LDCT screens per person screened | 21.2 | 18.0 | 14.8 | 17.2
Avg. age at first screen | 51.5 | 59.0 | 62.7 | 59.9
Avg. age at last screen | 71.6 | 76.0 | 76.6 | 76.1
Avg. age at screening | 59.9 | 62.9 | 63.6 | 63.5
LC deaths averted^*^ | 558 | 601 | 619 | 627
Mortality reduction | 14.4% | 15.5% | 16.0% | 16.2
Difference in LC deaths averted vs. A-50-80-20-25 strategy | NA | 7.7% | 10.9% | 12.4%
Avg. # screens per LC deaths averted | 897 | 796 | 800 | 816
LYG^*^ | 7,596 | 7,564 | 7,508 | 7,746
Difference in LYG vs. A-50-80-20-25 strategy | NA | −0.4% | −1.2% | 2.0%
Avg. # screens per LYG | 66 | 63 | 66 | 66
NNS | 42 | 44 | 54 | 47
False-positive screens per person screened | 2.5 | 2.1 | 1.7 | 2.0
Biopsies | 849 | 883 | 925 | 930
Overdiagnosed cases^*^ | 94 | 108 | 114 | 112
Overdiagnosis rate per screen-detected cancers | 6.0% | 6.3% | 6.4% | 6.3%
Radiation-related lung cancer deaths^*^ | 42.5 | 35.4 | 34.2 | 37.1

* Per 100,000 individuals.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Appendix C Table 23 Benefits of 41 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus Three Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1950 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC Deaths Averted | NNS
B-55-80-30-20 | 21.5 | 189,290 | 1,508 | 9.0 | 452 | 5,891 | 13.0 | 32 | 419 | 48
B-55-80-25-15 | 24.3 | 193,471 | 1,515 | 9.1 | 455 | 5,941 | 13.1 | 33 | 425 | 53
B-55-80-30-25 | 21.7 | 203,069 | 1,572 | 9.4 | 472 | 6,115 | 13.0 | 33 | 430 | 46
B-55-80-25-20 | 25.4 | 216,267 | 1,612 | 9.8 | 488 | 6,334 | 13.0 | 34 | 443 | 52
B-50-80-30-15 | 22.2 | 219,815 | 1,531 | 9.5 | 476 | 6,538 | 13.7 | 34 | 462 | 47
A-55-80-40-15 | 14.6 | 229,025 | 1,517 | 10.1 | 510 | 6,403 | 12.6 | 36 | 449 | 29
B-55-80-25-25 | 25.8 | 235,215 | 1,694 | 10.2 | 511 | 6,628 | 13.0 | 35 | 460 | 50
B-50-77-30-25 | 22.4 | 238,032 | 1,459 | 9.2 | 463 | 6,749 | 14.6 | 35 | 514 | 48
B-50-80-30-20 | 22.4 | 238,934 | 1,625 | 10.1 | 507 | 6,862 | 13.5 | 35 | 471 | 44
B-50-77-25-15 | 26.2 | 241,077 | 1,434 | 9.1 | 455 | 6,742 | 14.8 | 36 | 530 | 58
A-55-80-40-20 | 14.9 | 247,622 | 1,593 | 10.6 | 535 | 6,673 | 12.5 | 37 | 463 | 28
B-55-80-20-20 | 29.8 | 252,017 | 1,725 | 10.5 | 524 | 6,871 | 13.1 | 37 | 481 | 57
B-50-80-25-15 | 26.2 | 253,310 | 1,639 | 10.2 | 509 | 7,010 | 13.8 | 36 | 498 | 51
B-50-80-30-25 | 22.5 | 253,520 | 1,698 | 10.5 | 526 | 7,093 | 13.5 | 36 | 482 | 43
A-55-80-40-25 | 15.0 | 261,065 | 1,644 | 11.0 | 553 | 6,851 | 12.4 | 38 | 472 | 27
B-55-80-20-25 | 30.6 | 276,741 | 1,813 | 11.1 | 551 | 7,185 | 13.0 | 39 | 502 | 56
B-50-80-20-15 | 30.7 | 291,542 | 1,749 | 10.9 | 545 | 7,539 | 13.8 | 39 | 535 | 56
A-50-80-40-20 | 15.3 | 292,409 | 1,652 | 11.2 | 565 | 7,449 | 13.2 | 39 | 518 | 27
A-50-80-40-25 | 15.3 | 306,037 | 1,705 | 11.6 | 584 | 7,629 | 13.1 | 40 | 524 | 26
B-50-80-20-20 | 31.5 | 323,377 | 1,865 | 11.7 | 585 | 7,988 | 13.7 | 40 | 553 | 54
A-55-80-25-10 | 22.5 | 325,707 | 1,762 | 12.1 | 604 | 7,836 | 13.0 | 42 | 539 | 37
A-55-80-30-15 | 20.8 | 333,300 | 1,788 | 12.2 | 612 | 7,956 | 13.0 | 42 | 545 | 34
B-50-80-20-25 | 31.8 | 349,765 | 1,967 | 12.3 | 614 | 8,345 | 13.6 | 42 | 570 | 52
A-55-80-30-20 | 21.5 | 368,643 | 1,900 | 13.0 | 650 | 8,368 | 12.9 | 44 | 567 | 33
A-55-80-25-15 | 24.4 | 375,261 | 1,911 | 13.1 | 654 | 8,453 | 12.9 | 44 | 574 | 37
A-55-80-30-25 | 21.8 | 396,584 | 1,986 | 13.6 | 683 | 8,738 | 12.8 | 45 | 581 | 32
A-55-80-25-20 | 25.4 | 420,797 | 2,036 | 14.0 | 696 | 8,957 | 12.9 | 47 | 605 | 36
A-50-80-30-15 | 22.2 | 425,608 | 1,880 | 13.2 | 659 | 9,157 | 13.9 | 46 | 646 | 34
A-55-80-20-15 | 27.9 | 433,993 | 2,035 | 14.1 | 701 | 9,125 | 13.0 | 48 | 619 | 40
A-50-77-30-20 | 22.4 | 442,631 | 1,782 | 12.7 | 639 | 9,322 | 14.6 | 47 | 693 | 35
A-55-80-25-25 | 25.8 | 459,015 | 2,137 | 14.7 | 733 | 9,353 | 12.8 | 49 | 626 | 35
A-50-80-30-20 | 22.5 | 463,131 | 1,993 | 14.0 | 701 | 9,606 | 13.7 | 48 | 661 | 32
A-50-77-30-25 | 22.4 | 467,223 | 1,842 | 13.2 | 662 | 9,555 | 14.4 | 49 | 706 | 34
A-50-80-25-15 | 26.2 | 489,778 | 2,013 | 14.2 | 709 | 9,848 | 13.9 | 50 | 691 | 37
A-55-80-20-20 | 29.8 | 490,380 | 2,174 | 15.1 | 754 | 9,732 | 12.9 | 50 | 650 | 40
A-50-80-30-25 | 22.5 | 491,722 | 2,079 | 14.6 | 731 | 9,952 | 13.6 | 49 | 673 | 31
A-50-80-25-20 | 26.7 | 538,709 | 2,139 | 15.1 | 756 | 10,433 | 13.8 | 52 | 713 | 35
A-55-80-20-25 | 30.6 | 540,046 | 2,286 | 15.9 | 794 | 10,208 | 12.9 | 53 | 680 | 39
A-50-77-25-25 | 26.8 | 550,504 | 1,986 | 14.3 | 716 | 10,375 | 14.5 | 53 | 769 | 37
A-50-80-20-15 | 30.7 | 563,675 | 2,139 | 15.2 | 760 | 10,548 | 13.9 | 53 | 742 | 40
A-45-80-30-25 | 22.9 | 569,665 | 2,119 | 15.0 | 755 | 10,637 | 14.1 | 54 | 755 | 30
A-50-80-25-25 | 26.8 | 578,099 | 2,238 | 15.8 | 791 | 10,785 | 13.6 | 54 | 731 | 34
A-50-80-20-20 | 31.6 | 626,181 | 2,278 | 16.3 | 813 | 11,218 | 13.8 | 56 | 770 | 39
A-50-80-20-25 | 31.8 | 678,074 | 2,394 | 17.1 | 854 | 11,722 | 13.7 | 58 | 794 | 37

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy is a consensus-efficient scenario. The 2013 USPSTF-recommended strategy and selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 24 Harms of 41 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus Three Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1950 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-55-80-30-20 | 189,290 | 208,996 | 8.8 | 1.3 | 646 | 92 | 1.4 | 6.1 | 17.9
B-55-80-25-15 | 193,471 | 213,824 | 8.0 | 1.2 | 657 | 91 | 1.4 | 6.0 | 18.8
B-55-80-30-25 | 203,069 | 223,505 | 9.4 | 1.3 | 676 | 96 | 1.5 | 6.1 | 18.3
B-55-80-25-20 | 216,267 | 237,943 | 8.5 | 1.2 | 704 | 98 | 1.5 | 6.1 | 20.0
B-50-80-30-15 | 219,815 | 241,090 | 9.9 | 1.4 | 678 | 92 | 1.4 | 6.0 | 23.1
A-55-80-40-15 | 229,025 | 249,429 | 15.7 | 1.9 | 653 | 101 | 1.6 | 6.7 | 19.5
B-55-80-25-25 | 235,215 | 257,921 | 9.1 | 1.3 | 743 | 104 | 1.6 | 6.1 | 20.6
B-50-77-30-25 | 238,032 | 260,214 | 10.6 | 1.5 | 667 | 74 | 1.2 | 5.1 | 24.2
B-50-80-30-20 | 238,934 | 261,235 | 10.7 | 1.5 | 720 | 98 | 1.5 | 6.0 | 23.7
B-50-77-25-15 | 241,077 | 264,005 | 9.2 | 1.3 | 670 | 74 | 1.2 | 5.2 | 26.0
A-55-80-40-20 | 247,622 | 269,000 | 16.6 | 2.0 | 689 | 106 | 1.6 | 6.7 | 19.9
B-55-80-20-20 | 252,017 | 276,201 | 8.5 | 1.2 | 772 | 105 | 1.6 | 6.1 | 23.3
B-50-80-25-15 | 253,310 | 276,900 | 9.7 | 1.4 | 743 | 99 | 1.5 | 6.0 | 25.9
B-50-80-30-25 | 253,520 | 276,553 | 11.3 | 1.5 | 752 | 102 | 1.6 | 6.0 | 24.1
A-55-80-40-25 | 261,065 | 283,124 | 17.4 | 2.0 | 712 | 110 | 1.7 | 6.7 | 20.2
B-55-80-20-25 | 276,741 | 302,299 | 9.0 | 1.3 | 817 | 110 | 1.7 | 6.1 | 24.0
B-50-80-20-15 | 291,542 | 317,766 | 9.5 | 1.4 | 812 | 106 | 1.6 | 6.1 | 30.0
A-50-80-40-20 | 292,409 | 315,999 | 19.1 | 2.2 | 736 | 107 | 1.7 | 6.5 | 25.4
A-50-80-40-25 | 306,037 | 330,313 | 20.0 | 2.3 | 760 | 111 | 1.7 | 6.5 | 25.7
B-50-80-20-20 | 323,377 | 351,346 | 10.3 | 1.4 | 871 | 113 | 1.8 | 6.1 | 31.3
A-55-80-25-10 | 325,707 | 352,179 | 14.5 | 1.8 | 809 | 115 | 1.8 | 6.5 | 29.5
A-55-80-30-15 | 333,300 | 359,887 | 16.0 | 1.9 | 817 | 117 | 1.8 | 6.5 | 28.9
B-50-80-20-25 | 349,765 | 379,113 | 11.0 | 1.5 | 920 | 119 | 1.9 | 6.0 | 32.2
A-55-80-30-20 | 368,643 | 397,092 | 17.1 | 2.0 | 874 | 125 | 1.9 | 6.6 | 30.3
A-55-80-25-15 | 375,261 | 404,492 | 15.4 | 1.9 | 889 | 126 | 2.0 | 6.6 | 32.0
A-55-80-30-25 | 396,584 | 426,463 | 18.2 | 2.1 | 917 | 130 | 2.0 | 6.5 | 30.8
A-55-80-25-20 | 420,797 | 452,456 | 16.6 | 2.0 | 957 | 134 | 2.1 | 6.6 | 33.9
A-50-80-30-15 | 425,608 | 456,861 | 19.2 | 2.3 | 907 | 119 | 1.8 | 6.3 | 39.8
A-55-80-20-15 | 433,993 | 466,704 | 15.6 | 1.9 | 971 | 134 | 2.1 | 6.6 | 37.1
A-50-77-30-20 | 442,631 | 474,740 | 19.8 | 2.3 | 886 | 100 | 1.5 | 5.6 | 41.0
A-55-80-25-25 | 459,015 | 492,649 | 17.8 | 2.1 | 1,012 | 142 | 2.2 | 6.6 | 34.8
A-50-80-30-20 | 463,131 | 496,293 | 20.6 | 2.4 | 965 | 128 | 2.0 | 6.4 | 41.2
A-50-77-30-25 | 467,223 | 500,557 | 20.9 | 2.4 | 918 | 102 | 1.6 | 5.5 | 41.6
A-50-80-25-15 | 489,778 | 524,822 | 18.7 | 2.2 | 998 | 128 | 2.0 | 6.4 | 44.8
A-55-80-20-20 | 490,380 | 526,175 | 16.5 | 2.0 | 1,052 | 144 | 2.2 | 6.6 | 39.5
A-50-80-30-25 | 491,722 | 526,318 | 21.9 | 2.5 | 1,007 | 133 | 2.1 | 6.4 | 41.8
A-50-80-25-20 | 538,709 | 576,271 | 20.2 | 2.4 | 1,067 | 136 | 2.1 | 6.4 | 46.7
A-55-80-20-25 | 540,046 | 578,428 | 17.6 | 2.1 | 1,118 | 149 | 2.3 | 6.5 | 41.0
A-50-77-25-25 | 550,504 | 588,614 | 20.5 | 2.4 | 1,025 | 111 | 1.7 | 5.6 | 47.6
A-50-80-20-15 | 563,675 | 603,080 | 18.4 | 2.2 | 1,093 | 136 | 2.1 | 6.4 | 51.8
A-45-80-30-25 | 569,665 | 607,977 | 24.9 | 2.8 | 1,071 | 131 | 2.0 | 6.2 | 53.1
A-50-80-25-25 | 578,099 | 617,612 | 21.6 | 2.5 | 1,120 | 144 | 2.2 | 6.4 | 47.9
A-50-80-20-20 | 626,181 | 668,823 | 19.8 | 2.3 | 1,175 | 145 | 2.2 | 6.4 | 54.4
A-50-80-20-25 | 678,074 | 723,326 | 21.3 | 2.5 | 1,242 | 153 | 2.4 | 6.4 | 56.3

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

† Average of two models (MGH-HMS and University of Michigan).

The results are based on the US individuals who were born in 1950. Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy is a consensus-efficient scenario. The 2013 USPSTF-recommended strategy and selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 25 Sensitivity Analysis by Excluding Individuals With Life Expectancy of Less Than 5 Years From Screening

Benefits of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC Deaths Averted | NNS
B-55-80-20-20 | 21.3 | 176,841 | 1,025 | 8.6 | 334 | 4,482 | 13.4 | 39 | 529 | 64
B-55-80-20-25 | 22.0 | 193,275 | 1,074 | 9.0 | 350 | 4,685 | 13.4 | 41 | 552 | 63
B-50-80-25-25 | 18.5 | 195,846 | 1,050 | 9.0 | 348 | 4,835 | 13.9 | 41 | 563 | 53
A-55-80-30-15 | 13.6 | 211,055 | 992 | 9.4 | 364 | 4,864 | 13.4 | 43 | 580 | 37
A-55-80-25-10 | 15.4 | 216,689 | 1,017 | 9.7 | 375 | 4,974 | 13.3 | 44 | 578 | 41
B-50-80-20-20 | 22.8 | 224,867 | 1,104 | 9.5 | 367 | 5,198 | 14.2 | 43 | 613 | 62
A-55-80-30-20 | 14.0 | 232,601 | 1,051 | 10.0 | 388 | 5,144 | 13.3 | 45 | 599 | 36
B-50-80-20-25 | 23.0 | 242,588 | 1,160 | 10.0 | 386 | 5,418 | 14.0 | 45 | 628 | 60
A-55-80-25-15 | 16.7 | 247,982 | 1,099 | 10.5 | 406 | 5,354 | 13.2 | 46 | 611 | 41
A-55-80-30-25 | 14.3 | 249,780 | 1,098 | 10.5 | 405 | 5,331 | 13.2 | 47 | 617 | 35
A-55-80-25-20 | 17.4 | 276,641 | 1,168 | 11.2 | 432 | 5,694 | 13.2 | 49 | 640 | 40
A-55-80-25-25 | 17.7 | 300,973 | 1,223 | 11.7 | 454 | 5,928 | 13.1 | 51 | 663 | 39
A-55-80-20-15 | 19.9 | 306,810 | 1,203 | 11.7 | 452 | 6,019 | 13.3 | 51 | 679 | 44
A-50-80-30-25 | 14.9 | 313,451 | 1,152 | 11.1 | 430 | 6,042 | 14.1 | 52 | 729 | 35
A-50-80-25-15 | 18.1 | 322,939 | 1,158 | 11.3 | 436 | 6,166 | 14.1 | 52 | 741 | 42
A-55-80-20-20 | 21.3 | 343,972 | 1,285 | 12.4 | 479 | 6,366 | 13.3 | 54 | 718 | 44
A-50-80-20-10 | 20.7 | 347,165 | 1,174 | 11.5 | 445 | 6,386 | 14.4 | 54 | 780 | 47
A-50-80-25-20 | 18.4 | 354,112 | 1,229 | 11.9 | 461 | 6,497 | 14.1 | 55 | 768 | 40
A-55-80-20-25 | 22.0 | 376,912 | 1,349 | 13.1 | 505 | 6,656 | 13.2 | 57 | 746 | 44
A-50-80-25-25 | 18.5 | 379,485 | 1,283 | 12.5 | 484 | 6,757 | 14.0 | 56 | 784 | 38
A-50-80-20-15 | 22.1 | 393,642 | 1,270 | 12.5 | 482 | 6,888 | 14.3 | 57 | 817 | 46
A-50-80-20-20 | 22.8 | 435,612 | 1,351 | 13.3 | 513 | 7,257 | 14.1 | 60 | 849 | 44
A-45-80-25-25 | 19.1 | 456,251 | 1,314 | 12.9 | 500 | 7,269 | 14.5 | 63 | 913 | 38
A-50-80-20-25 | 23.0 | 470,506 | 1,414 | 13.8 | 535 | 7,533 | 14.1 | 62 | 879 | 43
A-45-80-20-20 | 23.6 | 528,012 | 1,382 | 13.8 | 534 | 7,919 | 14.8 | 67 | 989 | 44
A-45-80-20-25 | 23.7 | 563,449 | 1,445 | 14.4 | 557 | 8,182 | 14.7 | 69 | 1,012 | 43

* Strategies with at least 9.0 percent lung cancer mortality reduction.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 26 Sensitivity Analysis by Excluding Individuals With Life Expectancy of Less Than 5 Years From Screening

Harms of 25 Selected^*^ Consensus-Efficient Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria Ordered by LDCT Screens—1960 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-55-80-20-20 | 176,841 | 195,763 | 8.3 | 1.2 | 483 | 23 | 0.5 | 2.2 | 21.8
B-55-80-20-25 | 193,275 | 213,125 | 8.8 | 1.2 | 510 | 24 | 0.5 | 2.2 | 22.4
B-50-80-25-25 | 195,846 | 215,254 | 10.6 | 1.5 | 500 | 23 | 0.5 | 2.2 | 23.3
A-55-80-30-15 | 211,055 | 230,291 | 15.5 | 1.9 | 473 | 23 | 0.5 | 2.3 | 23.4
A-55-80-25-10 | 216,689 | 236,480 | 14.1 | 1.7 | 489 | 25 | 0.5 | 2.5 | 24.3
B-50-80-20-20 | 224,867 | 246,369 | 9.9 | 1.4 | 545 | 25 | 0.5 | 2.3 | 26.3
A-55-80-30-20 | 232,601 | 252,951 | 16.6 | 2.0 | 505 | 25 | 0.5 | 2.4 | 24.4
B-50-80-20-25 | 242,588 | 265,015 | 10.5 | 1.5 | 574 | 26 | 0.5 | 2.2 | 26.9
A-55-80-25-15 | 247,982 | 269,512 | 14.8 | 1.8 | 536 | 26 | 0.5 | 2.4 | 25.8
A-55-80-30-25 | 249,780 | 271,008 | 17.5 | 2.1 | 530 | 27 | 0.6 | 2.5 | 24.9
A-55-80-25-20 | 276,641 | 299,679 | 15.9 | 1.9 | 576 | 29 | 0.6 | 2.5 | 27.1
A-55-80-25-25 | 300,973 | 325,259 | 17.0 | 2.0 | 608 | 30 | 0.6 | 2.5 | 28.0
A-55-80-20-15 | 306,810 | 331,730 | 15.4 | 1.9 | 611 | 29 | 0.6 | 2.4 | 30.1
A-50-80-30-25 | 313,451 | 337,836 | 21.0 | 2.4 | 588 | 26 | 0.5 | 2.3 | 31.6
A-50-80-25-15 | 322,939 | 348,290 | 17.8 | 2.1 | 605 | 27 | 0.5 | 2.3 | 33.7
A-55-80-20-20 | 343,972 | 370,941 | 16.1 | 1.9 | 662 | 32 | 0.7 | 2.5 | 31.6
A-50-80-20-10 | 347,165 | 374,106 | 16.8 | 2.0 | 631 | 28 | 0.6 | 2.4 | 36.7
A-50-80-25-20 | 354,112 | 381,042 | 19.2 | 2.3 | 646 | 29 | 0.6 | 2.4 | 35.1
A-55-80-20-25 | 376,912 | 405,586 | 17.1 | 2.0 | 702 | 34 | 0.7 | 2.5 | 32.9
A-50-80-25-25 | 379,485 | 407,680 | 20.5 | 2.4 | 678 | 29 | 0.6 | 2.3 | 36.0
A-50-80-20-15 | 393,642 | 423,074 | 17.8 | 2.1 | 692 | 30 | 0.6 | 2.4 | 38.9
A-50-80-20-20 | 435,612 | 467,198 | 19.1 | 2.3 | 744 | 33 | 0.7 | 2.4 | 40.7
A-45-80-25-25 | 456,251 | 488,135 | 23.9 | 2.8 | 739 | 31 | 0.6 | 2.4 | 43.8
A-50-80-20-25 | 470,506 | 503,852 | 20.5 | 2.4 | 784 | 34 | 0.7 | 2.4 | 42.0
A-45-80-20-20 | 528,012 | 564,097 | 22.4 | 2.6 | 817 | 33 | 0.7 | 2.4 | 49.9
A-45-80-20-25 | 563,449 | 601,282 | 23.8 | 2.8 | 856 | 34 | 0.7 | 2.4 | 51.2

* Strategies with at least 9.0 percent lung cancer mortality reduction.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–minimum pack-years–maximum years since quitting. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; CT=computed tomography; LC=lung cancer; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 27 Sensitivity Analysis by Excluding Individuals With Life Expectancy of Less Than 5 Years From Screening

Benefits of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort

Scenario | % Eligible | LDCT Screens | Screen-Detected LC Cases | LC Mortality Reduction (%) | LC Deaths Averted | LYG | LYG per LC Deaths Averted | LDCT Screens per LYG | LDCT Screens per LC Deaths Averted | NNS
B-50-80-MLCDRAT-0.015 | 19.8 | 133,154 | 1,040 | 8.5 | 330 | 3,920 | 11.9 | 34 | 403 | 60
B-50-80-Bach-0.025 | 20.6 | 135,434 | 1,065 | 8.7 | 336 | 3,998 | 11.9 | 34 | 403 | 61
B-50-80-MPLCOm2012-0.014 | 18.9 | 138,947 | 1,058 | 8.8 | 339 | 4,162 | 12.3 | 33 | 410 | 56
B-55-80-Bach-0.024 | 20.9 | 139,022 | 1,058 | 8.6 | 333 | 4,009 | 12.0 | 35 | 417 | 63
B-50-80-Bach-0.024 | 21.1 | 141,852 | 1,086 | 8.9 | 345 | 4,114 | 11.9 | 34 | 411 | 61
B-50-80-MLCDRAT-0.014 | 20.7 | 142,739 | 1,074 | 8.8 | 341 | 4,080 | 12.0 | 35 | 419 | 61
B-55-80-MPLCOm2012-0.013 | 19.5 | 143,529 | 1,055 | 8.7 | 336 | 4,148 | 12.3 | 35 | 427 | 58
B-50-80-Bach-0.023 | 21.7 | 148,437 | 1,103 | 9.1 | 352 | 4,223 | 12.0 | 35 | 422 | 62
B-50-80-MPLCOm2012-0.013 | 19.7 | 149,217 | 1,087 | 9.0 | 348 | 4,331 | 12.4 | 34 | 429 | 57
A-55-80-MPLCOm2012-0.023 | 13.5 | 155,135 | 1,045 | 9.5 | 367 | 4,150 | 11.3 | 37 | 423 | 37
A-50-80-MPLCOm2012-0.023 | 13.5 | 155,203 | 1,044 | 9.5 | 366 | 4,143 | 11.3 | 37 | 424 | 37
B-50-80-Bach-0.022 | 22.3 | 155,387 | 1,121 | 9.3 | 358 | 4,328 | 12.1 | 36 | 434 | 62
A-55-80-MLCDRAT-0.023 | 14.8 | 157,918 | 1,038 | 9.4 | 365 | 4,056 | 11.1 | 39 | 433 | 41
B-55-80-Bach-0.021 | 22.7 | 158,593 | 1,111 | 9.1 | 352 | 4,290 | 12.2 | 37 | 451 | 64
B-50-80-MPLCOm2012-0.012 | 20.7 | 160,981 | 1,120 | 9.3 | 360 | 4,502 | 12.5 | 36 | 447 | 58
A-55-80-MPLCOm2012-0.022 | 13.9 | 163,721 | 1,069 | 9.8 | 379 | 4,313 | 11.4 | 38 | 432 | 37
A-50-80-MPLCOm2012-0.022 | 13.9 | 163,841 | 1,069 | 9.8 | 379 | 4,309 | 11.4 | 38 | 432 | 37
B-50-80-Bach-0.021 | 23.1 | 164,771 | 1,159 | 9.4 | 364 | 4,422 | 12.1 | 37 | 453 | 63
B-55-80-Bach-0.02 | 23.3 | 165,615 | 1,129 | 9.3 | 361 | 4,417 | 12.2 | 37 | 459 | 65
B-50-80-Bach-0.02 | 23.5 | 170,850 | 1,157 | 9.6 | 371 | 4,551 | 12.3 | 38 | 461 | 63
A-55-80-Bach-0.034 | 16.1 | 171,934 | 1,106 | 10.1 | 390 | 4,393 | 11.3 | 39 | 441 | 41
A-50-80-Bach-0.034 | 16.1 | 172,099 | 1,106 | 10.1 | 391 | 4,397 | 11.2 | 39 | 440 | 41
A-55-80-MPLCOm2012-0.021 | 14.4 | 172,750 | 1,095 | 10.0 | 388 | 4,452 | 11.5 | 39 | 445 | 37
B-55-80-Bach-0.019 | 23.9 | 172,895 | 1,143 | 9.5 | 367 | 4,519 | 12.3 | 38 | 471 | 65
A-50-80-MPLCOm2012-0.021 | 14.5 | 172,981 | 1,098 | 10.1 | 390 | 4,469 | 11.5 | 39 | 444 | 37
B-50-80-MPLCOm2012-0.011 | 21.8 | 174,712 | 1,151 | 9.6 | 372 | 4,718 | 12.7 | 37 | 470 | 59
A-55-80-Bach-0.033 | 16.5 | 180,029 | 1,127 | 10.3 | 397 | 4,503 | 11.3 | 40 | 453 | 42
A-50-80-Bach-0.033 | 16.5 | 180,254 | 1,128 | 10.4 | 401 | 4,532 | 11.3 | 40 | 450 | 41
B-50-80-Bach-0.019 | 24.3 | 180,905 | 1,202 | 9.9 | 382 | 4,678 | 12.2 | 39 | 474 | 64
A-55-80-MPLCOm2012-0.02 | 14.9 | 182,585 | 1,122 | 10.3 | 400 | 4,629 | 11.6 | 39 | 456 | 37
A-50-80-MPLCOm2012-0.02 | 15.0 | 182,997 | 1,123 | 10.3 | 399 | 4,623 | 11.6 | 40 | 459 | 38
A-50-80-MLCDRAT-0.02 | 16.5 | 186,517 | 1,124 | 10.3 | 400 | 4,537 | 11.3 | 41 | 466 | 41
A-55-80-Bach-0.032 | 17.0 | 188,493 | 1,150 | 10.5 | 407 | 4,631 | 11.4 | 41 | 463 | 42
A-50-80-Bach-0.032 | 17.0 | 188,809 | 1,151 | 10.6 | 408 | 4,654 | 11.4 | 41 | 463 | 42
B-50-80-MPLCOm2012-0.01 | 22.9 | 189,425 | 1,180 | 9.9 | 384 | 4,923 | 12.8 | 38 | 493 | 60
B-50-80-Bach-0.018 | 25.0 | 189,784 | 1,222 | 10.0 | 389 | 4,795 | 12.3 | 40 | 488 | 64
A-55-80-MPLCOm2012-0.019 | 15.5 | 193,387 | 1,149 | 10.6 | 412 | 4,817 | 11.7 | 40 | 469 | 38
A-50-80-MPLCOm2012-0.019 | 15.5 | 194,126 | 1,150 | 10.7 | 412 | 4,830 | 11.7 | 40 | 471 | 38
A-55-80-Bach-0.031 | 17.4 | 196,948 | 1,173 | 10.8 | 417 | 4,774 | 11.4 | 41 | 472 | 42
A-50-80-Bach-0.031 | 17.5 | 197,382 | 1,174 | 10.8 | 420 | 4,818 | 11.5 | 41 | 470 | 42
A-50-80-MLCDRAT-0.019 | 17.2 | 200,062 | 1,162 | 10.7 | 415 | 4,751 | 11.4 | 42 | 482 | 41
A-55-80-MPLCOm2012-0.018 | 16.1 | 204,873 | 1,174 | 10.9 | 422 | 4,956 | 11.7 | 41 | 485 | 38
A-50-80-MPLCOm2012-0.018 | 16.1 | 206,134 | 1,179 | 10.9 | 423 | 5,000 | 11.8 | 41 | 487 | 38
A-55-80-Bach-0.03 | 17.9 | 206,221 | 1,197 | 11.0 | 425 | 4,902 | 11.5 | 42 | 485 | 42
B-50-80-MPLCOm2012-0.009 | 24.1 | 206,519 | 1,218 | 10.3 | 397 | 5,144 | 13.0 | 40 | 520 | 61
A-50-80-Bach-0.03 | 18.0 | 206,796 | 1,197 | 11.0 | 425 | 4,929 | 11.6 | 42 | 487 | 42
B-50-80-Bach-0.016 | 26.2 | 207,372 | 1,237 | 10.3 | 400 | 5,040 | 12.6 | 41 | 518 | 66
A-55-80-MLCDRAT-0.018 | 17.7 | 210,294 | 1,189 | 11.0 | 425 | 4,893 | 11.5 | 43 | 495 | 42
A-50-80-MLCDRAT-0.018 | 17.7 | 210,318 | 1,188 | 11.0 | 425 | 4,903 | 11.5 | 43 | 495 | 42
A-55-80-30-15 | 13.6 | 211,055 | 992 | 9.4 | 364 | 4,864 | 13.4 | 43 | 580 | 37
A-55-80-Bach-0.029 | 18.4 | 215,368 | 1,217 | 11.3 | 436 | 5,035 | 11.5 | 43 | 494 | 42
A-50-80-Bach-0.029 | 18.5 | 216,161 | 1,221 | 11.2 | 435 | 5,036 | 11.6 | 43 | 497 | 43
A-55-80-MPLCOm2012-0.017 | 16.7 | 217,546 | 1,204 | 11.2 | 435 | 5,151 | 11.8 | 42 | 500 | 38
A-50-80-MPLCOm2012-0.017 | 16.8 | 219,544 | 1,211 | 11.3 | 436 | 5,212 | 12.0 | 42 | 504 | 39
A-55-80-Bach-0.028 | 19.0 | 225,598 | 1,240 | 11.5 | 443 | 5,144 | 11.6 | 44 | 509 | 43
B-50-80-MPLCOm2012-0.008 | 25.6 | 226,142 | 1,252 | 10.6 | 411 | 5,377 | 13.1 | 42 | 550 | 62
A-50-80-MLCDRAT-0.017 | 18.4 | 226,165 | 1,225 | 11.4 | 441 | 5,130 | 11.6 | 44 | 513 | 42
A-50-80-Bach-0.028 | 19.0 | 226,614 | 1,244 | 11.5 | 446 | 5,205 | 11.7 | 44 | 508 | 43
B-50-80-Bach-0.014 | 27.8 | 229,085 | 1,278 | 10.8 | 416 | 5,321 | 12.8 | 43 | 551 | 67
A-55-80-MPLCOm2012-0.016 | 17.4 | 230,908 | 1,234 | 11.5 | 446 | 5,339 | 12.0 | 43 | 518 | 39
A-50-80-MPLCOm2012-0.016 | 17.5 | 233,969 | 1,243 | 11.7 | 451 | 5,446 | 12.1 | 43 | 519 | 39
A-55-80-Bach-0.027 | 19.5 | 236,104 | 1,261 | 11.7 | 454 | 5,292 | 11.7 | 45 | 520 | 43
A-50-80-Bach-0.027 | 19.6 | 237,516 | 1,266 | 11.8 | 455 | 5,333 | 11.7 | 45 | 522 | 43
A-50-80-MLCDRAT-0.016 | 19.1 | 238,916 | 1,255 | 11.7 | 454 | 5,300 | 11.7 | 45 | 526 | 42
B-50-80-Bach-0.013 | 28.6 | 241,152 | 1,303 | 11.0 | 425 | 5,459 | 12.8 | 44 | 567 | 67
A-55-80-MPLCOm2012-0.015 | 18.1 | 245,890 | 1,265 | 11.9 | 460 | 5,556 | 12.1 | 44 | 535 | 39
A-55-80-Bach-0.026 | 20.0 | 246,562 | 1,286 | 11.9 | 462 | 5,419 | 11.7 | 45 | 534 | 43
A-50-80-Bach-0.026 | 20.1 | 248,267 | 1,290 | 12.0 | 465 | 5,491 | 11.8 | 45 | 534 | 43
B-50-80-MPLCOm2012-0.007 | 27.1 | 249,159 | 1,295 | 11.0 | 426 | 5,638 | 13.2 | 44 | 585 | 64
A-50-80-MPLCOm2012-0.015 | 18.2 | 250,423 | 1,275 | 12.0 | 464 | 5,661 | 12.2 | 44 | 540 | 39
B-50-80-Bach-0.012 | 29.5 | 254,312 | 1,326 | 11.2 | 434 | 5,579 | 12.9 | 46 | 586 | 68
A-50-80-MLCDRAT-0.015 | 19.9 | 256,318 | 1,292 | 12.1 | 467 | 5,514 | 11.8 | 46 | 549 | 43
A-50-77-MPLCOm2012-0.013 | 18.9 | 257,643 | 1,149 | 11.0 | 426 | 5,694 | 13.4 | 45 | 605 | 44
A-55-80-Bach-0.025 | 20.6 | 258,218 | 1,308 | 12.2 | 473 | 5,573 | 11.8 | 46 | 546 | 44
A-50-80-Bach-0.025 | 20.7 | 260,585 | 1,315 | 12.3 | 476 | 5,661 | 11.9 | 46 | 547 | 43
A-55-80-MPLCOm2012-0.014 | 18.9 | 262,322 | 1,296 | 12.2 | 473 | 5,729 | 12.1 | 46 | 555 | 40
B-50-80-Bach-0.011 | 30.5 | 268,617 | 1,343 | 11.4 | 442 | 5,770 | 13.1 | 47 | 608 | 69
A-50-80-MPLCOm2012-0.014 | 19.0 | 268,752 | 1,311 | 12.4 | 479 | 5,895 | 12.3 | 46 | 561 | 40
A-55-80-Bach-0.024 | 21.1 | 270,181 | 1,332 | 12.4 | 480 | 5,701 | 11.9 | 47 | 563 | 44
A-55-80-MLCDRAT-0.014 | 20.7 | 272,113 | 1,320 | 12.4 | 481 | 5,701 | 11.9 | 48 | 566 | 43
A-50-80-Bach-0.024 | 21.2 | 273,052 | 1,341 | 12.6 | 486 | 5,855 | 12.0 | 47 | 562 | 44
B-50-80-MPLCOm2012-0.006 | 28.9 | 274,258 | 1,332 | 11.4 | 442 | 5,871 | 13.3 | 47 | 620 | 65
A-50-80-MLCDRAT-0.014 | 20.8 | 274,909 | 1,327 | 12.5 | 483 | 5,794 | 12.0 | 47 | 569 | 43
A-50-77-MPLCOm2012-0.012 | 19.9 | 279,337 | 1,183 | 11.3 | 437 | 5,932 | 13.6 | 47 | 639 | 46
A-55-80-MPLCOm2012-0.013 | 19.7 | 279,923 | 1,327 | 12.5 | 483 | 5,894 | 12.2 | 47 | 580 | 41
A-55-80-Bach-0.023 | 21.7 | 282,290 | 1,356 | 12.7 | 490 | 5,850 | 11.9 | 48 | 576 | 44
B-50-80-Bach-0.01 | 31.5 | 283,740 | 1,371 | 11.6 | 449 | 5,889 | 13.1 | 48 | 632 | 70
A-50-80-Bach-0.023 | 21.8 | 285,981 | 1,366 | 12.8 | 496 | 5,964 | 12.0 | 48 | 577 | 44
A-55-80-MLCDRAT-0.013 | 21.6 | 288,408 | 1,352 | 12.7 | 493 | 5,897 | 12.0 | 49 | 585 | 44
A-50-80-MPLCOm2012-0.013 | 19.8 | 288,922 | 1,345 | 12.8 | 493 | 6,133 | 12.4 | 47 | 586 | 40
A-50-80-MLCDRAT-0.013 | 21.7 | 292,622 | 1,361 | 12.8 | 496 | 5,988 | 12.1 | 49 | 590 | 44
A-55-80-Bach-0.022 | 22.3 | 295,112 | 1,378 | 12.9 | 501 | 6,005 | 12.0 | 49 | 589 | 45
A-55-80-MPLCOm2012-0.012 | 20.6 | 299,594 | 1,362 | 12.9 | 498 | 6,124 | 12.3 | 49 | 602 | 41
A-50-80-Bach-0.022 | 22.4 | 299,744 | 1,388 | 13.1 | 507 | 6,147 | 12.1 | 49 | 591 | 44
B-50-80-Bach-0.009 | 32.7 | 300,632 | 1,397 | 12.0 | 465 | 6,116 | 13.2 | 49 | 647 | 70
B-50-80-MPLCOm2012-0.005 | 30.9 | 303,280 | 1,370 | 11.8 | 456 | 6,122 | 13.4 | 50 | 665 | 68
A-50-77-MPLCOm2012-0.011 | 20.8 | 303,627 | 1,215 | 11.7 | 452 | 6,190 | 13.7 | 49 | 672 | 46
A-55-80-20-15 | 19.9 | 306,810 | 1,203 | 11.7 | 452 | 6,019 | 13.3 | 51 | 679 | 44
A-55-80-Bach-0.021 | 22.9 | 308,714 | 1,400 | 13.2 | 513 | 6,166 | 12.0 | 50 | 602 | 45
A-55-80-MLCDRAT-0.012 | 22.7 | 309,691 | 1,388 | 13.1 | 507 | 6,106 | 12.0 | 51 | 611 | 45
A-50-80-MPLCOm2012-0.012 | 20.8 | 312,226 | 1,384 | 13.1 | 508 | 6,391 | 12.6 | 49 | 615 | 41
A-50-80-Bach-0.021 | 23.0 | 314,528 | 1,411 | 13.3 | 515 | 6,313 | 12.3 | 50 | 611 | 45
A-50-80-MLCDRAT-0.012 | 22.9 | 316,104 | 1,400 | 13.3 | 513 | 6,261 | 12.2 | 50 | 616 | 45
A-55-80-MPLCOm2012-0.011 | 21.6 | 319,813 | 1,391 | 13.2 | 512 | 6,313 | 12.3 | 51 | 625 | 42
A-55-80-Bach-0.02 | 23.5 | 322,574 | 1,418 | 13.5 | 521 | 6,318 | 12.1 | 51 | 619 | 45
A-50-80-Bach-0.02 | 23.6 | 329,953 | 1,434 | 13.6 | 527 | 6,493 | 12.3 | 51 | 626 | 45
A-50-77-MPLCOm2012-0.01 | 22.0 | 330,899 | 1,253 | 12.1 | 468 | 6,492 | 13.9 | 51 | 707 | 47
A-55-80-MLCDRAT-0.011 | 24.3 | 333,280 | 1,426 | 13.5 | 523 | 6,346 | 12.1 | 53 | 637 | 46
A-55-80-Bach-0.019 | 24.1 | 336,938 | 1,438 | 13.6 | 528 | 6,438 | 12.2 | 52 | 638 | 46
A-50-80-MPLCOm2012-0.011 | 21.9 | 338,238 | 1,420 | 13.6 | 526 | 6,644 | 12.6 | 51 | 643 | 42
A-55-80-MPLCOm2012-0.01 | 22.6 | 341,753 | 1,424 | 13.6 | 525 | 6,511 | 12.4 | 52 | 651 | 43
A-50-80-MLCDRAT-0.011 | 24.5 | 341,894 | 1,443 | 13.7 | 530 | 6,549 | 12.4 | 52 | 645 | 46
A-55-80-20-20 | 21.3 | 343,972 | 1,285 | 12.4 | 479 | 6,366 | 13.3 | 54 | 718 | 44
A-50-80-Bach-0.019 | 24.3 | 345,891 | 1,458 | 13.9 | 536 | 6,643 | 12.4 | 52 | 645 | 45
A-55-80-Bach-0.018 | 24.7 | 352,513 | 1,463 | 13.9 | 537 | 6,581 | 12.3 | 54 | 656 | 46
A-55-80-MLCDRAT-0.01 | 26.5 | 360,405 | 1,470 | 13.9 | 538 | 6,566 | 12.2 | 55 | 670 | 49
A-50-80-Bach-0.018 | 24.9 | 363,441 | 1,483 | 14.1 | 547 | 6,815 | 12.5 | 53 | 664 | 46
A-50-80-MPLCOm2012-0.01 | 23.0 | 367,433 | 1,456 | 14.0 | 541 | 6,952 | 12.9 | 53 | 679 | 43
A-55-80-Bach-0.017 | 25.4 | 368,501 | 1,487 | 14.2 | 548 | 6,746 | 12.3 | 55 | 672 | 46
A-50-80-MLCDRAT-0.01 | 26.7 | 371,729 | 1,492 | 14.2 | 550 | 6,851 | 12.5 | 54 | 676 | 49
A-55-80-20-25 | 22.0 | 376,912 | 1,349 | 13.1 | 505 | 6,656 | 13.2 | 57 | 746 | 44
A-50-80-Bach-0.017 | 25.6 | 382,161 | 1,505 | 14.4 | 559 | 7,000 | 12.5 | 55 | 684 | 46
A-55-80-Bach-0.016 | 26.1 | 385,000 | 1,504 | 14.3 | 554 | 6,836 | 12.3 | 56 | 695 | 47
A-55-80-MLCDRAT-0.009 | 29.0 | 393,326 | 1,518 | 14.4 | 556 | 6,831 | 12.3 | 58 | 707 | 52
A-50-80-20-15 | 22.1 | 393,642 | 1,270 | 12.5 | 482 | 6,888 | 14.3 | 57 | 817 | 46
A-55-80-MPLCOm2012-0.008 | 25.1 | 395,223 | 1,494 | 14.4 | 556 | 6,990 | 12.6 | 57 | 711 | 45
A-50-80-MPLCOm2012-0.009 | 24.2 | 400,893 | 1,499 | 14.4 | 558 | 7,264 | 13.0 | 55 | 718 | 43
A-50-80-Bach-0.016 | 26.3 | 401,912 | 1,530 | 14.6 | 566 | 7,130 | 12.6 | 56 | 710 | 46
A-55-80-Bach-0.015 | 26.8 | 402,313 | 1,525 | 14.7 | 567 | 7,021 | 12.4 | 57 | 710 | 47
A-50-80-MLCDRAT-0.009 | 29.2 | 408,368 | 1,542 | 14.7 | 570 | 7,129 | 12.5 | 57 | 716 | 51
A-55-80-Bach-0.014 | 27.5 | 420,368 | 1,546 | 14.8 | 572 | 7,133 | 12.5 | 59 | 735 | 48
A-50-80-Bach-0.015 | 27.1 | 422,671 | 1,552 | 14.9 | 577 | 7,331 | 12.7 | 58 | 733 | 47
A-55-80-MLCDRAT-0.008 | 31.8 | 430,892 | 1,569 | 14.9 | 578 | 7,128 | 12.3 | 60 | 745 | 55
A-50-80-20-20 | 22.8 | 435,612 | 1,351 | 13.3 | 513 | 7,257 | 14.1 | 60 | 849 | 44
A-55-80-Bach-0.013 | 28.3 | 439,639 | 1,569 | 15.0 | 582 | 7,268 | 12.5 | 60 | 755 | 49
A-50-80-MPLCOm2012-0.008 | 25.7 | 439,765 | 1,540 | 14.9 | 577 | 7,578 | 13.1 | 58 | 762 | 45
A-50-80-Bach-0.014 | 27.9 | 444,572 | 1,577 | 15.2 | 588 | 7,539 | 12.8 | 59 | 756 | 47
A-50-80-MLCDRAT-0.008 | 32.1 | 451,693 | 1,599 | 15.3 | 591 | 7,486 | 12.7 | 60 | 764 | 54
A-55-80-Bach-0.012 | 29.2 | 460,155 | 1,590 | 15.2 | 588 | 7,391 | 12.6 | 62 | 783 | 50
A-50-80-Bach-0.013 | 28.7 | 468,214 | 1,602 | 15.5 | 599 | 7,729 | 12.9 | 61 | 782 | 48
A-50-80-20-25 | 23.0 | 470,506 | 1,414 | 13.8 | 535 | 7,533 | 14.1 | 62 | 879 | 43
A-55-80-MLCDRAT-0.007 | 34.6 | 474,378 | 1,625 | 15.6 | 602 | 7,432 | 12.3 | 64 | 788 | 57
A-55-80-Bach-0.011 | 30.1 | 482,190 | 1,614 | 15.6 | 601 | 7,574 | 12.6 | 64 | 802 | 50
A-50-80-MPLCOm2012-0.007 | 27.2 | 483,401 | 1,582 | 15.4 | 594 | 7,871 | 13.3 | 61 | 814 | 46
A-50-80-Bach-0.012 | 29.6 | 493,841 | 1,627 | 15.8 | 610 | 7,917 | 13.0 | 62 | 810 | 49
A-50-80-MLCDRAT-0.007 | 35.0 | 503,486 | 1,661 | 16.0 | 618 | 7,898 | 12.8 | 64 | 815 | 57
A-55-80-Bach-0.01 | 31.0 | 505,254 | 1,635 | 15.8 | 612 | 7,768 | 12.7 | 65 | 826 | 51
A-50-80-Bach-0.011 | 30.6 | 521,832 | 1,654 | 16.1 | 624 | 8,160 | 13.1 | 64 | 836 | 49
A-55-80-MLCDRAT-0.006 | 37.3 | 527,189 | 1,677 | 16.2 | 625 | 7,804 | 12.5 | 68 | 844 | 60
A-50-80-MPLCOm2012-0.006 | 29.0 | 531,812 | 1,625 | 15.8 | 612 | 8,187 | 13.4 | 65 | 869 | 47
A-50-80-Bach-0.01 | 31.6 | 551,363 | 1,681 | 16.4 | 634 | 8,327 | 13.1 | 66 | 870 | 50

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: LC=lung cancer; LDCT=low-dose computed tomography; LYG=life-years gained; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; NNS=number (people) needed to screen (ever) to prevent one lung cancer death; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 28 Sensitivity Analysis by Excluding Individuals With Life Expectancy of Less Than 5 Years From Screening

Harms of 144 Selected^*^ Consensus-Efficient Risk Model–Based or Risk Factor–Based Screening Programs Plus the 2013 USPSTF-Recommended Criteria and Six Selected 20 Pack-Year Scenarios Ordered by LDCT Screens—1960 Birth Cohort

Scenario | LDCT Screens | LDCT Scans | Avg. LDCT Screens per Person Screened | Avg. False-Positive Results per Person Screened | Biopsies | Overdiagnosed Cases | Overdiagnosis: % of All LC Cases | Overdiagnosis: % of Screen-Detected LC Cases | Radiation-Related LC Deaths^†^
B-50-80-MLCDRAT-0.015 | 133,154 | 149,692 | 6.7 | 1.0 | 451 | 25 | 0.5 | 2.4 | 11.1
B-50-80-Bach-0.025 | 135,434 | 152,193 | 6.6 | 1.0 | 462 | 25 | 0.5 | 2.3 | 11.1
B-50-80-MPLCOm2012-0.014 | 138,947 | 155,617 | 7.4 | 1.0 | 460 | 24 | 0.5 | 2.3 | 12.0
B-55-80-Bach-0.024 | 139,022 | 155,950 | 6.7 | 1.0 | 462 | 24 | 0.5 | 2.3 | 11.6
B-50-80-Bach-0.024 | 141,852 | 159,021 | 6.7 | 1.0 | 473 | 26 | 0.5 | 2.4 | 11.9
B-50-80-MLCDRAT-0.014 | 142,739 | 159,905 | 6.9 | 1.0 | 470 | 26 | 0.5 | 2.4 | 12.1
B-55-80-MPLCOm2012-0.013 | 143,529 | 160,485 | 7.4 | 1.0 | 463 | 24 | 0.5 | 2.3 | 12.6
B-50-80-Bach-0.023 | 148,437 | 166,018 | 6.8 | 1.0 | 484 | 26 | 0.6 | 2.4 | 12.4
B-50-80-MPLCOm2012-0.013 | 149,217 | 166,526 | 7.6 | 1.1 | 477 | 25 | 0.5 | 2.3 | 13.4
A-55-80-MPLCOm2012-0.023 | 155,135 | 171,724 | 11.5 | 1.4 | 452 | 27 | 0.6 | 2.6 | 11.3
A-50-80-MPLCOm2012-0.023 | 155,203 | 171,793 | 11.5 | 1.4 | 452 | 27 | 0.6 | 2.6 | 11.3
B-50-80-Bach-0.022 | 155,387 | 173,405 | 7.0 | 1.0 | 495 | 27 | 0.6 | 2.4 | 12.9
A-55-80-MLCDRAT-0.023 | 157,918 | 174,848 | 10.7 | 1.3 | 454 | 27 | 0.6 | 2.6 | 11.0
B-55-80-Bach-0.021 | 158,593 | 176,781 | 7.0 | 1.0 | 495 | 25 | 0.5 | 2.3 | 13.1
B-50-80-MPLCOm2012-0.012 | 160,981 | 179,029 | 7.8 | 1.1 | 498 | 25 | 0.5 | 2.2 | 13.8
A-55-80-MPLCOm2012-0.022 | 163,721 | 180,796 | 11.8 | 1.4 | 466 | 27 | 0.6 | 2.5 | 12.2
A-50-80-MPLCOm2012-0.022 | 163,841 | 180,936 | 11.8 | 1.4 | 466 | 27 | 0.6 | 2.5 | 12.2
B-50-80-Bach-0.021 | 164,771 | 183,392 | 7.1 | 1.0 | 515 | 34 | 0.7 | 2.9 | 13.7
B-55-80-Bach-0.02 | 165,615 | 184,256 | 7.1 | 1.0 | 506 | 25 | 0.5 | 2.2 | 14.0
B-50-80-Bach-0.02 | 170,850 | 189,841 | 7.3 | 1.0 | 519 | 27 | 0.6 | 2.3 | 14.6
A-55-80-Bach-0.034 | 171,934 | 189,747 | 10.7 | 1.3 | 486 | 29 | 0.6 | 2.6 | 12.9
A-50-80-Bach-0.034 | 172,099 | 189,921 | 10.7 | 1.3 | 486 | 29 | 0.6 | 2.6 | 12.9
A-55-80-MPLCOm2012-0.021 | 172,750 | 190,361 | 12.0 | 1.5 | 481 | 28 | 0.6 | 2.6 | 13.3
B-55-80-Bach-0.019 | 172,895 | 191,977 | 7.2 | 1.0 | 517 | 25 | 0.5 | 2.2 | 14.6
A-50-80-MPLCOm2012-0.021 | 172,981 | 190,597 | 11.9 | 1.5 | 481 | 28 | 0.6 | 2.6 | 13.3
B-50-80-MPLCOm2012-0.011 | 174,712 | 193,613 | 8.0 | 1.1 | 518 | 25 | 0.5 | 2.2 | 15.4
A-55-80-Bach-0.033 | 180,029 | 198,322 | 10.9 | 1.3 | 498 | 30 | 0.6 | 2.7 | 13.6
A-50-80-Bach-0.033 | 180,254 | 198,559 | 10.9 | 1.3 | 499 | 29 | 0.6 | 2.6 | 13.7
B-50-80-Bach-0.019 | 180,905 | 200,531 | 7.4 | 1.1 | 541 | 36 | 0.7 | 3.0 | 15.3
A-55-80-MPLCOm2012-0.02 | 182,585 | 200,757 | 12.3 | 1.5 | 496 | 29 | 0.6 | 2.6 | 14.2
A-50-80-MPLCOm2012-0.02 | 182,997 | 201,200 | 12.2 | 1.5 | 496 | 28 | 0.6 | 2.5 | 14.3
A-50-80-MLCDRAT-0.02 | 186,517 | 205,129 | 11.3 | 1.4 | 501 | 29 | 0.6 | 2.6 | 13.4
A-55-80-Bach-0.032 | 188,493 | 207,274 | 11.1 | 1.4 | 512 | 30 | 0.6 | 2.6 | 14.2
A-50-80-Bach-0.032 | 188,809 | 207,606 | 11.1 | 1.4 | 512 | 30 | 0.6 | 2.6 | 14.3
B-50-80-MPLCOm2012-0.01 | 189,425 | 209,223 | 8.3 | 1.2 | 540 | 26 | 0.6 | 2.2 | 17.0
B-50-80-Bach-0.018 | 189,784 | 209,956 | 7.6 | 1.1 | 555 | 37 | 0.7 | 3.0 | 16.1
A-55-80-MPLCOm2012-0.019 | 193,387 | 212,182 | 12.5 | 1.5 | 512 | 29 | 0.6 | 2.5 | 15.2
A-50-80-MPLCOm2012-0.019 | 194,126 | 212,958 | 12.5 | 1.5 | 513 | 28 | 0.6 | 2.4 | 15.3
A-55-80-Bach-0.031 | 196,948 | 216,222 | 11.3 | 1.4 | 525 | 30 | 0.6 | 2.6 | 15.0
A-50-80-Bach-0.031 | 197,382 | 216,684 | 11.3 | 1.4 | 525 | 30 | 0.6 | 2.6 | 15.1
A-50-80-MLCDRAT-0.019 | 200,062 | 219,459 | 11.6 | 1.4 | 523 | 31 | 0.6 | 2.7 | 14.7
A-55-80-MPLCOm2012-0.018 | 204,873 | 224,318 | 12.7 | 1.5 | 528 | 28 | 0.6 | 2.4 | 15.9
A-50-80-MPLCOm2012-0.018 | 206,134 | 225,653 | 12.8 | 1.5 | 531 | 29 | 0.6 | 2.5 | 16.1
A-55-80-Bach-0.03 | 206,221 | 226,038 | 11.5 | 1.4 | 539 | 30 | 0.6 | 2.5 | 15.7
B-50-80-MPLCOm2012-0.009 | 206,519 | 227,383 | 8.6 | 1.2 | 565 | 27 | 0.6 | 2.2 | 18.6
A-50-80-Bach-0.03 | 206,796 | 226,646 | 11.5 | 1.4 | 539 | 31 | 0.7 | 2.6 | 15.7
B-50-80-Bach-0.016 | 207,372 | 228,614 | 7.9 | 1.1 | 574 | 28 | 0.6 | 2.3 | 18.2
A-55-80-MLCDRAT-0.018 | 210,294 | 230,274 | 11.9 | 1.4 | 539 | 31 | 0.6 | 2.6 | 15.7
A-50-80-MLCDRAT-0.018 | 210,318 | 230,310 | 11.9 | 1.4 | 538 | 30 | 0.6 | 2.5 | 15.7
A-55-80-30-15 | 211,055 | 230,291 | 15.5 | 1.9 | 473 | 23 | 0.5 | 2.3 | 23.4
A-55-80-Bach-0.029 | 215,368 | 235,718 | 11.7 | 1.4 | 552 | 31 | 0.6 | 2.5 | 16.3
A-50-80-Bach-0.029 | 216,161 | 236,548 | 11.7 | 1.4 | 553 | 31 | 0.7 | 2.5 | 16.5
A-55-80-MPLCOm2012-0.017 | 217,546 | 237,736 | 13.0 | 1.6 | 547 | 30 | 0.6 | 2.5 | 17.2
A-50-80-MPLCOm2012-0.017 | 219,544 | 239,821 | 13.1 | 1.6 | 550 | 30 | 0.6 | 2.5 | 17.5
A-55-80-Bach-0.028 | 225,598 | 246,529 | 11.9 | 1.4 | 566 | 31 | 0.7 | 2.5 | 17.0
B-50-80-MPLCOm2012-0.008 | 226,142 | 248,190 | 8.8 | 1.2 | 591 | 28 | 0.6 | 2.2 | 20.1
A-50-80-MLCDRAT-0.017 | 226,165 | 247,053 | 12.3 | 1.5 | 561 | 31 | 0.7 | 2.5 | 17.1
A-50-80-Bach-0.028 | 226,614 | 247,607 | 11.9 | 1.4 | 568 | 32 | 0.7 | 2.6 | 17.2
B-50-80-Bach-0.014 | 229,085 | 251,648 | 8.2 | 1.1 | 604 | 29 | 0.6 | 2.3 | 19.6
A-55-80-MPLCOm2012-0.016 | 230,908 | 251,859 | 13.3 | 1.6 | 565 | 30 | 0.6 | 2.4 | 18.4
A-50-80-MPLCOm2012-0.016 | 233,969 | 255,066 | 13.4 | 1.6 | 570 | 30 | 0.6 | 2.4 | 19.0
A-55-80-Bach-0.027 | 236,104 | 257,636 | 12.1 | 1.5 | 580 | 31 | 0.7 | 2.5 | 18.1
A-50-80-Bach-0.027 | 237,516 | 259,138 | 12.1 | 1.5 | 583 | 32 | 0.7 | 2.5 | 18.3
A-50-80-MLCDRAT-0.016 | 238,916 | 260,542 | 12.5 | 1.5 | 580 | 32 | 0.7 | 2.5 | 18.2
B-50-80-Bach-0.013 | 241,152 | 264,441 | 8.4 | 1.2 | 622 | 29 | 0.6 | 2.2 | 20.9
A-55-80-MPLCOm2012-0.015 | 245,890 | 267,695 | 13.6 | 1.6 | 586 | 30 | 0.6 | 2.4 | 19.6
A-55-80-Bach-0.026 | 246,562 | 268,706 | 12.3 | 1.5 | 595 | 32 | 0.7 | 2.5 | 18.8
A-50-80-Bach-0.026 | 248,267 | 270,517 | 12.4 | 1.5 | 598 | 33 | 0.7 | 2.6 | 19.0
B-50-80-MPLCOm2012-0.007 | 249,159 | 272,629 | 9.2 | 1.3 | 623 | 28 | 0.6 | 2.2 | 21.9
A-50-80-MPLCOm2012-0.015 | 250,423 | 272,463 | 13.8 | 1.6 | 592 | 30 | 0.6 | 2.4 | 20.3
B-50-80-Bach-0.012 | 254,312 | 278,410 | 8.6 | 1.2 | 639 | 30 | 0.6 | 2.3 | 22.2
A-50-80-MLCDRAT-0.015 | 256,318 | 278,938 | 12.9 | 1.6 | 604 | 33 | 0.7 | 2.6 | 19.3
A-50-77-MPLCOm2012-0.013 | 257,643 | 280,134 | 13.6 | 1.6 | 559 | 25 | 0.5 | 2.2 | 22.2
A-55-80-Bach-0.025 | 258,218 | 281,020 | 12.5 | 1.5 | 611 | 33 | 0.7 | 2.5 | 19.7
A-50-80-Bach-0.025 | 260,585 | 283,517 | 12.6 | 1.5 | 614 | 34 | 0.7 | 2.6 | 20.1
A-55-80-MPLCOm2012-0.014 | 262,322 | 285,055 | 13.9 | 1.7 | 607 | 31 | 0.6 | 2.4 | 20.6
B-50-80-Bach-0.011 | 268,617 | 293,565 | 8.8 | 1.2 | 656 | 30 | 0.6 | 2.2 | 23.1
A-50-80-MPLCOm2012-0.014 | 268,752 | 291,812 | 14.1 | 1.7 | 616 | 30 | 0.6 | 2.3 | 21.4
A-55-80-Bach-0.024 | 270,181 | 293,673 | 12.8 | 1.5 | 627 | 33 | 0.7 | 2.5 | 20.4
A-55-80-MLCDRAT-0.014 | 272,113 | 295,649 | 13.1 | 1.6 | 623 | 33 | 0.7 | 2.5 | 20.4
A-50-80-Bach-0.024 | 273,052 | 296,691 | 12.9 | 1.5 | 631 | 34 | 0.7 | 2.5 | 20.7
B-50-80-MPLCOm2012-0.006 | 274,258 | 299,256 | 9.5 | 1.3 | 655 | 30 | 0.6 | 2.3 | 23.9
A-50-80-MLCDRAT-0.014 | 274,909 | 298,582 | 13.2 | 1.6 | 627 | 33 | 0.7 | 2.5 | 20.8
A-50-77-MPLCOm2012-0.012 | 279,337 | 303,049 | 14.0 | 1.7 | 585 | 26 | 0.5 | 2.2 | 24.2
A-55-80-MPLCOm2012-0.013 | 279,923 | 303,665 | 14.2 | 1.7 | 629 | 32 | 0.7 | 2.4 | 22.0
A-55-80-Bach-0.023 | 282,290 | 306,471 | 13.0 | 1.6 | 643 | 34 | 0.7 | 2.5 | 21.1
B-50-80-Bach-0.01 | 283,740 | 309,625 | 9.0 | 1.2 | 677 | 31 | 0.6 | 2.3 | 24.5
A-50-80-Bach-0.023 | 285,981 | 310,346 | 13.1 | 1.6 | 648 | 34 | 0.7 | 2.5 | 21.6
A-55-80-MLCDRAT-0.013 | 288,408 | 312,879 | 13.4 | 1.6 | 645 | 34 | 0.7 | 2.5 | 21.4
A-50-80-MPLCOm2012-0.013 | 288,922 | 313,117 | 14.6 | 1.7 | 640 | 32 | 0.7 | 2.4 | 23.2
A-50-80-MLCDRAT-0.013 | 292,622 | 317,310 | 13.5 | 1.6 | 651 | 34 | 0.7 | 2.5 | 21.9
A-55-80-Bach-0.022 | 295,112 | 320,012 | 13.2 | 1.6 | 658 | 34 | 0.7 | 2.5 | 22.4
A-55-80-MPLCOm2012-0.012 | 299,594 | 324,423 | 14.5 | 1.7 | 653 | 33 | 0.7 | 2.4 | 23.5
A-50-80-Bach-0.022 | 299,744 | 324,882 | 13.4 | 1.6 | 665 | 35 | 0.7 | 2.5 | 23.0
B-50-80-Bach-0.009 | 300,632 | 327,539 | 9.2 | 1.3 | 699 | 32 | 0.7 | 2.3 | 25.8
B-50-80-MPLCOm2012-0.005 | 303,280 | 330,029 | 9.8 | 1.3 | 690 | 30 | 0.6 | 2.2 | 25.4
A-50-77-MPLCOm2012-0.011 | 303,627 | 328,670 | 14.6 | 1.7 | 612 | 26 | 0.5 | 2.1 | 26.2
A-55-80-20-15 | 306,810 | 331,730 | 15.4 | 1.9 | 611 | 29 | 0.6 | 2.4 | 30.1
A-55-80-Bach-0.021 | 308,714 | 334,386 | 13.5 | 1.6 | 675 | 34 | 0.7 | 2.4 | 23.2
A-55-80-MLCDRAT-0.012 | 309,691 | 335,384 | 13.6 | 1.6 | 671 | 35 | 0.7 | 2.5 | 23.1
A-50-80-MPLCOm2012-0.012 | 312,226 | 337,721 | 15.0 | 1.8 | 669 | 33 | 0.7 | 2.4 | 25.3
A-50-80-Bach-0.021 | 314,528 | 340,506 | 13.7 | 1.6 | 682 | 35 | 0.7 | 2.5 | 24.1
A-50-80-MLCDRAT-0.012 | 316,104 | 342,142 | 13.8 | 1.6 | 679 | 35 | 0.7 | 2.5 | 24.0
A-55-80-MPLCOm2012-0.011 | 319,813 | 345,797 | 14.8 | 1.7 | 677 | 33 | 0.7 | 2.4 | 24.8
A-55-80-Bach-0.02 | 322,574 | 349,024 | 13.7 | 1.6 | 690 | 35 | 0.7 | 2.5 | 24.2
A-50-80-Bach-0.02 | 329,953 | 356,778 | 14.0 | 1.7 | 700 | 35 | 0.7 | 2.4 | 25.1
A-50-77-MPLCOm2012-0.01 | 330,899 | 357,465 | 15.0 | 1.8 | 643 | 27 | 0.6 | 2.2 | 28.8
A-55-80-MLCDRAT-0.011 | 333,280 | 360,355 | 13.7 | 1.6 | 700 | 36 | 0.7 | 2.5 | 24.7
A-55-80-Bach-0.019 | 336,938 | 364,174 | 14.0 | 1.7 | 706 | 35 | 0.7 | 2.4 | 25.3
A-50-80-MPLCOm2012-0.011 | 338,238 | 365,171 | 15.4 | 1.8 | 698 | 33 | 0.7 | 2.3 | 27.4
A-55-80-MPLCOm2012-0.01 | 341,753 | 368,990 | 15.1 | 1.8 | 702 | 34 | 0.7 | 2.4 | 26.6
A-50-80-MLCDRAT-0.011 | 341,894 | 369,425 | 14.0 | 1.7 | 711 | 36 | 0.7 | 2.5 | 25.9
A-55-80-20-20 | 343,972 | 370,941 | 16.1 | 1.9 | 662 | 32 | 0.7 | 2.5 | 31.6
A-50-80-Bach-0.019 | 345,891 | 373,605 | 14.2 | 1.7 | 718 | 36 | 0.7 | 2.5 | 26.5
A-55-80-Bach-0.018 | 352,513 | 380,640 | 14.3 | 1.7 | 725 | 36 | 0.8 | 2.5 | 26.6
A-55-80-MLCDRAT-0.01 | 360,405 | 389,145 | 13.6 | 1.6 | 733 | 37 | 0.8 | 2.5 | 26.6
A-50-80-Bach-0.018 | 363,441 | 392,125 | 14.6 | 1.7 | 738 | 37 | 0.8 | 2.5 | 28.1
A-50-80-MPLCOm2012-0.01 | 367,433 | 395,967 | 16.0 | 1.9 | 729 | 34 | 0.7 | 2.3 | 30.0
A-55-80-Bach-0.017 | 368,501 | 397,510 | 14.5 | 1.7 | 743 | 37 | 0.8 | 2.5 | 28.2
A-50-80-MLCDRAT-0.01 | 371,729 | 401,058 | 13.9 | 1.7 | 748 | 37 | 0.8 | 2.5 | 28.3
A-55-80-20-25 | 376,912 | 405,586 | 17.1 | 2.0 | 702 | 34 | 0.7 | 2.5 | 32.9
A-50-80-Bach-0.017 | 382,161 | 411,883 | 14.9 | 1.8 | 758 | 37 | 0.8 | 2.5 | 30.3
A-55-80-Bach-0.016 | 385,000 | 414,941 | 14.8 | 1.7 | 760 | 37 | 0.8 | 2.5 | 29.3
A-55-80-MLCDRAT-0.009 | 393,326 | 424,082 | 13.6 | 1.6 | 773 | 38 | 0.8 | 2.5 | 29.5
A-50-80-20-15 | 393,642 | 423,074 | 17.8 | 2.1 | 692 | 30 | 0.6 | 2.4 | 38.9
A-55-80-MPLCOm2012-0.008 | 395,223 | 425,500 | 15.7 | 1.8 | 761 | 36 | 0.7 | 2.4 | 30.1
A-50-80-MPLCOm2012-0.009 | 400,893 | 431,266 | 16.6 | 1.9 | 765 | 35 | 0.7 | 2.3 | 32.5
A-50-80-Bach-0.016 | 401,912 | 432,726 | 15.3 | 1.8 | 779 | 38 | 0.8 | 2.5 | 31.8
A-55-80-Bach-0.015 | 402,313 | 433,217 | 15.0 | 1.8 | 778 | 38 | 0.8 | 2.5 | 30.5
A-50-80-MLCDRAT-0.009 | 408,368 | 439,889 | 14.0 | 1.7 | 790 | 38 | 0.8 | 2.5 | 31.6
A-55-80-Bach-0.014 | 420,368 | 452,275 | 15.3 | 1.8 | 797 | 38 | 0.8 | 2.5 | 31.9
A-50-80-Bach-0.015 | 422,671 | 454,637 | 15.6 | 1.8 | 800 | 38 | 0.8 | 2.4 | 33.5
A-55-80-MLCDRAT-0.008 | 430,892 | 463,909 | 13.6 | 1.6 | 816 | 39 | 0.8 | 2.5 | 31.6
A-50-80-20-20 | 435,612 | 467,198 | 19.1 | 2.3 | 744 | 33 | 0.7 | 2.4 | 40.7
A-55-80-Bach-0.013 | 439,639 | 472,634 | 15.5 | 1.8 | 817 | 38 | 0.8 | 2.4 | 33.5
A-50-80-MPLCOm2012-0.008 | 439,765 | 472,285 | 17.1 | 2.0 | 805 | 35 | 0.7 | 2.3 | 35.6
A-50-80-Bach-0.014 | 444,572 | 477,710 | 15.9 | 1.9 | 823 | 38 | 0.8 | 2.4 | 35.2
A-50-80-MLCDRAT-0.008 | 451,693 | 485,766 | 14.1 | 1.7 | 840 | 39 | 0.8 | 2.4 | 34.4
A-55-80-Bach-0.012 | 460,155 | 494,271 | 15.8 | 1.8 | 838 | 39 | 0.8 | 2.5 | 34.8
A-50-80-Bach-0.013 | 468,214 | 502,658 | 16.3 | 1.9 | 847 | 38 | 0.8 | 2.4 | 37.3
A-50-80-20-25 | 470,506 | 503,852 | 20.5 | 2.4 | 784 | 34 | 0.7 | 2.4 | 42.0
A-55-80-MLCDRAT-0.007 | 474,378 | 509,969 | 13.7 | 1.6 | 865 | 40 | 0.8 | 2.5 | 34.2
A-55-80-Bach-0.011 | 482,190 | 517,565 | 16.0 | 1.9 | 861 | 39 | 0.8 | 2.4 | 36.2
A-50-80-MPLCOm2012-0.007 | 483,401 | 518,318 | 17.8 | 2.1 | 848 | 36 | 0.8 | 2.3 | 38.8
A-50-80-Bach-0.012 | 493,841 | 529,690 | 16.7 | 1.9 | 872 | 39 | 0.8 | 2.4 | 39.4
A-50-80-MLCDRAT-0.007 | 503,486 | 540,551 | 14.4 | 1.7 | 896 | 40 | 0.8 | 2.4 | 37.9
A-55-80-Bach-0.01 | 505,254 | 541,900 | 16.3 | 1.9 | 883 | 40 | 0.8 | 2.4 | 37.7
A-50-80-Bach-0.011 | 521,832 | 559,192 | 17.1 | 2.0 | 899 | 40 | 0.8 | 2.4 | 41.4
A-55-80-MLCDRAT-0.006 | 527,189 | 565,798 | 14.1 | 1.7 | 919 | 42 | 0.9 | 2.5 | 37.4
A-50-80-MPLCOm2012-0.006 | 531,812 | 569,342 | 18.3 | 2.1 | 894 | 37 | 0.8 | 2.3 | 42.3
A-50-80-Bach-0.01 | 551,363 | 590,337 | 17.4 | 2.0 | 928 | 40 | 0.8 | 2.4 | 43.6

* Strategies with at least 9.0 percent lung cancer mortality reduction and fewer than 600,000 LDCTs.

† Average of two models (MGH-HMS and University of Michigan).

Numbers are per a 100 000-person cohort followed from ages 45 to 90 years and are based on averaged estimates across the four models. The screening programs are labeled as follows: frequency (A–annual and B–biennial)–age start–age stop–lung cancer risk prediction model (MPLCOm2012, MLCDRAT, Bach)–risk threshold. The 2013 USPSTF-recommended (A-55-80-30-15) strategy and the six selected 20 pack-year strategies are shown in bold.

Abbreviations: avg.=average; LC=lung cancer; LDCT=low-dose computed tomography; MGH-HMS=Massachusetts General Hospital–Harvard Medical School; MLCDRAT=Lung Cancer Death Risk Assessment Tool–modified; MPLCOm2012=modified PLCOm2012 model; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 29 Screening Eligibility in the United States and Proportional Distribution of 100,000 LDCT Screens by Sex According to the 2015 National Health Interview Survey

Scenario | | Men | Women | Total
2013 USPSTF (A-55-80-30-15) | Number eligible | 4,691,054 | 3,414,939 | 8,095,274
2013 USPSTF (A-55-80-30-15) | Percentage eligible^*^ | 4.2% | 2.8% | 3.5%
2013 USPSTF (A-55-80-30-15) | Number of LDCTs | 57,546 | 42,454 | 100,000
2013 USPSTF (A-55-80-30-15) | Percentage of LDCTs | 57.5% | 42.5% | 100.0%
A-55-80-20-15 | Number eligible | 6,400,415 | 5,321,359 | 11,711,857
A-55-80-20-15 | Percentage eligible^*^ | 5.7% | 4.4% | 5.0%
A-55-80-20-15 | Number of LDCTs | 54,287 | 45,713 | 100,000
A-55-80-20-15 | Percentage of LDCTs | 54.3% | 45.7% | 100.0%
A-55-80-20-20 | Number eligible | 7,488,322 | 5,818,536 | 13,286,967
A-55-80-20-20 | Percentage eligible^*^ | 6.7% | 4.8% | 5.7%
A-55-80-20-20 | Number of LDCTs | 55,831 | 44,169 | 100,000
A-55-80-20-20 | Percentage of LDCTs | 55.8% | 44.2% | 100.0%
A-55-80-20-25 | Number eligible | 8,143,360 | 6,292,519 | 14,411,807
A-55-80-20-25 | Percentage eligible^*^ | 7.3% | 5.2% | 6.2%
A-55-80-20-25 | Number of LDCTs | 55,924 | 44,076 | 100,000
A-55-80-20-25 | Percentage of LDCTs | 55.9% | 44.1% | 100.0%
A-50-80-20-15 | Number eligible | 8,460,913 | 6,698,602 | 15,136,661
A-50-80-20-15 | Percentage eligible^*^ | 7.6% | 5.5% | 6.5%
A-50-80-20-15 | Number of LDCTs | 55,338 | 44,662 | 100,000
A-50-80-20-15 | Percentage of LDCTs | 55.3% | 44.7% | 100.0%
A-50-80-20-20 | Number eligible | 9,629,964 | 7,255,481 | 16,847,872
A-50-80-20-20 | Percentage eligible^*^ | 8.6% | 6.0% | 7.2%
A-50-80-20-20 | Number of LDCTs | 56,428 | 43,572 | 100,000
A-50-80-20-20 | Percentage of LDCTs | 56.4% | 43.6% | 100.0%
A-50-80-20-25 | Number eligible | 10,318,296 | 7,756,939 | 18,031,876
A-50-80-20-25 | Percentage eligible^*^ | 9.2% | 6.4% | 7.7%
A-50-80-20-25 | Number of LDCTs | 56,439 | 43,561 | 100,000
A-50-80-20-25 | Percentage of LDCTs | 56.4% | 43.6% | 100.0%

* Of adults ages 18+

Abbreviation: LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force.

Appendix C Table 30 Screening Eligibility in the United States and Proportional Distribution of 100,000 LDCT Screens by Race/Ethnicity According to the 2015 National Health Interview Survey

Scenario | | NHW | NHB | Hispanic | Asian | AI/AN | Total
2013 USPSTF (A-55-80-30-15) | Number eligible | 6,808,288 | 534,109 | 283,030 | 157,602 | 43,201 | 8,095,274
2013 USPSTF (A-55-80-30-15) | Percentage eligible^*^ | 4.5% | 1.9% | 0.8% | 1.2% | 2.5% | 3.5%
2013 USPSTF (A-55-80-30-15) | Number of LDCTs | 87,003 | 6,815 | 3,618 | 2,012 | 552 | 100,000
2013 USPSTF (A-55-80-30-15) | Percentage of LDCTs | 87.0% | 6.8% | 3.6% | 2.0% | 0.6% | 100%
A-55-80-20-15 | Number eligible | 9,449,171 | 952,962 | 463,140 | 221,459 | 63,832 | 11,711,857
A-55-80-20-15 | Percentage eligible^*^ | 6.2% | 3.4% | 1.3% | 1.6% | 3.6% | 5.0%
A-55-80-20-15 | Number of LDCTs | 84,730 | 8,548 | 4,162 | 1,988 | 573 | 100,000
A-55-80-20-15 | Percentage of LDCTs | 84.7% | 8.5% | 4.2% | 2.0% | 0.6% | 100%
A-55-80-20-20 | Number eligible | 10,685,654 | 1,028,862 | 558,708 | 237,762 | 63,832 | 13,286,967
A-55-80-20-20 | Percentage eligible^*^ | 7.0% | 3.7% | 1.5% | 1.8% | 3.6% | 5.7%
A-55-80-20-20 | Number of LDCTs | 84,960 | 8,192 | 4,448 | 1,892 | 508 | 100,000
A-55-80-20-20 | Percentage of LDCTs | 85.0% | 8.2% | 4.4% | 1.9% | 0.5% | 100%
A-55-80-20-25 | Number eligible | 11,555,772 | 1,082,273 | 610,168 | 254,066 | 69,298 | 14,411,807
A-55-80-20-25 | Percentage eligible^*^ | 7.6% | 3.9% | 1.7% | 1.9% | 3.9% | 6.2%
A-55-80-20-25 | Number of LDCTs | 85,139 | 7,977 | 4,500 | 1,874 | 510 | 100,000
A-55-80-20-25 | Percentage of LDCTs | 85.1% | 8.0% | 4.5% | 1.9% | 0.5% | 100%
A-50-80-20-15 | Number eligible | 12,135,850 | 1,104,761 | 599,141 | 254,066 | 115,496 | 15,136,661
A-50-80-20-15 | Percentage eligible^*^ | 8.0% | 3.9% | 1.6% | 1.9% | 6.6% | 6.5%
A-50-80-20-15 | Number of LDCTs | 85,416 | 7,780 | 4,207 | 1,784 | 813 | 100,000
A-50-80-20-15 | Percentage of LDCTs | 85.4% | 7.8% | 4.2% | 1.8% | 0.8% | 100%
A-50-80-20-20 | Number eligible | 13,418,128 | 1,191,905 | 713,088 | 270,370 | 115,496 | 16,847,872
A-50-80-20-20 | Percentage eligible^*^ | 8.8% | 4.2% | 1.9% | 2.0% | 6.6% | 7.2%
A-50-80-20-20 | Number of LDCTs | 85,429 | 7,582 | 4,537 | 1,717 | 735 | 100,000
A-50-80-20-20 | Percentage of LDCTs | 85.4% | 7.6% | 4.5% | 1.7% | 0.7% | 100%
A-50-80-20-25 | Number eligible | 14,318,776 | 1,245,316 | 771,899 | 286,673 | 120,963 | 18,031,876
A-50-80-20-25 | Percentage eligible^*^ | 9.4% | 4.4% | 2.1% | 2.1% | 6.9% | 7.7%
A-50-80-20-25 | Number of LDCTs | 85,531 | 7,434 | 4,602 | 1,710 | 722 | 100,000
A-50-80-20-25 | Percentage of LDCTs | 85.5% | 7.4% | 4.6% | 1.7% | 0.7% | 100%

* Of adults ages 18+

Abbreviations: AI/AN=American Indian and Alaska Native; LDCT=low-dose computed tomography; NHB=non-Hispanic black; NHW=non-Hispanic white; USPSTF=U.S. Preventive Services Task Force.