# Appendix B Supplemental Figures

Appendix B Figure 1 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men. Appendix C, Figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort men. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 850 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. For all models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. The 2013 USPSTF-recommended strategy is among the most efficient for 3 out of the 4 models (Models 1, 3 and 4).

Appendix B Figure 2 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women. The figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort women. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 800 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. For all models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. The 2013 USPSTF-recommended strategy is among the most efficient for 3 out of the 4 models (Models 1, 3 and 4).

Appendix B Figure 3 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs=versus.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men. The figure 1 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort men. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 12,000 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. For all models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. In this case, the 2013 USPSTF-recommended strategy is among the most efficient for one of the four models (Model 1).

Appendix B Figure 4 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women

Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs=versus.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women. The figure 1 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort women. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 10,000 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. For all models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. In this case, the 2013 USPSTF-recommended strategy is among the most efficient for one of the four models (Model 1).

Appendix B Figure 5 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1950 Birth Cohort

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1950 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1950 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 1200 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. For all models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. The 2013 USPSTF-recommended strategy is among the most efficient for all the four models.

Appendix B Figure 6 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1950 Birth Cohort

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1950 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1950 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening stopping age (75, 77, 80 years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 15,500 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. For all models, the most efficient strategies have stopping age of 80 years. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. In this case, the 2013 USPSTF-recommended strategy is among the most efficient for three of the four models (Models 1, 3 and 4).

Appendix B Figure 7 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort (by Frequency and Age at Starting Screening)

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at starting screening (45, 50, 55). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening starting age (45, 50, 55 years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 800 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. For all models, the most efficient strategies have starting age of 50 or 55 years, except for high levels of screening (large number of LDCTs). Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models.

Appendix B Figure 8 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort (by Frequency and Pack-Years Criterion)

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the pack-years criterion (20, 25, 30, 40). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and the minimum pack-year criterion (20, 25, 30, 40 pack-years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 800 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. The number of LDCTs is higher for strategies with lower pack-year criterion. For 3 of the 4 models (Models 1, 3 and 4), there are annual screening efficient strategies with 20, 25, 30, 40 pack-years. For the other model, Model 2, most annual efficient strategies have 20 or 25 pack-years.

Appendix B Figure 9 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort (by Frequency and Years Since Quitting)

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the years since quitting (10, 15, 20, 25). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of lung cancer deaths averted per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and the maximum years since quitting criterion (10, 15, 20, 25 years). Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 800 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. There is no clear pattern observed for strategies by maximum years since quitting criterion, but few efficient strategies have maximum years since quitting of 10 years.

Appendix B Figure 10 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort (by Frequency and Age at Starting Screening)

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at starting screening (45, 50, 55). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and screening starting age (45, 50, 55 years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 10,000 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. Strategies with lower starting age result in more LDCT screens. For 3 of the 4 models (Models 1, 3 and 4), the most efficient strategies have starting age of 50 or 55. For the other model, model 2, the most efficient strategies have starting age of 45.

Appendix B Figure 11 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort (by Frequency and Pack-Years Criterion)

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the pack-years criterion (20, 25, 30, 40). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and minimum pack-year criterion (20, 25, 30, 40 pack-years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 10,000 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. Strategies with lower starting age result in more LDCT screens. For the 4 models, the most efficient strategies have 20 or 25 minimum pack-years, except for those with the lowest number of LDCT screens.

Appendix B Figure 12 Number of LDCT Screening Examinations vs. LYG in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort (by Frequency and Years Since Quitting)

Note: Each point represents a different scenario, and the line represents the estimated efficient frontier per model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the years since quitting (10, 15, 20, 25). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. Life Years Gained in Each of the 289 Risk Factor–Based Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure 1 shows the number of low-dose CT screens versus the number of life years gained per 100,000 individuals relative to no screening for each of the risk factor–based strategies analyzed for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual, biennial) and maximum years since quitting (10, 15, 20, 25 years). Number of LDCTs range from 0 to 600,000. Life years gained range from 0 to 10,000 per 100,000. The most efficient strategies are those resulting in the most life years gained averted for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. Strategies with lower starting age result in more LDCT screens. For the 4 models, the most efficient strategies have 20 or 25 minimum pack-years, except for those with the lowest number of LDCT screens. There is no clear pattern observed for strategies by maximum years since quitting criterion, but few efficient strategies have maximum years since quitting of 10 years.

Appendix B Figure 13 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men

Note: Risk factor–based screening scenarios (n=288) are represented with triangle points and risk model–based screening scenarios (n=804) by round points. The line represents the estimated overall efficient frontier per model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men. The figure shows the simulated number of LDCT screens and the lung cancer deaths averted per 100,000 for all risk factor–based and risk model–based screening strategies for the 1960 birth-cohort men. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and by type of eligibility criteria (risk factor–based or risk model–based). Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 1,100 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. The figure shows that across all CISNET models, risk model–based strategies result in larger numbers of lung cancer deaths averted for a given number of LDCT screens than risk factor–based strategies. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. Like other risk factor–based strategies, the 2013 USPSTF-recommended strategy is not among the most efficient for any of the CISNET models.

Appendix B Figure 14 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Factor–Based and Risk Model—Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women

Note: Risk factor–based screening scenarios (n=288) are represented with triangle points and risk model–based screening scenarios (n=804) by round points. The line represents the estimated overall efficient frontier per model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women. The figure shows the simulated number of LDCT screens and the lung cancer deaths averted per 100,000 for all risk factor–based and risk model–based screening strategies for the 1960 birth-cohort women. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and by type of eligibility criteria (risk factor–based or risk model–based). Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 1,100 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. The figure shows that across all CISNET models, risk model–based strategies result in larger numbers of lung cancer deaths averted for a given number of LDCT screens than risk factor–based strategies. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower lung cancer deaths averted. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more deaths averted. While the absolute number of deaths averted vary by model, the general patterns are consistent across CISNET models. Like other risk factor–based strategies, the 2013 USPSTF-recommended strategy is not among the most efficient for any of the CISNET models.

Appendix B Figure 15 Number of LDCT Screening Examinations vs. the LYG in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men

Note: Risk factor–based screening scenarios (n=288) are represented with triangle points and risk model–based screening scenarios (n=804) by round points. The line represents the estimated overall efficient frontier per model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Life Years Gained in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Men. The figure shows the simulated number of LDCT screens and the life years gained per 100,000 for all risk factor–based and risk model–based screening strategies for the 1960 birth-cohort men. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and by type of eligibility criteria (risk factor–based or risk model–based). Number of LDCTs range from 0 to 800,000. Life years gained range from 0 to 12,500 per 100,000. The most efficient strategies are those resulting in the most life years gained for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. The figure shows that across all CISNET models, risk model–based strategies tend to result in slightly larger numbers of life years gained for a given number of LDCT screens than risk factor–based strategies. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. Like other risk factor–based strategies, the 2013 USPSTF-recommended strategy is not among the most efficient for any of the CISNET models.

Appendix B Figure 16 Number of LDCT Screening Examinations vs. the LYG in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women

Note: Risk factor–based screening scenarios (n=288) are represented with triangle points and risk model–based screening scenarios (n=804) by round points. The line represents the estimated overall efficient frontier per model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Life Years Gained in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort Women. The figure shows the simulated number of LDCT screens and the life years gained per 100,000 for all risk factor–based and risk model–based screening strategies for the 1960 birth-cohort women. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and by type of eligibility criteria (risk factor–based or risk model–based). Number of LDCTs range from 0 to 800,000. Life years gained range from 0 to 12,000 per 100,000. The most efficient strategies are those resulting in the most life years gained for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. The figure shows that across all CISNET models, risk model–based strategies tend to result in slightly larger numbers of life years gained for a given number of LDCT screens than risk factor–based strategies. Biennial strategies are concentrated on the lower/left side of each panel because they result in fewer LDCT screens and lower life years gained. Annual strategies tend to be on the upper/right side because they result in more LDCT screens and generally more life years gained. While the absolute number of life years gained vary by model, the general patterns are consistent across CISNET models. Like other risk factor–based strategies, the 2013 USPSTF-recommended strategy is not among the most efficient for any of the CISNET models.

Appendix B Figure 17 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort

Note: Each point represents a different risk model–based screening scenario, and the line represents the estimated efficient frontier per model. Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the risk model (Bach, MLCDRAT, MPLCOm2012). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted in Each of the Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure shows the simulated number of LDCT screens and the lung cancer deaths averted per 100,000 for all risk model–based screening strategies for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and risk-prediction model (MPLCOm2012, Bach, MLCDRAT). Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 1,100 per 100,000. The most efficient strategies are those resulting in the most lung cancer deaths averted for a given level of LDCT screens. The figure shows that the most efficient strategies include scenarios with either risk-prediction model across LDCT screen levels, consistently for all CISNET simulation models.

Appendix B Figure 18 Number of LDCT Screening Examinations vs. the LYG in Each of the Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort

Note: Each point represents a different risk model–based screening scenario, and the line represents the estimated efficient frontier per model. Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the risk model (Bach, MLCDRAT, MPLCOm2012). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted.

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Life Years Gained in Each of the Risk Factor–Based and Risk Model–Based Eligibility Strategies Evaluated by the Four CISNET Models—1960 Birth Cohort. The figure shows the simulated number of LDCT screens and the life years gained per 100,000 for all risk model–based screening strategies for the 1960 birth-cohort. There are four panels that correspond to each of the four CISNET models. Scenarios are identified by screening frequency (annual or biennial) and risk-prediction model (MPLCOm2012, Bach, MLCDRAT). Number of LDCTs range from 0 to 800,000. Life years gained range from 0 to 12,500 per 100,000. The most efficient strategies are those resulting in the most life years gained for a given level of LDCT screens. The patterns are similar but show less variability than when considering lung cancer deaths averted instead of life years gained. The figure shows that the most efficient strategies include scenarios with either risk-prediction model across LDCT screen levels, consistently for all CISNET simulation models.

Appendix B Figure 19 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Men

Note: Each point represents a different scenario, and the curve represents the estimated efficient frontier for the average model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted. The panels show all 288 risk factor–based strategies but highlight (solid color points) those identified as consensus efficient. The horizontal line divides strategies with less than or at least a 9 percent lung cancer mortality reduction. The shaded region includes those scenarios with at least a 9 percent lung cancer mortality reduction (listed in Appendix C Tables 5 and 6).

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panels) and LYG (Right Panels) in Risk Factor–Based Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Men. The figure shows the average, across the four CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left panel) and LYG (right panel) for all risk factor–based strategies, highlighting the consensus-efficient scenarios. The consensus-efficient scenarios are those resulting in the most lung cancer deaths averted or life years gained for a given level of LDCT screens. Annual and biennial strategies are also highlighted. Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 600 per 100,000 and life years gained from 0 to 8,000. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of each panel, whereas annual consensus-efficient scenarios are located on the upper right side of each panel. The 2013 USPSTF-recommended scenario is consensus-efficient, thus it results in almost the most lung cancer deaths averted for their corresponding level of screening.

Appendix B Figure 20 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Women

Note: Each point represents a different scenario, and the curve represents the estimated efficient frontier for the average model. Strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). The colors differentiate strategies by frequency (annual–A vs. biennial–B) and the age at stopping screening (75, 77, 80 years). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted. The panels show all 288 risk factor–based strategies but highlight (solid color points) those identified as consensus efficient. The horizontal line divides strategies with less than or at least a 9 percent lung cancer mortality reduction. The shaded region includes those scenarios with at least a 9 percent lung cancer mortality reduction (listed in Appendix C Tables 7 and 8).

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panels) and LYG (Right Panels) in Risk Factor–Based Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Women. The figure shows the average, across the four CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left panel) and LYG (right panel) for all risk factor–based strategies, highlighting the consensus-efficient scenarios. The consensus-efficient scenarios are those resulting in almost most lung cancer deaths averted or life years gained for a given level of LDCT screens. Annual and biennial strategies are also highlighted. Number of LDCTs range from 0 to 600,000. Deaths averted range from 0 to 600 per 100,000 and life years gained from 0 to 8,000. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of each panel, whereas annual consensus-efficient scenarios are located on the upper right side of each results in almost the most lung cancer deaths averted for their corresponding level of screening.

Appendix B Figure 21 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based and Risk Model–Based Eligibility Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Men

Note: Risk factor–based scenarios are represented with triangle points and risk model–based screening scenarios by round points. The curve represents the estimated overall efficient frontier for the average model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted. The panels show all considered strategies but highlight (solid color points) those identified as consensus efficient. The vertical line represents 600,000 LDCT screens, and the horizontal line divides strategies with less than or at least a 9 percent lung cancer mortality reduction. The shaded region includes those scenarios with fewer than 600,000 LDCT screens per 100,000 population and providing at least a 9 percent lung cancer mortality reduction (listed in Appendix C Tables 13 and 14).

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based and Risk Model–Based Eligibility Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Men. The figure shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for all risk factor–based and risk model–based screening scenarios, highlighting the 267 consensus-efficient scenarios and the 2013 USPSTF-recommended scenario (A-55-80-30-15). The consensus-efficient scenarios are those resulting in almost the most lung cancer deaths averted or life years gained for a given level of LDCT screens. Annual and biennial strategies are also highlighted. Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 800 per 100,000 and life years gained from 0 to 10,000. Most consensus-efficient strategies are risk model–based. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of each panel, whereas annual consensus-efficient scenarios are located on the upper right side of each panel. The 2013 USPSTF-recommended does not result in the most lung cancer deaths averted nor life years gained for its corresponding level of screening, and is thus not consensus-efficient for either metric, although it is closer to the most efficient for life-years gained.

Appendix B Figure 22 Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based and Risk Model–Based Eligibility Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Women

Note: Risk factor–based scenarios are represented with triangle points and risk model–based screening scenarios by round points. The curve represents the estimated overall efficient frontier for the average model. Risk factor–based strategies vary by age at starting and stopping screening, frequency, pack-years criterion, and years since quitting (Table 2). Risk model–based strategies vary by risk model, risk thresholds, and frequency (Table 3). The colors differentiate strategies by frequency (annual–A vs. biennial–B). The no-screening (black dot) and the 2013 USPSTF-recommended (“⊗” mark) scenarios are highlighted. The panels show all considered strategies but highlight (solid color points) those identified as consensus efficient. The vertical line represents 600,000 LDCT screens, and the horizontal line divides strategies with less than or at least a 9 percent lung cancer mortality reduction. The shaded region includes those scenarios with fewer than 600,000 LDCT screens per 100,000 population and providing at least a 9 percent lung cancer mortality reduction (listed in Appendix C Tables 15 and 16).

Abbreviations: CISNET=Cancer Intervention and Surveillance Modeling Network; LDCT=low-dose computed tomography; LYG=life-years gained; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Number of LDCT Screening Examinations vs. the Number of Lung Cancer Deaths Averted (Left Panel) and LYG (Right Panel) in Risk Factor–Based and Risk Model–Based Eligibility Strategies—Average Values Across the Four CISNET Models—1960 Birth Cohort Women. The figure shows the average, across CISNET models, number of LDCT screens vs. the number of lung cancer deaths averted (left) and LYG (right) for all risk factor–based and risk model–based screening scenarios, highlighting the 267 consensus-efficient scenarios and the 2013 USPSTF-recommended scenario (A-55-80-30-15). The consensus-efficient scenarios are those resulting in almost the most lung cancer deaths averted or life years gained for a given level of LDCT screens. Annual and biennial strategies are also highlighted. Number of LDCTs range from 0 to 800,000. Deaths averted range from 0 to 800 per 100,000 and life years gained from 0 to 10,000. Most consensus-efficient strategies are risk model–based. Consensus-efficient biennial scenarios result in fewer LDCT screens, lung cancer deaths averted, and LYG than annual strategies and thus are located on the lower left side of each panel, whereas annual consensus-efficient scenarios are located on the upper right side of each panel. The 2013 USPSTF-recommended does not result in the most lung cancer deaths averted nor life years gained for its corresponding level of screening, and is thus not consensus-efficient for either metric, although it is closer to the most efficient for life-years gained.