# Appendix A CISNET Lung Model Descriptions

## Model 1 Erasmus-MISCAN

The Erasmus-Microsimulation Screening Analysis (MISCAN)-Lung Model is a microsimulation model that simulates a population of individual life histories. For each individual, a smoking history (including never smoking) is generated using the Smoking History Generator (SHG).^1^ Lung cancer is modeled through a multistep procedure. Once a person’s age at death from causes other than lung cancer is generated by the SHG, which is influenced by the person’s smoking history, the integrated Two-Stage Clonal Expansion (TSCE) model is used to determine whether lung cancer develops in that individual.^2,^ ^3^ MISCAN-Lung distinguishes four histological types of lung cancer: squamous cell carcinoma, adenocarcinoma, other non-small cell carcinoma, and small-cell carcinoma.

Once lung cancer has developed, it progresses to more advanced preclinical stages until it is detected. Lung cancers can be detected either clinically (due to symptoms) or by screening. The incidence of clinically detected lung cancers depends on the preclinical duration and the probability of clinical detection, which both vary by cancer stage and histology (and sex for the preclinical durations). Data from the National Lung Screening Trial (NLST) and the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial (PLCO) were used to calibrate MISCAN-Lung, from which information on the natural history and screen detectability of lung cancer was derived.^4–7^ Through incorporating information on the preclinical duration, probability of clinical detection, and screen detectability of lung cancer, as well as a person’s death from causes other than lung cancer, MISCAN-Lung can account for the effects of lead time and overdiagnosis.

If screening does not occur, lung cancers can only be clinically detected. If persons die of lung cancer before dying from other causes, their ages of death are adjusted accordingly. Upon activating the screening component, preclinical lung cancers may be detected by screening, which may cure patients, allowing them to resume their normal (cancer-free) life history. The probability of cure differs by the stage of cancer at detection and was based on data from the NLST. Upon clinical or screen detection (if no curation occurs) of lung cancer, the patient is assigned a histological type-, stage- and sex-specific survival time, which follows a piecewise uniform distribution.

In the decision analysis, the model evaluated different properties of the screening test (such as sensitivity), and various screening policies (e.g., starting/stopping age, screening frequency, smoking eligibility criteria) can be specified. For each of these properties and screening policies, the model can evaluate various simulated events in the presence and absence of screening, such as the mortality due to lung cancer and other causes, life-years gained, and overdiagnosis.

MISCAN-Lung has previously been used to evaluate the effect of tobacco control on U.S. lung cancer mortality.^8^ MISCAN-Lung contributed to the analyses of the CISNET Lung Group, which were used to inform the U.S. Preventive Services Task Force (USPSTF) for their 2013 recommendations for lung cancer screening.^4,^ ^9–11^ The model was used to evaluate the cost-effectiveness of lung cancer screening in Ontario, Canada.^12^ The model was also used in recent comparative modeling studies by the CISNET Lung Group: 1) evaluation of the effects of risk-stratified screening^13^ and 2) analysis of the cost-effectiveness of lung cancer screening in the United States.^14^

## Model 2 MGH-HMS

The Massachusetts General Hospital–Harvard Medical School (MGH-HMS) group’s model is a comprehensive state-transition microsimulation model that simulates a patient’s lung cancer development, progression, detection, followup, treatment, and survival.^9,^ ^10,^ ^15–22^ The MGH-HMS model was originally developed to evaluate the clinical effectiveness and cost-effectiveness of low-dose computed tomography (LDCT) screening for lung cancer.^17,^ ^18,^ ^20^ The model has been extended to estimate the effect of reduced tobacco smoking on lung cancer mortality in the United States,^21^ the number of radiation-induced cancers from lung cancer screening,^9,^ ^16^ cost-effectiveness of followup of incidentally detected pulmonary nodules,^15^ and effectiveness of treatment strategies for stage IA/IB non-small cell carcinoma patients who were nonoperative candidates.^22^ The model was used in the 2013 CISNET lung cancer decision analysis for the USPSTF.^4,^ ^9,^ ^10^

The MGH-HMS model is a Monte Carlo microsimulation model coded in C++. The model initially populates with disease-free persons who then go through different health states according to monthly transition probabilities. In each monthly cycle, an individual may develop lung cancer, have an existing cancer grow, or develop symptoms or metastases. The risk of lung cancer is related to persons’ smoking history, which is updated monthly (the model also includes cancers in nonsmokers). Smoking exposure history is supplied by the SHG. Lung cancers can be detected by an evaluation of symptoms through incidental imaging or by LDCT screening (with different tumor behavior for screen-detected cases). Persons with suspected lung cancer receive diagnostic and staging tests and then may undergo treatment. The screening module can be turned on and off to allow for analyses of treatment effectiveness for screen-detected vs. nonscreen-detected cases.

Each simulated individual in the MGH-HMS model can develop up to three cancers from any of five lung cancer cell types (adenocarcinoma, large cell, squamous cell, small cell, and other non-small cell carcinoma). For each cell type, the monthly probability of cancer development is described by a logistic equation with seven natural history parameters: a type-specific intercept, type-specific coefficients for age, age squared, years of cigarette exposure (pack-years), an interaction term between pack-years and age squared, the average number of cigarettes smoked per day (cigarettes per day), and the years since quitting smoking. The MGH-HMS model also explicitly simulates the followup schedule of small incidentally detected or screen-detected lung nodules, which allows the model to examine the effectiveness of followup recommendations by the Fleischner Society or the Lung Imaging Reporting and Data System (Lung-RADS). In the MGH-HMS model, the levels of simulated disease characteristics allow the staging of patients according to the Tumor Node Metastasis classification,^23^ permitting the model to simulate the most up-to-date treatment options according to current clinical practices. The natural history parameters related to unobservable events (i.e., the initiation of the first cancer cell) were estimated by calibrating the model using Surveillance, Epidemiology, and End Results (SEER) registry data (cancer incidence by cell type, stage distribution at diagnosis, and stage-specific survival), published cohort studies, and clinical trial data. The details of model calibration and validation of the original natural history parameters have been described in our previous publications.^4,^ ^24^

The MGH-HMS model’s flexibility allows for evaluation of multiple components in a lung cancer screening program, including screening eligibility, smoking cessation, followup, staging, and treatment. Improvements in any of these components may affect patient outcomes and may influence the effectiveness of interventions in other areas. The MGH-HMS model does not rely on data from a single trial to inform the parameter estimates but rather incorporates data from multiple sources and can incorporate new data as they emerge. The MGH-HMS model can thus be used to evaluate screening in populations not included in ongoing trials and can address the “moving target” problem of improved test performance or treatment effectiveness.

## Model 3 Stanford

The Lung Cancer Outcomes Simulator (LCOS) Model (Stanford University) is based on a natural history model of lung cancer that assumes exponential growth for the primary tumor and growth of metastasis proportional to the primary tumor growth.^4,^ ^25^ The natural history model simulates the individual’s tumor growth in the absence of any intervention, based on sex and histologic subtype, providing outcomes such as tumor volume doubling time, time for onset of metastasis, tumor size at clinical detection, and survival time. The parameters of the natural history model are estimated using SEER survival data.

In the natural history model, the primary tumor grows exponentially with growth rate r, and its corresponding tumor volume doubling time is given as (log2)/r. When the tumor reaches a certain size (Vp), it prompts symptoms that lead to a clinical detection of the primary tumor. The tumor volume and the growth rate parameter are modeled as a bivariate log-normal distribution. Fatal metastases start growing at a certain time, and we assume that the volume of the primary tumor at this time (Vc) is a threshold for cure (cure threshold) so that only if the primary tumor is detected and treated earlier than this point is the patient cured. The metastatic burden grows proportionally to the primary tumor size with fraction “f” until it reaches a maximum burden size (BD). The time at which BD is reached is a survival time if the primary tumor is not detected and treated before reaching the cure threshold. If this metastatic burden grows to a certain size (c1BD, where 0<c1<1), it becomes an observable metastasis; thus, if detection (either clinical or screen detection) occurs earlier than this point, the tumor is staged as early stage. Otherwise, the tumor is staged as advanced. When the metastatic burden grows to a certain size (c2BD, where 0<c2<1), it becomes clinically symptomatic; hence, detection is due to either the primary tumor or metastasis, depending on which becomes symptomatic first.

The LCOS superimposes a specific screening intervention to each individual and estimates individual-level outcomes, which can be aggregated for evaluating population-level outcomes. Key inputs for the LCOS include sex, individual-level smoking history (e.g., pack-years and age for starting/quitting smoking), and age of entry to the screening program. The LCOS uses the TSCE model to predict annual hazards for lung cancer incidence in the absence of screening given smoking history, sex, and age.^3^ The parameters of the TSCE model were estimated based on data from Nurses’ Health Study (NHS)/Health Professionals’ Followup Study (HPFS) with further adjustments.^26^

For each lung cancer, a histologic subtype (adenocarcinoma, squamous, large cell, or small cell) is assigned by sampling from the observed proportions from SEER data. The lung cancer cases with indeterminate diagnosis follow the Lung-RADS guidelines,^4^ which are explicitly incorporated in the LCOS.^26^ The LCOS compares the performance of the screening program of interest against the no-screen scenario estimating the benefit of screening. It can estimate sex-specific benefits and harms of screening strategies with various starting and stopping screening ages, smoking exposure levels, screening frequencies, and followup protocols. Outcome measures include lung cancer deaths avoided, all-cause and lung cancer–specific mortality reduction, number of detected cases by mode of detection, number of screening examinations, number of false-positive results, and number of overdiagnosed cases, among others.

## Model 4 University of Michigan

The University of Michigan Lung Cancer Screening Model is a combination of a multistage carcinogenesis model and a discrete-state microsimulation model. The model was developed to evaluate the effect of screening on lung cancer incidence and mortality, survival outcomes, overdiagnosis, and quality of life. This model consists of two components: natural history and screening. It was used for the 2013 USPSTF lung cancer screening decision analyses^4,^ ^9^ but has been updated considerably to simplify its use and enhance its applicability. The model was recently used to assess the cost-effectiveness of LDCT in the United States^14^ and the effect of risk-based screening strategies in collaboration with the other CISNET Lung groups.^13^

The natural history component simulates individual lung cancer–oriented life events in the absence of screening given the individual’s smoking history. The age at clinical detection of lung cancer (dose-response) is simulated through a TSCE model.^2,^ ^3^ The TSCE model assumes that two mutation (rate-limiting) events are required for the initiation of premalignant lung tumors, and it explicitly models the dynamics of premalignant and malignant tumors. The TSCE model was fitted to lung cancer incidence in the NHS and the HPFS using a likelihood-based approach. If an individual develops clinically diagnosed lung cancer, the natural history model also simulates the age at lung cancer onset, histology, stage at diagnosis, preclinical sojourn time for each stage, and age at lung cancer death. Lung cancer histology is classified into four main groups: small cell, adenocarcinoma, squamous, and other. Histology is simulated using a multinomial logistic regression accounting for sex, age, and smoking exposure model based on the PLCO. Preclinical sojourn times for each stage follow a Weibull distribution with shape and scale parameters depending on sex, stage, and histology.^5^ The preclinical sojourn times are simulated for all stages for each clinically diagnosed lung cancer case and used in the screening component to model the effect of screening. Lung cancer–specific survival time conditioned on sex, age at diagnosis, histology, and stage are estimated by using cure models with lognormal survival distributions, which were fitted to lung cancer survival data in SEER 18.

The outputs from the natural history component serve as inputs for the screening component to simulate the effect of screening on lung cancer incidence, stage, and survival. The model uses sensitivity and specificity rates to simulate screening results: true positive, false positive, or negative. Sensitivity estimates were obtained from ten Haaf et al^5^ and vary by screening round, lung cancer histology, and stage. These estimates, originally based on NLST, were adjusted to conform to Lung-RADS criteria by multiplying them by a scaling factor, given by the ratio of the overall sensitivity from Lung-RADS over that from NLST.^27^ Specificity rates by screening round were also based on a retrospective analysis of NLST outcomes using the Lung-RADS criteria.^27^

The model simulates additional screening outcomes such as the number of followup tests and potential complications based on NLST rates.^6,^ ^28^ The rates of specificity and sensitivity for screening simulation were chosen based on other published literature.^5,^ ^6,^ ^28^ For true-positive cases, lung cancer–specific survival time and stage burden were updated given the stage and age at diagnosis.

A version of this model using an alternative dose-response model (Bach’s lung cancer risk model^29^) was recently used to evaluate the preference-sensitivity of LDCT at different levels of underlying risk.^30^

## References

1 Jeon J, Meza R, Krapcho M, . Chapter 5: actual and counterfactual smoking prevalence rates in the U.S. population via microsimulation. Risk Anal. 2012 Jul;32(Suppl 1):S51–68. doi: 10.1111/j.1539-6924.2011.01775.x. PMID: 22882892.22882892
2 Hazelton WD, Jeon J, Meza R, . Chapter 8: the FHCRC lung cancer model. Risk Anal. 2012 Jul;32(Suppl 1):S99–S116. doi: 10.1111/j.1539-6924.2011.01681.x. PMID: 22882896.22882896
3 Meza R, Hazelton WD, Colditz GA, . Analysis of lung cancer incidence in the Nurses’ Health and the Health Professionals’ Follow-Up Studies using a multistage carcinogenesis model. Cancer Causes Control. 2008 Apr;19(3):317–28. doi: 10.1007/s10552-007-9094-5. PMID: 18058248.18058248
4 Meza R, ten Haaf K, Kong CY, . Comparative analysis of 5 lung cancer natural history and screening models that reproduce outcomes of the NLST and PLCO trials. Cancer. 2014 Jun 1;120(11):1713–24. doi: 10.1002/cncr.28623. PMID: 24577803.24577803
5 ten Haaf K, van Rosmalen J, de Koning HJ. Lung cancer detectability by test, histology, stage, and gender: estimates from the NLST and the PLCO trials. Cancer Epidemiol Biomarkers Prev. 2015 Jan;24(1):154–61. doi: 10.1158/1055-9965.epi-14-0745. PMID: 25312998.25312998
6 National Lung Screening Trial Research Team, Aberle DR, Adams AM, . Reduced lung-cancer mortality with low-dose computed tomographic screening. N Engl J Med. 2011 Aug 4;365(5):395–409. doi: 10.1056/NEJMoa1102873. PMID: 21714641.21714641
7 Oken MM, Hocking WG, Kvale PA, . Screening by chest radiograph and lung cancer mortality: the Prostate, Lung, Colorectal, and Ovarian (PLCO) randomized trial. JAMA. 2011 Nov 2;306(17):1865–73. doi: 10.1001/jama.2011.1591. PMID: 22031728.22031728
8 Schultz FW, Boer R, de Koning HJ. Chapter 7: description of MISCAN-lung, the Erasmus MC Lung Cancer microsimulation model for evaluating cancer control interventions. Risk Anal. 2012 Jul;32(Suppl 1):S85–98. doi: 10.1111/j.1539-6924.2011.01752.x. PMID: 22882895.22882895
9 de Koning HJ, Meza R, Plevritis SK, . Benefits and harms of computed tomography lung cancer screening strategies: a comparative modeling study for the U.S. Preventive Services Task Force. Ann Intern Med. 2014 Mar 4;160(5):311–20. doi: 10.7326/M13-2316. PMID: 24379002.24379002
10 McMahon PM, Meza R, Plevritis SK, . Comparing benefits from many possible computed tomography lung cancer screening programs: extrapolating from the National Lung Screening Trial using comparative modeling. PLoS One. 2014;9(6):e99978. doi: 10.1371/journal.pone.0099978. PMID: 24979231.24979231
11 Moyer VA, U. S. Preventive Services Task Force. Screening for lung cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014 Mar 4;160(5):330–8. doi: 10.7326/M13-2771. PMID: 24378917.24378917
12 ten Haaf K, Tammemagi MC, Bondy SJ, . Performance and cost-effectiveness of computed tomography lung cancer screening scenarios in a population-based setting: a microsimulation modeling analysis in Ontario, Canada. PLoS Med. 2017 Feb;14(2):e1002225. doi: 10.1371/journal.pmed.1002225. PMID: 28170394.28170394
13 Ten Haaf K, Bastani M, Cao P, . A comparative modeling analysis of risk-based lung cancer screening strategies. J Natl Cancer Inst. 2019doi: 10.1093/jnci/djz164.
14 Criss SD, Cao P, Bastani M, . Cost-effectiveness analysis of lung cancer screening in the United States: a comparative modeling study. Ann Intern Med. 2019 Nov 5doi: 10.7326/m19-0322. PMID: 31683314.31683314
15 Goehler A, McMahon PM, Lumish HS, . Cost-effectiveness of follow-up of pulmonary nodules incidentally detected on cardiac computed tomographic angiography in patients with suspected coronary artery disease. Circulation. 2014 Aug 19;130(8):668–75. doi: 10.1161/circulationaha.113.007306. PMID: 25015342.25015342
16 Kong CY, Lee JM, McMahon PM, . Using radiation risk models in cancer screening simulations: important assumptions and effects on outcome projections. Radiology. 2012 Mar;262(3):977–84. doi: 10.1148/radiol.11110352. PMID: 22357897.22357897
17 McMahon PM, Kong CY, Bouzan C, . Cost-effectiveness of computed tomography screening for lung cancer in the United States. J Thorac Oncol. 2011 Nov;6(11):1841–8. doi: 10.1097/JTO.0b013e31822e59b3. PMID: 21892105.21892105
18 McMahon PM, Kong CY, Johnson BE, . Estimating long-term effectiveness of lung cancer screening in the Mayo CT screening study. Radiology. 2008 Jul;248(1):278–87. doi: 10.1148/radiol.2481071446. PMID: 18458247.18458247
19 McMahon PM, Kong CY, Johnson BE, . Chapter 9: the MGH-HMS lung cancer policy model: tobacco control versus screening. Risk Anal. 2012 Jul;32(Suppl 1):S117–24. doi: 10.1111/j.1539-6924.2011.01652.x. PMID: 22882882.22882882
20 McMahon PM, Kong CY, Weinstein MC, . Adopting helical CT screening for lung cancer: potential health consequences during a 15-year period. Cancer. 2008 Dec 15;113(12):3440–9. doi: 10.1002/cncr.23962. PMID: 18988293.18988293
21 Moolgavkar SH, Holford TR, Levy DT, . Impact of reduced tobacco smoking on lung cancer mortality in the United States during 1975–2000. J Natl Cancer Inst. 2012 Apr 4;104(7):541–8. doi: 10.1093/jnci/djs136. PMID: 22423009.22423009
22 Tramontano AC, Sheehan DF, McMahon PM, . Evaluating the impacts of screening and smoking cessation programmes on lung cancer in a high-burden region of the USA: a simulation modelling study. BMJ Open. 2016 Feb 29;6(2):e010227. doi: 10.1136/bmjopen-2015-010227. PMID: 26928026.26928026
23 Detterbeck FC, Boffa DJ, Kim AW, . The eighth edition lung cancer stage classification. Chest. 2017 Jan;151(1):193–203. doi: 10.1016/j.chest.2016.10.010. PMID: 27780786.27780786
24 Kong CY, McMahon PM, Gazelle GS. Calibration of disease simulation model using an engineering approach. Value Health. 2009 Jun;12(4):521–9. doi: 10.1111/j.1524-4733.2008.00484.x. PMID: 19900254.19900254
25 Lin RS, Plevritis SK. Comparing the benefits of screening for breast cancer and lung cancer using a novel natural history model. Cancer Causes Control. 2012 Jan;23(1):175–85. doi: 10.1007/s10552-011-9866-9. PMID: 22116537.22116537
26 Han SS, Erdogan SA, Toumazis I, . Evaluating the impact of varied compliance to lung cancer screening recommendations using a microsimulation model. Cancer Causes Control. 2017 Sep;28(9):947–58. doi: 10.1007/s10552-017-0907-x. PMID: 28702814.28702814
27 Pinsky PF, Gierada DS, Black W, . Performance of Lung-RADS in the National Lung Screening Trial: a retrospective assessment. Ann Intern Med. 2015 Apr 7;162(7):485–91. doi: 10.7326/m14-2086. PMID: 25664444.25664444
28 Aberle DR, DeMello S, Berg CD, . Results of the two incidence screenings in the National Lung Screening Trial. N Engl J Med. 2013 Sep 5;369(10):920–31. doi: 10.1056/NEJMoa1208962. PMID: 24004119.24004119
29 Bach PB, Kattan MW, Thornquist MD, . Variations in lung cancer risk among smokers. J Natl Cancer Inst. 2003 Mar 19;95(6):470–8. PMID: 12644540.12644540
30 Caverly TJ, Cao P, Hayward RA, . Identifying patients for whom lung cancer screening is preference-sensitive: a microsimulation study. Ann Intern Med. 2018 Jul 3;169(1):1–9. doi: 10.7326/m17-2561. PMID: 29809244.29809244