# References

1 Moyer VA. Screening for lung cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014 Mar 04;160(5):330–8. doi: 10.7326/m13-2771. PMID: 24378917.24378917
2 Travis WD, Brambilla E, Nicholson AG, . The 2015 World Health Organization classification of lung tumors: impact of genetic, clinical and radiologic advances since the 2004 classification. J Thorac Oncol. 2015 Sep;10(9):1243–60. doi: 10.1097/JTO.0000000000000630. PMID: 26291008.26291008
3 National Cancer Institute Surveillance, Epidemiology, and End Results Program. Cancer stat facts: lung and bronchus cancer. National Cancer Institute; n.d. https://seer.cancer.gov/statfacts/html/lungb.html. Accessed December 28, 2020.
4 National Cancer Institute. A snapshot of lung cancer. National Cancer Institute. https://www.cancer.gov/types/lung. Accessed Oct 19, 2016.
5 National Cancer Institute. Non-small cell lung cancer treatment (PDQ®)-health professional version. National Cancer Institute; 2016. https://www.cancer.gov/types/lung/hp/non-small-cell-lung-treatment-pdq. Accessed Oct 19, 2016.
6 American Cancer Society Medical and Editorial Team. Key statistics for lung cancer. Atlanta, GA American Cancer Society; 2017. https://www.cancer.org/cancer/non-small-cell-lung-cancer/about/key-statistics.html. Accessed October 23, 2017.
7 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2015. CA Cancer J Clin. 2015 Jan-Feb;65(1):5–29. doi: 10.3322/caac.21254. PMID: 25559415.25559415
8 Alberg AJ, Brock MV, Ford JG, . Epidemiology of lung cancer: diagnosis and management of lung cancer, 3rd ed: American College of Chest Physicians evidence-based clinical practice guidelines. Chest. 2013 May;143:(5 Suppl):e1S–e29S. doi: 10.1378/chest.12-2345. PMID: 23649439.23649439
9 Samet JM. Health benefits of smoking cessation. Clin Chest Med. 1991 Dec;12(4):669–79. PMID: 1747986.1747986
10 Hackshaw AK, Law MR, Wald NJ. The accumulated evidence on lung cancer and environmental tobacco smoke. BMJ. 1997 Oct 18;315(7114):980–8. PMID: 9365295.9365295
11 U.S. Department of Health and Human Services. The health consequences of involuntary exposure to tobacco smoke: a report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, ; 2006.
12 Aldrich MC, Mercaldo SF, Sandler KL, . Evaluation of USPSTF lung cancer screening guidelines among African American adult smokers. JAMA Oncol. 2019 Jun 27doi: 10.1001/jamaoncol.2019.1402. PMID: 31246249.31246249
13 Krewski D, Lubin JH, Zielinski JM, . Residential radon and risk of lung cancer: a combined analysis of 7 North American case-control studies. Epidemiology. 2005 Mar;16(2):137–45. PMID: 15703527.15703527
14 Straif K, Benbrahim-Tallaa L, Baan R, . A review of human carcinogens--Part C: metals, arsenic, dusts, and fibres. Lancet Oncol. 2009 May;10(5):453–4. PMID: 19418618.19418618
15 Ibrahim EM, Kazkaz GA, Abouelkhair KM, . Increased risk of second lung cancer in Hodgkin’s lymphoma survivors: a meta-analysis. Lung. 2013 Feb;191(1):117–34. doi: 10.1007/s00408-012-9418-4. PMID: 23053567.23053567
16 Grantzau T, Overgaard J. Risk of second non-breast cancer after radiotherapy for breast cancer: a systematic review and meta-analysis of 762,468 patients. Radiother Oncol. 2015 Jan;114(1):56–65. doi: 10.1016/j.radonc.2014.10.004. PMID: 25454172.25454172
17 Brenner DR, Boffetta P, Duell EJ, . Previous lung diseases and lung cancer risk: a pooled analysis from the International Lung Cancer Consortium. Am J Epidemiol. 2012 Oct 01;176(7):573–85. doi: 10.1093/aje/kws151. PMID: 22986146.22986146
18 Hopkins RJ, Duan F, Chiles C, . Reduced expiratory flow rate among heavy smokers increases lung cancer risk. Results from the National Lung Screening Trial-American College of Radiology Imaging Network Cohort. Ann Am Thorac Soc. 2017 Mar;14(3):392–402. doi: 10.1513/AnnalsATS.201609-741OC. PMID: 28076701.28076701
19 Saracci R. The interactions of tobacco smoking and other agents in cancer etiology. Epidemiol Rev. 1987;9:175–93. PMID: 3315716.3315716
20 American Cancer Society Medical and Editorial Content Team. Non-small cell lung cancer risk factors. Atlanta, GA: American Cancer Society; 2016. https://www.cancer.org/cancer/non-small-cell-lung-cancer/causes-risks-prevention/risk-factors.html. Accessed October 23, 2017.
21 Lissowska J, Foretova L, Dabek J, . Family history and lung cancer risk: international multicentre case-control study in Eastern and Central Europe and meta-analyses. Cancer Causes Control. 2010 Jul;21(7):1091–104. doi: 10.1007/s10552-010-9537-2. PMID: 20306329.20306329
22 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2017. CA Cancer J Clin. 2017 Jan;67(1):7–30. doi: 10.3322/caac.21387. PMID: 28055103.28055103
23 American Cancer Society Medical and Editorial Team. About non-small cell lung cancer. Atlanta, GA: American Cancer Society; 2019. https://www.cancer.org/cancer/non-small-cell-lung-cancer/about/what-is-non-small-cell-lung-cancer.html. Accessed March 18, 2019.
24 Ma J, Ward EM, Smith R, . Annual number of lung cancer deaths potentially avertable by screening in the United States. Cancer. 2013 Apr 01;119(7):1381–5. doi: 10.1002/cncr.27813. PMID: 23440730.23440730
25 Howard DH, Richards TB, Bach PB, . Comorbidities, smoking status, and life expectancy among individuals eligible for lung cancer screening. Cancer. 2015 Dec 15;121(24):4341–7. doi: 10.1002/cncr.29677. PMID: 26372542.26372542
26 Hirales Casillas CE, Flores Fernandez JM, Padilla Camberos E, . Current status of circulating protein biomarkers to aid the early detection of lung cancer. Future Oncol. 2014 Jun;10(8):1501–13. doi: 10.2217/fon.14.21. PMID: 25052758.25052758
27 Oken MM, Hocking WG, Kvale PA, . Screening by chest radiograph and lung cancer mortality: the Prostate, Lung, Colorectal, and Ovarian (PLCO) randomized trial. JAMA. 2011 Nov 02;306(17):1865–73. doi: 10.1001/jama.2011.1591. PMID: 22031728.22031728
28 American College of Radiology. Lung CT screening reporting and data system ACR.org: American College of Radiology; n.d. https://www.acr.org/Clinical-Resources/Reporting-and-Data-Systems/Lung-Rads. Accessed March 7, 2019.
29 Rivera MP, Mehta AC, Wahidi MM. Establishing the diagnosis of lung cancer: diagnosis and management of lung cancer, 3rd ed: American College of Chest Physicians evidence-based clinical practice guidelines. Chest. 2013 May;143(5 Suppl):e142S–e65S. doi: 10.1378/chest.12-2353. PMID: 23649436.23649436
30 Ettinger DS, Akerley W, Borghaei H, . Non-small cell lung cancer, version 2.2013. J Natl Compr Canc Netw. 2013 Jun 01;11(6):645–53; quiz 53. PMID: 23744864.23744864
31 Yan TD, Black D, Bannon PG, . Systematic review and meta-analysis of randomized and nonrandomized trials on safety and efficacy of video-assisted thoracic surgery lobectomy for early-stage non-small-cell lung cancer. J Clin Oncol. 2009 May 20;27(15):2553–62. doi: 10.1200/jco.2008.18.2733. PMID: 19289625.19289625
32 Aberle DR, Adams AM, Berg CD, . Reduced lung-cancer mortality with low-dose computed tomographic screening. N Engl J Med. 2011 Aug 04;365(5):395–409. doi: 10.1056/NEJMoa1102873. PMID: 21714641.21714641
33 Horeweg N, Scholten ET, de Jong PA, . Detection of lung cancer through low-dose CT screening (NELSON): a prespecified analysis of screening test performance and interval cancers. Lancet Oncol. 2014 Nov;15(12):1342–50. doi: 10.1016/s1470-2045(14)70387-0. PMID: 25282284.25282284
34 Huo J, Shen C, Volk RJ, . Use of CT and chest radiography for lung cancer screening before and after publication of screening guidelines: intended and unintended uptake. JAMA Intern Med. 2017 Mar 1;177(3):439–41. doi: 10.1001/jamainternmed.2016.9016. PMID: 28135349.28135349
35 Nishi S, Zhou J, Kuo YF, . Use of lung cancer screening with low-dose computed tomography in the Medicare population. Mayo Clin Proc Innov Qual Outcomes. 2019 Mar;3(1):70–7. doi: 10.1016/j.mayocpiqo.2018.12.003. PMID: 30899910.30899910
36 Zahnd WE, Eberth JM. Lung cancer screening utilization: a behavioral risk factor surveillance system analysis. Am J Prev Med. 2019;57(2):250–5. doi: 10.1016/j.amepre.2019.03.015.31248742
37 Zeliadt SB, Hoffman RM, Birkby G, . Challenges implementing lung cancer screening in federally qualified health centers. Am J Prev Med. 2018 Apr;54(4):568–75. doi: 10.1016/j.amepre.2018.01.001. PMID: 29429606.29429606
38 Kinsinger LS, Anderson C, Kim J, . Implementation of lung cancer screening in the Veterans Health Administration. JAMA Intern Med. 2017 Mar 01;177(3):399–406. doi: 10.1001/jamainternmed.2016.9022. PMID: 28135352.28135352
39 Redberg RF, O’Malley PG. Important questions about lung cancer screening programs when incidental findings exceed lung cancer nodules by 40 to 1. JAMA Intern Med. 2017 Mar 1;177(3):311–2. doi: 10.1001/jamainternmed.2016.9446. PMID: 28135358.28135358
40 Centers for Medicare & Medicaid Services. Proposed decision memo for screening for lung cancer with low dose computed tomography (LDCT) (CAG-00439N). Baltimore, MD: U.S. Centers for Medicare & Medicaid Services; 2014. https://www.cms.gov/medicare-coverage-database/details/nca-proposed-decision-memo.aspx?NCAId=274 Accessed Nov 20, 2017.
41 Brenner A, James S, Malo TL, . Analysis of patient-provider conversations to assess quality of shared decision making about lung cancer screening. SciAbstracts: Lineberger Comprehensive Cancer Center, University of North Carolina at Chapel Hill; 2018.
42 Reuland DS, Cubillos L, Brenner AT, . A pre-post study testing a lung cancer screening decision aid in primary care. BMC Med Inform Decis Mak. 2018 Jan 12;18(1):5. doi: 10.1186/s12911-018-0582-1. PMID: 29325548.29325548
43 Network NCC.Network NCC, ed Clinical Practice Guidelines in Oncology: Lung Cancer Screening, Version 1.2020. 2019. https://www.nccn.org/professionals/physician_gls/pdf/lung_screening.pdf. Accessed June 19, 2019.
44 American Academy of Family Physicians. Clinical Preventive Service recommendation: lung cancer. American Academy of Family Physicians; 2017. http://www.aafp.org/patient-care/clinical-recommendations/all/lung-cancer.html. Accessed Nov 20, 2017.
45 Seehusen DA. Should family physicians routinely screen for lung cancer in high-risk populations? No: the USPSTF’s recommendation for lung cancer screening is overreaching. Am Fam Physician. 2014 Jul 15;90(2):73d–4d. PMID: 25077590.25077590
46 Humphrey L, Deffebach M, Pappas M, . Screening for lung cancer: systematic review to update the U.S. Preventive Services Task Force Recommendation. Evidence Syntheses, No. 105. Report No.: 13-05188-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; July 2013. PMID: 2402779324027793.
47 Humphrey LL, Deffebach M, Pappas M, . Screening for lung cancer with low-dose computed tomography: a systematic review to update the US Preventive Services Task Force recommendation. Ann Intern Med. 2013 Sep 17;159(6):411–20. doi: 10.7326/0003-4819-159-6-201309170-00690. PMID: 23897166.23897166
48 Cheung LC, Berg CD, Castle PE, . Life-gained-based versus risk-based selection of smokers for lung cancer screening. Ann Intern Med. 2019 Oct 22doi: 10.7326/M19-1263. PMID: 31634914.31634914
49 Cheung LC, Katki HA, Chaturvedi AK, . Preventing lung cancer mortality by computed tomography screening: the effect of risk-based versus U.S. Preventive Services Task Force eligibility criteria, 2005-2015. Ann Intern Med. 2018 Jan 2doi: 10.7326/M17-2067. PMID: 29297008.29297008
50 Jahan S. Human development report 2016: human development for everyone. The United Nations Development Programme. New York, NY: 2016. http://hdr.undp.org/sites/default/files/2016_human_development_report.pdf
51 U.S. Preventive Services Task Force. Appendix VI. Criteria for assessing internal validity of individual studies. 2015. In Procedure Manual [cited 5/17/2017]. Rockville, MD: U.S. Preventive Services Task Force. 2015. Available from: https://www.uspreventiveservicestaskforce.org/Page/Name/appendix-vi-criteria-for-assessing-internal-validity-of-individual-studies. ClinicalTrials.gov Identifier:
52 Sterne JA, Hernan MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. BMJ. 2016 Oct 12;355:i4919. doi: 10.1136/bmj.i4919. PMID: 27733354.27733354
53 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
54 Moons KG, de Groot JA, Bouwmeester W, . Critical appraisal and data extraction for systematic reviews of prediction modelling studies: the CHARMS checklist. PLoS Med. 2014 Oct;11(10):e1001744. doi: 10.1371/journal.pmed.1001744. PMID: 25314315.25314315
55 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Agency for Healthcare Research and Quality. 10-EHC070-EF. Rockville (MD): 2010. PMID: 2143333721433337. https://www.ncbi.nlm.nih.gov/pubmed/21433337
56 Kovalchik SA, Tammemagi M, Berg CD, . Targeting of low-dose CT screening according to the risk of lung-cancer death. N Engl J Med. 2013 Jul 18;369(3):245–54. doi: 10.1056/NEJMoa1301851. PMID: 23863051.23863051
57 Church TR, Black WC, Aberle DR, . Results of initial low-dose computed tomographic screening for lung cancer. N Engl J Med. 2013 May 23;368(21):1980–91. doi: 10.1056/NEJMoa1209120. PMID: 23697514.23697514
58 Aberle DR, DeMello S, Berg CD, . Results of the two incidence screenings in the National Lung Screening Trial. N Engl J Med. 2013 Sep 05;369(10):920–31. doi: 10.1056/NEJMoa1208962. PMID: 24004119.24004119
59 Becker N, Motsch E, Gross ML, . Randomized study on early detection of lung cancer with MSCT in Germany: results of the first 3 years of follow-up after randomization. J Thorac Oncol. 2015 Jun;10(6):890–6. doi: 10.1097/jto.0000000000000530. PMID: 25783198.25783198
60 Becker N, Motsch E, Gross ML, . Randomized study on early detection of lung cancer with MSCT in Germany: study design and results of the first screening round. J Cancer Res Clin Oncol. 2012 Sep;138(9):1475–86. doi: 10.1007/s00432-012-1228-9. PMID: 22526165.22526165
61 Infante M, Cavuto S, Lutman FR, . Long-term follow-up results of the DANTE Trial, a randomized study of lung cancer screening with spiral computed tomography. Am J Respir Crit Care Med. 2015 May 15;191(10):1166–75. doi: 10.1164/rccm.201408-1475OC. PMID: 25760561.25760561
62 Paci E, Puliti D, Lopes Pegna A, . Mortality, survival and incidence rates in the ITALUNG randomised lung cancer screening trial. Thorax. 2017 Sep;72(9):825–31. doi: 10.1136/thoraxjnl-2016-209825. PMID: 28377492.28377492
63 Pinsky PF, Church TR, Izmirlian G, . The National Lung Screening Trial: results stratified by demographics, smoking history, and lung cancer histology. Cancer. 2013 Nov 15;119(22):3976–83. doi: 10.1002/cncr.28326. PMID: 24037918.24037918
64 Pinsky PF, Gierada DS, Hocking W, . National Lung Screening Trial findings by age: Medicare-eligible versus under-65 population. Ann Intern Med. 2014 Nov 04;161(9):627–33. doi: 10.7326/m14-1484. PMID: 25199624.25199624
65 Saghir Z, Dirksen A, Ashraf H, . CT screening for lung cancer brings forward early disease. The randomised Danish Lung Cancer Screening Trial: status after five annual screening rounds with low-dose CT. Thorax. 2012 Apr;67(4):296–301. doi: 10.1136/thoraxjnl-2011-200736. PMID: 22286927.22286927
66 Tanner NT, Gebregziabher M, Hughes Halbert C, . Racial differences in outcomes within the National Lung Screening Trial. Implications for widespread implementation. Am J Respir Crit Care Med. 2015 Jul 15;192(2):200–8. doi: 10.1164/rccm.201502-0259OC. PMID: 25928649.25928649
67 Wille MM, Dirksen A, Ashraf H, . Results of the randomized Danish Lung Cancer Screening Trial with focus on high-risk profiling. Am J Respir Crit Care Med. 2016 Mar 01;193(5):542–51. doi: 10.1164/rccm.201505-1040OC. PMID: 26485620.26485620
68 Schabath MB, Massion PP, Thompson ZJ, . Differences in patient outcomes of prevalence, interval, and screen-detected lung cancers in the CT arm of the national lung screening trial. PLoS One. 2016;11(8):e0159880. doi: 10.1371/journal.pone.0159880. PMID: 27509046.27509046
69 Gohagan JK, Marcus PM, Fagerstrom RM, . Final results of the Lung Screening Study, a randomized feasibility study of spiral CT versus chest X-ray screening for lung cancer. Lung Cancer. 2005 Jan;47(1):9–15. doi: 10.1016/j.lungcan.2004.06.007. PMID: 15603850.15603850
70 Gohagan J, Marcus P, Fagerstrom R, . Baseline findings of a randomized feasibility trial of lung cancer screening with spiral CT scan vs chest radiograph: the Lung Screening Study of the National Cancer Institute. Chest. 2004 Jul;126(1):114–21. doi: 10.1378/chest.126.1.114. PMID: 15249451.15249451
71 Infante M, Cavuto S, Lutman FR, . A randomized study of lung cancer screening with spiral computed tomography: three-year results from the DANTE trial. Am J Respir Crit Care Med. 2009 Sep 1;180(5):445–53. doi: 10.1164/rccm.200901-0076OC. PMID: 19520905.19520905
72 Infante M, Lutman FR, Cavuto S, . Lung cancer screening with spiral CT: baseline results of the randomized DANTE trial. Lung Cancer. 2008 Mar;59(3):355–63. doi: 10.1016/j.lungcan.2007.08.040. PMID: 17936405.17936405
73 Becker N, Motsch E, Trotter A, . Lung cancer mortality reduction by LDCT screening-Results from the randomized German LUSI trial. Int J Cancer. 2020 Mar 15;146(6):1503–13. doi: 10.1002/ijc.32486. PMID: 31162856.31162856
74 Black WC, Chiles C, Church TR, . Lung cancer incidence and mortality with extended follow-up in the National Lung Screening Trial National Lung Screening Trial Writing Team (1). J Thorac Oncol. 2019 Jun 13;14(10):1732–42. doi: 10.1016/j.jtho.2019.05.044. PMID: 31260833.31260833
75 Doroudi M, Pinsky PF, Marcus PM. Lung cancer mortality in the Lung Screening Study Feasibility Trial. JNCI Cancer Spectr. 2018 Jul;2(3):pky042. doi: 10.1093/jncics/pky042. PMID: 31360863.31360863
76 de Koning HJ, van der Aalst CM, de Jong PA, . Reduced lung-cancer mortality with volume CT screening in a randomized trial. N Engl J Med. 2020 Feb 6;382(6):503–13. doi: 10.1056/NEJMoa1911793. PMID: 31995683.31995683
77 Ru Zhao Y, Xie X, de Koning HJ, . NELSON lung cancer screening study. Cancer Imaging. 2011 Oct 03;11 Spec No A:S79–84. doi: 10.1102/1470-7330.2011.9020. PMID: 22185865.22185865
78 Walter JE, Heuvelmans MA, de Jong PA, . Occurrence and lung cancer probability of new solid nodules at incidence screening with low-dose CT: analysis of data from the randomised, controlled NELSON trial. Lancet Oncol. 2016 Jul;17(7):907–16. doi: 10.1016/s1470-2045(16)30069-9. PMID: 27283862.27283862
79 Xu DM, Gietema H, de Koning H, . Nodule management protocol of the NELSON randomised lung cancer screening trial. Lung Cancer. 2006 Nov;54(2):177–84. doi: 10.1016/j.lungcan.2006.08.006. PMID: 16989922.16989922
80 Pastorino U, Rossi M, Rosato V, . Annual or biennial CT screening versus observation in heavy smokers: 5-year results of the MILD trial. Eur J Cancer Prev. 2012 May;21(3):308–15. doi: 10.1097/CEJ.0b013e328351e1b6. PMID: 22465911.22465911
81 Pastorino U, Silva M, Sestini S, . Prolonged lung cancer screening reduced 10-year mortality in the MILD trial: new confirmation of lung cancer screening efficacy. Ann Oncol. 2019 Jun 5doi: 10.1093/annonc/mdz169. PMID: 31168572.31168572
82 Sverzellati N, Silva M, Calareso G, . Low-dose computed tomography for lung cancer screening: comparison of performance between annual and biennial screen. Eur Radiol. 2016 Nov;26(11):3821–9. doi: 10.1007/s00330-016-4228-3. PMID: 26868497.26868497
83 ten Haaf K, Jeon J, Tammemagi MC, . Risk prediction models for selection of lung cancer screening candidates: a retrospective validation study. PLoS Med. 2017 Apr;14(4):e1002277. doi: 10.1371/journal.pmed.1002277. PMID: 28376113.28376113
84 Katki HA, Kovalchik SA, Berg CD, . Development and validation of risk models to select ever-smokers for CT lung cancer screening. JAMA. 2016 Jun 07;315(21):2300–11. doi: 10.1001/jama.2016.6255. PMID: 27179989.27179989
85 Tammemagi MC, Katki HA, Hocking WG, . Selection criteria for lung-cancer screening. N Engl J Med. 2013 Feb 21;368(8):728–36. doi: 10.1056/NEJMoa1211776. PMID: 23425165.23425165
86 Weber M, Yap S, Goldsbury D, . Identifying high risk individuals for targeted lung cancer screening: independent validation of the PLCOm2012 risk prediction tool. Int J Cancer. 2017 Jul 15;141(2):242–53. doi: 10.1002/ijc.30673. PMID: 28249359.28249359
87 Tammemagi MC, Church TR, Hocking WG, . Evaluation of the lung cancer risks at which to screen ever- and never-smokers: screening rules applied to the PLCO and NLST cohorts. PLoS Med. 2014 Dec;11(12):e1001764. doi: 10.1371/journal.pmed.1001764. PMID: 25460915.25460915
88 de-Torres JP, Wilson DO, Sanchez-Salcedo P, . Lung cancer in patients with chronic obstructive pulmonary disease. Development and validation of the COPD Lung Cancer Screening Score. Am J Respir Crit Care Med. 2015 Feb 1;191(3):285–91. doi: 10.1164/rccm.201407-1210OC. PMID: 25522175.25522175
89 Landy R, Cheung LC, Berg CD, . Contemporary implications of U.S. Preventive Services Task Force and risk-based guidelines for lung cancer screening eligibility in the United States. Ann Intern Med. 2019 Jun 4doi: 10.7326/M18-3617. PMID: 31158854.31158854
90 Bach PB, Kattan MW, Thornquist MD, . Variations in lung cancer risk among smokers. J Natl Cancer Inst. 2003 Mar 19;95(6):470–8. PMID: 12644540.12644540
91 Khera N, Holland JC, Griffin JM. Setting the stage for universal financial distress screening in routine cancer care. Cancer. 2017 Nov 01;123(21):4092–6. doi: 10.1002/cncr.30940. PMID: 28817185.28817185
92 Cassidy A, Myles JP, van Tongeren M, . The LLP risk model: an individual risk prediction model for lung cancer. Br J Cancer. 2008 Jan 29;98(2):270–6. doi: 10.1038/sj.bjc.6604158. PMID: 18087271.18087271
93 Meza R, Hazelton WD, Colditz GA, . Analysis of lung cancer incidence in the nurses’ health and the health professionals’ follow-up studies using a multistage carcinogenesis model. Cancer Causes Control. 2008 Apr;19(3):317–28. doi: 10.1007/s10552-007-9094-5. PMID: 18058248.18058248
94 Hazelton WD, Clements MS, Moolgavkar SH. Multistage carcinogenesis and lung cancer mortality in three cohorts. Cancer Epidemiol Biomarkers Prev. 2005 May;14(5):1171–81. doi: 10.1158/1055-9965.EPI-04-0756. PMID: 15894668.15894668
95 Markaki M, Tsamardinos I, Langhammer A, . A validated clinical risk prediction model for lung cancer in smokers of all ages and exposure types: a HUNT study. EBioMedicine. 2018 May;31:36–46. doi: 10.1016/j.ebiom.2018.03.027. PMID: 29678673.29678673
96 Knoke JD, Burns DM, Thun MJ. The change in excess risk of lung cancer attributable to smoking following smoking cessation: an examination of different analytic approaches using CPS-I data. Cancer Causes Control. 2008 Mar;19(2):207–19. doi: 10.1007/s10552-007-9086-5. PMID: 17992575.17992575
97 Field JK, Duffy SW, Baldwin DR, . UK Lung Cancer RCT Pilot Screening Trial: baseline findings from the screening arm provide evidence for the potential implementation of lung cancer screening. Thorax. 2016 Feb;71(2):161–70. doi: 10.1136/thoraxjnl-2015-207140. PMID: 26645413.26645413
98 Horeweg N, van der Aalst CM, Vliegenthart R, . Volumetric computed tomography screening for lung cancer: three rounds of the NELSON trial. Eur Respir J. 2013 Dec;42(6):1659–67. doi: 10.1183/09031936.00197712. PMID: 23845716.23845716
99 Lopes Pegna A, Picozzi G, Falaschi F, . Four-year results of low-dose CT screening and nodule management in the ITALUNG trial. J Thorac Oncol. 2013 Jul;8(7):866–75. doi: 10.1097/JTO.0b013e31828f68d6. PMID: 23612465.23612465
100 Pinsky PF, Gierada DS, Black W, . Performance of Lung-RADS in the National Lung Screening Trial: a retrospective assessment. Ann Intern Med. 2015 Apr 07;162(7):485–91. doi: 10.7326/m14-2086. PMID: 25664444.25664444
101 Pinsky PF, Gierada DS, Nath H, . ROC curves for low-dose CT in the National Lung Screening Trial. J Med Screen. 2013;20(3):165–8. doi: 10.1177/0969141313500666. PMID: 24009092.24009092
102 Pinsky PF, Gierada DS, Nath PH, . National lung screening trial: variability in nodule detection rates in chest CT studies. Radiology. 2013 Sep;268(3):865–73. doi: 10.1148/radiol.13121530. PMID: 23592767.23592767
103 Scholten ET, Horeweg N, de Koning HJ, . Computed tomographic characteristics of interval and post screen carcinomas in lung cancer screening. Eur Radiol. 2015 Jan;25(1):81–8. doi: 10.1007/s00330-014-3394-4. PMID: 25187382.25187382
104 Yip R, Henschke CI, Yankelevitz DF, . CT screening for lung cancer: alternative definitions of positive test result based on the national lung screening trial and international early lung cancer action program databases. Radiology. 2014 Nov;273(2):591–6. doi: 10.1148/radiol.14132950. PMID: 24955929.24955929
105 Yankelevitz DF, Yip R, Smith JP, . CT screening for lung cancer: Nonsolid nodules in baseline and annual repeat rounds. Radiology. 2015 Nov;277(2):555–64. doi: 10.1148/radiol.2015142554. PMID: 26101879.26101879
106 Henschke CI, Yip R, Smith JP, . CT screening for lung cancer: part-solid nodules in baseline and annual repeat rounds. AJR Am J Roentgenol. 2016 Dec;207(6):1176–84. doi: 10.2214/ajr.16.16043. PMID: 27726410.27726410
107 Henschke CI, Yip R, Yankelevitz DF, . Definition of a positive test result in computed tomography screening for lung cancer: a cohort study. Ann Intern Med. 2013 Feb 19;158(4):246–52. doi: 10.7326/0003-4819-158-4-201302190-00004. PMID: 23420233.23420233
108 Wille MM, Thomsen LH, Dirksen A, . Emphysema progression is visually detectable in low-dose CT in continuous but not in former smokers. Eur Radiol. 2014 Nov;24(11):2692–9. doi: 10.1007/s00330-014-3294-7. PMID: 25038853.25038853
109 Zhao YR, Heuvelmans MA, Dorrius MD, . Features of resolving and nonresolving indeterminate pulmonary nodules at follow-up CT: the NELSON study. Radiology. 2014 Mar;270(3):872–9. doi: 10.1148/radiol.13130332. PMID: 24475806.24475806
110 Gierada DS, Pinsky PF, Duan F, . Interval lung cancer after a negative CT screening examination: CT findings and outcomes in National Lung Screening Trial participants. Eur Radiol. 2017 Aug;27(8):3249–56. doi: 10.1007/s00330-016-4705-8. PMID: 28050695.28050695
111 Crucitti P, Gallo IF, Santoro G, . Lung cancer screening with low dose CT: experience at Campus Bio-Medico of Rome on 1500 patients. Minerva Chir. 2015 Dec;70(6):393–9. PMID: 25700151.25700151
112 Wang Y, van Klaveren RJ, de Bock GH, . No benefit for consensus double reading at baseline screening for lung cancer with the use of semiautomated volumetry software. Radiology. 2012 Jan;262(1):320–6. doi: 10.1148/radiol.11102289. PMID: 22106357.22106357
113 van Riel SJ, Sanchez CI, Bankier AA, . Observer variability for classification of pulmonary nodules on low-dose CT images and its effect on nodule management. Radiology. 2015 Dec;277(3):863–71. doi: 10.1148/radiol.2015142700. PMID: 26020438.26020438
114 Heuvelmans MA, Oudkerk M, de Bock GH, . Optimisation of volume-doubling time cutoff for fast-growing lung nodules in CT lung cancer screening reduces false-positive referrals. Eur Radiol. 2013 Jul;23(7):1836–45. doi: 10.1007/s00330-013-2799-9. PMID: 23508275.23508275
115 Tammemagi MC, Schmidt H, Martel S, . Participant selection for lung cancer screening by risk modelling (the Pan-Canadian Early Detection of Lung Cancer [PanCan] study): a single-arm, prospective study. Lancet Oncol. 2017 Nov;18(11):1523–31. doi: 10.1016/s1470-2045(17)30597-1. PMID: 29055736.29055736
116 McWilliams A, Tammemagi MC, Mayo JR, . Probability of cancer in pulmonary nodules detected on first screening CT. N Engl J Med. 2013 Sep 5;369(10):910–9. doi: 10.1056/NEJMoa1214726. PMID: 24004118.24004118
117 Field JK, Duffy SW, Baldwin DR, . The UK Lung Cancer Screening Trial: a pilot randomised controlled trial of low-dose computed tomography screening for the early detection of lung cancer. Health Technol Assess. 2016 May;20(40):1–146. doi: 10.3310/hta20400. PMID: 27224642.27224642
118 Wagnetz U, Menezes RJ, Boerner S, . CT screening for lung cancer: implication of lung biopsy recommendations. AJR Am J Roentgenol. 2012 Feb;198(2):351–8. doi: 10.2214/ajr.11.6726. PMID: 22268177.22268177
119 Croswell JM, Baker SG, Marcus PM, . Cumulative incidence of false-positive test results in lung cancer screening: a randomized trial. Ann Intern Med. 2010 Apr 20;152(8):505–12, w176–80. doi: 10.7326/0003-4819-152-8-201004200-00007. PMID: 20404381.20404381
120 van Klaveren RJ, Oudkerk M, Prokop M, . Management of lung nodules detected by volume CT scanning. N Engl J Med. 2009 Dec 3;361(23):2221–9. doi: 10.1056/NEJMoa0906085. PMID: 19955524.19955524
121 Menezes RJ, Roberts HC, Paul NS, . Lung cancer screening using low-dose computed tomography in at-risk individuals: the Toronto experience. Lung Cancer. 2010 Feb;67(2):177–83. doi: 10.1016/j.lungcan.2009.03.030. PMID: 19427055.19427055
122 Pedersen JH, Ashraf H, Dirksen A, . The Danish randomized lung cancer CT screening trial--overall design and results of the prevalence round. J Thorac Oncol. 2009 May;4(5):608–14. doi: 10.1097/JTO.0b013e3181a0d98f. PMID: 19357536.19357536
123 Tsushima K, Sone S, Hanaoka T, . Radiological diagnosis of small pulmonary nodules detected on low-dose screening computed tomography. Respirology. 2008 Nov;13(6):817–24. doi: 10.1111/j.1440-1843.2008.01379.x. PMID: 18811880.18811880
124 Veronesi G, Bellomi M, Scanagatta P, . Difficulties encountered managing nodules detected during a computed tomography lung cancer screening program. J Thorac Cardiovasc Surg. 2008 Sep;136(3):611–7. doi: 10.1016/j.jtcvs.2008.02.082. PMID: 18805261.18805261
125 Lopes Pegna A, Picozzi G, Mascalchi M, . Design, recruitment and baseline results of the ITALUNG trial for lung cancer screening with low-dose CT. Lung Cancer. 2009 Apr;64(1):34–40. doi: 10.1016/j.lungcan.2008.07.003. PMID: 18723240.18723240
126 Toyoda Y, Nakayama T, Kusunoki Y, . Sensitivity and specificity of lung cancer screening using chest low-dose computed tomography. Br J Cancer. 2008 May 20;98(10):1602–7. doi: 10.1038/sj.bjc.6604351. PMID: 18475292.18475292
127 Veronesi G, Bellomi M, Mulshine JL, . Lung cancer screening with low-dose computed tomography: a non-invasive diagnostic protocol for baseline lung nodules. Lung Cancer. 2008 Sep;61(3):340–9. doi: 10.1016/j.lungcan.2008.01.001. PMID: 18308420.18308420
128 Henschke CI, Yankelevitz DF, Libby DM, . Survival of patients with stage I lung cancer detected on CT screening. N Engl J Med. 2006 Oct 26;355(17):1763–71. doi: 10.1056/NEJMoa060476. PMID: 17065637.17065637
129 Henschke CI, Yip R, Miettinen OS. Women’s susceptibility to tobacco carcinogens and survival after diagnosis of lung cancer. JAMA. 2006 Jul 12;296(2):180–4. doi: 10.1001/jama.296.2.180. PMID: 16835423.16835423
130 Swensen SJ, Jett JR, Hartman TE, . CT screening for lung cancer: five-year prospective experience. Radiology. 2005 Apr;235(1):259–65. doi: 10.1148/radiol.2351041662. PMID: 15695622.15695622
131 Henschke CI, Yankelevitz DF, Smith JP, . CT screening for lung cancer assessing a regimen’s diagnostic performance. Clin Imaging. 2004 Sep-Oct;28(5):317–21. doi: 10.1016/j.clinimag.2004.05.001. PMID: 15471661.15471661
132 Chung K, Jacobs C, Scholten ET, . Lung-RADS category 4X: Does it improve prediction of malignancy in subsolid nodules? Radiology. 2017 Jul;284(1):264–71. doi: 10.1148/radiol.2017161624. PMID: 28339311.28339311
133 Walker BL, Williamson C, Regis SM, . Surgical outcomes in a large, clinical, low-dose computed tomographic lung cancer screening program. Ann Thorac Surg. 2015 Oct;100(4):1218–23. doi: 10.1016/j.athoracsur.2015.04.112. PMID: 26209493.26209493
134 Rampinelli C, De Marco P, Origgi D, . Exposure to low dose computed tomography for lung cancer screening and risk of cancer: secondary analysis of trial data and risk-benefit analysis. BMJ. 2017 Feb 8;356:j347. doi: 10.1136/bmj.j347. PMID: 28179230.28179230
135 Veronesi G, Maisonneuve P, Bellomi M, . Estimating overdiagnosis in low-dose computed tomography screening for lung cancer: a cohort study. Ann Intern Med. 2012 Dec 4;157(11):776–84. doi: 10.7326/0003-4819-157-11-201212040-00005. PMID: 23208167.23208167
136 Mascalchi M, Belli G, Zappa M, . Risk-benefit analysis of X-ray exposure associated with lung cancer screening in the Italung-CT trial. AJR Am J Roentgenol. 2006 Aug;187(2):421–9. doi: 10.2214/ajr.05.0088. PMID: 16861547.16861547
137 Wilson DO, Weissfeld JL, Fuhrman CR, . The Pittsburgh Lung Screening Study (PLuSS): outcomes within 3 years of a first computed tomography scan. Am J Respir Crit Care Med. 2008 Nov 1;178(9):956–61. doi: 10.1164/rccm.200802-336OC. PMID: 18635890.18635890
138 van’t Westeinde SC, Horeweg N, Vernhout RM, . The role of conventional bronchoscopy in the workup of suspicious CT scan screen-detected pulmonary nodules. Chest. 2012 Aug;142(2):377–84. doi: 10.1378/chest.11-2030. PMID: 22302298.22302298
139 Pinsky PF, Bellinger CR, Miller DP, Jr. False-positive screens and lung cancer risk in the National Lung Screening Trial: implications for shared decision-making. J Med Screen. 2018 Jun;25(2):110–2. doi: 10.1177/0969141317727771. PMID: 28929865.28929865
140 Infante M, Chiesa G, Solomon D, . Surgical procedures in the DANTE trial, a randomized study of lung cancer early detection with spiral computed tomography: comparative analysis in the screening and control arm. J Thorac Oncol. 2011 Feb;6(2):327–35. doi: 10.1097/JTO.0b013e318200f523. PMID: 21178639.21178639
141 Heleno B, Siersma V, Brodersen J. Estimation of overdiagnosis of lung cancer in low-dose computed tomography screening: a secondary analysis of the Danish Lung Cancer Screening Trial. JAMA Intern Med. 2018 Oct 1;178(10):1420–2. doi: 10.1001/jamainternmed.2018.3056. PMID: 30276415.30276415
142 Patz EF, Jr., Pinsky P, Gatsonis C, . Overdiagnosis in low-dose computed tomography screening for lung cancer. JAMA Intern Med. 2014 Feb 01;174(2):269–74. doi: 10.1001/jamainternmed.2013.12738. PMID: 24322569.24322569
143 Thalanayar PM, Altintas N, Weissfeld JL, . Indolent, potentially inconsequential lung cancers in the Pittsburgh Lung Screening Study. Ann Am Thorac Soc. 2015 Aug;12(8):1193–6. doi: 10.1513/AnnalsATS.201412-577OC. PMID: 26107281.26107281
144 Young RP, Duan F, Chiles C, . Airflow limitation and histology shift in the National Lung Screening Trial. The NLST-ACRIN Cohort Substudy. Am J Respir Crit Care Med. 2015 Nov 1;192(9):1060–7. doi: 10.1164/rccm.201505-0894OC. PMID: 26199983.26199983
145 Ashraf H, Tonnesen P, Holst Pedersen J, . Effect of CT screening on smoking habits at 1-year follow-up in the Danish Lung Cancer Screening Trial (DLCST). Thorax. 2009 May;64(5):388–92. doi: 10.1136/thx.2008.102475. PMID: 19052048.19052048
146 Hasegawa M, Sone S, Takashima S, . Growth rate of small lung cancers detected on mass CT screening. Br J Radiol. 2000 Dec;73(876):1252–9. doi: 10.1259/bjr.73.876.11205667. PMID: 11205667.11205667
147 Ashraf H, Saghir Z, Dirksen A, . Smoking habits in the randomised Danish Lung Cancer Screening Trial with low-dose CT: final results after a 5-year screening programme. Thorax. 2014 Jun;69(6):574–9. doi: 10.1136/thoraxjnl-2013-203849. PMID: 24443174.24443174
148 van der Aalst CM, van den Bergh KA, Willemsen MC, . Lung cancer screening and smoking abstinence: 2 year follow-up data from the Dutch-Belgian randomised controlled lung cancer screening trial. Thorax. 2010 Jul;65(7):600–5. doi: 10.1136/thx.2009.133751. PMID: 20627916.20627916
149 Clark MA, Gorelick JJ, Sicks JD, . The relations between false positive and negative screens and smoking cessation and relapse in the National Lung Screening Trial: implications for public health. Nicotine Tob Res. 2016 Jan;18(1):17–24. doi: 10.1093/ntr/ntv037. PMID: 25746779.25746779
150 Anderson CM, Yip R, Henschke CI, . Smoking cessation and relapse during a lung cancer screening program. Cancer Epidemiol Biomarkers Prev. 2009 Dec;18(12):3476–83. doi: 10.1158/1055-9965.epi-09-0176. PMID: 19959698.19959698
151 Styn MA, Land SR, Perkins KA, . Smoking behavior 1 year after computed tomography screening for lung cancer: Effect of physician referral for abnormal CT findings. Cancer Epidemiol Biomarkers Prev. 2009 Dec;18(12):3484–9. doi: 10.1158/1055-9965.epi-09-0895. PMID: 19959699.19959699
152 Townsend CO, Clark MM, Jett JR, . Relation between smoking cessation and receiving results from three annual spiral chest computed tomography scans for lung carcinoma screening. Cancer. 2005 May 15;103(10):2154–62. doi: 10.1002/cncr.21045. PMID: 15825210.15825210
153 van der Aalst CM, van Klaveren RJ, van den Bergh KA, . The impact of a lung cancer computed tomography screening result on smoking abstinence. Eur Respir J. 2011 Jun;37(6):1466–73. doi: 10.1183/09031936.00035410. PMID: 21148233.21148233
154 Cox LS, Clark MM, Jett JR, . Change in smoking status after spiral chest computed tomography scan screening. Cancer. 2003 Dec 1;98(11):2495–501. doi: 10.1002/cncr.11813. PMID: 14635086.14635086
155 Taylor KL, Cox LS, Zincke N, . Lung cancer screening as a teachable moment for smoking cessation. Lung Cancer. 2007 Apr;56(1):125–34. doi: 10.1016/j.lungcan.2006.11.015. PMID: 17196298.17196298
156 Gareen IF, Duan F, Greco EM, . Impact of lung cancer screening results on participant health-related quality of life and state anxiety in the National Lung Screening Trial. Cancer. 2014 Nov 01;120(21):3401–9. doi: 10.1002/cncr.28833. PMID: 25065710.25065710
157 Kaerlev L, Iachina M, Pedersen JH, . CT-Screening for lung cancer does not increase the use of anxiolytic or antidepressant medication. BMC Cancer. 2012 May 23;12:188. doi: 10.1186/1471-2407-12-188. PMID: 22621716.22621716
158 Rasmussen JF, Siersma V, Pedersen JH, . Psychosocial consequences in the Danish randomised controlled lung cancer screening trial (DLCST). Lung Cancer. 2015 Jan;87(1):65–72. doi: 10.1016/j.lungcan.2014.11.003. PMID: 25433982.25433982
159 van den Bergh KA, Essink-Bot ML, Borsboom GJ, . Long-term effects of lung cancer computed tomography screening on health-related quality of life: the NELSON trial. Eur Respir J. 2011 Jul;38(1):154–61. doi: 10.1183/09031936.00123410. PMID: 21148229.21148229
160 Aggestrup LM, Hestbech MS, Siersma V, . Psychosocial consequences of allocation to lung cancer screening: a randomised controlled trial. BMJ Open. 2012;2(2):e000663. doi: 10.1136/bmjopen-2011-000663. PMID: 22382119.22382119
161 Byrne MM, Weissfeld J, Roberts MS. Anxiety, fear of cancer, and perceived risk of cancer following lung cancer screening. Med Decis Making. 2008 Nov-Dec;28(6):917–25. doi: 10.1177/0272989x08322013. PMID: 18725404.18725404
162 van den Bergh KA, Essink-Bot ML, Borsboom GJ, . Short-term health-related quality of life consequences in a lung cancer CT screening trial (NELSON). Br J Cancer. 2010 Jan 5;102(1):27–34. doi: 10.1038/sj.bjc.6605459. PMID: 19935789.19935789
163 Dunn CE, Edwards A, Carter B, . The role of screening expectations in modifying short-term psychological responses to low-dose computed tomography lung cancer screening among high-risk individuals. Patient Educ Couns. 2017 Aug;100(8):1572–9. doi: 10.1016/j.pec.2017.02.024. PMID: 28274672.28274672
164 Julian LJ. Measures of anxiety: State-Trait Anxiety Inventory (STAI), Beck Anxiety Inventory (BAI), and Hospital Anxiety and Depression Scale-Anxiety (HADS-A). Arthritis Care Res (Hoboken). 2011 November;63(S11):S467–S72. doi: 10.1002/acr.20561.22588767
165 Norman GR, Sloan JA, Wyrwich KW. Interpretation of changes in health-related quality of life: the remarkable universality of half a standard deviation. Med Care. 2003 May;41(5):582–92. doi: 10.1097/01.MLR.0000062554.74615.4C. PMID: 12719681.12719681
166 Nguyen XV, Davies L, Eastwood JD, . Extrapulmonary findings and malignancies in participants screened with chest CT in the National Lung Screening Trial. J Am Coll Radiol. 2017 Mar;14(3):324–30. doi: 10.1016/j.jacr.2016.09.044. PMID: 28259326.28259326
167 Morgan L, Choi H, Reid M, . Frequency of incidental findings and subsequent evaluation in low-dose computed tomographic scans for lung cancer screening. Ann Am Thorac Soc. 2017 Sep;14(9):1450–6. doi: 10.1513/AnnalsATS.201612-1023OC. PMID: 28421812.28421812
168 Swensen SJ, Jett JR, Sloan JA, . Screening for lung cancer with low-dose spiral computed tomography. Am J Respir Crit Care Med. 2002 Feb 15;165(4):508–13. doi: 10.1164/ajrccm.165.4.2107006. PMID: 11850344.11850344
169 O’Grady TJ, Kitahara CM, DiRienzo AG, . Randomization to screening for prostate, lung, colorectal and ovarian cancers and thyroid cancer incidence in two large cancer screening trials. PLoS One. 2014;9(9):e106880. doi: 10.1371/journal.pone.0106880. PMID: 25192282.25192282
170 Scheel PJ, 3rd, Crabtree TD, Bell JM, . Does surgeon experience affect outcomes in pathologic stage I lung cancer? J Thorac Cardiovasc Surg. 2015 Apr;149(4):998–1004.e1. doi: 10.1016/j.jtcvs.2014.12.032. PMID: 25636526.25636526
171 Guerrera F, Errico L, Evangelista A, . Exploring stage I non-small-cell lung cancer: development of a prognostic model predicting 5-year survival after surgical resectiondagger. Eur J Cardiothorac Surg. 2015 Jun;47(6):1037–43. doi: 10.1093/ejcts/ezu410. PMID: 25391390.25391390
172 Zhai R, Yu X, Shafer A, . The impact of coexisting COPD on survival of patients with early-stage non-small cell lung cancer undergoing surgical resection. Chest. 2014 Feb;145(2):346–53. doi: 10.1378/chest.13-1176. PMID: 24008835.24008835
173 Nakamura H, Saji H, Kurimoto N, . Impact of intraoperative blood loss on long-term survival after lung cancer resection. Ann Thorac Cardiovasc Surg. 2015;21(1):18–23. doi: 10.5761/atcs.oa.13-00312. PMID: 24583702.24583702
174 Su S, Scott W, Allen M, . Patterns of survival and recurrence after surgical treatment of early stage non-small cell lung carcinoma in the ACOSOG Z0030 (ALLIANCE) trial. J Thorac Cardiovasc Surg; 2014. p. 747–52: Discussion 52-3.24290575
175 Lakha S, Gomez JE, Flores RM, . Prognostic significance of visceral pleural involvement in early-stage lung cancer. Chest. 2014 Dec;146(6):1619–26. doi: 10.1378/chest.14-0204. PMID: 25032521.25032521
176 Landreneau RJ, Normolle DP, Christie NA, . Recurrence and survival outcomes after anatomic segmentectomy versus lobectomy for clinical stage I non-small-cell lung cancer: a propensity-matched analysis. J Clin Oncol. 2014 Aug 10;32(23):2449–55. doi: 10.1200/jco.2013.50.8762. PMID: 24982447.24982447
177 Mediratta N, Shackcloth M, Page R, . Should males ever undergo wedge resection for stage 1 non-small-cell lung cancer? A propensity analysis. Eur J Cardiothorac Surg. 2014 Aug;46(2):267–73; discussion 73. doi: 10.1093/ejcts/ezt603. PMID: 24420371.24420371
178 Khullar OV, Gillespie T, Nickleach DC, . Socioeconomic risk factors for long-term mortality after pulmonary resection for lung cancer: an analysis of more than 90,000 patients from the National Cancer Data Base. J Am Coll Surg. 2015 Feb;220(2):156–68.e4. doi: 10.1016/j.jamcollsurg.2014.10.009. PMID: 25488349.25488349
179 Tsutani Y, Miyata Y, Nakayama H, . Sublobar resection for lung adenocarcinoma meeting node-negative criteria on preoperative imaging. Ann Thorac Surg. 2014 May;97(5):1701–7. doi: 10.1016/j.athoracsur.2014.02.024. PMID: 24679941.24679941
180 Razi SS, John MM, Sainathan S, . Sublobar resection is equivalent to lobectomy for T1a non-small cell lung cancer in the elderly: a surveillance, epidemiology, and end results database analysis. J Surg Res. 2016 Feb;200(2):683–9. doi: 10.1016/j.jss.2015.08.045. PMID: 26490227.26490227
181 Brunelli A, Ferguson MK, Salati M, . Thoracic revised cardiac risk index is associated with prognosis after resection for stage I lung cancer. Ann Thorac Surg. 2015 Jul;100(1):195–200. doi: 10.1016/j.athoracsur.2015.03.103. PMID: 26004925.26004925
182 Stephens N, Rice D, Correa A, . Thoracoscopic lobectomy is associated with improved short-term and equivalent oncological outcomes compared with open lobectomy for clinical Stage I non-small-cell lung cancer: a propensity-matched analysis of 963 cases. Eur J Cardiothorac Surg. 2014 Oct;46(4):607–13. doi: 10.1093/ejcts/ezu036. PMID: 24603446.24603446
183 Zhao ZR, Situ DR, Lau RWH, . Comparison of segmentectomy and lobectomy in Stage IA adenocarcinomas. J Thorac Oncol. 2017 May;12(5):890–6. doi: 10.1016/j.jtho.2017.01.012. PMID: 28111235.28111235
184 Maeda R, Yoshida J, Ishii G, . Influence of cigarette smoking on survival and tumor invasiveness in clinical stage IA lung adenocarcinoma. Ann Thorac Surg. 2012 May;93(5):1626–32. doi: 10.1016/j.athoracsur.2012.01.005. PMID: 22421592.22421592
185 Rosen JE, Salazar MC, Wang Z, . Lobectomy versus stereotactic body radiotherapy in healthy patients with stage I lung cancer. J Thorac Cardiovasc Surg. 2016 Jul;152(1):44–54.e9. doi: 10.1016/j.jtcvs.2016.03.060. PMID: 27131846.27131846
186 Cox ML, Yang CJ, Speicher PJ, . The role of extent of surgical resection and lymph node assessment for clinical stage I pulmonary lepidic adenocarcinoma: an analysis of 1991 patients. J Thorac Oncol. 2017 Apr;12(4):689–96. doi: 10.1016/j.jtho.2017.01.003. PMID: 28082103.28082103
187 Speicher PJ, Gu L, Gulack BC, . Sublobar resection for clinical stage IA non-small-cell lung cancer in the United States. Clin Lung Cancer. 2016 Jan;17(1):47–55. doi: 10.1016/j.cllc.2015.07.005. PMID: 26602547.26602547
188 Fernandez FG, Crabtree TD, Liu J, . Sublobar resection versus definitive radiation in patients with stage IA non-small cell lung cancer. Ann Thorac Surg. 2012 Aug;94(2):354–60; discussion 60-1. doi: 10.1016/j.athoracsur.2011.12.092. PMID: 22429673.22429673
189 Khullar OV, Liu Y, Gillespie T, . Survival after sublobar resection versus lobectomy for clinical stage IA lung cancer: an analysis from the national cancer data base. J Thorac Oncol. 2015 Nov;10(11):1625–33. doi: 10.1097/jto.0000000000000664. PMID: 26352534.26352534
190 Sawabata N, Miyaoka E, Asamura H, . Japanese lung cancer registry study of 11,663 surgical cases in 2004: demographic and prognosis changes over decade. J Thorac Oncol. 2011 Jul;6(7):1229–35. doi: 10.1097/JTO.0b013e318219aae2. PMID: 21610521.21610521
191 Maeda R, Yoshida J, Ishii G, . Long-term survival and risk factors for recurrence in stage I non-small cell lung cancer patients with tumors up to 3 cm in maximum dimension. Chest. 2010 Aug;138(2):357–62. doi: 10.1378/chest.09-3046. PMID: 20435660.20435660
192 Chang MY, Mentzer SJ, Colson YL, . Factors predicting poor survival after resection of stage IA non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007 Oct;134(4):850–6. doi: 10.1016/j.jtcvs.2007.03.044. PMID: 17903494.17903494
193 Okada M, Koike T, Higashiyama M, . Radical sublobar resection for small-sized non-small cell lung cancer: a multicenter study. J Thorac Cardiovasc Surg. 2006 Oct;132(4):769–75. doi: 10.1016/j.jtcvs.2006.02.063. PMID: 17000286.17000286
194 Strand TE, Rostad H, Moller B, . Survival after resection for primary lung cancer: a population based study of 3211 resected patients. Thorax. 2006 Aug;61(8):710–5. doi: 10.1136/thx.2005.056481. PMID: 16601091.16601091
195 Goya T, Asamura H, Yoshimura H, . Prognosis of 6644 resected non-small cell lung cancers in Japan: a Japanese lung cancer registry study. Lung Cancer. 2005 Nov;50(2):227–34. doi: 10.1016/j.lungcan.2005.05.021. PMID: 16061304.16061304
196 Bryant AK, Mundt RC, Sandhu AP, . Stereotactic body radiation therapy versus surgery for early lung cancer among US veterans. Ann Thorac Surg. 2018 Feb;105(2):425–31. doi: 10.1016/j.athoracsur.2017.07.048. PMID: 29198624.29198624
197 Sun B, Brooks ED, Komaki RU, . 7-year follow-up after stereotactic ablative radiotherapy for patients with stage I non-small cell lung cancer: results of a phase 2 clinical trial. Cancer. 2017 Aug 15;123(16):3031–9. doi: 10.1002/cncr.30693. PMID: 28346656.28346656
198 Matsuo Y, Chen F, Hamaji M, . Comparison of long-term survival outcomes between stereotactic body radiotherapy and sublobar resection for stage I non-small-cell lung cancer in patients at high risk for lobectomy: A propensity score matching analysis. Eur J Cancer. 2014 Nov;50(17):2932–8. doi: 10.1016/j.ejca.2014.09.006. PMID: 25281527.25281527
199 Arnold BN, Thomas DC, Rosen JE, . Effectiveness of local therapy for stage I non-small-cell lung cancer in nonagenarians. Surgery. 2017 Sep;162(3):640–51. doi: 10.1016/j.surg.2017.04.025. PMID: 28697883.28697883
200 Koshy M, Malik R, Weichselbaum RR, . Increasing radiation therapy dose is associated with improved survival in patients undergoing stereotactic body radiation therapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2015 Feb 1;91(2):344–50. doi: 10.1016/j.ijrobp.2014.10.002. PMID: 25636759.25636759
201 Eba J, Nakamura K, Mizusawa J, . Stereotactic body radiotherapy versus lobectomy for operable clinical stage IA lung adenocarcinoma: comparison of survival outcomes in two clinical trials with propensity score analysis (JCOG1313-A). Jpn J Clin Oncol. 2016 Aug;46(8):748–53. doi: 10.1093/jjco/hyw058. PMID: 27174959.27174959
202 Lam A, Yoshida EJ, Bui K, . A National Cancer Database analysis of radiofrequency ablation versus stereotactic body radiotherapy in early-stage non-small cell lung cancer. J Vasc Interv Radiol. 2018 Jul 27doi: 10.1016/j.jvir.2018.04.029. PMID: 30061058.30061058
203 Jeppesen SS, Hansen NCG, Schytte T, . Survival of localized NSCLC patients without active treatment or treated with SBRT. Acta Oncol. 2018 Feb;57(2):219–25. doi: 10.1080/0284186x.2017.1374558. PMID: 28885080.28885080
204 Brooks ED, Sun B, Zhao L, . Stereotactic ablative radiation therapy is highly safe and effective for elderly patients with early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2017 Jul 15;98(4):900–7. doi: 10.1016/j.ijrobp.2016.12.022. PMID: 28258887.28258887
205 Nagata Y, Hiraoka M, Shibata T, . Prospective trial of stereotactic body radiation therapy for both operable and inoperable T1N0M0 non-small cell lung cancer: japan clinical oncology group study JCOG0403. Int J Radiat Oncol Biol Phys. 2015 Dec 1;93(5):989–96. doi: 10.1016/j.ijrobp.2015.07.2278. PMID: 26581137.26581137
206 Ubels RJ, Mokhles S, Andrinopoulou ER, . Quality of life during 5 years after stereotactic radiotherapy in stage I non-small cell lung cancer. Radiat Oncol. 2015 Apr 22;10:98. doi: 10.1186/s13014-015-0405-9. PMID: 25896787.25896787
207 Lindberg K, Nyman J, Riesenfeld Kallskog V, . Long-term results of a prospective phase II trial of medically inoperable stage I NSCLC treated with SBRT - the Nordic experience. Acta Oncol. 2015;54(8):1096–104. doi: 10.3109/0284186x.2015.1020966. PMID: 25813471.25813471
208 National Cancer Institute. Surveillance, epidemiology, and end results (SEER). Bethesda, MD: National Cancer Institute, Division of Cancer Control and Population Sciences, Surveillance Research Program; 2018. https://seer.cancer.gov/about/factsheets/SEER_Overview.pdf. Accessed May 14, 2019.
209 American College of Surgeons. About the National Cancer Database. Chicago, IL: American College of Surgeons; 2019. Accessed May 15, 2019.
210 Numata T, Araya J, Yoshii Y, . Clinical efficacy of anti-glycopeptidolipid-core IgA test for diagnosing Mycobacterium avium complex infection in lung. Respirology. 2015 Nov;20(8):1277–81. doi: 10.1111/resp.12640. PMID: 26338466.26338466
211 Charlson ME, Pompei P, Ales KL, . A new method of classifying prognostic comorbidity in longitudinal studies: development and validation. J Chronic Dis. 1987;40(5):373–83. PMID: 3558716.3558716
212 Brunelli A, Varela G, Salati M, . Recalibration of the revised cardiac risk index in lung resection candidates. Ann Thorac Surg. 2010 Jul;90(1):199–203. doi: 10.1016/j.athoracsur.2010.03.042. PMID: 20609775.20609775
213 Thomas DC, Blasberg JD, Arnold BN, . Validating the thoracic revised cardiac risk index following lung resection. Ann Thorac Surg. 2017 Aug;104(2):389–94. doi: 10.1016/j.athoracsur.2017.02.006. PMID: 28499655.28499655
214 Moon MH, Moon YK, Moon SW. Segmentectomy versus lobectomy in early non-small cell lung cancer of 2 cm or less in size: a population-based study. Respirology. 2018 Jul;23(7):695–703. doi: 10.1111/resp.13277. PMID: 29465766.29465766
215 Zhou H, Zhang Y, Qiu Z, . Nomogram to predict cause-specific mortality in patients with surgically resected stage I non-small-cell lung cancer: a competing risk analysis. Clin Lung Cancer. 2018 Mar;19(2):e195–e203. doi: 10.1016/j.cllc.2017.10.016. PMID: 29153966.29153966
216 Berry MF, Canchola AJ, Gensheimer MF, . Factors associated with treatment of clinical stage I non-small-cell lung cancer: a population-based analysis. Clin Lung Cancer. 2018 Sep;19(5):e745–e58. doi: 10.1016/j.cllc.2018.05.009. PMID: 30149883.30149883
217 Dziedzic R, Zurek W, Marjanski T, . Stage I non-small-cell lung cancer: long-term results of lobectomy versus sublobar resection from the Polish National Lung Cancer Registry. Eur J Cardiothorac Surg. 2017 Aug 1;52(2):363–9. doi: 10.1093/ejcts/ezx092. PMID: 28402455.28402455
218 Handa Y, Tsutani Y, Ikeda T, . Reassessment of right middle lobe lung cancer: comparison of segments 4 and 5 tumors. Ann Thorac Surg. 2018 May;105(5):1543–50. doi: 10.1016/j.athoracsur.2017.12.007. PMID: 29329989.29329989
219 Liu Y, Shen J, Liu L, . Impact of examined lymph node counts on survival of patients with stage IA non-small cell lung cancer undergoing sublobar resection. J Thorac Dis. 2018 Dec;10(12):6569–77. doi: 10.21037/jtd.2018.11.49. PMID: 30746202.30746202
220 Lutz JA, Seguin-Givelet A, Grigoroiu M, . Oncological results of full thoracoscopic major pulmonary resections for clinical Stage I non-small-cell lung cancer. Eur J Cardiothorac Surg. 2019 Feb 1;55(2):263–70. doi: 10.1093/ejcts/ezy245. PMID: 30052990.30052990
221 Lv X, Cao J, Dai X, . Survival rates after lobectomy versus sublobar resection for early-stage right middle lobe non-small cell lung cancer. Thorac Cancer. 2018 Aug;9(8):1026–31. doi: 10.1111/1759-7714.12782. PMID: 29927089.29927089
222 Sekihara K, Aokage K, Oki T, . Long-term survival after complete resection of non-small-cell lung cancer in patients with interstitial lung disease. Interact Cardiovasc Thorac Surg. 2018 Apr 1;26(4):638–43. doi: 10.1093/icvts/ivx400. PMID: 29272403.29272403
223 Jeppesen SS, Schytte T, Jensen HR, . Stereotactic body radiation therapy versus conventional radiation therapy in patients with early stage non-small cell lung cancer: an updated retrospective study on local failure and survival rates. Acta Oncol. 2013 Oct;52(7):1552–8. doi: 10.3109/0284186x.2013.813635. PMID: 23902274.23902274
224 Inoue T, Katoh N, Onimaru R, . Stereotactic body radiotherapy using gated radiotherapy with real-time tumor-tracking for stage I non-small cell lung cancer. Radiat Oncol. 2013 Mar 21;8:69. doi: 10.1186/1748-717x-8-69. PMID: 23518013.23518013
225 Lagerwaard FJ, Verstegen NE, Haasbeek CJ, . Outcomes of stereotactic ablative radiotherapy in patients with potentially operable stage I non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2012 May 1;83(1):348–53. doi: 10.1016/j.ijrobp.2011.06.2003. PMID: 22104360.22104360
226 Onishi H, Shirato H, Nagata Y, . Hypofractionated stereotactic radiotherapy (HypoFXSRT) for stage I non-small cell lung cancer: updated results of 257 patients in a Japanese multi-institutional study. J Thorac Oncol. 2007 Jul;2(7 Suppl 3):S94–100. doi: 10.1097/JTO.0b013e318074de34. PMID: 17603311.17603311
227 Baumann P, Nyman J, Lax I, . Factors important for efficacy of stereotactic body radiotherapy of medically inoperable stage I lung cancer. A retrospective analysis of patients treated in the Nordic countries. Acta Oncol. 2006;45(7):787–95. doi: 10.1080/02841860600904862. PMID: 16982541.16982541
228 Uhlig J, Ludwig JM, Goldberg SB, . Survival rates after thermal ablation versus stereotactic radiation therapy for stage 1 non-small cell lung cancer: a national cancer database study. Radiology. 2018 Dec;289(3):862–70. doi: 10.1148/radiol.2018180979. PMID: 30226453.30226453
229 Karasawa K, Hayakawa S, Machitori Y, . Accelerated hypofractionated radiotherapy versus stereotactic body radiotherapy for the treatment of stage I nonsmall cell lung cancer-a single institution experience with long-term follow-up. Technol Cancer Res Treat. 2018 Jan 1;17:1533033818806318. doi: 10.1177/1533033818806318. PMID: 30317929.30317929
230 Manyam BV, Videtic GMM, Verdecchia K, . Effect of tumor location and dosimetric predictors for chest wall toxicity in single-fraction stereotactic body radiation therapy for stage I non-small cell lung cancer. Pract Radiat Oncol. 2019 Mar;9(2):e187–e95. doi: 10.1016/j.prro.2018.11.011. PMID: 30529796.30529796
231 Detillon D, Aarts MJ, De Jaeger K, . Video-assisted thoracic lobectomy versus stereotactic body radiotherapy for stage I non-small cell lung cancer in elderly patients: a propensity matched comparative analysis. Eur Respir J. 2019 Mar 28doi: 10.1183/13993003.01561-2018. PMID: 30923188.30923188
232 Baine MJ, Sleightholm R, Neilsen BK, . Stereotactic body radiation therapy versus nonradiotherapeutic ablative procedures (laser/cryoablation and electrocautery) for early-stage non-small cell lung cancer. J Natl Compr Canc Netw. 2019 May 1;17(5):450–8. doi: 10.6004/jnccn.2018.7269. PMID: 31085762.31085762
233 Cummings MA, Ma SJ, Hermann G, . Comparison of single- and five-fraction regimens of stereotactic body radiation therapy for peripheral early-stage non-small-cell lung cancer: a two-institution propensity-matched analysis. Clin Lung Cancer. 2018 Nov;19(6):511–7. doi: 10.1016/j.cllc.2018.07.006. PMID: 30131257.30131257
234 Lee S, Song SY, Kim SS, . Feasible optimization of stereotactic ablative radiotherapy dose by tumor size for stage I non-small-cell lung cancer. Clin Lung Cancer. 2018 Mar;19(2):e253–e61. doi: 10.1016/j.cllc.2017.11.001. PMID: 29196082.29196082
235 Wink KCJ, Lock S, Rossi M, . Contact of a tumour with the pleura is not associated with regional recurrence following stereotactic ablative radiotherapy for early stage non-small cell lung cancer. Radiother Oncol. 2019 Feb;131:120–6. doi: 10.1016/j.radonc.2018.11.024. PMID: 30773178.30773178
236 Shibamoto Y, Hashizume C, Baba F, . Stereotactic body radiotherapy using a radiobiology-based regimen for stage I nonsmall cell lung cancer: a multicenter study. Cancer. 2012 Apr 15;118(8):2078–84. doi: 10.1002/cncr.26470. PMID: 22009495.22009495
237 Shirvani SM, Jiang J, Chang JY, . Comparative effectiveness of 5 treatment strategies for early-stage non-small cell lung cancer in the elderly. Int J Radiat Oncol Biol Phys. 2012 Dec 1;84(5):1060–70. doi: 10.1016/j.ijrobp.2012.07.2354. PMID: 22975611.22975611
238 Louie BE, Wilson JL, Kim S, . Comparison of video-assisted thoracoscopic surgery and robotic approaches for clinical Stage I and Stage II non-small cell lung cancer using the Society of Thoracic Surgeons Database. Ann Thorac Surg. 2016 Sep;102(3):917–24. doi: 10.1016/j.athoracsur.2016.03.032. PMID: 27209613.27209613
239 Husain ZA, Kim AW, Yu JB, . Defining the high-risk population for mortality after resection of early stage NSCLC. Clin Lung Cancer. 2015 Nov;16(6):e183–7. doi: 10.1016/j.cllc.2015.04.007. PMID: 25979646.25979646
240 Samson P, Patel A, Garrett T, . Effects of delayed surgical resection on short-term and long-term outcomes in clinical stage I non-small cell lung cancer. Ann Thorac Surg. 2015 Jun;99(6):1906–12; discussion 13. doi: 10.1016/j.athoracsur.2015.02.022. PMID: 25890663.25890663
241 Shirvani SM, Jiang J, Chang JY, . Lobectomy, sublobar resection, and stereotactic ablative radiotherapy for early-stage non-small cell lung cancers in the elderly. JAMA Surg. 2014 Dec;149(12):1244–53. doi: 10.1001/jamasurg.2014.556. PMID: 25321323.25321323
242 Puri V, Crabtree TD, Bell JM, . National cooperative group trials of “high-risk” patients with lung cancer: are they truly “high-risk”? Ann Thorac Surg. 2014 May;97(5):1678–83; discussion 83-5. doi: 10.1016/j.athoracsur.2013.12.028. PMID: 24534644.24534644
243 Melvan JN, Sancheti MS, Gillespie T, . Nonclinical factors associated with 30-day mortality after lung cancer resection: an analysis of 215,000 patients using the National Cancer Data Base. J Am Coll Surg. 2015 Aug;221(2):550–63. doi: 10.1016/j.jamcollsurg.2015.03.056. PMID: 26206651.26206651
244 Rosen JE, Hancock JG, Kim AW, . Predictors of mortality after surgical management of lung cancer in the National Cancer Database. Ann Thorac Surg. 2014 Dec;98(6):1953–60. doi: 10.1016/j.athoracsur.2014.07.007. PMID: 25443003.25443003
245 Samson P, Crabtree T, Broderick S, . Quality measures in clinical stage I non-small cell lung cancer: improved performance is associated with improved survival. Ann Thorac Surg. 2017 Jan;103(1):303–11. doi: 10.1016/j.athoracsur.2016.07.003. PMID: 27665480.27665480
246 Valle LF, Jagsi R, Bobiak SN, . Variation in definitive therapy for localized non-small cell lung cancer among national comprehensive cancer network institutions. Int J Radiat Oncol Biol Phys. 2016 Feb 1;94(2):360–7. doi: 10.1016/j.ijrobp.2015.10.030. PMID: 26853344.26853344
247 Shapiro M, Mhango G, Kates M, . Extent of lymph node resection does not increase perioperative morbidity and mortality after surgery for stage I lung cancer in the elderly. Eur J Surg Oncol. 2012 Jun;38(6):516–22. doi: 10.1016/j.ejso.2011.12.018. PMID: 22244908.22244908
248 Schuchert MJ, Awais O, Abbas G, . Influence of age and IB status after resection of node-negative non-small cell lung cancer. Ann Thorac Surg. 2012 Mar;93(3):929–35; discussion 35-6. doi: 10.1016/j.athoracsur.2011.09.047. PMID: 22364984.22364984
249 Licht PB, Jorgensen OD, Ladegaard L, . A national study of nodal upstaging after thoracoscopic versus open lobectomy for clinical stage I lung cancer. Ann Thorac Surg. 2013 Sep;96(3):943–9; discussion 9-50. doi: 10.1016/j.athoracsur.2013.04.011. PMID: 23684159.23684159
250 Yang CF, Sun Z, Speicher PJ, . Use and outcomes of minimally invasive lobectomy for stage I non-small cell lung cancer in the national cancer data base. Ann Thorac Surg. 2016 Mar;101(3):1037–42. doi: 10.1016/j.athoracsur.2015.11.018. PMID: 26822346.26822346
251 Stokes WA, Bronsert MR, Meguid RA, . Post-treatment mortality after surgery and stereotactic body radiotherapy for early-stage non-small-cell lung cancer. J Clin Oncol. 2018 Mar 1;36(7):642–51. doi: 10.1200/jco.2017.75.6536. PMID: 29346041.29346041
252 Puri V, Crabtree TD, Bell JM, . Treatment outcomes in stage I lung cancer: a comparison of surgery and stereotactic body radiation therapy. J Thorac Oncol. 2015 Dec;10(12):1776–84. doi: 10.1097/jto.0000000000000680. PMID: 26334753.26334753
253 Brown LM, Louie BE, Jackson N, . Recurrence and survival after segmentectomy in patients with prior lung resection for early-stage non-small cell lung cancer. Ann Thorac Surg. 2016 Oct;102(4):1110–8. doi: 10.1016/j.athoracsur.2016.04.037. PMID: 27350237.27350237
254 Bibault JE, Mirabel X, Lacornerie T, . Adapted prescription dose for Monte Carlo algorithm in lung SBRT: clinical outcome on 205 patients. PLoS One. 2015;10(7):e0133617. doi: 10.1371/journal.pone.0133617. PMID: 26207808.26207808
255 Katoh N, Soda I, Tamamura H, . Clinical outcomes of stage I and IIA non-small cell lung cancer patients treated with stereotactic body radiotherapy using a real-time tumor-tracking radiotherapy system. Radiat Oncol. 2017 Jan 5;12(1):3. doi: 10.1186/s13014-016-0742-3. PMID: 28057036.28057036
256 Grills IS, Hope AJ, Guckenberger M, . A collaborative analysis of stereotactic lung radiotherapy outcomes for early-stage non-small-cell lung cancer using daily online cone-beam computed tomography image-guided radiotherapy. J Thorac Oncol. 2012 Sep;7(9):1382–93. doi: 10.1097/JTO.0b013e318260e00d. PMID: 22843086.22843086
257 Haidar YM, Rahn DA, 3rd, Nath S, . Comparison of outcomes following stereotactic body radiotherapy for non-small cell lung cancer in patients with and without pathological confirmation. Ther Adv Respir Dis. 2014 Feb;8(1):3–12. doi: 10.1177/1753465813512545. PMID: 24334338.24334338
258 Rosen LR, Fischer-Valuck BW, Katz SR, . Helical image-guided stereotactic body radiotherapy (SBRT) for the treatment of early-stage lung cancer: a single-institution experience at the Willis-Knighton Cancer Center. Tumori. 2014 Jan-Feb;100(1):42–8. doi: 10.1700/1430.15814. PMID: 24675490.24675490
259 Allibhai Z, Taremi M, Bezjak A, . The impact of tumor size on outcomes after stereotactic body radiation therapy for medically inoperable early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2013 Dec 1;87(5):1064–70. doi: 10.1016/j.ijrobp.2013.08.020. PMID: 24210082.24210082
260 Mathieu D, Campeau MP, Bahig H, . Long-term quality of life in early-stage non-small cell lung cancer patients treated with robotic stereotactic ablative radiation therapy. Pract Radiat Oncol. 2015 Jul-Aug;5(4):e365–73. doi: 10.1016/j.prro.2014.12.002. PMID: 25680997.25680997
261 Taremi M, Hope A, Lindsay P, . Predictors of radiotherapy induced bone injury (RIBI) after stereotactic lung radiotherapy. Radiat Oncol. 2012 Sep 17;7:159. doi: 10.1186/1748-717x-7-159. PMID: 22985910.22985910
262 Ferrero C, Badellino S, Filippi AR, . Pulmonary function and quality of life after VMAT-based stereotactic ablative radiotherapy for early stage inoperable NSCLC: a prospective study. Lung Cancer. 2015 Sep;89(3):350–6. doi: 10.1016/j.lungcan.2015.06.019. PMID: 26164208.26164208
263 Videtic GM, Hu C, Singh AK, . A randomized phase 2 study comparing 2 stereotactic body radiation therapy schedules for medically inoperable patients with stage I peripheral non-small cell lung cancer: NRG oncology RTOG 0915 (NCCTG N0927). Int J Radiat Oncol Biol Phys. 2015 Nov 15;93(4):757–64. doi: 10.1016/j.ijrobp.2015.07.2260. PMID: 26530743.26530743
264 Taremi M, Hope A, Dahele M, . Stereotactic body radiotherapy for medically inoperable lung cancer: prospective, single-center study of 108 consecutive patients. Int J Radiat Oncol Biol Phys. 2012 Feb 1;82(2):967–73. doi: 10.1016/j.ijrobp.2010.12.039. PMID: 21377293.21377293
265 Crabtree T, Puri V, Timmerman R, . Treatment of stage I lung cancer in high-risk and inoperable patients: comparison of prospective clinical trials using stereotactic body radiotherapy (RTOG 0236), sublobar resection (ACOSOG Z4032), and radiofrequency ablation (ACOSOG Z4033). J Thorac Cardiovasc Surg. 2013 Mar;145(3):692–9. doi: 10.1016/j.jtcvs.2012.10.038. PMID: 23174176.23174176
266 Robinson CG, DeWees TA, El Naqa IM, . Patterns of failure after stereotactic body radiation therapy or lobar resection for clinical stage I non-small-cell lung cancer. J Thorac Oncol. 2013 Feb;8(2):192–201. doi: 10.1097/JTO.0b013e31827ce361. PMID: 23287852.23287852
267 Nyman J, Hallqvist A, Lund JA, . SPACE - A randomized study of SBRT vs conventional fractionated radiotherapy in medically inoperable stage I NSCLC. Radiother Oncol. 2016 Oct;121(1):1–8. doi: 10.1016/j.radonc.2016.08.015. PMID: 27600155.27600155
268 Jeon W, Ahn SJ, Kim YC, . Correlation of biologically effective dose and the tumor control in Stage I (<5 cm) non-small cell lung cancer with stereotactic ablative radiotherapy: a single institutional cohort study. Jpn J Clin Oncol. 2018 Feb 1;48(2):144–52. doi: 10.1093/jjco/hyx172. PMID: 29194510.29194510
269 Ma SJ, Serra LM, Syed YA, . Comparison of single- and three-fraction schedules of stereotactic body radiation therapy for peripheral early-stage non-small-cell lung cancer. Clin Lung Cancer. 2018 Mar;19(2):e235–e40. doi: 10.1016/j.cllc.2017.10.010. PMID: 29153897.29153897
270 Badellino S, Muzio JD, Schivazappa G, . No differences in radiological changes after 3D conformal vs VMAT-based stereotactic radiotherapy for early stage non-small cell lung cancer. Br J Radiol. 2017 Oct;90(1078):20170143. doi: 10.1259/bjr.20170143. PMID: 28749172.28749172
271 Videtic GM, Stephans KL, Woody NM, . 30 Gy or 34 Gy? Comparing 2 single-fraction SBRT dose schedules for stage I medically inoperable non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2014 Sep 1;90(1):203–8. doi: 10.1016/j.ijrobp.2014.05.017. PMID: 25015198.25015198
272 Timmerman R, Paulus R, Galvin J, . Stereotactic body radiation therapy for inoperable early stage lung cancer. JAMA. 2010 Mar 17;303(11):1070–6. doi: 10.1001/jama.2010.261. PMID: 20233825.20233825
273 Ezer N, Kale M, Sigel K, . Outcomes after video-assisted thoracoscopic lobectomy versus open lobectomy for early-stage lung cancer in older adults. Ann Am Thorac Soc. 2018 Jan;15(1):76–82. doi: 10.1513/AnnalsATS.201612-980OC. PMID: 29121474.29121474
274 Ueda T, Suzuki K, Matsunaga T, . Postoperative atrial fibrillation is less frequent in pulmonary segmentectomy compared with lobectomy. Gen Thorac Cardiovasc Surg. 2018 Feb;66(2):95–100. doi: 10.1007/s11748-017-0858-x. PMID: 29134538.29134538
275 Weiss E, Wijesooriya K, Dill SV, . Tumor and normal tissue motion in the thorax during respiration: analysis of volumetric and positional variations using 4D CT. Int J Radiat Oncol Biol Phys. 2007 Jan 1;67(1):296–307. doi: 10.1016/j.ijrobp.2006.09.009. PMID: 17189078.17189078
276 National Cancer Institute. Common terminology criteria for adverse events (CTCAE). Version 4.0. U.S. Department of Health and Human Services, National Institutes of Health and the National Cancer Institute. Washington, DC: June 14 2010. https://www.eortc.be/services/doc/ctc/CTCAE_4.03_2010-06-14_QuickReference_5x7.pdf
277 RTOG Foundation. Cooperative group common toxicity criteria Philadelphia, PA: NRG Oncology Philadelphia West Research Center; 2019. Accessed May 15, 2019.
278 Factor OB, Vu CC, Schneider JG, . Stereotactic body radiation therapy for stage I non-small cell lung cancer: a small academic hospital experience. Front Oncol. 2014;4:287. doi: 10.3389/fonc.2014.00287. PMID: 25368843.25368843
279 Stanic S, Paulus R, Timmerman RD, . No clinically significant changes in pulmonary function following stereotactic body radiation therapy for early- stage peripheral non-small cell lung cancer: an analysis of RTOG 0236. Int J Radiat Oncol Biol Phys. 2014 Apr 1;88(5):1092–9. doi: 10.1016/j.ijrobp.2013.12.050. PMID: 24661663.24661663
280 Guckenberger M, Allgauer M, Appold S, . Safety and efficacy of stereotactic body radiotherapy for stage 1 non-small-cell lung cancer in routine clinical practice: a patterns-of-care and outcome analysis. J Thorac Oncol. 2013 Aug;8(8):1050–8. doi: 10.1097/JTO.0b013e318293dc45. PMID: 23817193.23817193
281 Fischer-Valuck BW, Durci M, Katz SR, . Influence of patient characteristics on survival following treatment with helical stereotactic body radiotherapy (SBRT) in stage I non-small-cell lung cancer. Thorac Cancer. 2013 Feb;4(1):27–34. doi: 10.1111/j.1759-7714.2012.00137.x. PMID: 28920325.28920325
282 Chang JY, Liu H, Balter P, . Clinical outcome and predictors of survival and pneumonitis after stereotactic ablative radiotherapy for stage I non-small cell lung cancer. Radiat Oncol. 2012 Sep 10;7:152. doi: 10.1186/1748-717x-7-152. PMID: 22963661.22963661
283 Lagerwaard FJ, Aaronson NK, Gundy CM, . Patient-reported quality of life after stereotactic ablative radiotherapy for early-stage lung cancer. J Thorac Oncol. 2012 Jul;7(7):1148–54. doi: 10.1097/JTO.0b013e318252cfef. PMID: 22610256.22610256
284 Westover KD, Seco J, Adams JA, . Proton SBRT for medically inoperable stage I NSCLC. J Thorac Oncol. 2012 Jun;7(6):1021–5. doi: 10.1097/JTO.0b013e31824de0bf. PMID: 22551902.22551902
285 Matsuo Y, Shibuya K, Nakamura M, . Dose--volume metrics associated with radiation pneumonitis after stereotactic body radiation therapy for lung cancer. Int J Radiat Oncol Biol Phys. 2012 Jul 15;83(4):e545–9. doi: 10.1016/j.ijrobp.2012.01.018. PMID: 22436782.22436782
286 Bongers EM, Haasbeek CJ, Lagerwaard FJ, . Incidence and risk factors for chest wall toxicity after risk-adapted stereotactic radiotherapy for early-stage lung cancer. J Thorac Oncol. 2011 Dec;6(12):2052–7. doi: 10.1097/JTO.0b013e3182307e74. PMID: 22052227.22052227
287 Mutter RW, Liu F, Abreu A, . Dose-volume parameters predict for the development of chest wall pain after stereotactic body radiation for lung cancer. Int J Radiat Oncol Biol Phys. 2012 Apr 1;82(5):1783–90. doi: 10.1016/j.ijrobp.2011.03.053. PMID: 21868173.21868173
288 Olsen JR, Robinson CG, El Naqa I, . Dose-response for stereotactic body radiotherapy in early-stage non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011 Nov 15;81(4):e299–303. doi: 10.1016/j.ijrobp.2011.01.038. PMID: 21477948.21477948
289 Palma D, Visser O, Lagerwaard FJ, . Impact of introducing stereotactic lung radiotherapy for elderly patients with stage I non-small-cell lung cancer: a population-based time-trend analysis. J Clin Oncol. 2010 Dec 10;28(35):5153–9. doi: 10.1200/jco.2010.30.0731. PMID: 21041709.21041709
290 Barriger RB, Forquer JA, Brabham JG, . A dose-volume analysis of radiation pneumonitis in non-small cell lung cancer patients treated with stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 2012 Jan 1;82(1):457–62. doi: 10.1016/j.ijrobp.2010.08.056. PMID: 21035956.21035956
291 Haasbeek CJ, Lagerwaard FJ, Antonisse ME, . Stage I nonsmall cell lung cancer in patients aged > or =75 years: outcomes after stereotactic radiotherapy. Cancer. 2010 Jan 15;116(2):406–14. doi: 10.1002/cncr.24759. PMID: 19950125.19950125
292 Lagerwaard FJ, Haasbeek CJ, Smit EF, . Outcomes of risk-adapted fractionated stereotactic radiotherapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2008 Mar 1;70(3):685–92. doi: 10.1016/j.ijrobp.2007.10.053. PMID: 18164849.18164849
293 Ball D, Mai GT, Vinod S, . Stereotactic ablative radiotherapy versus standard radiotherapy in stage 1 non-small-cell lung cancer (TROG 09.02 CHISEL): a phase 3, open-label, randomised controlled trial. Lancet Oncol. 2019 Apr;20(4):494–503. doi: 10.1016/S1470-2045(18)30896-9. PMID: 30770291.30770291
294 Ye L, Xu F, Shi S, . A SUVmax-based propensity matched analysis of stereotactic body radiotherapy versus surgery in stage I non-small cell lung cancer: unveiling the role of 18F-FDG PET/CT in clinical decision-making. Clin Transl Oncol. 2018 Aug;20(8):1026–34. doi: 10.1007/s12094-017-1819-7. PMID: 29327241.29327241
295 Ackerson BG, Tong BC, Hong JC, . Stereotactic body radiation therapy versus sublobar resection for stage I NSCLC. Lung Cancer. 2018 Nov;125:185–91. doi: 10.1016/j.lungcan.2018.09.020. PMID: 30429018.30429018
296 Bach PB, Cramer LD, Schrag D, . The influence of hospital volume on survival after resection for lung cancer. N Engl J Med. 2001 Jul 19;345(3):181–8. doi: 10.1056/nejm200107193450306. PMID: 11463014.11463014
297 Robbins HA, Callister M, Sasieni P, . Benefits and harms in the National Lung Screening Trial: expected outcomes with a modern management protocol. Lancet Respiratory Medicine. 2019doi: 10.1016/S2213-2600(19)30136-5.
298 Rachet B, Siemiatycki J, Abrahamowicz M, . A flexible modeling approach to estimating the component effects of smoking behavior on lung cancer. J Clin Epidemiol. 2004 Oct;57(10):1076–85. doi: 10.1016/j.jclinepi.2004.02.014. PMID: 15528059.15528059
299 Remen T, Pintos J, Abrahamowicz M, . Risk of lung cancer in relation to various metrics of smoking history: a case-control study in Montreal. BMC Cancer. 2018 Dec 19;18(1):1275. doi: 10.1186/s12885-018-5144-5. PMID: 30567516.30567516
300 Meza R, de Koning HJ, Kong C-Y, . Evaluation of the benefits and harms of lung cancer screening with with low-dose CT: a collaborative modeling study for the U.S. Preventive Services Task Force. Prepared by the Cancer Intervention and Surveillance Modeling Network (CISNET), Lung Cancer Working Group under Contract No. HHSA-290-2015-00011-I, Task Order 11. Rockville, MD: Agency for Healthcare Research and Quality; in process.
301 Lovinfosse P, Janvary ZL, Coucke P, . FDG PET/CT texture analysis for predicting the outcome of lung cancer treated by stereotactic body radiation therapy. Eur J Nucl Med Mol Imaging. 2016 Jul;43(8):1453–60. doi: 10.1007/s00259-016-3314-8. PMID: 26830299.26830299
302 Woody NM, Stephans KL, Andrews M, . A histologic basis for the efficacy of SBRT to the lung. J Thorac Oncol. 2017 Mar;12(3):510–9. doi: 10.1016/j.jtho.2016.11.002. PMID: 28017592.28017592
303 Horner-Rieber J, Bernhardt D, Dern J, . Histology of non-small cell lung cancer predicts the response to stereotactic body radiotherapy. Radiother Oncol. 2017 Nov;125(2):317–24. doi: 10.1016/j.radonc.2017.08.029. PMID: 28919006.28919006
304 Shultz DB, Trakul N, Abelson JA, . Imaging features associated with disease progression after stereotactic ablative radiotherapy for stage I non-small-cell lung cancer. Clin Lung Cancer. 2014 Jul;15(4):294–301.e3. doi: 10.1016/j.cllc.2013.12.011. PMID: 24594400.24594400
305 Atallah S, Cho BC, Allibhai Z, . Impact of pretreatment tumor growth rate on outcome of early-stage lung cancer treated with stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 2014 Jul 1;89(3):532–8. doi: 10.1016/j.ijrobp.2014.03.003. PMID: 24929163.24929163
306 Marwaha G, Stephans KL, Woody NM, . Lung stereotactic body radiation therapy: regional nodal failure is not predicted by tumor size. J Thorac Oncol. 2014 Nov;9(11):1693–7. doi: 10.1097/jto.0000000000000313. PMID: 25185531.25185531
307 Hamamoto Y, Kataoka M, Yamashita M, . Lung-cancer related chest events detected by periodical follow-up CT after stereotactic body radiotherapy for stage I primary lung cancer: retrospective analysis of incidence of lung-cancer related chest events and outcomes of salvage treatment. Jpn J Radiol. 2012 Oct;30(8):671–5. doi: 10.1007/s11604-012-0107-2. PMID: 22836906.22836906
308 Mak RH, Hermann G, Lewis JH, . Outcomes by tumor histology and KRAS mutation status after lung stereotactic body radiation therapy for early-stage non-small-cell lung cancer. Clin Lung Cancer. 2015 Jan;16(1):24–32. doi: 10.1016/j.cllc.2014.09.005. PMID: 25450872.25450872
309 Kishi T, Matsuo Y, Ueki N, . Pretreatment Modified Glasgow Prognostic Score predicts clinical outcomes after stereotactic body radiation therapy for early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2015 Jul 1;92(3):619–26. doi: 10.1016/j.ijrobp.2015.02.018. PMID: 26068494.26068494
310 Paul S, Lee PC, Mao J, . Long term survival with stereotactic ablative radiotherapy (SABR) versus thoracoscopic sublobar lung resection in elderly people: national population based study with propensity matched comparative analysis. BMJ. 2016 Jul 8;354:i3570. doi: 10.1136/bmj.i3570. PMID: 27400862.27400862
311 Roach MC, Rehman S, DeWees TA, . It’s never too late: smoking cessation after stereotactic body radiation therapy for non-small cell lung carcinoma improves overall survival. Pract Radiat Oncol. 2016 Jan-Feb;6(1):12–8. doi: 10.1016/j.prro.2015.09.005. PMID: 26598909.26598909
312 Sun V, Kim JY, Williams AC, . Quality of life and symptoms following stereotactic body radiotherapy in early-stage lung cancer patients. J Community Support Oncol. 2014 Nov;12(11):407–14. PMID: 25789332.25789332
313 Koshy M, Malik R, Mahmood U, . Stereotactic body radiotherapy and treatment at a high volume facility is associated with improved survival in patients with inoperable stage I non-small cell lung cancer. Radiother Oncol. 2015 Feb;114(2):148–54. doi: 10.1016/j.radonc.2014.12.004. PMID: 25586951.25586951
314 van den Bergh KA, Essink-Bot ML, Bunge EM, . Impact of computed tomography screening for lung cancer on participants in a randomized controlled trial (NELSON trial). Cancer. 2008 Jul 15;113(2):396–404. doi: 10.1002/cncr.23590. PMID: 18484588.18484588
315 Mazzone PJ, Silvestri GA, Patel S, . Screening for Lung Cancer: CHEST Guideline and Expert Panel Report. Chest. 2018 Jan 24doi: 10.1016/j.chest.2018.01.016. PMID: 29374513.29374513
316 Sullivan FM, Farmer E, Mair FS, . Detection in blood of autoantibodies to tumour antigens as a case-finding method in lung cancer using the EarlyCDT(R)-Lung Test (ECLS): study protocol for a randomized controlled trial. BMC Cancer. 2017 Mar 11;17(1):187. doi: 10.1186/s12885-017-3175-y. PMID: 28284200.28284200
317 Sagawa M, Nakayama T, Tanaka M, . A randomized controlled trial on the efficacy of thoracic CT screening for lung cancer in non-smokers and smokers of <30 pack-years aged 50-64 years (JECS study): research design. Jpn J Clin Oncol. 2012 Dec;42(12):1219–21. doi: 10.1093/jjco/hys157. PMID: 23042771.23042771
318 Yang W, Qian F, Teng J, . Community-based lung cancer screening with low-dose CT in China: Results of the baseline screening. Lung Cancer. 2018 Mar;117:20–6. doi: 10.1016/j.lungcan.2018.01.003. PMID: 29496251.29496251
319 Detterbeck FC, Boffa DJ, Kim AW, . The eighth edition lung cancer stage classification. Chest. 2017 Jan;151(1):193–203. doi: 10.1016/j.chest.2016.10.010. PMID: 27780786.27780786
320 Reck M, Rabe KF. Precision diagnosis and treatment for advanced non-small-cell lung cancer. N Engl J Med. 2017 Aug 31;377(9):849–61. doi: 10.1056/NEJMra1703413. PMID: 28854088.28854088
321 Morrow DA. Chest discomfort. In Harrison’s principles of internal medicine. [cited 1/22/18]. New York, NY: McGraw-Hill. 2014. Available from: http://accessmedicine.mhmedical.com/content.aspx?bookid=1130&sectionid=79724231. ClinicalTrials.gov Identifier:
322 Ettinger DS, Wood DE, Aisner DL, . Non-small cell lung cancer, version 5.2017, NCCN Clinical Practice Guidelines in Oncology. J Natl Compr Canc Netw. 2017 Apr;15(4):504–35. PMID: 28404761.28404761
323 American Cancer Society Medical and Editorial Content Team. Non-small cell lung cancer survival rates, by stage. Atlanta, GA: American Cancer Society; 2017. https://www.cancer.org/cancer/non-small-cell-lung-cancer/detection-diagnosis-staging/survival-rates.html. Accessed January 22, 2018.
324 Hazelton WD, Jeon J, Meza R, . Chapter 8: the FHCRC lung cancer model. Risk Anal. 2012 Jul;32 Suppl 1:S99–S116. doi: 10.1111/j.1539-6924.2011.01681.x. PMID: 22882896.22882896
325 Heuvelmans MA, Oudkerk M, de Jong PA, . The impact of radiologists’ expertise on screen results decisions in a CT lung cancer screening trial. Eur Radiol. 2015 Mar;25(3):792–9. doi: 10.1007/s00330-014-3467-4. PMID: 25366707.25366707
326 National Comprehensive Cancer Network. NCCN clinical practice guidelines in oncology: small cell lung cancer. Version 2.2017. Fort Washington, PA: National Comprehensive Cancer Network; September 15 2016. https://www.tri-kobe.org/nccn/guideline/lung/english/small.pdf
327 Chen VW, Ruiz BA, Hsieh MC, . Analysis of stage and clinical/prognostic factors for lung cancer from SEER registries: AJCC staging and collaborative stage data collection system. Cancer. 2014 Dec 1;120 Suppl 23:3781–92. doi: 10.1002/cncr.29045. PMID: 25412390.25412390
328 Wender R, Fontham ET, Barrera E, Jr., . American Cancer Society lung cancer screening guidelines. CA Cancer J Clin. 2013 Mar-Apr;63(2):107–17. doi: 10.3322/caac.21172. PMID: 23315954.23315954
329 Smith RA, Andrews K, Brooks D, . Cancer screening in the United States, 2016: a review of current American Cancer Society guidelines and current issues in cancer screening. CA Cancer J Clin. 2016 Mar-Apr;66(2):96–114. doi: 10.3322/caac.21336. PMID: 26797525.26797525
330 American Lung Association. Providing guidance on lung cancer screening to patients and physicians. An update from the American Lung Association Screening Committee. American Lung Association. April 30, 2015 2015. http://www.lung.org/assets/documents/lung-cancer/lung-cancer-screening-report.pdf
331 Jaklitsch MT, Jacobson FL, Austin JH, . The American Association for Thoracic Surgery guidelines for lung cancer screening using low-dose computed tomography scans for lung cancer survivors and other high-risk groups. J Thorac Cardiovasc Surg. 2012 Jul;144(1):33–8. doi: 10.1016/j.jtcvs.2012.05.060. PMID: 22710039.22710039
332 Oudkerk M, Devaraj A, Vliegenthart R, . European position statement on lung cancer screening. Lancet Oncol. 2017 Dec;18(12):e754–e66. doi: 10.1016/S1470-2045(17)30861-6. PMID: 29208441.29208441
333 Wood DE, Eapen GA, Ettinger DS, . Lung cancer screening. J Natl Compr Canc Netw. 2012 Feb;10(2):240–65. PMID: 22308518.22308518
334 Lewin G, Morissette K, Dickinson J, . Recommendations on screening for lung cancer. CMAJ. 2016 Apr 05;188(6):425–32. doi: 10.1503/cmaj.151421. PMID: 26952527.26952527
335 Wiener RS, Gould MK, Arenberg DA, . An official American Thoracic Society/American College of Chest Physicians policy statement: implementation of low-dose computed tomography lung cancer screening programs in clinical practice. Am J Respir Crit Care Med. 2015 Oct 1;192(7):881–91. doi: 10.1164/rccm.201508-1671ST. PMID: 26426785.26426785
336 Mazzone P, Powell CA, Arenberg D, . Components necessary for high-quality lung cancer screening: American College of Chest Physicians and American Thoracic Society Policy Statement. Chest. 2015 Feb;147(2):295–303. doi: 10.1378/chest.14-2500. PMID: 25356819.25356819
337 Fintelmann FJ, Bernheim A, Digumarthy SR, . The 10 pillars of lung cancer screening: rationale and logistics of a lung cancer screening program. Radiographics. 2015 Nov-Dec;35(7):1893–908. doi: 10.1148/rg.2015150079. PMID: 26495797.26495797
338 Ramsey SD, Malin JL, Goulart B, . Implementing lung cancer screening using low-dose computed tomography: recommendations from an expert panel. J Oncol Pract. 2015 Jan;11(1):e44–9. doi: 10.1200/JOP.2014.001528. PMID: 25491043.25491043
339 Mulshine JL, D’Amico TA. Issues with implementing a high-quality lung cancer screening program. CA Cancer J Clin. 2014 Sep-Oct;64(5):352–63. doi: 10.3322/caac.21239. PMID: 24976072.24976072
340 Carter-Harris L, Gould MK. Multilevel barriers to the successful implementation of lung cancer screening: why does it have to be so hard? Ann Am Thorac Soc. 2017 Aug;14(8):1261–5. doi: 10.1513/AnnalsATS.201703-204PS. PMID: 28541749.28541749
341 Wood DE, Kazerooni EA, Baum SL, . Lung cancer screening, version 3.2018, NCCN clinical practice guidelines in oncology. J Natl Compr Canc Netw. 2018 Apr;16(4):412–41. doi: 10.6004/jnccn.2018.0020. PMID: 29632061.29632061
342 Goodwin JS, Nishi S, Zhou J, . Use of the shared decision-making visit for lung cancer screening among Medicare enrollees. JAMA Intern Med. 2019 Jan 14doi: 10.1001/jamainternmed.2018.6405. PMID: 30640388.30640388
343 Brenner AT, Malo TL, Margolis M, . Evaluating shared decision making for lung cancer screening. JAMA Intern Med. 2018 Aug 13doi: 10.1001/jamainternmed.2018.3054. PMID: 30105393.30105393
344 Couet N, Desroches S, Robitaille H, . Assessments of the extent to which health-care providers involve patients in decision making: a systematic review of studies using the OPTION instrument. Health Expect. 2015 Aug;18(4):542–61. doi: 10.1111/hex.12054. PMID: 23451939.23451939
345 Crothers K, Kross EK, Reisch LM, . Patients’ attitudes regarding lung cancer screening and decision aids. A survey and focus group study. Ann Am Thorac Soc. 2016 Nov;13(11):1992–2001. doi: 10.1513/AnnalsATS.201604-289OC. PMID: 27652509.27652509
346 Henderson LM, Jones LM, Marsh MW, . Opinions, practice patterns, and perceived barriers to lung cancer screening among attending and resident primary care physicians. Risk Manag Healthc Policy. 2017;10:189–95. doi: 10.2147/RMHP.S143152. PMID: 29403320.29403320
347 Hoffman RM, Sussman AL, Getrich CM, . Attitudes and beliefs of primary care providers in New Mexico about lung cancer screening using low-dose computed tomography. Prev Chronic Dis. 2015 Jul 9;12:E108. doi: 10.5888/pcd12.150112. PMID: 26160294.26160294
348 Simmons VN, Gray JE, Schabath MB, . High-risk community and primary care providers knowledge about and barriers to low-dose computed topography lung cancer screening. Lung Cancer. 2017 Apr;106:42–9. doi: 10.1016/j.lungcan.2017.01.012. PMID: 28285693.28285693
349 Lewis JA, Petty WJ, Tooze JA, . Low-Dose CT lung cancer screening practices and attitudes among primary care providers at an academic medical center. Cancer Epidemiol Biomarkers Prev. 2015 Apr;24(4):664–70. doi: 10.1158/1055-9965.Epi-14-1241. PMID: 25613118.25613118
350 Hoffmann TC, Del Mar C. Patients’ expectations of the benefits and harms of treatments, screening, and tests: a systematic review. JAMA Intern Med. 2015 Feb;175(2):274–86. doi: 10.1001/jamainternmed.2014.6016. PMID: 25531451.25531451
351 Hoffmann TC, Del Mar C. Clinicians’ expectations of the benefits and harms of treatments, screening, and tests: a systematic review. JAMA Intern Med. 2017 Mar 1;177(3):407–19. doi: 10.1001/jamainternmed.2016.8254. PMID: 28097303.28097303
352 Hoffman RM, Couper MP, Zikmund-Fisher BJ, . Prostate cancer screening decisions: results from the National Survey of Medical Decisions (DECISIONS study). Arch Intern Med. 2009 Sep 28;169(17):1611–8. doi: 10.1001/archinternmed.2009.262. PMID: 19786681.19786681
353 Dobler CC, Midthun DE, Montori VM. Quality of shared decision making in lung cancer screening: the right process, with the right partners, at the right time and place. Mayo Clin Proc. 2017 Nov;92(11):1612–6. doi: 10.1016/j.mayocp.2017.08.010. PMID: 29101930.29101930
354 Goodson JD. POINT: Should only primary care physicians provide shared decision-making services to discuss the risks/benefits of a low-dose chest CT scan for lung cancer screening? Yes. Chest. 2017 Jun;151(6):1213–5. doi: 10.1016/j.chest.2016.11.057. PMID: 28041890.28041890
355 Dobler CC. Shared decision making rarely happens for lung cancer screening. JAMA Intern Med. 2019 Jan 1;179(1):122. doi: 10.1001/jamainternmed.2018.6983. PMID: 30615081.30615081
356 Reuland DS, Malo TL, Brenner AT. Shared decision making rarely happens for lung cancer screening-reply. JAMA Intern Med. 2019 Jan 1;179(1):122–3. doi: 10.1001/jamainternmed.2018.6986. PMID: 30615085.30615085
357 Dharod A, Bellinger C, Foley K, . The reach and feasibility of an interactive lung cancer screening decision aid delivered by patient portal. Appl Clin Inform. 2019 Jan;10(1):19–27. doi: 10.1055/s-0038-1676807. PMID: 30625501.30625501
358 Mazzone PJ, Tenenbaum A, Seeley M, . Impact of a lung cancer screening counseling and shared decision-making visit. Chest. 2017 Mar;151(3):572–8. doi: 10.1016/j.chest.2016.10.027. PMID: 27815154.27815154
359 Brenner AT, Cubillos L, Birchard K, . Improving the implementation of lung cancer screening guidelines at an academic primary care practice. J Healthc Qual. 2018 Jan/Feb;40(1):27–35. doi: 10.1097/jhq.0000000000000089. PMID: 28885238.28885238
360 Eberth JM, Qiu R, Adams SA, . Lung cancer screening using low-dose CT: the current national landscape. Lung Cancer. 2014 Sep;85(3):379–84. doi: 10.1016/j.lungcan.2014.07.002. PMID: 25088660.25088660
361 Eberth JM, Bozorgi P, Lebron LM, . Geographic availability of low-dose computed tomography for lung cancer screening in the United States, 2017. Prev Chronic Dis. 2018 Oct 4;15:E119. doi: 10.5888/pcd15.180241. PMID: 30289107.30289107
362 American College of Radiology. Accredited facility search. Reston, VA: ACR Accreditation; n.d.
363 Iaccarino JM, Clark J, Bolton R, . A national survey of pulmonologists’ views on low-dose computed tomography screening for lung cancer. Ann Am Thorac Soc. 2015 Nov;12(11):1667–75. doi: 10.1513/AnnalsATS.201507-467OC. PMID: 26368003.26368003
364 Carter-Harris L, Brandzel S, Wernli KJ, . A qualitative study exploring why individuals opt out of lung cancer screening. Fam Pract. 2017 Apr 01;34(2):239–44. doi: 10.1093/fampra/cmw146. PMID: 28122849.28122849
365 Cardarelli R, Roper KL, Cardarelli K, . Identifying community perspectives for a lung cancer screening awareness campaign in Appalachia Kentucky: the Terminate Lung Cancer (TLC) Study. J Cancer Educ. 2017 Mar;32(1):125–34. doi: 10.1007/s13187-015-0914-0. PMID: 26411308.26411308
366 Heny J. Kaiser Family Foundation. 2017 Employer Health Benefits Survey. San Francisco, CA: Kaiser Family Foundation; 2017. Accessed May 20, 2019.
367 Aberle DR, Adams AM, Berg CD, . Baseline characteristics of participants in the randomized national lung screening trial. J Natl Cancer Inst. 2010 Dec 1;102(23):1771–9. doi: 10.1093/jnci/djq434. PMID: 21119104.21119104
368 Curry SJ, Krist AH, Owens DK, . Risk assessment for cardiovascular disease with nontraditional risk factors: US Preventive Services Task Force recommendation statement. JAMA. 2018 Jul 17;320(3):272–80. doi: 10.1001/jama.2018.8359. PMID: 29998297.29998297
369 Siu AL, Bibbins-Domingo K, Grossman DC, . Screening for chronic obstructive pulmonary disease: US Preventive Services Task Force recommendation statement. JAMA. 2016 Apr 5;315(13):1372–7. doi: 10.1001/jama.2016.2638. PMID: 27046365.27046365
370 Lin JS, Bowles EJA, Williams SB, . Thyroid cancer: screening. Evidence Synthesis No. 151. AHRQ Publication No. 15-05221-EF-1. Rockville, MD: Quality AfHRa; May 2017.
371 LeFevre ML, U. S. Preventive Services Task Force. Screening for abdominal aortic aneurysm: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014 Aug 19;161(4):281–90. doi: 10.7326/M14-1204. PMID: 24957320.24957320
372 Guirguis-Blake JM, Beil TL, Sun X, . Primary care screening for abdominal aortic aneurysm: a systematic evidence review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 109. AHRQ Publication No. 14-05202-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; January 2014.
373 Tanner NT, Kanodra NM, Gebregziabher M, . The association between smoking abstinence and mortality in the National Lung Screening Trial. Am J Respir Crit Care Med. 2016 Mar 01;193(5):534–41. doi: 10.1164/rccm.201507-1420OC. PMID: 26502000.26502000
374 Syrek JT, Chin J, Ashby L, . Center for Medicare & Medicaid Services Decision memo for screening for lung cancer with low dose computed tomography (LDCT) (CAG-00439N). Baltimore, MD: Centers for Medicare & Medicaid Services; 2015. http://www.cms.gov/medicare-coverage-database/details/nca-decision-memo.aspx?NCAId=274. Accessed May 20, 2019.
375 Siu AL. Behavioral and pharmacotherapy interventions for tobacco smoking cessation in adults, including pregnant women: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2015 Oct 20;163(8):622–34. doi: 10.7326/m15-2023. PMID: 26389730.26389730
376 Pineiro B, Simmons VN, Palmer AM, . Smoking cessation interventions within the context of low-dose computed tomography lung cancer screening: a systematic review. Lung Cancer. 2016 Aug;98:91–8. doi: 10.1016/j.lungcan.2016.05.028. PMID: 27393513.27393513
377 Iaccarino JM, Duran C, Slatore CG, . Combining smoking cessation interventions with LDCT lung cancer screening: a systematic review. Prev Med. 2019 Apr;121:24–32. doi: 10.1016/j.ypmed.2019.02.016. PMID: 30753860.30753860
378 Shea BJ, Reeves BC, Wells G, . AMSTAR 2: a critical appraisal tool for systematic reviews that include randomised or non-randomised studies of healthcare interventions, or both. BMJ. 2017 Sep 21;358:j4008. doi: 10.1136/bmj.j4008. PMID: 28935701.28935701
379 Clark MM, Cox LS, Jett JR, . Effectiveness of smoking cessation self-help materials in a lung cancer screening population. Lung Cancer. 2004 Apr;44(1):13–21. doi: 10.1016/j.lungcan.2003.10.001. PMID: 15013579.15013579
380 van der Aalst CM, de Koning HJ, van den Bergh KA, . The effectiveness of a computer-tailored smoking cessation intervention for participants in lung cancer screening: a randomised controlled trial. Lung Cancer. 2012 May;76(2):204–10. doi: 10.1016/j.lungcan.2011.10.006. PMID: 22054915.22054915
381 Ferketich AK, Otterson GA, King M, . A pilot test of a combined tobacco dependence treatment and lung cancer screening program. Lung Cancer. 2012 May;76(2):211–5. doi: 10.1016/j.lungcan.2011.10.011. PMID: 22088938.22088938
382 Pozzi P, Munarini E, Bravi F, . A combined smoking cessation intervention within a lung cancer screening trial: a pilot observational study. Tumori. 2015 May-Jun;101(3):306–11. doi: 10.5301/tj.5000282. PMID: 25838249.25838249
383 Filippo L, Principe R, Cesario A, . Smoking cessation intervention within the framework of a lung cancer screening program: preliminary results and clinical perspectives from the “Cosmos-II” Trial. Lung. 2015 Feb;193(1):147–9. doi: 10.1007/s00408-014-9661-y. PMID: 25323328.25323328
384 Taylor KL, Hagerman CJ, Luta G, . Preliminary evaluation of a telephone-based smoking cessation intervention in the lung cancer screening setting: A randomized clinical trial. Lung Cancer. 2017 Jun;108:242–6. doi: 10.1016/j.lungcan.2017.01.020. PMID: 28216065.28216065
385 Marshall HM, Courtney DA, Passmore LH, . Brief tailored smoking cessation counseling in a lung cancer screening population is feasible: a pilot randomized controlled trial. Nicotine Tob Res. 2016 Jul;18(7):1665–9. doi: 10.1093/ntr/ntw010. PMID: 26834052.26834052
386 Dhanasopon AP, Salazar MC, Hoag JR, . Fate of pneumonectomy patients variably captured by non-small cell lung cancer staging system. Ann Thorac Surg. 2017 Dec;104(6):1829–36. doi: 10.1016/j.athoracsur.2017.06.073. PMID: 29074151.29074151
387 Lee SY, Hong MJ, Jeon HS, . Functional intronic ERCC1 polymorphism from regulomeDB can predict survival in lung cancer after surgery. Oncotarget. 2015 Sep 15;6(27):24522–32. doi: 10.18632/oncotarget.4083. PMID: 26056042.26056042
388 Miura H, Inoue T, Shiomi H, . Differences in rates of radiation-induced true and false rib fractures after stereotactic body radiation therapy for Stage I primary lung cancer. J Radiat Res. 2015 Mar;56(2):332–7. doi: 10.1093/jrr/rru107. PMID: 25504640.25504640
389 Yousaf-Khan U, van der Aalst C, de Jong PA, . Final screening round of the NELSON lung cancer screening trial: the effect of a 2.5-year screening interval. Thorax. 2017 Jan;72(1):48–56. doi: 10.1136/thoraxjnl-2016-208655. PMID: 27364640.27364640
390 Zhou H, Tapias LF, Gaissert HA, . Lymph node assessment and impact on survival in video-assisted thoracoscopic lobectomy or segmentectomy. Ann Thorac Surg. 2015 Sep;100(3):910–6. doi: 10.1016/j.athoracsur.2015.04.034. PMID: 26165483.26165483
391 Brain K, Lifford KJ, Carter B, . Long-term psychosocial outcomes of low-dose CT screening: results of the UK Lung Cancer Screening randomised controlled trial. Thorax. 2016 Nov;71(11):996–1005. doi: 10.1136/thoraxjnl-2016-208283. PMID: 27471048.27471048
392 Brain K, Carter B, Lifford KJ, . Impact of low-dose CT screening on smoking cessation among high-risk participants in the UK Lung Cancer Screening Trial. Thorax. 2017 Oct;72(10):912–8. doi: 10.1136/thoraxjnl-2016-209690. PMID: 28710339.28710339
393 Pinsky PF, Marcus PM, Kramer BS, . Diagnostic procedures after a positive spiral computed tomography lung carcinoma screen. Cancer. 2005 Jan 1;103(1):157–63. doi: 10.1002/cncr.20746. PMID: 15529306.15529306
394 Li K, Husing A, Sookthai D, . Selecting high-risk individuals for lung cancer screening: a prospective evaluation of existing risk models and eligibility criteria in the German EPIC Cohort. Cancer Prev Res (Phila). 2015 Sep;8(9):777–85. doi: 10.1158/1940-6207.capr-14-0424. PMID: 26076698.26076698
395 McKee BJ, Regis SM, McKee AB, . Performance of ACR Lung-RADS in a clinical CT lung screening program. J Am Coll Radiol. 2015 Mar;12(3):273–6. doi: 10.1016/j.jacr.2014.08.004. PMID: 25176499.25176499
396 Colinet B, Jacot W, Bertrand D, . A new simplified comorbidity score as a prognostic factor in non-small-cell lung cancer patients: description and comparison with the Charlson’s index. Br J Cancer. 2005 Nov 14;93(10):1098–105. doi: 10.1038/sj.bjc.6602836. PMID: 16234816.16234816