# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their support, commitment, and contributions: Howard Tracer, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current and former members of the USPSTF; M. Patricia Rivera, MD, Professor of Medicine, Division of Pulmonary Diseases and Critical Care Medicine at UNC Chapel Hill for her expert input and her review of an earlier draft of this report; expert reviewers Deni Aberle, MD, UCLA Medical Center; Peter Bach, MD, MAPP, Memorial Sloan-Kettering Cancer Center; Tanner Caverly, MD, University of Michigan; Michael Jaklitsch, MD, Brigham and Women’s Hospital; and Renda Soylemez Wiener, MD, MPH, U.S. Department of Veteran’s Affairs, Boston University School of Medicine; federal partners from the Centers for Disease Control and Prevention, the National Cancer Institute, and the National Institute of Nursing Research; Sharon Barrell, MA, editor, Loraine Monroe, publications specialist; and Carol Woodell, EPC Program Manager.