# Chapter 3 Results

## Literature Search

We identified 11,541 unique records and assessed 2,212 full-text articles for eligibility (Figure 2). We excluded 1,989 articles for various reasons, detailed in Appendix C, and included 223 publications. Of these, 26 publications reported eligible outcomes for the overarching question, KQ 1. Details of quality assessments of included studies and studies excluded because of poor quality are in Appendix D Tables 1–11.

Figure 2 Summary of Evidence Search and Selection

Abbreviations: KQ=key question; SBRT/SABR=SBRT=stereotactic body radiotherapy/SABR= stereotactic ablative radiation.

Figure 2 is a flow diagram that documents the search and selection of articles. There were 9,228 unique records identified by searching PubMed (n=9,038) and Cochrane Library (n=190). In addition, 2,313 records were identified from prior USPSTF reviews (n=90), handsearching (n=230), WHO ICTRP (n=380), and ClinicalTrials.gov (n=1,613). In total, 11,541 titles and abstracts were screened for potential inclusion. Of these, 2,212 were deemed appropriate for full-text review to determine eligibility. After full-text review, 1,989 were excluded: 3 for wrong language/non-English; 21 for being abstracts only; 934 for ineligible population; 51 for ineligible risk prediction model; 91 for ineligible screening modality; 103 for ineligible intervention; 74 for ineligible comparator; 179 for ineligible outcome(s); 20 for ineligible study design as a systematic review; 162 for ineligible study design of another type; 290 for ineligible sample size; 8 for ineligible study duration for KQ 6 (surgery studies only); 28 for ineligible study duration for KQ 6 (SBRT/SABR); 8 for ineligible country; 6 were irretrievable; and 11 for poor quality. Two hundred twenty-three articles met inclusion criteria. Twenty-six articles were included for Key Question 1. Nine articles were included for Key Question 2. Fifty-three articles were included for Key Question 3. Seventy-five articles were included for Key Question 4. Eighteen articles were included for Key Question 5. Sixty-one articles were included for Key Question 6. Eighty-five articles were included for Key Question 7. Three articles were included for Key Question 8.

## Results by Key Question

### Key Question 1

KQ 1a Does screening for lung cancer with LDCT change the incidence of lung cancer and the distribution of lung cancer types and stages (i.e., stage shift)?
b Does screening for lung cancer with LDCT change all-cause mortality, lung cancer mortality, or quality of life?
c Does the effectiveness of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
d Does the effectiveness of screening for lung cancer with LDCT differ by the number or frequency of LDCT scans (e.g., annual screening for 3 years, the protocol used in the NLST, vs. other approaches)?

#### Summary of Included Trials

We included seven randomized, clinical trials (described in 26 articles) that evaluated lung cancer screening with LDCT (Table 2): NLST, Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays (DANTE), Danish Lung Cancer Screening Trial (DLCST), Italian Lung Cancer Screening Trial (ITALUNG), Lung Screening Study (LSS), the German Lung Cancer Screening Intervention Trial (LUSI), and the Nederlands-Leuvens Longkanker Screenings Onderzoek (NELSON) study.^32,^ ^33,^ ^56–79^ All seven trials reported data on lung cancer incidence, lung cancer mortality, and all-cause mortality. Two trials conducted in the United States compared LDCT with CXR (LSS and NLST), and five trials conducted in Europe compared LDCT with no screening (DANTE, DLCST, ITALUNG, LUSI, and NELSON). Only the NLST (53,454 participants) and NELSON (15,792 participants) were adequately powered to assess for a lung cancer mortality benefit.^32,^ ^76^ Sample sizes ranged from 2,472 (DANTE) to 4,104 (DLCST) for the other five trials.^59,^ ^62,^ ^65,^ ^69,^ ^71^ The age range for eligibility was similar across trials, with all ranges falling within 50 to 74 years of age. Current smokers ranged from 48 to 77 percent of the participants in each trial. The majority of participants were male in all trials (range, 56% to 100%); the DANTE trial enrolled 100 percent male participants and NELSON enrolled 84 percent males. The majority of participants were white in all trials; in the NLST, 91 percent were white, less than 5 percent were black, and less than 2 percent were Hispanic or Latino. Six of the included trials evaluated annual screening, although the number of screening rounds varied, ranging from two (LSS) to five (DANTE, DLCST, and LUSI). NELSON evaluated four rounds of screening with increasing intervals for each round (baseline and after 1, 3, and 5.5 years). NELSON was also unique in using volumetric measurements of detected nodules and calculating volume-doubling time to define positive screening results (see KQ 3 for further details about definitions of positive tests for all trials).

Table 2 Characteristics of Included RCTs Evaluating Screening with LDCT Compared No Screening^*^

Study | Recruitment Years | Sample Size; Country | Mean Age (Ages Eligible) | % Male | Baseline Smoking Status | Eligibility Criteria for Pack-Years; Years Since Quitting | Screening Rounds, n | Screening Intervals, y | Total Median Followup, y | Quality
DANTE^61,^ ^71,^ ^72^ | 2001–2006 | 2,472; Italy | 65; (60–74) | 100 | Current: 57%; Former: 43%; Mean pack-years: 47 | ≥20; <10 y | 5 | 0, 1, 2, 3, 4 | 8.4 | Fair
DLCST^65,^ ^67^ | 2004–2006 | 4,104; Denmark | 58; (50–70) | 56 | Current: 76%; Former: 24%; Mean pack-years: 36 | ≥20; quit after age 50 and <10 y ago | 5 | 0, 1, 2, 3, 4 | 9.8 | Fair
ITALUNG^62^ | 2004–2006 | 3,206; Italy | 61; (55–69) | 65 | Current: 65%; Former: 35%; Median pack-years: 39 | ≥20 in the last 10 years or quit within the last 10 year | 4 | 0, 1, 2, 3 | 9.3^†^ | Fair
LSS^69,^ ^70,^ ^75^ | 2000–2001 | 3,318; U.S. | NR; (55–74) | 59 | Current: 58%; Former: 42%; Median pack-years: 54 | ≥30; <10 y | 2 | 0, 1 | 5.2 | Fair
LUSI^59,^ ^60,^ ^73^ | 2007–2011 | 4,052; Germany | NR; (50–69) | 65 | Current: 62%; Former: 35%; Mean pack-years: NR | ≥25 y of 15 cigarettes^‡^ or ≥30 y of 10 cigarettes^‡^; ≤10 y | 5 | 0, 1, 2, 3, 4 | 8.8 | Fair
NELSON^33,^ ^76–79^ | 2003–2006 | 15,792; the Netherlands and Belgium | 58 median; (50–74) | 84 | Current: 55%; Former: 45%; Median pack-years: 38 | >15 cigarettes/day for >25 years or >10 cigarettes/day for >30 years; ≤10 y | 4 | 0, 1, 3, 5.5 | 10 | Fair
NLST^32,^ ^56–58,^ ^63,^ ^64,^ ^66,^ ^68,^ ^74^ | 2002–2004 | 53,542; U.S. | 61; (55–74) | 59 | Current: 48%; Former: 52%; Mean pack-years: 56 | ≥30; ≤15 y | 3 | 0, 1, 2 | 7 (and post-trial followup to 12.3 years) | Good

* NLST and LSS compared screening with LDCT vs. screening with CXR. All other trials compared screening with LDCT with no screening.

† The ITALUNG study reported 9.3 years for lung cancer–specific mortality and 8.5 years for lung cancer incidence.

‡ The LSS was a feasibility pilot study.

Abbreviations: CXR=chest X-ray; DANTE=Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LDCT=low-dose computed tomography; LSS=Lung Screening Study; LUSI=The German Lung Cancer Screening Intervention Trial; n=number; NLST=National Lung Screening Trial; NR=not reported; RCT=randomized, controlled trial.

Trials varied in their definition of a positive screen and in the followup evaluation process (see KQ 3 and KQs 4/5 section on false positives for details). All trials began enrollment between 2000 and 2007. Median duration of followup for lung cancer mortality (including publications describing long-term post-trial followup) ranged from 5.2 (LSS) to 12.3 (NLST) years. Compared with the prior systematic review conducted for the USPSTF, longer followup or more complete endpoint verification was available from DANTE,^61^ DLCST,^67^ LSS,^75^ and the NLST,^63,^ ^74^ and three additional trials—NELSON,^76^ ITALUNG,^62^ and LUSI^59,^ ^73^—reported data relevant to this KQ.

The NLST was rated as good quality for the main trial outcomes.^32,^ ^57,^ ^58^ The extended post-trial followup of NLST was rated as fair quality because of using different ascertainment methods during trial years (with a verification committee) than for post-trial years (relying on registries and without a verification committee); lack of information on any post-trial screening with LDCT that may have taken place in either the LDCT or the CXR group; missing data for lung cancer incidence for 11 out of 33 centers (representing 12.4% of trial participants) that did not have a home state cancer registry available for linkages (this was not a concern for mortality outcomes because linkage to the National Death Index was available for all but 2.2% of trial participants); and, for estimates of overdiagnosis, risk of biasing estimates toward the null because the comparison group received CXR (rather than no screening test).

The main methodological limitations of the NELSON trial included risk of ascertainment bias and lacking details on potential harms of screening (e.g., further testing after screening, such as biopsies, and related harms). Ascertainment included a blinded review of medical files for 296 out of 426 (69.5%) of deceased Dutch patients with known lung cancer; the ascertainment therefore lacked blinded review for over 30 percent of deceased Dutch patients with known lung cancer and for over 80 percent of all 1,728 deaths that occurred. The limited blinded review revealed concordance of 86.1 percent among members of the independent expert committee and a sensitivity and specificity of 92.6 percent and 98.8 percent of the official death certificate for the study’s primary outcome (lung cancer mortality). It was not reported whether the 296 blinded medical files reviewed were equally divided between the screening and control groups, raising additional concerns for differential bias in ascertainment. Methods used by the various registries for ascertainment were not reported. For females, there was limited reporting of some information, such as recruitment and selection for the study and adherence to the screening intervention.

We excluded one trial (the Multi-centric Italian Lung Detection [MILD] study) for poor quality;^80,^ ^81^ sensitivity analyses in Appendix E show results of that trial for lung cancer mortality and all-cause mortality. As in the prior report for the USPSTF, MILD was considered to have a high risk of bias because of significant differences between the LDCT and no-screening groups at baseline, raising concerns about inadequate randomization, differential followup between groups (with less followup among the control group), high risk of measurement bias, and inability to reach its planned sample size (of 10,000 participants).

#### Incidence of Lung Cancer and Distribution of Lung Cancer Types and Stages

Overall, the cumulative incidence of lung cancer was higher in LDCT screening groups than in control groups for all studies except for the ITALUNG study (Figure 3 and Appendix E Table 2. Adenocarcinomas were the most commonly diagnosed lung cancer type in both arms of all trials (ranging from 35% [NLST] to 68% [LUSI] of lung cancers diagnosed in LDCT arms) (Appendix E Table 2). All included trials reported more Stage I cancers in LDCT groups than in control groups (Appendix E Table 2). Most trials reported between 45 and 50 percent Stage I lung cancers in the LDCT groups; absolute between-group differences for Stage I lung cancers ranged from 8 (LSS) to 48 percent (LUSI). Figure 4 shows the increases in early stage (I-II) and decreases in late stage (III-IV) lung cancer incidence, representing stage shift. At 6.5 years followup, the NLST reported a higher incidence of lung cancer among LDCT participants (4.1%; 1,089 lung cancers; 662 per 100,000 person-years) than among CXR participants (3.6%; 969 lung cancers; 558 per 100,000 person-years). The calculated incidence rate ratio was 1.12 (95% CI, 1.02 to 1.22). The LDCT and CXR groups had similar proportions of adenocarcinomas (35% vs. 34% of incident cancers), squamous cell carcinomas (22% vs. 22%), small cell carcinoma (13% vs. 16%), and other lung cancer types (Appendix E Table 2). For stage distribution, the trial reported more Stage I lung cancers in the LDCT group than the CXR group (520 vs. 289 Stage I lung cancers; 50% vs. 31% of incident lung cancers) and fewer Stage IV lung cancers (226 vs. 335; 22% vs. 36%, respectively). An extended followup of the NLST reported no statistically significant difference between groups for overall lung cancer incidence (1,701 lung cancers for the LDCT group vs. 1,681 for the CXR group; calculated incidence rate ratio of 1.01 [0.95, 1.08] Figure 3). For stage distribution after 11.3 years, the extended followup identified more Stage I lung cancers in the LDCT group than in the CXR group (40% vs. 27% of incident lung cancers) and fewer Stage IV lung cancers (28% vs. 36%, respectively) (Appendix E Table 2). The extended followup used linkages to state cancer registries and the National Death Index to ascertain outcomes beyond the original trial (rather than the same ascertainment methods used for the original trial).

Figure 3 Trial results for lung cancer incidence (KQ 1)

Note: G1=LDCT; G2=Control; Favors Intervention indicates fewer incident lung cancers with intervention (LDCT screening); Favors Control indicates more incident lung cancers with intervention. Two rows are included in the figure for the NLST, showing the data from the 6.5-year followup and from the extended post-screening followup data at a median of 11.3 years after randomization for lung cancer incidence. The NELSON trial reported lung cancer incidence for the 13,195 males enrolled in the trial, excluding the 2,594 females that were enrolled. Therefore, the NELSON results in the figure above include only data for male participants (data were not reported for the female participants). The trial did not report total person-years of followup for lung cancer incidence, but those were able to be calculated from other data that were reported (5.58 cases per 1,000 person-years vs. 4.91 cases per 1,000 person-years at 10 years; RR, 1.14 [95% CI, 0.97, 1.33]). The Nelson trial reported median age and median pack-years instead of mean age and mean pack years. The LUSI trial was not included in the figure above because it did not reporting person-years of followup. The LUSI trial reported 85 lung cancers in the intervention group and 67 in the control group at a mean of 8.8 years follow up (p=0.16).

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LUSI=Lung cancer Screening Intervention; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Figure 3 displays a forest plot reporting the trial results for lung cancer incidence (KQ1). The figure includes trials that compared LDCT screening to control. For the NLST trial the figure displays the data for 6.5 years and 11.3 years of follow up. At 6.5 years, the NLST trial reported a higher incidence of lung cancer in the intervention group compared to control (1,089 vs. 969 events; RR, 1.12 [95% CI, 1.02 to 1.22]). At 11.3 years of follow up, the NLST trial reported a higher incidence of lung cancer in the intervention group compared to control (1,701 vs. 1,681 events; RR, 1.01 [95% CI, 0.95 to 1.08]). For the DANTE trial, a higher incidence of lung cancer was reported in the intervention group compared to control (106 vs. 73 events; RR, 1.35 [95% CI, 1.00 to 1.81]). For the DLCST trial, a higher incidence of lung cancer was reported in the intervention group compared to control (100 vs. 53 events; RR, 1.89 [95% CI, 1.36 to 2.64]). For the ITALUNG trial, a higher incidence of lung cancer was reported in the control group compared to the intervention group (71 vs. 67 events; RR, 0.92 [95% CI, 0.66 to 1.28]). For the NELSON trial, a higher incidence of lung cancer was reported in the intervention group compared to control (341 vs. 304 events; RR, 1.14 [95% CI, 0.97 to 1.33]).

Figure 4 Trial results for incidence of early (I-II) and late (III-IV) stage lung cancer (KQ 1)

Note: G1=LDCT; G2=Control; The MILD trial randomized participants to annual screening, biennial screening, or a control group. For the 10-year followup, the annual and biennial screening groups were combined. At the 10-year followup, the median duration of screening for those in the screening groups was 6.2 years.

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; MILD=Multicentric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Figure 4 displays two forest plots reporting the trial results for early(I-II) and late (III-IV) stage lung cancer incidence. The figure includes five trials that compare LDCT screening to control. The left side of the figure displays early stage lung cancer incidence and the right side of the figure displays late stage lung cancer incidence. All five trials reported increases in early stage lung cancer incidence for the intervention group compared to control. The NLST trial reported 818 events of early stage lung cancer in the intervention group compared to 615 events in the control group (RR, 1.33 [95% CI, 1.20 to 1.48]). The DANTE trial reported 54 events of early stage lung cancer in the intervention group compared to 21 events in the control group (RR, 2.38 [95% CI, 1.44 to 3.94]). The DLCST trial reported 54 events of early stage lung cancer in the intervention group compared to 10 events in the control group (RR, 5.42 [95% CI, 2.76 to 10.63]). The ITALUNG trial reported 29 events of early stage lung cancer in the intervention group compared to 13 events in the control group (RR, 2.17 [95% CI, 1.13 to 4.16]). The NELSON trial reported 168 events of early stage lung cancer in the intervention group compared to 71 events in the control groups (RR, 2.39 [95% CI, 1.81 to 3.16]). Four of the five trials reported decreases in late stage lung cancer incidence in the intervention group compared to control. The NLST trial reported 766 events of late stage lung cancer in the intervention group compared to 918 events in the control group (RR, 0.84 [95% CI, 0.76 to 0.92]). The DANTE trial reported 43 events of late stage lung cancer in the intervention group compared to 45 in the control groups (RR, 0.89 [95% CI, 0.59 to 1.35]). The DLCST trial reported 46 events of late stage lung cancer in the intervention group compared to 41 in the control groups (RR, 1.13 [95% CI, 0.74 to 1.72]). The ITALUNG trial reported 33 events of late stage lung cancer in the intervention group compared to 43 in the control group (RR, 0.75 [95% CI, 0.47 to 1.17]). The NELSON trial reported 153 events of late stage lung cancer in the intervention group compared to 216 events in the control group (RR, 0.72 [95% CI, 0.58 to 0.88].

#### Lung Cancer Mortality

Figure 5 shows the calculated IRRs for the trials that reported lung cancer mortality. Only the NLST and NELSON had sufficiently large sample sizes to detect a difference between groups. The original publication of the main results from the NLST reported a relative risk reduction in lung cancer mortality of 20.0 percent (95% CI, 6.8 to 26.7);^32^ a subsequent publication with additional endpoint verification for lung cancer deaths (with approximately an additional year of followup covered, going to the prespecified endpoint) reported a relative reduction of 16 percent (95% CI, 5 to 25).^63^ Over almost 7 years of followup, and over 140,000 person-years of followup in each group, the NLST found a significant reduction in lung cancer mortality with three rounds of annual LDCT screening compared with CXR (469 vs. 552 lung cancer deaths;^63^ 280 per 100,000 person-years vs. 332 per 100,000 person-years; calculated IRR, 0.85 [95% CI, 0.75 to 0.96]). These findings indicate an NNS to prevent one lung cancer death of 323 over 6.5 years of followup. This calculated NNS is similar to the NNS reported by the initial NLST results publication (i.e., NNS 320 among those undergoing ≥1 screens; intention-to-screen analysis, NNS of 310 [95% CI, 190 to 840]) but is slightly different because of the incorporation of the additional endpoint verification. Analysis of extended followup data of NLST participants at 12.3 years after randomization found a similar absolute difference between groups (1,147 vs. 1,236 lung cancer deaths; RR, 0.92 [95% CI, 0.85 to 1.00]; absolute difference between groups of 3.3 [95% CI, −0.2 to 6.8] lung cancer deaths per 1,000 participants). The NELSON trial reported a reduction in lung cancer mortality for four rounds of screening with increasing intervals between LDCTs (at baseline, 1 year, 3 years, and 5.5 years). Combining NELSON data for males and females, there were 181 lung cancer deaths among participants in the screening group and 242 in the control group (calculated IRR, 0.75 [95% CI, 0.61 to 0.90]) over 10 years of followup. These findings indicate a NNS to prevent one lung cancer death of 130 over 10 years of followup. Results of the other trials were very imprecise and did not show statistically significant differences between screening with LDCT and no screening (Figure 5).

Figure 5 Trial results for lung cancer mortality (KQ 1)

Note: G1=LDCT; G2=Control. The NLST trial reported extended post-screening followup data at 12.3 years after randomization (not included in the figure above because person-years of followup were not reported): 1,147 lung cancer deaths occurred in the LDCT screening group (42.9 cases per 1,000 participants) and 1236 occurred in the CXR control group (46.2 cases per 1,000 participants) (RR, 0.92 [95% CI, 0.85, 1.00] and absolute difference between groups of 3.3 [95% CI, −0.2, 6.8] lung cancer deaths per 1,000 participants). The ITALUNG and LSS trials reported median pack per years instead of mean pack per years. The NELSON trial reported its main results for the 13,195 males enrolled in the trial (excluding the females enrolled), reporting 156 lung cancer deaths in the screening group and 206 lung cancer deaths in the control group for males at 10 years of followup (rate ratio 0.76 [95% CI, 0.61 to 0.94]). For the 2,594 females, NELSON reported 25 lung cancer deaths in the screening group and 36 in the control group at 10 years of followup (rate ratio 0.67 [95% CI, 0.38 to 1.14]). The NELSON results in the figure above combine data for all participants in the trial. The Nelson trial reported median age and median pack-years instead of mean age and mean pack-years. The LUSI trial was not included in the figure above because it did not report person-years of followup. The study reported 29 lung cancer deaths in the intervention group and 40 lung cancer deaths in the control group at a mean of 8.8 years follow up (p=0.19).

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LSS=Lung Screening Study; LUSI=Lung cancer Screening Intervention; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Figure 5 displays a forest plot reporting the trial results for lung cancer mortality. The figure includes six trials that compared LDCT screening to control. For the NLST trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (280 vs. 332 deaths per 100,000 person-years; RR, 0.85 [95% CI, 0.75 to 0.96]. For the DANTE trial, a similar number of lung cancer deaths were reported in the intervention and control group (543 vs. 544 deaths per 100,000 person-years; RR, 1.00 [95% CI, 0.69 to 1.44]. For the DLCST trial, fewer lung cancer deaths were reported in the control group compared to the intervention group (194 vs. 201 deaths per 100,000 person-years; RR, 1.03 [95% CI, 0.66 to 1.61]). For the ITALUNG trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (293 vs. 421 deaths per 100,000 person-years; RR, 0.70 [95% CI, 0.47 to 1.03]). For the LSS trial, fewer lung cancer deaths were reported in the control group compared to the intervention group (310 vs. 383 deaths per 100,000 person-years; RR, 1.24 [95% CI, 0.74 to 2.07]. For the NELSON trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (241 vs. 324 deaths per 100,000 person-years; RR, 0.75 [95% CI, 0.61 to 0.90]).

#### All-cause Mortality

Figure 6 shows the calculated IRRs for the trials that reported all-cause mortality. The NLST found a reduction in all-cause mortality with LDCT screening compared with CXR (1,912 vs. 2,039 deaths; 1,141 per 100,000 person-years vs. 1,225 per 100,000 person-years; calculated IRR of 0.93 [95% CI, 0.88 to 0.99]). To prevent one death from any cause, the NNS from the NLST was 219 (95% CI, 112 to 5,000). The other trials found no statistically significant differences between screening with LDCT and no screening, but results were imprecise (Figure 6). In the NELSON trial, there were more all-cause deaths in the LDCT screening group than in the control group (868 vs. 860), although the difference between groups was not statistically significant.

Figure 6 Trial results for all-cause mortality (KQ 1)

Note: G1=LDCT; G2=Control. The NLST trial reported extended post-screening followup data at 12.3 years after randomization (not included in the figure above because person-years of followup were not reported): 5,253 deaths occurred in the LDCT screening group (196.6 cases per 1,000 participants) and 5,366 deaths in the CXR group (200.7 cases per 1,000 participants) (RR, 0.97 [95% CI, 0.94, 1.01]). The ITALUNG and LSS trials reported median pack per years instead of mean pack per years. The NELSON trial reported all-cause mortality for its primary analysis of the 13,195 males enrolled in the trial, excluding the 2,594 females that were enrolled. Therefore, the NELSON results in the figure above include only data for male participants (data were not reported for the female participants). The Nelson trial reported median age and median pack-years instead of mean age and mean pack-years.

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LSS=Lung Screening Study; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Figure 6 displays a forest plot reporting the trial results for all-cause mortality. The figure includes six trials that compared LDCT screening to control. For the NLST trial, fewer deaths were reported in the intervention group compared to the control group (1,141 vs. 1,225 deaths per 100,000 person-years; RR, 0.93 [95% CI 0.88 to 0.99]). For the DANTE trial, fewer deaths were reported in the intervention group compared to the control group (1,655 vs. 1,742 deaths per 100,000 person-years; RR, 0.95 [95% CI, 0.77 to 1.17]). For the DLCST trial, fewer deaths were reported in the control group compared to the intervention group (834 vs. 849 deaths per 100,000 person-years; RR, 1.02 [95% CI, 0.82 to 1.26]). For the ITALUNG trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (1,051 vs. 1,270 deaths per 100,000 person-years; RR, 0.83 [95% CI, 0.67 to 1.03]. For the LSS trial, fewer deaths were reported in the control group compared to the intervention group (1,384 vs. 1,667 deaths per 100,000 person-years; RR, 1.20 [95% CI, 0.94 to 1.53]). For the NELSON trial, fewer lung cancer deaths were reported in the control group compared to the intervention group (1,376 vs. 1,393 deaths per 100,000 person-years; RR, 1.01 [95% CI, 0.92 to 1.11]).

#### Quality of Life

None of the included trials assessed for potential benefits of LDCT screening on quality of life (some evaluated short-term quality of life to assess for possible psychosocial harms of screening, as described in KQ 4, but none evaluated quality of life over the longer course of the trial).

#### Subgroups

All included trials enrolled participants at high risk for lung cancer (based on age and smoking history). Seven publications using DLCST, LUSI, NELSON, or NLST data described subgroup analyses for at least one of the following; age, sex, race/ethnicity, smoking status and pack-years, history of COPD, and other pulmonary conditions.^63,^ ^64,^ ^66,^ ^67,^ ^73,^ ^74,^ ^76^ A post hoc analysis of NLST data reported that 88 percent of the mortality benefit was achieved by screening the 60 percent of participants at highest risk for lung cancer death.^56^ The 20 percent of participants at lowest risk accounted for just 1 percent of prevented lung-cancer deaths.^56^ Other post hoc analyses of NLST data reported lung cancer mortality by sex (RR 0.73 for women vs. 0.92 for men, p=0.08), age (RR 0.82 for <65 vs. 0.87 for ≥65, p=0.60), race/ethnicity (hazard ratio [HR] 0.61 for black individuals vs. 0.86 for whites, p=0.29), and smoking status (RR 0.81 for current smokers vs. 0.91 for former smokers, p=0.40), and did not identify statistically significant differences between groups.^63,^ ^64,^ ^66^ A long-term followup of NLST participants at 12.3 years reported similar results for subgroups and did not identify statistically significant interactions by sex, age, or smoking status (sex: RR 0.86 for women vs. 0.97 for men, p=0.17; age: RR 0.86 for <65 years vs. 1.01 for ≥65 years, p=0.051; smoking status: RR 0.88 for current smokers vs. 1.01 for former smokers, p=0.12).^74^ Both LUSI and NELSON reported a similar pattern for subgroups by sex as found in NLST that was not statistically significantly different between groups (LUSI: women, HR=0.31 [95% CI, 0.10 to 0.96] vs. men, HR=0.94 [95% CI, 0.54 to 1.61], p=0.09) or without reporting an interaction test (NELSON: women, RR 0.67 [95% CI, 0.38 to 1.14] vs. men, RR 0.76 [95% CI, 0.61 to 0.94] at 10 years of followup).^73,^ ^76^ NELSON reported analyses by age group among the men in the trial (not including the women in those analyses) but did not report interaction tests for subgroups defined by age (RRs ranged from 0.59 [95% CI, 0.35 to 0.98] for persons aged 65 to 69 years at randomization to 0.85 [95% CI, 0.48 to 1.50] for persons aged 50 to 54 years at randomization).^76^ In a post hoc analysis of the DLSCT trial, age and having both COPD and greater than or equal to 35 pack-years of smoking were associated with an increased risk of death from lung cancer.^67^

#### Difference in Effectiveness by the Number or Frequency of LDCT Scans

Only the MILD study, which was excluded for poor quality, had a direct comparison by frequencies, comparing annual screening, biennial screening, and no screening.^82^ No good- or fair-quality studies directly compared number or frequency of LDCT scans. Screening intervals were similar for all trials except for NELSON (which used increasing intervals between tests for each of its four screening rounds), with screening done annually. The number of screening rounds varied across studies; the NLST had three annual scans. Reported participation rates across studies varied somewhat but were 90 percent or greater for all studies except for ITALUNG (adherence to screening of 81% across all rounds of screening) and LSS (77% at year 1 among participants with positive baseline screen).

### Key Question 2 Does the Use of Risk Prediction Models for Identifying Adults at Higher Risk of Lung Cancer Mortality Improve the Balance of Benefits and Harms of Screening Compared With the Use of Trial Eligibility Criteria (e.g., NLST Criteria) or the 2013 USPSTF Recommendations?

#### Summary

For benefits, four studies of three different risk prediction models (a modified version of a model developed from participants of the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial [PLCOm2012], the Lung Cancer Death Risk Assessment Tool [LCDRAT], and Kovalchik model) estimating outcomes in four different cohorts reported increased screen-preventable deaths compared with the risk factor–based criteria used by the NLST or USPSTF (in the 2013 recommendations). Three studies demonstrated improved screening efficiency (determined by the NNS) of risk prediction models compared with risk factor−based screening, while one study showed mixed results. For harms, eight studies of 13 different risk prediction models (PLCOm2012, simplified PLCOm2012, Bach, Liverpool Lung Project [LLP], simplified LLP, Knoke, Two-Stage Clonal Expansion [TSCE] incidence, TSCE Cancer Prevention Study [CPS] death, TSCE Nurses’ Health Study [NHS]/Health Professionals Followup Study [HPFS] death), the Hunt Lung Cancer model, LCDRAT, COPD-LUCSS, Kovalchik model) estimating outcomes in four different cohorts reported similar numbers of false-positive selections from risk prediction with respect to lung cancer events (i.e., the risk prediction model selected people to be screened who did not have or develop lung cancer or death from lung cancer) and mixed findings for rates of false-positive selections with respect to lung cancer events when comparing risk prediction models with the risk factor–based criteria used by the NLST or USPSTF. In general, estimates of benefits and harms were consistent but imprecise, primarily because of a lack of an established risk threshold to apply the model.

#### Description of Included Studies

Nine good- or fair-quality studies were included, which evaluated 13 different risk prediction models.^56,^ ^83–88^ Table 3 summarizes the predictors included in each model. The PLCOm2012 model was the most commonly evaluated model compared with risk factor–based criteria in five studies;^83,^ ^85–87,^ ^89^ the LCDRAT model was evaluated by two studies;^84,^ ^89^ the other models were evaluated by one study each. Risk models included personal history, smoking history, family history of cancer, occupational exposures like asbestos, and lung conditions (e.g., COPD, emphysema).

Table 3 Predictors Used in Risk Prediction Models for Identifying Adults at Higher Risk of Lung Cancer Mortality and Model Applicability

Model Name | LCDRAT^84^ | Kovalchik Model^56^ | PLCOm2012^85^ | Simplified PLCOm2012^83^ | COPD-LUCSS^88^ | Bach Model^90^ | LLP Model^92^ | Simplified LLP^83,^ ^92,*^ | TSCE Incidence Model^93^ | Knoke Model^96^ | TSCE CPS Death Model^94^ | TSCE NHS/HPFS Death Model^324^ | HUNT Lung Cancer Model^95^
Risk Factors
Personal
Age | X | X | X | X | X^†^ | X | X | X | X | X | X | X | X
Sex | X | | | | | X | X | X | X | | X | X
Race and/or ethnicity | X | | X | | | | | | | X^‡^
Body mass index | X | X | X | | X^§^ | | | | | | | | X
Education (levels) | X^∥^ | | X^∥^
Previous malignant tumor | | | X | | | | X
Smoking History
Smoking status | | | | | | | | | X | X | X | X
Cessation age | | | | | | | | | | X
Smoking duration | X | | X | X | | X | X^¶^ | X^¶^ | X | X | X | X
Cigarettes per day | X | | X | X | | X | | | X | X | X | X | X
Pack-years | X^#^ | X | | | X^#^ | | | | | | | | X
Quit duration | X | X^††^ | X | X | | X | | | X | X | X | X | X
Family History of Cancer
Cases of lung cancer | X^‡‡^ | X^‡‡^ | X | | | | X
Age of onset of lung cancer | | | | | | | X^§§^
Exposures and Lung Conditions
Emphysema | X | X | | | X^∥∥^
COPD | | | X
Pneumonia | | | | | | | X
Daily cough | | | | | | | | | | | | | X
Daily indoor exposure to smoke (hours) | | | | | | | | | | | | | X
Asbestos exposure | | | | | | X | X
Applying the Model Information
Applicable to never smokers | | | | | | | X | X | X | X | X | X
Applicable to former smokers | X | X | X | X | X | X | X | X | X | X | X | X | X
Applicable to current smokers | X | X | X | X | X | X | X | X | X | X | X | X | X
Model predicts risk of incidence | X | | X | X | X | X | X | X | X | | | | X
Model predicts survival | X^¶¶^ | X | | | | | | | | X | X | X
Time horizon of prediction | 5 y | 5 y | 6 y | 6 y | NR | 1 y (iterative) | 5 y | 5 y | 1 y (iterative) | 1 y (iterative) | 1 y (iterative) | 1 y (iterative) | 6 and 16 years
Model formula printed | | | X | X | X | X | X | X | X | X | X | X | X
Discrimination & calibration^##^
Discrimination for lung cancer incidence (AUC) range | 0.70–0.80 | - | 0.69–0.89 | 0.68–0.78 | NR | 0.68–0.78 | 0.66–0.79 | 0.66–0.74 | 0.67–0.78 | 0.67–0.77 | 0.62–0.74 | 0.67–0.78 | 0.87 (6 years)
Discrimination for lung cancer mortality (AUC) range | 0.73–0.81 | 0.80 | 0.72–0.81 | 0.71–0.80 | NR | 0.71–0.80 | 0.67–0.77 | 0.68–0.79 | 0.68–0.79 | 0.68–0.78 | 0.63–0.77 | 0.68–0.79 | NR
Calibration of model for lung cancer incidence; range | 0.94–1.06 | - | 0.87–0.98 | 1.02–1.04 | NR | 0.99–1.09 | 0.68–1.05 | 0.76–1.07 | 0.79–0.87 | 0.70–1.09 | 0.59–0.90 | 0.76–0.85 | NR (shown as calibration plots that show fairly good calibration)
Calibration of model for lung cancer mortality, range | 0.94–1.31 | 0.97 | 0.95–1.01 | 1.02–1.19 | NR | 0.97–1.21 | 0.69–1.18 | 0.79–1.12 | 0.84–0.94 | 0.79–0.89 | 0.64–0.99 | 0.80–0.92 | NR

* The simplified version of the LLP model uses the same parameter estimates as the original LLP model. However, when applying this model to a participant, it is assumed that only information on age and smoking history is known. Thus, the simplified model assumes that the participant had no prior diagnosis of pneumonia, no occupational exposure to asbestos, no prior diagnosis of a malignant tumor, and no family history of lung cancer.

† Age > 60

‡ Only applicable to white males ages 40 to 79 years.

§ BMI <25.

∥ 1≤12 grade; 2=high school graduate; 3=post-high school but not college; 4=some college; 5=bachelor’s degree; 6=graduate school.

¶ Smoking duration levels for model: never; 1–20 years; 21–40 years; 41–60 years; >60 years.

# Binary: >1 pack/day.

** Pack-years: >60.

†† Categories: 0=less than 1 year; 1=1 to 5 years; 2=more than 5 years.

‡‡ 0=No first-degree relatives with lung cancer; 1=1 first-degree relative with lung cancer; 2=2 or more first-degree relatives with lung cancer.

§§ Early onset (age <60 years); late onset (age ≥60 years).

∥∥ Radiologic emphysema.

¶¶ Model can estimate 10-year risk, but authors report 5-year estimates because the NLST only had 5.5 years of followup data.

## LCDRAT: Cohorts used for external validation: PLCO-CXR and NLST-CXR. Discrimination higher in NHIS and PLCO vs. NLST cohorts. Calibration metric: Ratio of model-predicted cases to observed cases. A value of 1 indicates optimal calibration. Kovalchik: Cohort used for external validation: PLCO-CXR. Calibration metric: Ratio of model-predicted cases to observed cases.

PLCOm2012: Cohorts used for external validation: PLCO-CXR and control, 45 and UP study, NLST-CT and CXR, NHIS. Discrimination higher in PLCO vs. NLST cohorts. Calibration metric reported in table from ten Haaf et al: slope of calibration plot observed vs. expected. Perfect calibration if slope=1. Two studies reported calibration as the median (or mean) and 90th percentile absolute differences between observed and predicted risk probabilities, which ranged from 0.006–0.009 and 0.016–0.042, respectively. For all other models except the HUNT model, discrimination and calibration are reported from the ten Haaf study. The range of discrimination and calibration outcomes are estimated using the NLST CT and CXR arms, and the PLCO-CXR and control arms. In general, discrimination and calibration were better in the PLCO cohorts than in the NLST cohorts. An exhaustive search and synthesis of risk model performance metrics was not in the scope of this review; thus, the numbers in this table are not a comprehensive description of discrimination and calibration reported in all studies of these models (inclusion was limited to studies that reported eligible benefits and harms outcomes and compared with USPSTF 2013 or NLST criteria).

Abbreviations: AUC=area under the curve; BMI=body mass index; COPD=chronic obstructive pulmonary disease; COPD-LUCSS=COPD-Lung Cancer Screening Score; CPS=Cancer Prevention Study; HPFS=Health Professionals Follow-Up Study; LCDRAT=Lung Cancer Death Risk Assessment Tool; LLP=Liverpool Lung Project; NHS=Nurses’ Health Study; NLST=National Lung Screening Trial; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; TSCE=Two Stage Clonal Expansion Model.

The PLCOm2012 model was developed in ever-smokers in the PLCO control arm. Compared with USPSTF criteria, the PLCOm2012 model includes more personal factors (e.g., history of malignancy), more detailed smoking history, family history, and a personal history of COPD.^85^ The Lung Cancer Risk Assessment Tool (LCRAT) and LCDRAT are risk models developed and validated in the control and CXR arms of the PLCO, respectively.^84^ Additional eligible models for this systematic review included the Kovalchik model, the Bach model, the LLP model, simplified LLP model, the Knoke model, the Hunt Lung Cancer model, and three TSCE models predicting lung cancer incidence and death. Models included a variety of additional risk factors, such as smoking intensity (cigarettes per day);^56,^ ^84,^ ^85,^ ^90,^ ^91^ occupational asbestos exposure;^90,^ ^92^ lung conditions of emphysema, COPD, and pneumonia;^56,^ ^84,^ ^85,^ ^88,^ ^92^ and family history of lung cancer.^56,^ ^84,^ ^85,^ ^92^

The models included in the evidence review were developed across several cohorts: smokers in the PLCO control arm,^84,^ ^85^ NLST control arm,^56^ the Pittsburg Lung Screening Study,^88^ the Carotene and Retinol Efficacy Trial,^90^ the Liverpool Lung Project case-control study,^92^ the NHS, HPFS,^93^ the American Cancer Society’s first Cancer Prevention Study (CPS-I), the American Cancer Society’s second Cancer Prevention Study (CPS-II),^94^ and the HUNT study.^95^ The models were externally validated in four cohorts in the United States,^56,^ ^83–85^ one in Spain,^88^ one in Norway,^95^ and one in Australia.^86^ Specifically, these cohorts included the NLST control (CXR) arm or pooled arms,^84,^ ^85^ smokers from the CXR and control arms of the PLCO Screening Trial 2003–2009,^56,^ ^83–85^ the NHIS 2010–2012,^84^ NHIS 2015,^89^ the Australian 45 and Up Study (cohort of 267,017 Medicare-eligible individuals 2006–2009),^86^ the CONOR database in Norway,^95^ and the Pamplona-International Early Lung Cancer Detection Program (572 individuals 2001–2013).^88^ Models predicted lung cancer incidence,^85^ lung cancer death,^56,^ ^94,^ ^96^ or both.^90^ The time horizon of the predictions was 1 year for the Bach model and TSCE models,^90,^ ^93,^ ^94^ although to obtain predictions for longer time frames, investigators repeated the risk prediction for multiple years: 5 years for the LLP model,^92^ the Katki model (LCDRAT and LCRAT),^84^ and the Kovalchik model;^56^ 6 years for the PLCOm2012 model, the HUNT model,^95^ and the Knoke model;^96^ or were not reported.^88^

Outcomes were estimated by applying each risk model to the cohort (or cohorts) used for external validation. There are currently no consensus risk thresholds to deploy risk prediction models for lung cancer screening. In other words, there is not a particular 5- or 6-year calculated risk for lung cancer incidence or lung cancer death that is agreed upon as the threshold for recommending screening. Individual study investigators employed one or more of the following strategies to determine a risk threshold, which could be used to estimate benefit or harm outcomes of using a risk-based approach to screening compared with NLST or USPSTF criteria:

1. Fixed-USPSTF (or NLST) population size: select model risk threshold such that the number screened matches the number of USPSTF (or NLST) screen-eligible smokers in the United States^83–87^
2. Fixed-USPSTF effectiveness estimate: select model risk threshold such that the NNS matches the NNS of USPSTF-eligible smokers in the United States^84^
3. Stratification by risk quantiles or quintiles^56,^ ^95^
4. Comparable or improved mortality compared with the NLST: select risk threshold at which lung cancer mortality rates were consistently lower in the CT arm vs. CXR arm of the NLST^86,^ ^87^
5. Optimal classification based on receiver operator curve^86^
6. Risk threshold ≥2% absolute risk^86^

Twelve models demonstrated fair to good discrimination for both lung cancer incidence and lung cancer mortality. Area under the curve [AUC] ranged from 0.62 to 0.89 for eligible studies with better discrimination for lung cancer mortality than for lung cancer incidence and better discrimination in PLCO cohorts compared with the NLST or other cohorts (Table 3). For lung cancer mortality, the Katki model, Kovalchik model, PLCOm2012 model (full and simplified), and Bach models generally had better discrimination (and satisfactory calibration) than the other risk prediction models.^56,^ ^83–86^ For one model (COPD-Lung Cancer Screening Score [LUCSS]), the included study did not report discrimination or calibration.^88^ Studies reporting discrimination or calibration for these models that did not also report eligible KQ 2 outcomes are not included in this summary.

#### Results of Included Studies

##### Studies of the PLCOm2012 Model, the Most Commonly Evaluated Model

Five studies evaluated the PLCOm2012 model using five different risk thresholds estimating outcomes over 6 years (Table 4).^83,^ ^85–87,^ ^89^ Additionally, a simplified version of the PLCOm2012 model was evaluated that included age, and smoking history only.^83^ Two studies of the PLCOm2012 model calculated an increase in screen-prevented lung cancer deaths compared with the NLST criteria over 6 years using assumptions of NLST-like reduction in lung cancer mortality (20%) among smokers in the CXR arm of the PLCO.^85,^ ^89^ These two studies also evaluated NNS to prevent one lung cancer death. One study found a reduction in NNS to prevent one lung cancer death (174 vs. 203).^85^ The other study evaluated three risk thresholds (1.3%, 1.51%, and 2.19%) with NNS decreasing as the risk threshold increased (222, 207, and 169) such that the NNS was higher when using a risk prediction model for the two lowest risk thresholds compared with risk factor−based screening.^89^

Table 4 PLCOm2012 Model Estimated Benefits and Harms Over 6 Years Compared With USPSTF or NLST Criteria

Author, Year | Method for Determining Lung Cancer Incidence Risk Threshold | Risk Threshold | Cohort to Estimate Outcomes | Benefits | Harms: False-Positive Number (%) | Harms: False-Positive Rate
Tammemagi et al, 2013^85^ | Fixed NLST population | 1.35% | PLCO-CXR arm | [underlined: Screen-prevented deaths]:; PLCOm2012: 81; NLST: 69; [underlined: NNS]:; PLCOm2012: 174; NLST: 203 | Model: 13,581 (96%); NLST: 13,662 (96.6%) | Model: 37.1; NLST: 37.3
Landy 2019^89^ | Fixed NLST population^32^ | 1.3% | NHIS 2015 data | [underlined: Screen-prevented deaths]:; PLCOm2012: 56,528; USPSTF: 41,298; [underlined: NNS]:; PLCOm2012: 222; USPSTF: 194 | NR | NR
ten Haaf et al, 2017^83^ | Fixed NLST population | 1.35% | PLCO-CXR arm | NR | Model: 24904 (97.5%); NLST: 24784 (97.9%) | Model: 37.5; NLST: 37.8
ten Haaf et al, 2017^83^ | Fixed NLST population | 1.36% | PLCO-control arm | NR | Model: 24287 (97.7%); NLST: 24248 (97.8%) | Model: 38.3; NLST: 38.1
Weber et al, 2017^86^ | Fixed NLST population | 1.73% | 45 and Up Study | NR | Model: 12,982 (96.9%); NLST: 12,929 (97.3%) | Model: 24.8; NLST: 24.7
Tammemagi et al, 2014^87^ | NLST mortality benefit | 1.51% | PLCO-CXR arm | [underlined: NNS]:; Model: 225; USPSTF: NR | Model: 12378 (95.8%); USPSTF: 13688 (96.6%) | Model: 33.8; USPSTF: 37.3
Landy 2019^89^ | NLST mortality benefit^58^ | 1.51% | NHIS 2015 data | [underlined: Screen-prevented deaths]:; PLCOm2012: 54,456; USPSTF: 41,298; [underlined: NNS]:; PLCOm2012: 207; USPSTF: 194 | NR | NR
Weber et al, 2017^86^ | NLST mortality benefit | 1.51% | 45 and Up Study | NR | Model: 14,642 (97.1%); USPSTF: 13,800 (97.1%) | Model: 28.0; USPSTF: 23.7
Weber et al, 2017^86^ | Optimal ROC classification | 1.49% | 45 and Up Study | NR | Model: 14,774 (97.1%); USPSTF: 13,800 (97.1%) | Model: 28.2; USPSTF: 23.7
Weber et al, 2017^86^ | Conservative | 2% | 45 and Up Study | NR | Model: 11,168 (96.6%); USPSTF: 13,800 (97.1%) | Model: 21.3; USPSTF: 23.7
Landy 2019^89^ | Fixed USPSTF population | 2.19% | NHIS 2015 data | [underlined: Screen-prevented deaths]:; PLCOm2012: 47,401; USPSTF: 41,298; [underlined: NNS]:; PLCOm2012: 169; USPSTF: 194 | NR | NR

Abbreviations: CXR=chest X-ray; NLST=National Lung Screening Trial; NHIS=National Health Interview Survey; NNS=number needed to screen; NR=not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; ROC=receiver operating characteristics; USPSTF=U.S. Preventive Services Task Force.

Across studies of the PLCOm2012 model using a fixed-population approach to setting a risk threshold, there were a similar percentage of false-positive selections for screening and similar rates of false-positive selections for screening with respect to lung cancer deaths when compared with the USPSTF or NLST criteria (range 96.0 to 97.9%, and 37.1 to 38.1 rates, respectively). In the 45 and Up Study, the rate of false-positive selections for screening with respect to lung cancer incidence was lower compared with PLCO cohorts, but similar to false-positive rates for the risk prediction model and risk factor–based screening criteria. Additionally, a simplified version of the PLCOm2012 model including age, and smoking history only was evaluated using fixed-NLST population risk thresholds (1.19% to 1.20%) and similarly found no difference between number of false positive selections for screening or rates of false-positive selections for screening with respect to lung cancer incidence or death when compared with the NLST criteria.^83^

Using the risk threshold of at least 2 percent yielded a lower number of false-positive selections for screening and rates of false-positive selections for screening with respect to lung cancer incidence compared with USPSTF criteria in one study^86^ and a lower number of false-positive selections per prevented deaths in another.^89^ Studies using a risk threshold based on or close to the NLST mortality benefit (1.51%, 1.49% for optimal receiver operating characteristic curve classification) generally had similar numbers of false-positive selections, but mixed results with respect to rates of false-positive selections, depending on the cohort that was used to estimate outcomes. Two studies applied the PLCOm2012 model to cohorts of ever-smokers where the risk prediction model yielded mixed rates of false-positive selections with respect to lung cancer incidence compared with risk factor–based criteria: in the PLCO-CXR cohort, 33.8 (risk threshold ≥ 1.51%) vs. 37.3 (USPSTF criteria) and the 45 and Up Study, 28.0 for risk threshold ≥ 1.51 percent, 28.2 for risk threshold ≥ 1.49 percent, 23.7 for USPSTF criteria.^86,^ ^87^ Neither of these two studies evaluated the effect of risk prediction models on screen-prevented lung cancer deaths or NNS.

##### Studies of Risk Prediction Models Reporting Benefits and Harms

For the LCRAT and LCDRAT, fixed-USPSTF-population, fixed-USPSTF effectiveness strategies, and comparable mortality benefit to NLST were used to select risk thresholds to apply the model to the NHIS 2010–2012 and NHIS 2015.^84,^ ^89^ Study investigators assumed NLST-like increases in lung cancer incidence and 20 percent reduction in lung cancer mortality to estimate screen-preventable deaths, NNS, false-positive selections per prevented death (also called “screening efficiency”), and overdiagnosed lung cancer per prevented death. Kovalchik et al developed a risk model predicting lung cancer death in the NLST control arm and applied the model to the NLST-CT arm to estimate the outcomes above.^56^ Several risk thresholds were evaluated in Kovalchik et al based on risk quintiles; results for quintiles 3–5 and 4–5 corresponding to risk thresholds of 0.84 percent and 1.23 percent are shown in Table 5.^56^

Table 5 Summary of Modeling Studies Evaluating Screen-Prevented Lung Cancer Deaths and NNS to Prevent One Lung Cancer Death^*^

Author, Year | Model | Comparator | Time Horizon, y | Risk Threshold (Selection Method) | Cohort to Estimate Outcomes (Sample Size) | Screen-Prevented Lung Cancer Deaths, Model vs. Comparator | NNS, Model vs. Comparator | FP per Prevented Deaths, Model vs. Comparator | Overdiagnosed Lung Cancers per Prevented Death, Model vs. Comparator
Tammemagi, 2013^85^ | PLCOm2012 model | NLST | 6 | 1.35% (fixed population) | PLCO-CXR arm; (37,327) | 81 vs. 69 | 174 vs. 203 | 167 vs. 196 | 1.04 vs. 1.04
Landy 2019^89^ | PLCOm2012 model | USPSTF | 6 | 1.3% (Reference Tammemagi et al 2013^32^) | NHIS 2015; (12,600,000) | 56,528 vs. 41,298 | 222 vs. 194 | 150 vs. 133 | NR
Landy 2019^89^ | PLCOm2012 model | USPSTF | 6 | 1.51% (NLST mortality benefit-Reference Tammemagi et al 2014^58^) | NHIS 2015; (11,300,000) | 54,456 vs. 41,298 | 207 vs. 194 | 141 vs. 133 | NR
Landy 2019^89^ | PLCOm2012 model | USPSTF | 6 | 2.19% (fixed population) | NHIS 2015; (8,000,000) | 47,401 vs. 41,298 | 169 vs. 194 | 119 vs. 133 | NR
Katki, 2016^84^ | LCDRAT model | NLST | 5 | 1.2% (fixed population) | NHIS 2010–2012; (9,018,130) | 55,717 (95% CI, 53,033 to 58,400) vs. 46,488 (95% CI, 43,924 to 49,053) | 162 (157–166) vs. 194 (187–201) | 116 (113–119) vs. 133 (128–137) | 0.91 vs. 0.93
Landy 2019^89^ | LCDRAT model | USPSTF | 5 | 1.2% (reference Katki, 2016^3^) | NHIS 2015; (9,000,000) | 53,732 vs. 41,298 | 168 vs. 194 | 119 vs. 133 | NR
Landy 2019^89^ | LCDRAT model | USPSTF | 5 | 1.33% (fixed population) | NHIS 2015; (8,000,000) | 51,019 vs. 41,298 | 156 vs. 194 | 112 vs. 133 | NR
Katki, 2016^84^ | LCDRAT model | NLST | 5 | 0.9% (fixed effectiveness) | NHIS 2010–2012; (12,101,749) | 62,382 (95% CI, 59,567 to 65,196) vs. 46,488 (95% CI, 43,924 to 49,053) | 194 (188–200) vs. 194 (187–201) | 134 (131–138) vs. 133 (128–137) | 0.92 vs. 0.93
Kovalchik, 2013^56^ | Kovalchik et al | NLST | 5 | 0.84% (risk quintile 3–5) | NLST-CT; (26,604) | 77 vs. 88 | 208 vs. 302 | 78 vs. 108 | NR
Kovalchik, 2013^56^ | Kovalchik et al | NLST | 5 | 1.23% (risk quintile 4–5) | NLST-CT; (26,604) | 64 vs. 88 | 166 vs. 302 | 64 vs. 108 | NR

* Kovalchik et al applied a model to NLST, intrinsically conferring NLST benefits in lung cancer detection and mortality reduction. The other two studies assumed NLST-like benefits to calculated outcomes.

Abbreviations: CI=confidence interval; CXR=chest X-ray; FP=false positive; LCDRAT=Lung Cancer Death Risk Assessment Tool; NHIS=National Health Interview Survey; NLST=National Lung Screening Trial; NLST-CT=National Lung Screening Trial-Computerized Tomography arm; NNS=number needed to screen; NR=not reported; PLCO= Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; vs.=versus.

Studies of the PLCOm2012 model and LCDRAT model estimated a greater number of screen-preventable lung cancer deaths than with the NLST criteria. Calculations for some studies yielded a much higher total number of estimated screen-preventable lung cancer deaths because larger national samples of smokers were used (size of sample greater than 9 million) compared with the samples used to estimate outcomes for the other models (i.e., PLCO and NLST trial arms that included ~20,000–30,000 persons).^84,^ ^89^ Kovalchik et al reported outcomes for high-risk subsets of the NLST CT screening arm, so screen-preventable lung cancer deaths were intrinsically smaller for the subset compared with the whole trial arm.

Most studies of the three risk prediction models estimated a lower NNS than screening with the NLST criteria, ranging from 29 to 136 fewer subjects screened per lung cancer death prevented. Exceptions included a study of the LCDRAT that used the PLCO-fixed effectiveness threshold, which intentionally sets the NNS equal to that achieved by the NLST criteria,^84^ and one study that used a fixed-population risk threshold (1.3%) and NLST-like mortality benefit threshold (1.51%) in a more modern cohort (NHIS 2015) in which NNS was higher using the risk prediction model compared with risk factor−based criteria (222 and 207, respectively, vs. 194).^89^

Screening efficiency also improved in most cases when a risk-based approach was applied compared with the NLST criteria (range of false-positive selections per prevented lung cancer death: 64–167 for risk models vs. 108–196 for the NLST criteria). The exception was application of the PLCOm2012 model to the 2015 NHIS cohort in which risk thresholds of 1.35 percent and 1.51 percent were used; false-positive selections per prevented deaths ranged from 207 to 222 compared with 194 for USPSTF criteria.^89^ For the two thresholds of LCDRAT evaluated, overdiagnosis was similar for risk-based screening and screening using the NLST criteria.

##### Other Studies of Risk Prediction Models Reporting Only Harms

For the remaining models included in the systematic review—the Bach, LLP, simplified LLP, Knoke, TSCE model, HUNT Lung Cancer Model, estimates of false-positive selections and rates of false-positive selections with respect to lung cancer incidence or death were compared with the NLST criteria using PLCO cohorts (fixed-NLST population-based risk threshold).^83,^ ^95^ In general, false-positive percentages and rates using risk-based screening were similar to screening using the NLST criteria (range of false-positive selections 97 to 98%; range of rates of false-positive selections 21 to 38%).

The COPD-LUCSS score predicts lung cancer incidence in subjects with COPD, including risk factors of age, body mass index, smoking in pack-years, and radiologic emphysema.^88^ Using a risk threshold of COPD-LUCSS score of 7 to 10, this score had a lower number of false-positive selections for screening with respect to lung cancer incidence than the NLST criteria (86% vs. 91%).

### Key Question 3 Accuracy

a. What is the accuracy of screening for lung cancer with LDCT?
b. Does the accuracy of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
c. Does the accuracy of screening for lung cancer with LDCT differ for various approaches to nodule classification (i.e., those based on nodule size and characteristics)?

#### Summary

Fifty-three articles were eligible for this KQ.^32,^ ^33,^ ^38,^ ^57–61,^ ^64,^ ^70,^ ^71,^ ^76–79,^ ^82,^ ^97–132^ Of those, many reported information from the same study (i.e., redundant data), incomplete data, or preliminary data that were later updated in another publication. Therefore, we focused on the results from the 24 publications with the most complete data.^59,^ ^61,^ ^64,^ ^76,^ ^82,^ ^97,^ ^99–101,^ ^103,^ ^104,^ ^107,^ ^108,^ ^111,^ ^113,^ ^115,^ ^119,^ ^121–123,^ ^126,^ ^127,^ ^130,^ ^131^ Sensitivity of LDCT from 13 studies (76,856 total participants) ranged from 59 to 100 percent; all but three studies reported sensitivity over 80 percent. Specificity of LDCT from 13 studies (75,819 total participants) ranged from 26.4 to 99.7 percent; all but three reported specificity over 75 percent. Positive predictive value (14 studies, 77,840 participants) ranged from 3.3 to 43.5 percent. Negative predictive value (9 studies, 47,496 participants) ranged from 97.7 to 100 percent. Variability in accuracy was mainly attributed to heterogeneity of eligibility criteria, heterogeneity of screening protocols (e.g., number of screening rounds, screening intervals), heterogeneity and completeness of followup length (e.g., to identify false-negative screens), and heterogeneity in the definitions (e.g., of positive tests, indeterminate tests, false-positive test, false-negative tests). Three studies (2,211 observations) reported on reliability, finding fair to moderate reliability among radiologists.^103,^ ^108,^ ^113^ Regarding subgroups, one study demonstrated that LDCT had higher sensitivity and lower specificity for persons 65 or older than for younger persons.^64^ Three studies (73,404 participants) compared various approaches to nodule classification (Lung-RADS or I-ELCAP) using the NLST protocol as the basis for comparison.^100,^ ^104,^ ^107^ These demonstrated that using Lung-RADS in the NLST would have increased specificity while decreasing sensitivity, and that increases in positive predictive value (PPV) are seen with increasing nodule size thresholds.

#### Detailed Results: Accuracy

RCTs and nonrandomized studies that reported on sensitivity, specificity, or predictive values (or provided the data that allowed us to calculate measures of accuracy) are summarized in Tables 6 and 7, respectively. Six RCTs^59,^ ^61,^ ^76,^ ^82,^ ^99,^ ^101^ and seven nonrandomized studies^115,^ ^121,^ ^123,^ ^126,^ ^127,^ ^130,^ ^131^ provided sensitivity data. Sensitivity in the RCTs ranged from 59 to 95 percent. Sensitivity in the nonrandomized studies ranged from 87.7 to 100 percent, with five of the nonrandomized studies having sensitivity greater than 90 percent. Six RCTs^59,^ ^61,^ ^76,^ ^82,^ ^99,^ ^101^ and seven nonrandomized studies^111,^ ^121,^ ^123,^ ^126,^ ^127,^ ^130,^ ^131^ provided specificity data. Specificity in the RCTs ranged from 26.4 to 99.2 percent, and specificity in the nonrandomized studies ranged from 34.0 to 99.7 percent. All but two of the nonrandomized studies^111,^ ^130^ had specificity greater than 90 percent. Nine RCTs^59,^ ^61,^ ^76,^ ^82,^ ^99,^ ^101,^ ^119,^ ^122^ and five nonrandomized studies^107,^ ^111,^ ^123,^ ^130,^ ^131^ provided PPV data. PPV ranged from 3.3 to 43.5 percent in the RCTs and from 3.5 to 20.9 percent in the nonrandomized studies. Six RCTs^59,^ ^61,^ ^76,^ ^82,^ ^99,^ ^101^ and three nonrandomized studies^123,^ ^130,^ ^131^ provided negative predictive value (NPV) data. NPV ranged from 97.7 to 99.9 percent in the RCTs and from 99.2 to 100 percent in the nonrandomized studies.

Table 6 Accuracy of LDCT for Lung Cancer Screening in RCTs

Trial Name; Author, Year | Number Analyzed | Nodule Classification Framework^*^ | Threshold for Positive^†^ | Screening Protocol | Sn | Sp | PPV | NPV
DANTE; Infante, 2015^61^ | 2,450 | I-ELCAP | >5-mm average diameter | 5 annual screens | 79.5% | 75.5% | 18.6% | 98.1%
DLCST; Pedersen, 2009^122^ | 4,104 | DLCST | >15-mm maximum diameter or 5–15 mm with >25% volume increase on 3-month repeat | 5 annual screens (4 reported) | NR | NR | 9.5% | NR
ITALUNG; Lopes Pegna, 2013^99^ | 1,406 | I-ELCAP | ≥5-mm average diameter solid nodule, ≥10-mm GGN average diameter, any part-solid nodule | 4 annual screens^‡^ | 95.0% | 26.4% | 3.6% | 99.4%
LSS; Croswell, 2010^119^ | 1,610 | NLST | ≥3-mm maximum diameter T0, ≥4 mm maximum diameter for T1 | 2 annual screens | NR | NR | 7.0% | NR
LUSI; Becker, 2015^59^ | 2,028 | I-ELCAP | ≥5-mm average diameter | 5 annual screens (4 completed) | 93.5% | 62% | 7.2% | 99.7%
MILD; Sverzellati, 2016^82^ | 1,152 | Modified NELSON | Volume >250 mm^3^ or 60–250 mm^3^ with >25% volume increase on 3-month repeat | 5 annual screens | 68.5% | 99.2% | 40.6% | 99.7%
MILD; Sverzellati, 2016^82^ | 1,151 | Modified NELSON | Volume >250 mm^3^ or 60–250 mm^3^ with >25% volume increase on 3-month repeat | 3 biennial screens | 73.5% | 99.2% | 42.4% | 99.8%
NELSON; De Koning, 2020^76^ | 6,583^§^ | NELSON | Volume >500 mm^3^ or 50–500 mm^3^ with VDT<400 d on 3-month repeat | 4 rounds; baseline and after 1 y, 3 y, 5.5 y | 59.0% | 95.8%^§^ | 43.5%^§^ | 97.7%^§^
NLST; Pinsky, 2013^101^ | 26,022 | NLST | ≥4-mm longest diameter | 3 annual screens | 93.1% | 76.5% | 3.3% | 99.9%
UKLS; Field, 2016^97^ | 1,994 | Modified NELSON^∥^ | Volume >500 mm^3^ or 50–500 mm^3^ with VDT<400 d on 3-month repeat | 1 screen | NR | NR | 36.8% | NR
Mean, range | NA | NA | NA | NA | 80.3%, 59.0%–95.0% | 76.4%, 26.4%–99.2% | 21.3%, 3.3%–43.5% | 99.2%, 97.7%–99.9%

* We categorized whether the approach to nodule classification was most similar to the approach used in NLST, NELSON, DLCST, or I-ELCAP.

† These are the abbreviated criteria for a positive screen. Studies also considered specific features of nodules, for example.

‡ Study ongoing at the time of this publication.

§ This evaluation excluded some NELSON participants because it was limited to males in the screening group (data were not presented for the 1,317 females in the screening group). The accuracy calculations in this row used NELSON’s approach to classifying results, with indeterminate results that required a 3-month followup LDCT being categorized as negatives as long as the 3-month followup LDCT was negative (whereas other studies categorized the same type of thing, when any additional LDCT was required for evaluation, as a false positive).

∥ Nodules with volumes <50 mm^3^ were split into two categories. Those <15 mm^3^ received no further followup. Those 15–49 mm^3^ received followup LDCT scan in 1 year.

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; GGN=ground-glass nodule; I-ELCAP=International Early Lung Cancer Action Program; ITALUNG=Italian Lung Cancer Screening Trial; LDCT=low-dose computed tomography; LSS=Lung Screening Study; LUSI=The German Lung Cancer Screening Intervention Trial; MILD=Multi-centric Italian Lung Detection; NA=not applicable; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial; NR=not reported; NPV=negative predictive value; PPV=positive predictive value; RCT=randomized, controlled trial; Sn=sensitivity; Sp=specificity; UKLS= UK Lung cancer Screening; VDT=volume doubling time.

Table 7 Accuracy of LDCT for Lung Cancer Screening in Nonrandomized Studies

Author, Year | Trial/Database | Country | Number Analyzed | Threshold for Positive^*^ | Screening Protocol | Sn | Sp | PPV | NPV
Crucitti, 2015^111^ | “Un respiro per la vita” | Italy | 1,500 | >4 mm, avg max and min | 1 scan | NR | 34.0% | 4.6% | NR
Henschke, 2004^131^ | I-ELCAP | U.S. | 2,698 | ≥5 mm, avg max and min | 2 annual scans | 97.0% | 90.0% | Baseline: 20.9%; Annual: 11.0% | Baseline: 99.2%; Annual: 100%
Henschke, 2013^107^ | I-ELCAP | Multinational | 21,136 | ≥5 mm, avg max and min; ≥6 mm, avg max and min | Annual scans; data is from baseline scans | NR^†^; NR^†^ | NR^†^; NR^†^ | 3.5%^†^; 5.5%^†^ | NR^†^; NR^†^
Toyoda, 2008^126^ | Osaka | Japan | 18,070 | “Need for further clinical exam” | 2 annual scans | 88.9% | 92.6% | NR | NR
Tsushima, 2008^123^ | Azumi & Shinshu | Japan | 2,486 | >3 mm | Annual scans | 100.0% | 96.9% | 9.9% | 100.0%
Tammemagi, 2017^115^ | PanCan | Canada | 2,537 | ≥1 mm | T0: Baseline; T1: 1 year; T4: 4 years | 92.7% | NR | NR | NR
Swensen, 2005^130^ | Mayo | U.S. | 1,520 | NCN >4 mm, avg max and min | 5 annual scans | 95.5% | 37.9% | 5.8% | 99.3%
Menezes, 2010^121^ | Toronto | Canada | 3,552 | ≥5 mm, avg max and min | 6 annual screenings | 87.7% | 99.3% | NR | NR
Veronesi, 2008^127^ | COSMOS | Italy | 5,201 | ≥5 mm | 1 scan | 91.0% | 99.7% | NR | NR
Mean, range | NA | NA | NA | NA | NA | 93.3%, 87.7% to 100% | 78.6%, 34.0% to 99.7% | 8.7%, 3.5% to 20.9% | 99.6%, 99.2% to 100%

* These are the abbreviated criteria for a positive screen. Studies also considered specific features of nodules, for example.

† Study reported data to allow calculation of PPV (reporting total positives and true positives) but did not report data to allow calculation of Sn, Sp, or NPV. However, an investigator from the study team submitted public comments on the draft report stating the following: Sn 97.5%, Sp 84.4%, and NPV 100% for the 5-mm threshold for a positive test and Sn 97.5%, Sp 90.3%, and NPV 100% for the 6-mm threshold for a positive test. The study also reported data for higher thresholds (7 mm, 8 mm, and 9 mm) that would allow calculation of PPV.

Abbreviations: avg=average; COSMOS=Continuing Observation of Smoking Subjects; I-ELCAP=International Early Lung Cancer Action Program; LDCT=low-dose computed tomography; max=maximum; min=minimum; NA=not applicable; NCN=National Cancer Network; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; Sn=sensitivity; Sp=specificity; U.S.=United States.

Among the trials that reported a reduction in lung cancer mortality, NLST and NELSON, the reported sensitivities were 93.1 and 59 percent and reported specificities were 76.5 and 95.8 percent, respectively.^76,^ ^101^ Although the NPVs were similar for the NLST and NELSON (99.9% and 97.7%, respectively), the PPVs were vastly different (3.3% and 43.5%, respectively). This difference could potentially be accounted for by the difference in screening protocols—NELSON used a volumetric approach and provided for an indeterminate nodule result category and the NLST used an approach of maximum diameter without an indeterminate category—or possibly by the prevalence of lung cancer in each of the trial settings. Alternatively, these data could represent two different positions on the same ROC curve, illustrative of tradeoffs between sensitivity and specificity.

Numerous factors may account for the variability in accuracy across studies. There was heterogeneity in the screening protocols, particularly for the number of screening LDCT scans performed, the interval between screening rounds, and threshold for a positive test. The studies also varied in terms of their followup lengths, and some had incomplete followup data. For instance, most of the nonrandomized studies did not report the length of followup after the last screening scan. As a result of differential and incomplete followup data, some studies may not have adequately captured false-positive and false-negative screens, perhaps because of an inability to ascertain complete data on the workup of screen-positive nodules or the development of interval cancers after a negative screen. As well, the definitions for positive test, indeterminate test, false-positive test, and false-negative test varied across studies. The three most common methods for defining a positive test were similar to those used by the NLST (NCN ≥4-mm maximum diameter), I-ELCAP (NCN ≥5-mm average of maximum length and width, later changed to 6 mm), or NELSON protocols (e.g., volume of NCN ≥500 mm^3^).

#### Reliability

Three studies (2,211 observations) conducted analyses of RCT data to report reliability outcomes, finding fair to moderate reliability among radiologists.^103,^ ^108,^ ^113^ Two of these studies calculated kappa values among radiologists; all average outcomes either had fair (kappa 0.21 to 0.40) or moderate (kappa 0.41 to 0.60) agreement levels. One study using data from three NELSON trial sites evaluated agreement among radiologists for a set of 160 nodules equally distributed across solid, part-solid with large solid component, part-solid with small solid component, and ground glass nodule definitions, finding moderate agreement (kappa 0.51 [95% CI, 0.30 to 0.68]).^113^ Another study using 1990 scans from the DLCST focused on identifying emphysema (and other outcomes not eligible for this review) but also reported some outcomes eligible for this review. Specifically, it reported moderate agreement in identifying pleural nodules (kappa 0.53), centrilobular nodules (kappa 0.41), and masses (kappa 0.42), with fair agreement for subpleural/paraseptal nodules (kappa 0.24).^108^ Finally, a study of data from the NELSON trial found that 22 of the 61 interval or post-screen cancers diagnosed in NELSON were, in retrospect, visible on the prior LDCT.^103^ It was determined that 20 of these 22 were detection errors (i.e., the radiologic abnormality was not detected), and the other two were detected but were misinterpreted. The study did not report kappa statistics.

#### Variation by Subgroups

Two studies (44,792 participants) assessed how the accuracy of LDCT varied by subgroups.^64,^ ^126^ An analysis of NLST data stratified by age of Medicare eligibility (age ≥65) demonstrated increased sensitivity (94.3% vs. 93.2%), decreased specificity (72.3% vs. 78.0%), and increased PPV (4.9% vs. 3.0%, p < 0.001) for Medicare-eligible participants. The increased PPV was attributed to higher cancer prevalence in this population.^64^ Data from the Osaka Cancer Registry Database were stratified by sex and smoking status, finding no statistically significant differences between women and men for sensitivity (84.6% [95% CI, 65.0 to 100] vs. 90.6% [95% CI, 80.5 to 100]) or specificity (93.5% [95% CI, 92.6 to 94.4] vs. 92.1% [95% CI, 91.3 to 92.9]) or by smoking status for sensitivity (current 84.0% [95% CI, 69.6 to 98.4], former 85.7% [95% CI, 59.8 to 100], nonsmoker 100% [95% CI, NR]), or specificity (current 92.4% [95% CI, 91.6 to 93.3], former 91.5% [95% CI, 89.9 to 93.1], nonsmoker 93.5% [95% CI, 92.5 to 94.4]).^126^

#### Variation by Approaches to Nodule Classification

Three retrospective studies compared how various approaches to nodule classification would alter the accuracy of LDCT.^100,^ ^104,^ ^107^ The first study (26,722 participants) was a retrospective analysis that applied Lung-RADS criteria to NLST data and found that using Lung-RADS (with Lung-RADS categories 1 and 2 considered negative results) was estimated to increase the specificity of LDCT (from 73.4% to 87.2% at baseline, p<0.001; from 78.2% to 94.7% after baseline, p<0.001) but decrease the sensitivity (from 93.5% to 84.9% at baseline, p<0.001; from 93.8% to 78.6% after baseline, p<0.001) compared with using the NLST criteria.^100^ The second study (5,848 NLST participants with positive LDCT screens) evaluated how using I-ELCAP criteria and other thresholds for a positive test (e.g., 5-mm average diameter, 6 mm, etc.) alters the frequency of positive results and related outcomes compared with the NLST criteria (4-mm longest diameter).^104^ The study did not report measures of accuracy, but the data reported allow for calculation of PPV and show that using a 5-mm average diameter criterion (applied to NLST data) increases the PPV (from 4% to 5.7%), as does increasing the threshold further (e.g., PPV 8.5% for 6 mm, PPV 12.2% for 7 mm). However, this analysis did not calculate other test characteristics (sensitivity, specificity, NPV) and excluded 848 nonsolid noncalcified nodules that would have otherwise met the criteria for a positive screen.^104^ Similarly, the third study estimated that PPV would increase with increasing thresholds for defining a positive result (from 5-mm to 6-mm average diameter).^107^

Comparing volumetric and nonvolumetric (i.e., maximum diameter or average maximum length and width) approaches indicates that the PPV in trials using volumetric approaches to nodule classification tends to be higher than in those using nonvolumetric approaches. However, because there are no direct comparisons of these approaches, differences in study populations (e.g., lung cancer incidence) and other contributors to heterogeneity across studies may account for the differences in PPV. The NPVs are universally high using both approaches, and no trends in sensitivities or specificities are apparent.

### Key Questions 4 and 5 Harms of Screening, Workup, or Surveillance

KQ 4a What are the harms associated with screening for lung cancer with LDCT?
b Do the harms of screening for lung cancer with LDCT differ with the use of Lung-RADS, I-ELCAP, or similar approaches (e.g., to reduce false-positive results)?
c Do the harms of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
KQ 5a What are the harms associated with workup or surveillance of nodules?
b Do the harms of workup or surveillance of nodules differ with the use of Lung-RADS, I-ELCAP, or similar approaches (e.g., to reduce false-positive results)?
c Do the harms of workup or surveillance of nodules differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?

#### Radiation Exposure

Nine publications reported on radiation associated with LDCT (Table 8).^32,^ ^67,^ ^111,^ ^117,^ ^124,^ ^130,^ ^133–135^ Most of those reported the radiation associated with one LDCT, with ranges from 0.65 mSv to 2.36 mSv. Two of the studies evaluated the cumulative radiation exposure for participants undergoing screening with LDCT.^134,^ ^136^ Using the results of those two studies to estimate the cumulative radiation exposure for 25 years of annual screening (i.e., annual screening from age 55 to 80 as recommended by the USPSTF in 2013) yields 20.8 mSv to 32.5 mSv.

Table 8 LDCT Parameters, by Study Type

| kV | mAs | Slice Width (mm) | Overlap^*^ | Multi/Single Detector | Estimated Dose/Study (mSv)
Trials
COSMOS^124,^ ^134^ | 140 | 30 | 2.5 | NR | MDCT | 1.0 (men), 1.4 (women)
DANTE^71^ | 140 | 40 | 5 | Yes | Both | NR
DLCST^122^ | 120 | 40 | 3 and 1, 1.5 and 1 | Yes | MDCT | NR
ITALUNG^125^ | 120–140 | 20–43 | 3 | NR | Both | NR
LSS^70^ | 120–140 | 60 | 5 | NR | NR | NR
LUSI^60^ | NR | NR | 1 | NR | MDCT | 1.6–2
MILD^80^ | 120 | 30 | 0.75 | NR | Both | 0.7
NELSON^77^ | 80–140 | 40–80 | 0.7 | Yes | MDCT | NR
NLST^32^ | 120–140 | 40–80 | 1–2.5 | Yes | MDCT | 1.5
Cohort Studies
Crucitti et al, 2015^111^ | 120 | 35 | 1 | No | MDCT | 2.36
Mayo Lung Project^152^ | 120 | 40 | 3.75 | NR | MDCT | 0.65
PLuSS^137^ | 140 | 40–60 | 2.5 | No | NR | NR
Toronto^118^ | 120 | 40–60 | 1–1.25 | Yes | MDCT | NR
Tsushima et al, 2008^123^ | 120 | 25 | 5 | NR | MDCT | NR

* Overlap is an approach to image reconstruction. Helical (spiral) CT allows overlapping image reconstruction at arbitrary positions without additional radiation exposure to patients, theoretically increasing ability to detect smaller nodules (compared with consecutive reconstruction).

Abbreviations: COSMOS=Continuing Observation of Smoking Subjects; DANTE=Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LSS=Lung Screening Study; LUSI=The German Lung Cancer Screening Intervention Trial; MDCT=multidetector computed tomography; MILD=Multi-centric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial; NR=not reported; PLuSS=Pittsburgh Lung Screening Study.

One of the two studies describing cumulative exposure reported that screened participants in the ITALUNG trial had cumulative radiation exposure of 3.3 mSv for multidetector CT (MDCT).^136^ The authors estimated this would result in a lifetime risk of fatal cancer of 0.11 per 1,000 subjects for MDCT after the four screening rounds.

The other evaluated the Continuing Observation of Smoking Subjects (COSMOS) study and reported a cumulative radiation dose from LDCT and positron emission tomography (PET) CT scans (individual PET CTs had a median radiation dose 4.0 mSv) to be 13.0 mSv for women and 9.3 mSv for men after 10 years of annual screening.^134^ This study also noted cumulative dosing by interval years and sex, with men averaging 3.0 mSv (range 1.9 to 27.4) after 3 years and 5.2 mSv (range 2.9 to 39.6) after 5 years and women averaging 4.2 mSv (range 2.9 to 23.3) after 3 years and 7.2 mSv (range 4.1 to 26.8) after 5 years (p values for comparison by sex not reported). This study additionally estimated lifetime attributable risk of cancer estimated with the National Research Council’s Biological Effects of Ionizing Radiation VII report, which estimated the lifetime attributable risk of cancer incidence after radiation exposure for specific organs. Using this report, the estimated lifetime risk of cancer from radiation of 10 annual LDCTs was 2.6 to 8.1 major cancers per 10,000 people screened (converting to every 1,000 people screened: 0.26 to 0.81 major cancers). The study reported that men and women starting at an earlier age (50–54 years old) will have a higher number of radiation-induced major cancers (males 3.7 and females 8.1 cancers per 10,000 screened) than older (≥65 years old) participants (males 2.6 and females 5.1 cancers per 10,000 screened); no statistical testing for differences was reported. Projected risk specifically for radiation-induced lung cancer was similar, with younger patients (beginning at ages 50–54) having a higher risk than those beginning screening at age 65 years or older (males 2.1 and females 5.5 cancers per 10,000 screened vs. 1.4 and 3.8 cancers per 10,000 screened for those 65 years or older, respectively). The authors estimated that there will be one major radiation-induced cancer (lung, stomach, colon, liver, bladder, thyroid, breast, ovaries, uterus, or leukemia) for approximately every 100 lung cancers detected by screening during the 10 years of the study.

None of the included studies provided estimates for the lifetime risk of radiation-induced cancers or fatal cancers from continuing annual screening up to age 80.

#### False-Positive Results and Followup Evaluations

Twenty seven publications reported false-positive rates or enough information to determine the rate of false positives, defined as any result leading to additional evaluation (repeat LDCT scan prior to next annual screening, PET scan, biopsy, etc.) that did not result in a diagnosis of cancer.^32,^ ^38,^ ^57–59,^ ^64,^ ^65,^ ^69,^ ^70,^ ^76,^ ^82,^ ^102,^ ^104,^ ^107,^ ^111,^ ^117,^ ^120–123,^ ^128,^ ^130–132,^ ^137–139^ False-positive rates varied widely across studies, most likely due to differences in definitions of positive results, such as cut-offs for nodule size (e.g., 4 mm vs. 5 mm vs. 6 mm), use of volume doubling time, and various nodule characteristics considered. We determined the false-positive rate by dividing the number of false positives by the number of individuals screened with LDCT. The range of false-positive rates overall was 7.9 to 49.3 percent for baseline screening and 0.6 to 28.6 percent for individual incidence screening rounds, although rates for some subgroups were higher (e.g., age ≥65 years) (Table 9). For trials, rates ranged from 7.9 to 26.9 percent for baseline screening and 0.6 to 27.2 percent for incidence screening.^32,^ ^57,^ ^59,^ ^64,^ ^76,^ ^117,^ ^120,^ ^122^ For cohort studies, false-positive rates ranged from 9.6 to 49.3 percent for baseline screening and 5.0% to 28.6 percent for incident screening.^38,^ ^82,^ ^107,^ ^121,^ ^128,^ ^130,^ ^131,^ ^137^ False-positive rates generally declined with each screening round.^64,^ ^82,^ ^120,^ ^121,^ ^128,^ ^131^

Table 9 Number and Percentage of False-Positive Results After Screening With LDCT

Study; Author, Year | Country | I-ELCAP or Lung-RADS | Screening Years | Definition of Positive Nodule by Study Authors^*^ | False-Positive Results^*^ | False-Positive Percentage^*^
Clinical Trials
DLCST; Pedersen, 2009^122^; Saghir 2012^65^ | Denmark | NA | Baseline | ≥5 mm | T0: 162; T1: 34; T2: 39; T3: 32; T4: 35 | T0: 7.90%; T1: 1.7%; T2: 2.0%; T3: 1.6%; T4: 1.9%
LSS; Gohagan, 2004^70^; Gohagan, 2005^69^ | U.S. | NA | 0, 1 | Baseline: >3 mm; Year 1: ≥4 mm | T0: 295; T1: 352 | T0: 18.6%; T1: 25.2%
LUSI; Becker, 2015^59^ | Germany | NA | 0, 1, 2, 3, 4 | ≥5 mm; Incidence nodules: VDT <600 of known nodule | T0: 428; T1: 77; T2: 65; T3: 95; T4: 82 | T0: 21.1%; T1: 4.1%; T2: 3.5%; T3: 5.2%; T4: 5.2%
MILD; Sverzellati, 2016^82^ | Italy | NA | LDCT1 (annual screening): 0, T1, T2, T3, T4, T5, T6; LDCT2 (biennial screening): 0, T1, T2, T3 (T0.1, T1.1, and T2.1 indicate those converted to annual screening) | >60 mm^3^; Incidence nodules: volume increase >25% | LDCT1:; T0: 160; T1: 31; T2: 48; T3: 25; T4: 18; T5: 5; T6: 11; LDCT2; T0: 152; T0.1: 3; T1: 46; T1.1: 8; T2: 26; T2.1: 9; T3: 33; Total: 271 | LDCT1:; T0: 13.9%; T1: 2.8%; T2: 4.4%; T3: 2.4%; T4: 1.8%; T5: 0.6%; T6: 2.6%; LDCT2; T0: 13.2%; T0.1: 2.0%; T1: 4.2%; T1.1: 4.6%; T2: 2.6%; T2.1: 5.4%; T3: 4.4%; Total: 6.1%
NELSON; van Klaveren, 2009^120^; de Koning 2020^76^ | Netherlands and Belgium | NA | 0, 1, 3, 5.5 | Volume >50 mm^3^; (>9.8 mm in diameter); Incidence nodules: VDT <400 days | T0: 1,500^†^; T1: 516^†^; T2 (males only): 521; T3 (males only): 175 | T0: 19.8%^‡^; T1: 7.1%^‡^; T2 (males only): 9.0%; T3 (males only): 3.9%
NLST; Aberle, 2011^32^; Pinsky, 2014^64^ | U.S. | NA | 0, 1, 2 | ≥4 mm | T0: 6,921; T1: 6,733; T2: 3,843; <65 subgroup:; T0: 4,796; T1: 4,678; T2: 2,603; ≥65 subgroup:; T0: 2,125; T1: 2,058; T2: 1,232 | T0: 26.3%; T1: 27.2%; T2: 15.9%; <65 subgroup:; T0: 24.8%; T1: 25.7%; T2: 14.6%; ≥65 subgroup:; T0: 30.3%; T1: 31.5%; T2: 19.5%
UKLS,; Field, 2016^117^ | U.K. | NA | Baseline | >50mm^3^ | 494 | 26.90%
Cohort Studies
NA; Henschke, 2013^107^ | International | I-ELCAP | Baseline | Based on size cut-off as indicated | 5 mm: 3,277; 6 mm: 2,040; 7 mm: 1,385; 8 mm: 965; 9 mm: 727 | 5 mm: 15.5%; 6 mm: 9.7%; 7 mm: 6.6%; 8 mm: 4.6%; 9 mm: 3.4%
NLST LDCT cohort; Yip, 2014^104^ | U.S. | NA | Baseline | Based on size cutoff as indicated; assessed how false-positive screens would have been reduced if the NLST had used higher thresholds | 5 mm: 3,848; 6 mm: 2,470; 7 mm: 1,621; 8 mm: 1,144; 9 mm: 858 | 5 mm: 14.4%; 6 mm: 9.2%; 7 mm: 6.1%; 8 mm: 4.3%; 9 mm: 3.2%
NLST LDCT cohort, if using Lung-RADS; Pinsky, 2018^139^ | U.S. | NA | Baseline, cumulative (includes up to 2 annual screens) | Lung-RADS | NR | Risk decile (based on Tammemagi risk prediction model, 6-year lung cancer risk):; Baseline; 1: 8.3%; 2: 9.8%; 3: 11.0%; 4: 10.1%; 5: 11.6%; 6: 11.9%; 7: 13.1%; 8: 13.8%; 9: 14.7%; 10:17.6%; Cumulative; 1: 12.9%; 2: 15.3%; 3: 16.2%; 4: 15.7%; 5: 18.3%; 6: 19.2%; 7: 21.3%; 8: 20.7%; 9: 22.3%; 10: 25.9%
VHA demonstration; Kinsinger, 2017^38^ | U.S. | NA | Baseline | Not reported clearly in the paper but cited Fleischner guidelines from 2013 state any nodule ≥5 mm; also recommended followup of small nodules if they were new, were growing, or had suspicious features. | All sites: 1,226; Site 1: 333; Site 2: 66; Site 3: 178; Site 4: 238; Site 5: 153; Site 6: 61; Site 7: 109; Site 8: 88 | All sites: 58% of veterans screened; 28.9% of those eligible for screening; Percentages below are of those eligible for screening:; Site 1: 38.3%; Site 2: 14.0%; Site 3: 45.8%; Site 4: 30.6%; Site 5: 53.1%; Site 6: 22.4%; Site 7: 12.6%; Site 8: 28.0%
NA; Menezes, 2010^121^ | Canada | I-ELCAP | 0, 1, 2, 3, 4, 5 | ≥5 mm | Baseline: 556; Y1: 249; Y2: 64; Y3: 9; Y4: 5; Y5: 2 | Baseline: 16.6%; Y1: 9.3%; Y2: 9.6%; Y3: 5.2%; Y4: 13.9%; Y5: 28.6%
NA; Henschke, 2006^128^ | Japan | I-ELCAP | 0, 1 | ≥5 mm; Incidence nodules: any new nodule | Baseline: 3,781; Annual: 1,386 | Baseline:12%; Annual: 5.0%
NA; Henschke, 2004^131^ | U.S. | I-ELCAP | 0, 1 | ≥5 mm; Incidence nodules : any new nodule | I-ELCAP 1:; Baseline: 130; Annual: 137; I-ELCAP 2:; Baseline: 238; Annual: 117 | I-ELCAP 1:; Baseline: 9.6%; Annual: 12.2%; I-ELCAP 2:; Baseline: 9.9%; Annual: 5.2%
NA; Swensen, 2005^130^ | U.S. | NA | 0, 1, 2, 3, 4 | >4 mm (initially followup for any nodule was at least 6 months but later moved out to 12 months) | Baseline:; All nodules: 749; >4 mm: 404; Incidence:; All nodules: 773; >4 mm: 378 | Baseline:; All nodules: 49.3%; >4 mm: 26.6%; Incidence:; All nodules: could not calculate; >4 mm: could not calculate
NA Tsushima, 2008^123^ | Japan | NA | Baseline | <3 mm solid | 175 | 7.0%
PLuSS; Wilson, 2008^137^ | U.S. | NA | 0,1 | 0.5–0.9 cm average diameter with spiculated border or > 1.0 cm average diameter. | 741 | 20.30%
NA; Crucitti, 2015^111^ | Italy | NA | 0, 1 | Noncalcified nodule of any size resulted in another CT after 1 year; NCN ≥5 mm indicated further evaluation | Baseline: 500 | Baseline: 33.3%

* Definition of positive for these calculations was the threshold leading to further evaluation (further CT scans, biopsy, etc.), including CT scans at intervals shorter than the next routine screening CT scan. False-positive results calculated using the number of tests leading to further evaluation (further CT scans, biopsy, etc.) and false-positive percentage calculated by dividing the number of false-positive results by the number of people screened with LDCT scan.

† Data reported here based on the systematic review’s definition of positive tests. If indeterminant results are reclassified based on 3-month followup LDCT scans, then the number of false-positive results for the first two screening rounds would be 196 and 128, respectively. The protocol for reading nodules included the freedom of radiologists to manually up- or downgrade results. This led to a net decrease of 119 false-positive results in the baseline round.^325^

‡ Data reported here based on the systematic review’s definition of positive tests. If indeterminant results are reclassified based on 3-month followup LDCT scans, then the false-positive percentage (percentage of all persons screened) would be 1.7 percent and 1.0 percent, respectively.

Abbreviations: DLCST=Danish Lung Cancer Screening Trial; I-ELCAP=International Early Lung Cancer Action Program; LDCT=low-dose computed tomography; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multi-centric Italian Lung Detection; NA=not applicable; NCN=National Cancer Network; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial; NLST-CT=National Lung Screening Trial-Computed Tomography; PLuSS=Pittsburgh Lung Screening Study; T=time; U.K.=United Kingdom; UKLS= UK Lung cancer Screening; U.S.=United States; VHA=Veterans Health Administration; VDT=volume doubling time.

Among the trials that found lung cancer screening mortality benefit and cohort studies based in the United States, false-positive rates were 9.6 percent to 28.9 percent for baseline and 5.0 percent to 28.6 percent for incident rounds. The NLST reported false-positive rates for baseline, year 1, and year 2 of 26.3, 27.2, and 15.9 percent, respectively.^32^ The NELSON trial noted false-positive rates of 19.8 percent at baseline, 7.1 percent at year 1, 9.0 percent for males at year 3, and 3.9 percent for males at year 5.5 of screening.^76,^ ^120^ One study of 112 radiologists from 32 screening centers who each interpreted 100 or more NLST scans reported a mean false-positive rate of 28.7 percent (standard deviation 13.7, range 3.8% to 69.0%).^102^ Mean rates were similar for academic (25 centers) and nonacademic (7 centers) centers (27.9% vs. 26.7%, respectively).^102^ An implementation study through the Veterans Administration revealed a false-positive rate of 28.9 percent of veterans eligible for screening (58% of those who were actually screened) at baseline screening.^38^ False-positive rates varied across eight study sites, ranging from 12.6 to 45.8 percent of veterans eligible for screening.^38^

Regarding whether harms of screening differ with the use of Lung-RADS, I-ELCAP, or similar approaches (KQs 4b and 5b), we found no eligible studies that directly compared Lung-RADS vs. I-ELCAP within a common set of participants. Three studies assessed how use of Lung-RADS would have affected false-positive result rates.^100,^ ^132,^ ^139^ One found a false-positive rate among baseline results for Lung-RADS of 12.8 percent (95% CI, 12.4% to 13.2%) vs. 26.6 percent (95% CI, 26.1% to 27.1%) for the NLST approach. Another study used NLST baseline data to evaluate whether Lung-RADS category 4X improves prediction of malignancy in subsolid nodules.^132^ It reported false-positive rates (i.e., upgrade of a benign nodule to category 4X) for nodules in category 3 of 7 percent (95% CI, 5% to 9%), category 4A of 7 percent (95% CI, 4% to 10%), and category 4B of 19 percent (95% CI, 13% to 24%).^132^ The third stratified NLST participants by risk (using the Tammemagi lung cancer risk prediction model) and found increasing false-positive rates for increasing risk, ranging from 8.3 to 17.6 percent for baseline rates and 12.9 to 25.9 percent for cumulative rates.^139^ Among studies using I-ELCAP criteria, the false-positive rate ranged from 9.6 to 16.6 percent for baseline screening to 5.0 to 28.6 percent for incident screening.^121,^ ^128,^ ^131^

For subgroups, one study evaluating NLST data on two annual rounds of LDCT scans found a cumulative risk of at least one false-positive test to be 33 percent.^119^ It reported that after a second round of screening, smokers with more pack-years had 1.5 times the odds of a false-positive result (OR, 1.53 [95% CI, 1.08 to 2.18]). Another subgroup analysis of the NLST data found higher false-positive rates in those older than 65 years (23.5% for all participants; 22.0% vs. 27.7% for those <65 years vs. ≥65 years for all rounds, p=0.001).^64^

#### False-Positive Evaluations

The most detrimental harms of false-positive results occur in the workup of these nodules, which can include further imaging (LDCT, CT, or PET), biopsy, or surgical procedures. Fourteen studies reported on the evaluation of false-positive results.^32,^ ^57,^ ^60,^ ^64,^ ^99,^ ^117–119,^ ^121,^ ^127,^ ^130,^ ^133,^ ^135,^ ^140^ Definitions of procedures and groupings of procedures varied among studies. Among all patients screened, the percentage who had a needle biopsy for a false-positive result ranged from 0.09 to 0.56 percent (Table 10). Complication rates from needle biopsy for false positives ranged from 0.03 to 0.07 percent of all those screened. Surgical procedures (and surgical resections) for false positives were reported in 0.5 to 1.3 percent (0.1% to 0.5%) of all screened participants.

Table 10 False-Positive Evaluations

Author, Year; Country | Associated Trial; Nodule Management (I-ELCAP or Lung-RADS); N Participants Screened with LDCT | Needle Biopsies and Complications Following a False Positive Result Among Participants Screened with LDCT; N (%) | Other Procedures and Complications Following a False Positive Result Among Participants Screened with LDCT; N (%) | Surgical Procedures and Complications Following a False Positive Result Among Participants Screened with LDCT; N (%)
Aberle, 2011^32^; U.S. | NLST; NA; 26,722 | 66 (0.25); Most severe complication classified as major:^*^ 0 (0); Most severe complication classified as intermediate:^†^ 6 (0.02); Most severe complication classified as minor:^‡^ 1 (0.004); Death within 60 days: 0 (0) | Bronchoscopy: 227 (0.85); Most severe complication classified as major:^*^ 2 (0.007); Most severe complication classified as intermediate:^†^ 9 (0.034); Most severe complication classified as minor:^‡^ 0 (0); Death within 60 days: 4 (0.015) | Thoracotomy, thoracoscopy, or mediastinoscopy: 164 (0.61); Most severe complication classified as major:^*^ 9 (0.034); Most severe complication classified as intermediate:^†^ 13 (0.049); Most severe complication classified as minor:^‡^ 4 (0.015); Death within 60 days: 2 (0.007)
Becker, 2012^60^; Germany | LUSI; NA; 2,029 | 9 (0.44) | NR | NR
Church, 2013^57^; U.S. | NLST; NA; 26,715 | Bronchoscopy, with biopsy: 108 (0.40) | Bronchoscopy, without biopsy: 42 (0.16); Other procedure: 122 (0.46) | Mediastinoscopy or mediastinotomy: 12 (0.045); Thoracoscopy: 38 (0.14); Thoracotomy: 41 (0.15)
Croswell, 2010^119^; U.S. | NA; NA; 1,610 | NR | Bronchoscopy (minimally invasive): 25 (1.55); Lung biopsy, mediastinoscopy, mediastinotomy, thoracentesis, or VATS thoracoscopy (moderately invasive): 20 (1.24) | Lung resection and thoracotomy (major surgical procedure): 8 (0.50)
Field, 2016^117^; U.K. | UKLS Trial; NA; 1,994 | 7 (0.35) | EBUS: 1 (0.05) | NR
Infante, 2011^140^; Italy | DANTE; NA; 1,276 | NR | NR | Total surgical procedure: 17 (1.33); Mediastinoscopy: 3 (0.24); VATS wedge resection: 7 (0.55); Open wedge resection: 6 (0.47); Open segmentectomy:1 (0.08)
Lopes Pegna, 2013^99^; Italy | ITALUNG; I-ELCAP; 1,406 | 1 (0.07) | NR | Surgical resection: 4 (0.28)
Menezes, 2010^121^; Canada | NA; I-ELCAP; 3,352 | 3 (0.09)^§^; Pneumothorax: 1 (0.03) | NR | NR
Pinsky, 2014^64^; U.S. | NLST; NA; Under 65 Cohort; Year 0: 19,306; Year 1: 18,184; Year 2: 17,798; Total: 55,288 LDCTs; 65+ Cohort; Year 0: 7,003; Year 1: 6,531; Year 2: 6,304; Total: 19,838 LDCTs | NR; Total complications:; Year 0: 18 (0.07); Year 1: 16 (0.06); Year 2: 13 (0.05); Note: these were reported as complications for invasive procedures and NR how many were attributable to biopsies. | Invasive Procedures / Total Complications / Major Complications; Under 65; Year 0: 168 (0.87) / 10 (0.05) / 1 (0.01); Year 1: 84 (0.46) / 14 (0.08) / 2 (0.01); Year 2: 73 (0.41) / 8 (0.04) / 3 (0.02); Total: 325 (0.59) / 32 (0.06) / 6 (0.01); 65+; Year 0: 86 (1.23) / 8 (0.11) / 2 (0.03); Year 1: 44 (0.67) / 2 (0.03) / 2 (0.03); Year 2: 47 (0.75) / 5 (0.08) / 2 (0.03); Total: 177 (0.89) / 15 (0.08) / 6 (0.03); Of all LDCTs, invasive procedures after false-positive screens: 3.3% vs. 2.7% for those ≥65 vs. <65 (p=0.039). | Under 65; Baseline: 60 (0.31); Year 1: 34 (0.19); Year 2: 25 (0.14); Total: 119 (0.22); 65+; Baseline: 29 (0.41); Year 1: 17 (0.26); Year 2: 18 (0.29); Total: 64 (0.32)
Swensen, 2005^130^; U.S. | NA; NA; 1,520 | NR | NR | 13 (0.86) participants underwent 15 surgeries; Surgical mortality: 0 (0)
van ‘t Westeinde, 2012^138^; Netherlands/Belgium | NELSON; NA; 7915 | NR | Bronchoscopy: 121 (1.53) | NR
Veronesi, 2008^127^; Italy | NA; NA; 5,201 | NR | NR | Surgical biopsy: 15 (0.29)
Veronesi, 2012^135^; Italy | COSMOS; NA; 5,203 | 29 (0.56) | NR | NR
Wagnetz, 2012^118^; Canada | NA; I-ELCAP; 4,782 | 20 (0.42) | NR | VATS: 5 (0.10)
Walker, 2015^133^; U.S. | NA; Lung-RADS; 1,654 | NR | NR | 5 (0.30); Surgery-related deaths: 0 (0)

* Major complications: Acute respiratory failure, anaphylaxis, bronchopulmonary fistula, stroke, cardiac arrest, cardiac vascular accident, congestive heart failure, tube placement, death, hemothorax, myocardial infarction, respiratory arrest, tube thoracostomy or other drainage for more than 4 days, wound dehiscence; bronchial stump leak, empyema, injury to vital organ or vessel, mechanical ventilation over 48 hours post‐op, complications requiring intervention, thromboembolic complication, chylous fistula, brachial plexopathy, lung collapse, infarcted sigmoid colon.

† Intermediate complications: Blood loss requiring a transfusion, cardiac arrhythmia requiring medical attention, fever requiring antibiotics, hospitalization post procedure, referral to a pain specialist, pneumothorax requiring tube placement, rib fracture(s), vocal cord immobility/paralysis, requiring antibiotics, ST elevation, infections, cardiac ischemia, bronchitis, pneumonia, pleural effusion, sepsis, respiratory distress, mucous plug requiring bronchoscopy, steroid-induced diabetes.

‡ Minor complications: Allergic reaction, bronchospasm, vasovagal reaction/hypotension, subcutaneous emphysema, atelectasis, pneumothorax with no chest tube, ileus, seroma, paresthesias/hyperesthesias.

§ Four additional individuals who were not diagnosed with lung cancer (although followup was ongoing at the time of publication) were recommended to have biopsies. Of those four, two people had insufficient biopsies limited by low cellularity, one had a pneumothorax prior to a sample being obtained, and one had resolution of the nodule prior to a biopsy being obtained.

Abbreviations: COSMOS=Continuing Observation of Smoking Subjects; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; EBUS=endobronchial ultrasound; I-ELCAP=International Early Lung Cancer Action Program; ITALUNG=Italian Lung Cancer Screening Trial; LUSI=German Lung Cancer Screening Intervention Trial; N=number of participants; NA=not applicable; NLST=National Lung Screening Trial; NR=not reported; U.K.=United Kingdom; UKLS=UK Lung cancer Screening; U.S.=United States; VATS=video-assisted thoracoscopic surgery; Y=year.

In the NLST, false-positive results led to invasive procedures (needle biopsy, thoracotomy, thoracoscopy, mediastinoscopy, and bronchoscopy) in 1.7 percent of those screened. Complications occurred in 0.1 percent of those screened, with major, intermediate, and minor complications occurring in 0.03 percent, 0.05 percent, and 0.01 percent, respectively, of those screened. Death in the 60 days following the most invasive procedure performed occurred in 0.007 percent of those screened.^32^

No studies directly compared the workup of nodules identified by I-ELCAP or Lung-RADS, but rates of biopsy for false positives ranged from 0.09 to 0.42 percent of all persons screened in I-ELCAP studies.^118,^ ^121^ The one study using Lung-RADS found a rate for surgical procedures (e.g., mediastinoscopy, video-assisted thoracoscopic [VATS], or thoracotomy) of 0.3 percent for false positives among all those screened.^133^ An evaluation using NLST data estimated that 117 invasive procedures for false positives (23.4% of all invasive procedures for false positives from the NLST) would be prevented by using Lung-RADS criteria (preventing an invasive procedure for a false positive screening result for 0.44% of all persons screened).^100^

For subgroups, a study using the NLST data evaluating age differences for invasive procedures after false positives reported a rate of 3.3 percent of all LDCT screens for those 65 years or older and 2.7 percent of all LDCT screens in those younger than 65 (p=0.039).^64^

#### Overdiagnosis

Five studies specifically examined overdiagnosis,^135,^ ^141–144^ and we examined seven trials for differences in cancer incidence between LDCT and comparison groups.^32,^ ^62,^ ^70,^ ^72,^ ^76,^ ^80,^ ^145^ Overdiagnosis is the detection of a cancer in a patient that would not have become clinically apparent in the patient’s lifetime. In addition to the psychological consequences of being diagnosed with cancer, the major harm of this detection is unnecessary treatment (e.g., chemotherapy, radiation, and/or surgical resection) of something that would never have caused a problem. The presence of overdiagnosis is supported by multiple trials demonstrating an excess of early-stage cancers in the screening group without eventual catch-up of cancer cases in the comparison group in the followup period.^32,^ ^70,^ ^72,^ ^80,^ ^145^ In the initial publication of NLST results, there were an excess of 119 lung cancers after three screening rounds and 6.5 years of followup (total cancers: 1,060 from the LDCT group and 941 from the CXR group).^32^ The post-trial followup of NLST reported that there was no significant overall increase in lung cancer incidence at a median of 11.3 years of followup (1,701 vs. 1,681, respectively, RR, 1.01 [95% CI, 0.95 to 1.09]).^74^ However, the extended post-trial followup of NLST had some important methodologic limitations for ascertaining lung cancer incidence and overdiagnosis. These included using different methods during trial years (with a verification committee) than for post-trial years (relying on registries and without a verification committee); lack of information on any post-trial screening with LDCT that may have taken place in either the LDCT or the CXR group; missing data for lung cancer incidence for 11 out of 33 centers (representing 12.4% of trial participants) that did not have a home state cancer registry available for linkages; and risk of biasing overdiagnosis estimates toward the null because the comparison group received CXR (rather than no screening test). In the NELSON trial, there were an excess of 40 lung cancers after 10 years of followup since randomization, the a priori planned followup duration (total cancers 648: 344 from LDCT group and 304 from the control group; after 11 years of followup there was an excess of 14 cancers).^76^ The ITALUNG trial reported a catch-up of lung cancers in the 5 years following the end of five rounds of annual screening.^62^ However, inadequate duration of followup and heterogeneity of followup duration across trials limit the evaluation of overdiagnosis.

Determining the rate of overdiagnosis in screening is challenging because calculations of excess cancers are influenced by followup periods. One modeling study using the NLST data, limited by 6.5 years of followup, reported a probability of 18.5 percent (95% CI, 5.4% to 30.6%) that any detected lung cancer by screening is overdiagnosis (for NSCLC specifically, probability 22.5% [95% CI, 9.7% to 34.3%]).^142^ The study reported 1.38 cases of overdiagnosis in every 320 patients needed to screen to prevent one death from lung cancer. This study additionally modeled risk of overdiagnosis with lifetime followup after five annual screens, finding an overdiagnosis rate of 12 percent (95% CI, 7% to 15%) for all NSCLC after five annual LDCT scans with lifetime followup compared with no screening. A study using data from DLCST revealed an excess of 43 cancers (96 cancers overall and 64 screen-detected in the LDCT group vs. 53 in control group) after five annual LDCT scans and 5 years of followup, placing the estimate of overdiagnosis at 67.2 percent (95% CI, 37.1% to 95.4%) (absolute difference of cancers divided by screen-detected cancers).^141^

One study sought to determine characteristics of potential overdiagnosis cases by evaluating volume doubling time (VDT),^135^ finding about 25% of cancers are slow growing or indolent. The authors acknowledge, however, that it has also been reported that previously stable nodules can increase their rate of growth rapidly.^146^ A review of the Pittsburgh Lung Screening Study (PLuSS) trial cancer cases found 17/93 (18.5%) of prevalent cancers were indolent using a cut-off VDT of >400 days and a standardized uptake value of ≤1 on the PET scan.^143^ Sixteen out of the 17 (94.1%) were histologically adenocarcinomas, representing potential histologic shift.

To better determine populations at greater risk of overdiagnosis, one study evaluated overdiagnosis by COPD status in a subgroup of the NLST and found an excess of 26 adenocarcinoma-associated cancers in the COPD absent group. The authors argue that an excess of this histologic group, which is predominantly early stage, may represent a histologic shift to more indolent cancers identified by screening and not a clinically significant stage shift.^144^

#### Smoking Behavior

One RCT (DLCST, 4,075 participants) reported in two publications, three publications reporting on studies of participants from RCTs (NELSON, NLST, LSS, 19,426 total participants), and three cohort studies (ELCAP, Mayo Lung Project, and PLuSS, 5,537 total participants) included an evaluation of the impact of LDCT screening or screening results on smoking cessation and relapse. Evidence comparing LDCT vs. controls (no screening or CXR, depending on study) for smoking cessation or abstinence outcomes does not indicate that screening leads to false reassurance. Abnormal or indeterminate screening test results may increase cessation and continued abstinence, but normal screening test results had no influence. Regarding smoking intensity, evidence was minimal, and no study showed any influence of screening or test result on smoking intensity. Regarding smoking cessation and continued abstinence, studies showed that study participation, which could be a proxy for participation in a lung screening program, may have influenced smoking cessation. Below, we describe evidence showing the (1) impact of LDCT vs. CXR or no screening on smoking cessation and intensity (using data from RCTs); (2) impact of abnormal (true positive and false positive) or indeterminate screening results vs. normal results on smoking cessation, abstinence, and relapse (using data from RCTs and uncontrolled studies); and (3) potential impact of study participation (regardless of arm assignment or treatment) on cessation, abstinence, and relapse.

One RCT (DLCST; described in two publications) and one report of participants from an RCT (NELSON) showed mixed results regarding smoking cessation when comparing participants who were screened with those who were not screened.^145,^ ^147,^ ^148^ In a report of the 4,075 participants from the DLCST, the quit rate at year 1 among baseline current smokers was almost identical for the LDCT and no screening groups (11.9% vs. 11.8%, p=0.95).^145^ The annual proportion of nonsmokers increased in each of the five study years but was not different across study arms (LDCT vs. no screening: baseline: 25% vs. 23%, p=0.213; year 2: 31% vs. 30%, p=0.537; year 3: 36% vs. 37%, p=0.599; year 4: 40% vs. 40%, p=0.827; year 5: 43% vs. 43%, p=0.909).^147^ Conversely, in a paper reporting on 1,284 participants from the NELSON trial, both study arms showed relatively high abstinence rates (compared with general adult population rates of 3% to 7%), but the control arm was somewhat higher (LDCT vs. no screening on smoking abstinence at 2 years–no smoking in past 7 days: 15.1% vs. 19.8%, p=0.04; fewer than five cigarettes within 2 weeks of quit date: 14.5% vs. 19.1%, p=0.04; fewer than five cigarettes since quit date: 13.9% vs. 18.7%, p=0.03).^148^ This same analysis of NELSON trial participants showed no influence of LDCT screening on smoking intensity compared with no screening (reduced intensity: 53.1% vs. 53.8%, p=0.23; increased intensity: 17.7% vs. 13.8%, p=NR; remained stable: 29.2% vs. 32.4%, p=NR).^148^

One RCT (DLCST, N=3,745) and one paper reporting on screening arm participants from the NLST showed some evidence that screening results (positive or indeterminate vs. normal) may increase smoking cessation and decrease relapse.^145,^ ^149^ From the analysis of the 16,964 screening arm participants from the NLST, any false-positive result was associated with a greater point abstinence (first report of no longer smoking: HR, 1.23 [95% CI, 1.13 to 1.35]) and sustained abstinence (for at least 6 months: HR, 1.28 [95% CI, 1.15 to 1.43]) among smokers. In addition, recent quitters with at least one false-positive result were less likely to relapse than those with negative results (HR, 0.72 [95% CI, 0.54 to 0.96]).^149^ Among the 3,745 DLCST participants with complete data on smoking habits, baseline smokers with positive results were more likely to quit than those with negative results (17.7% vs. 11.4%, p=0.04) and baseline ex-smokers were with positive results were less likely to relapse than those with negative results (4.7% vs. 10.6%, p<0.01).^145^

In four uncontrolled studies that compared positive or indeterminate vs. normal screening results, outcomes for smoking cessation and relapse were mixed.^150–153^ A study of 2,078 ELCAP participants reported that those with negative results had higher cumulative point abstinence than those with any positive result (HR, 1.39 [95% CI, 1.01 to 1.90]; p<0.05) but did not have higher prolonged abstinence (HR, 1.34 [95% CI, 0.90 to 1.99]).^150^ From the NELSON trial, a random sample of 990 male smokers with indeterminate results made more quit attempts than those with negative test results (1.9 +/− 2.7 attempts vs. 1.5 +/− 2.0 attempts, p=0.016), but there was no difference in point (12.2% vs. 10.4%, p=0.39) or prolonged (11.5% vs. 8.9%, p=0.19) abstinence.^153^ Among 1,365 participants from the Mayo Lung Study, an abnormal result among baseline smokers was predictive of smoking abstinence (OR, 1.37 [95% CI, 1.12 to 1.67]; p=0.002) but not among baseline ex-smokers.^152^ Among a cohort of 2,094 baseline active smokers from the PLuSS study, those who received a referral to further evaluation (e.g., additional scans) as a result of any non-normal initial LDCT result, compared with those with no referral, reported more smoking cessation. The most pronounced difference compared those with referral for results with moderate to high suspicion for cancer (delta, reported quit attempts 18.8% [95% CI, 11.1% to 26.5%]; reported quit more than 30 days, 17.7% [95% CI, 9.4% to 26.0%]; reported quit more than 30 days without relapse at 1 year 12.2% [95% CI, 4.9% to 19.5%]).^151^

Two uncontrolled studies^154,^ ^155^ reported the impact of screening (or study) participation on cessation, relapse, or motivation to quit. Among 1,473 baseline current smokers in the Mayo Lung Study, 14.9% reported abstinence at 1 year of followup, compared with 5 to 7 percent in the general population.^154^ Finally, a description of reasons for study participation among 144 LSS participants and 169 NLST participants suggests that those willing to participate in a screening program might be more open to receiving cessation counseling.^155^ Both studies concluded that LDCT screening may be a “teachable moment” with regard to smoking cessation. One RCT (DLCST, N=4,075)^147^ and one sample of RCT participants (NELSON, N=1,284)^148^ also suggested that study participation, which could represent participation in a screening program, may, in and of itself, increase smoking cessation rates.

We did not find eligible studies reporting whether smoking behavior after LDCT differs for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors.

#### Psychosocial Harms

Four RCTs (DLCST, NELSON, NLST, and UK Lung Cancer Screening [UKLS] trial, 12,096 total participants), reported in six publications,^117,^ ^156–160^ one uncontrolled cohort study (PLuSS, 400 participants),^161^ and two studies of participants from the screening arm of an RCT (NELSON, 630 participants;^162^ UKLS, 1,589 participants^163^) included an evaluation of potential psychosocial consequences of undergoing LDCT screening for lung cancer. These studies evaluated general health-related quality of life (HRQoL; 3 studies),^156,^ ^159,^ ^162^ anxiety (8 studies),^117,^ ^156–162^ depression (2 studies),^117,^ ^157^ distress (3 studies),^117,^ ^159,^ ^162^ and other psychosocial consequences of LDCT screening (5 studies).^117,^ ^158,^ ^160,^ ^161,^ ^163^ Taken together, there is moderate evidence to suggest that, compared with no screening, individuals who receive LDCT screening do not have worse general HRQoL, anxiety, or distress over two years of followup. Some evidence suggests differential consequences by screening result such that general HRQoL and anxiety were worse, at least in the short term, for individuals who received true-positive results compared with other screening results; distress was worse for participants who received an indeterminate screening result compared with other results. The strength of evidence is low for other psychosocial consequences, largely because of unknown consistency, imprecision, and only one or two studies assessed outcomes. The following paragraphs describe evidence for LDCT vs. no screening or CXR and for comparisons of people with different LDCT screening results (e.g., comparing those with false-positive results vs. negative results), on general HRQoL, anxiety and depression, distress, and other psychosocial consequences.

##### General Quality of Life

To measure general HRQoL, the NELSON trial used the SF-12 and EuroQol visual analog scale [EQ-5D VAS] questionnaires.^159^ The SF-12 consists of a Physical Component Score [PCS] and a Mental Component Score [MCS]; scores range from 0 (lower level of health) to 100 (higher level of health). The EQ-5D VAS asks participants to rate their health on a scale of 0 (worst imaginable status) to 100 (best imaginable status). Regarding general HRQoL, the NELSON trial reported no statistically significant differences over 2 years of followup between individuals who had LDCT screening for lung cancer and those who were assigned to a no-screening control arm (mean PCS from the SF-12: 49.95 screening arm vs. 49.07 control arm; mean MCS from the SF-12: 52.50 screening arm vs. 51.69 control arm; mean EQ-5D VAS: 79.53 screening arm vs. 77.45 control arm; 931 participants).^159^ The authors used a minimal important difference (MID) threshold of at least half of a standard deviation of the mean to determine whether the differences between assessment points were clinically relevant. Moreover, no differences in HRQoL were observed for individuals with a negative or indeterminate result from baseline to 6 months after the second-round screening (mean PCS: 50.20 negative result vs. 49.24 indeterminate result; mean MCS: 52.70 negative result vs. 51.82 indeterminate result; mean EQ-5D VAS: 80.12 negative result vs. 78.22 indeterminate result). Similarly, findings from the NLST suggest no statistically significant differences in general HRQoL (measured using a PCS and MCS derived from the SF-36) from baseline to 6 months followup between individuals with false-positive, positive for significant incidental findings, or negative screen results.^156^ Compared with those receiving negative results and after adjusting for potential confounders (e.g., baseline age, sex, race/ethnicity), regression estimates were not statistically significantly different for PCS or MCS from baseline to short-term (1 month) and long-term (6 months) followup for those receiving false-positive results (PCS baseline to 1 month: 0.46, 95% confidence limit [CL], −0.04 to 0.97; PCS baseline to 6 months: 0.30, 95% CL, −0.27 to 0.87; MCS baseline to 1 month: −0.22, 95% CL, −0.82 to 0.37; MCS baseline to 6 months: 0.03, 95% CL, −0.65 to 0.70) or significant incidental findings results (PCS baseline to 1 month: 0.13, 95% CL, −0.62 to 0.88; PCS baseline to 6 months: −0.16, 95% CL, −1.01 to 0.69; MCS baseline to 1 month: −0.04, 95% CL, −0.93 to 0.84; MCS baseline to 6 months: 0.29, 95% CL, −0.72 to 1.31). However, short-term and long-term HRQoL were worse for individuals receiving true-positive results compared with those receiving other screening results. Regression analyses revealed statistically significant changes for those receiving true-positive results compared with those receiving negative results from baseline to 1 month for MCS (−3.95, 95% CL, −5.87 to −2.04) and baseline to 6 months for PCS (−7.02, 95% CL, −8.80 to −5.24) and MCS (−4.15, 95% CL, −6.27 to −2.03) but not for baseline to 1 month for PCS (−1.18, 95% CL, −2.81 to 0.45). These findings should be interpreted with the awareness that participants in this trial received extensive counseling as part of the consent process, including information about the high risk of a false-positive screen and related followup. General HRQoL did not differ between those receiving LDCT screening and those receiving a CXR. Compared with participants randomized to receive a CXR, those who were randomized to LDCT screening did not exhibit better or worse general HRQoL (PCS baseline to 1 month: 0.07, 95% CL, −0.44 to 0.59; PCS baseline to 6 months: 0.50, 95% CL, −0.06 to 1.07; MCS baseline to 1 month: 0.23, 95% CL, −0.37 to 0.83; MCS baseline to 6 months: 0.07, 95% CL, −0.61 to 0.74).^156^

##### Anxiety and Depression

Some evidence suggests individuals experience short-term increases in anxiety after undergoing LDCT screening for lung cancer, but these increases tend to diminish over time. In an uncontrolled cohort study, the PLuSS,^161^ participants who had an indeterminate screening result had increased state anxiety (i.e., anxiety about an event, measured using the State-Trait Anxiety Inventory [STAI]) at 1 to 2 weeks postscreen (mean [M]=37.7, standard deviation [SD]=13.8) and 6 months (M=37.3, SD=12.6) compared with baseline (M=34.4, SD=12.3), but state anxiety returned to baseline levels 12 months after screening (M=35.3, SD=13.5). For reference, a score of 39 to 40 or 54 to 55 for older adults, has been suggested for detecting clinically meaningful symptoms of state anxiety.^164^ In multivariable analysis, the regression coefficient for the interaction between an indeterminate screening result and survey time (7.50; standard error [SE], 2.00) and the interaction between an indeterminate screening result and survey time squared (−1.41; SE, 0.39) were both statistically significant at p < .001. Analyses for trait anxiety (i.e., anxiety as a personal characteristic) did not yield any statistically significant associations for the survey time or screening result (negative, indeterminate, or suspicious result) variables. Findings from the NLST suggest differential anxiety levels (measured using STAI Form Y-1) by screening result such that anxiety was substantially higher (worse) among individuals who received a true-positive result (1-month score: M=41.06, SD=15.10; 6-month score: M=37.69, SD=12.04) compared with those who received false-positive (1-month score: M=34.34, SD=12.58; 6-month score: M=33.92, SD=12.77), significant incidental findings (1-month score: M=33.83, SD=12.68; 6-month score: M=33.19, SD=12.41), or negative screen results (1-month score: M=32.67, SD=11.97; 6-month score: M=32.76, SD=12.36).^156^ Anxiety did not differ by screening arm; compared with participants randomized to receive a CXR, those who were randomized to LDCT screening did not exhibit better or worse anxiety (STAI ratio at 1 month: 1.01, 95% CL, 0.93 to 1.10; STAI ratio at 6 months: 1.02, 95% CL, 0.93 to 1.12). Conversely, data from the DLCST did not indicate that undergoing LDCT screening for lung cancer increases the risk of receiving prescription medications for anxiety or depression during the period from baseline to 3 years followup compared with the control arm (adjusted HR: 1.00 [95% CI, 0.90 to 1.12]).^157^ As the authors note, the use of prescriptions would likely identify only more severe anxiety and depression.

##### Distress

Research also suggests short-term increased distress levels following LDCT screening for lung cancer for individuals receiving an indeterminate result.^162^ In the NELSON trial, the 15-item Impact of Events Scale (IES) was tailored to measure lung cancer–specific distress. In addition to producing a total summary score (range: 0–75), the IES yields scores for the intrusive subscale (e.g., having trouble staying asleep because pictures or thoughts about the event came to mind; range: 0–35) and avoidance subscale (e.g., trying to remove the event from memory; range: 0–40). In the short term (2 months after a baseline scan), the NELSON trial data revealed that distress levels were higher (worse) among individuals who received an indeterminate result (IES total score: M=8.3, SD=11.3) compared with those who received a negative result (IES total score: M=2.4, SD=5.5). These differences were both statistically significant (p<.01) and considered clinically relevant by the authors (using a MID threshold of at least half of a standard deviation of the mean),^162^ although the effect was small because the average IES total score for those with indeterminate results was just 8.3 on a scale that ranges from 0 to 75. For those who received an indeterminate result, distress levels returned to near-baseline levels 2 years after baseline screening.^159^ Similarly, findings from the UKLS Trial suggest higher levels of distress among individuals who undergo LDCT screening for lung cancer compared with no screening, but these effects were short term and were only among individuals with low scores at baseline (intervention arm: M=8.54 [95% CI, 8.44 to 8.64]; control arm: M=8.26 [95% CI, 8.16 to 8.36]).^117^ Data from this trial also suggest differential distress levels by screening result; individuals who received a multidisciplinary team referral (indicating a major lung abnormality) reported the highest distress.

##### Other Psychosocial Consequences

Participants in the DLCST were assessed for other potential psychosocial consequences of LDCT screening, measured using the Consequences of Screening (COS) and Consequences of Screening in Lung Cancer (COS-LC).^158,^ ^160^ COS scales included anxiety (range of values: 0–18), behavior (range: 0–21), dejection (range: 0–18), and sleep (range: 0–12); single items included busy to take mind off things (range: 0–3), less interest in sex (range: 0–3), and self-rated health (range: 0–4). COS-LC scales included self-blame (range: 0–15), focus on (airway) symptoms (range: 0–24), stigmatization (range: 0–12), introvert (range: 0–18), harm of smoking (range: 0–6), and anxiety (anxiety for COS-LC was the same scale used in COS plus an extra item: shocked; range: 0–21); single items included busy to take mind off things (range: 0–3), less interest in sex (range: 0–3), and self-rated health (range: 0–4). For reference, higher scores indicate more negative psychosocial consequences. Among participants with negative screening results in the LDCT screening arm and those in the control arm, mean scores significantly worsened from the prevalence round (prerandomization to study arm) to the incidence round (postrandomization) on the behavior scale (mean increase: 1.0535 screen arm, 1.1962 control arm), dejection scale (mean increase: 0.4076 screen arm, 0.5371 control arm), and sleep scale (mean increase: 1.0271 screen arm, 1.1025 control arm) and on two single items: busy to take mind off things (mean increase: 0.0539 screen arm, 0.0760 control arm) and less interest in sex (mean increase: 0.2253 screen arm, 0.1811 control arm; all p < .01).^160^ The significantly worse scores for the three scales persisted for another three rounds of screening. At the incidence round, scores were worse for the control arm than for the LDCT screening arm for three COS scales: anxiety (M=1.50, SD=2.52 screen arm vs. M=1.71, SD=2.79 control arm), behavior (M=1.76, SD=2.85 screen arm vs. M=2.02, SD=3.04 control arm), and dejection (M=1.61, SD=2.71 screen arm vs. M=1.88, SD=2.98 control arm). Scores were also worse for the control arm for four COS-LC scales: self-blame (M=2.32, SD=3.53 screen arm vs. M=2.62, SD=3.75 control arm), focus on (airway) symptoms (M=3.30, SD=3.58 screen arm vs. M=3.80, SD=3.93 control arm), introvert (M=1.89, SD=1.76 screen arm vs. M=2.22, SD=2.96 control arm), and anxiety (M=1.55, SD=2.67 screen arm vs. M=1.77, SD=2.93 control arm). The authors note that one possible explanation for the worse psychosocial consequences in the control arm is that compared with participants in the LDCT screening arm control arm participants did not benefit from the reassurance that a normal screening result may offer. Although these differences meet the threshold for statistical significance, it is unclear whether they are clinically meaningful. Using at least a half of a standard deviation of the mean as a threshold for determining the MID,^165^ we found that none of the statistically significant differences would be considered clinically meaningful.

The UKLS Trial assessed participants’ satisfaction with their decision to participate in an LDCT trial using the Satisfaction with Decision Scale.^117^ This six-item scale has five response categories that span from strongly disagree to strongly agree; items are summed and averaged for a total possible score ranging from 1 to 5. The authors dichotomized this score such that a score less than 5 is considered “not very satisfied” and a score of 5 is considered “very satisfied.” Findings suggest decision satisfaction varied by LDCT screening result. In the short term (2 weeks after receiving scan results), 57 percent of participants who were positive for multidisciplinary team referral were very satisfied with their decision to participate in the trial, whereas 46 percent with a negative result, 44 percent with a negative result who also had an incidental finding, and 36 percent with a positive for repeat scan result were very satisfied with their decision. In the long term (10 to 27 months after recruitment), 71 percent of participants with a true-positive result were very satisfied with their decision to participate in the trial compared with 39 percent with a true-negative result, 45 percent with an incidental finding, and 41 percent with a false-positive result.

The UKLS Trial also assessed perceived concern about the LDCT scan result, which was used to represent perceived threat.^163^ The authors examined whether there was an association between perceived concern and expectation-result congruence. Two weeks after they received their LDCT scan result, participants completed a questionnaire that included a single-item measure of perceived concern: “How concerned were you by your CT scan result?” Participants responded by selecting “not at all concerned,” “not very concerned,” “fairly concerned,” or “very concerned.” At baseline, participants were asked to report their expected scan result: “normal/clear scan result” (renamed “negative”) or “unclear or abnormal scan result.” Actual scan results were categorized as negative or positive for a repeat scan or MDT referral. Four expectation-result congruence groups were formed: (1) expected negative, (2) unexpected followup, (3) unexpected negative, and (4) expected followup. Findings indicate that although most (82%) of the 1,589 participants expected a negative result, 48 percent actually had a negative result. There was a statistically significant association between perceived concern about the LDCT scan result and expectation-result congruence (p<.001). Participants who received an expected negative result were statistically significantly less concerned (57% not at all concerned) about their scan result compared with those who did not have an expected negative result (p<.001). Participants who received an unexpected followup result reported more concern (54% fairly or very concerned) compared with those with an expected negative result (22% fairly or very concerned) and those with an unexpected negative result (36% fairly or very concerned)(p<.001). Among those who expected a followup result, 65 percent reported they were fairly or very concerned. Younger age, those in the most deprived group (vs. the most affluent, measured using the Index of Multiple Deprivation), and those with an experience of lung cancer were more concerned about the result (all p=.01).

The PLuSS assessed fear of lung cancer and perceived risk of lung cancer among participants who had LDCT screening.^161^ Three questions, adapted from the Psychological Consequences Questionnaire, were used to assess the effects of screening on fear. The five-point response scale ranged from “never” to “most of the time.” Scores were summed to obtain a total score; higher scores suggested greater fear of cancer. Average fear of lung cancer scores varied by LDCT screening result. Fear of lung cancer scores remained fairly level over time for participants with negative screen results (M=7.0, SD=2.5 initial; M=7.0, SD=2.4 at postscreen; M=6.5, SD=2.4 at 6-month followup; M=6.7, SD=2.3 at 12-month followup) or indeterminate screen results (M=7.2, SD=2.8 initial; M=7.5, SD=2.7 at postscreen; M=7.1, SD=2.6 at 6-month followup; M=7.1, SD=2.7 at 12-month followup). Among participants with a suspicious screen result, fear of cancer increased after screening. This increase diminished over time but did not return to baseline levels by the 12-month followup survey (M=6.4, SD=2.3 initial; M=8.5, SD=2.6 at postscreen; M=7.4, SD=3.0 at 6-month followup; M=7.1, SD=2.5 at 12-month followup). The authors also highlighted that fear of lung cancer did not diminish over time for participants with a negative screen result, as might be expected, and that perhaps a negative result does not bring peace of mind. Perceived risk of lung cancer was measured by asking participants how likely they believed it was that they had or will get lung cancer. Participants indicated their risk on a scale from no chance (0%) to certain (100%). As for perceived risk of lung cancer, average scores also varied by LDCT screening result. Perceived risk of lung cancer decreased after screening for those with a negative screen result (M=17.1, SD=20.4 initial; M=11.2, SD=20.2 at postscreen; M=13.1, SD=20.8 at 6-month followup; M=13.1, SD=19.9 at 12-month followup). For those with an indeterminate result, perceived risk increased at postscreen (M=20.1, SD=25.0 compared with M=18.9, SD=22.9 initial), decreased at 6 months (M=14.8, SD=19.7), and increased to baseline levels at 12-month followup (M=18.9, SD=25.2). For those with a suspicious screening result, perceived risk nearly doubled at postscreen (M=34.5, SD=28.0 compared with M=18.6, SD=15.7 initial), then decreased at 6 months (M=30.3, SD=28.0), and increased at 12-month followup (M=31.2, SD=28.9).

##### Subgroups

We did not identify studies reporting whether psychosocial consequences of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors.

### Incidental Findings Leading to Additional Tests and Subsequent Harms

#### Summary

Studies reported a wide range of screening-related incidental findings (4.4% to 40.7%) that were deemed significant and/or requiring further evaluation (Appendix E Table 3). Rates varied considerably in part because there was no consistent definition of what constitutes an incidental finding nor which findings were “actionable” or “clinically significant.” Older age was associated with a greater likelihood of incidental findings. Common incidental findings included coronary artery calcification, aortic aneurysms, emphysema, and infectious and inflammatory processes. Other common findings were masses, nodules, or cysts of the kidney, breast, adrenal, liver, thyroid, pancreas, spine, and lymph nodes. Cancers involving the kidney, thyroid, or liver were ultimately diagnosed in 0.39 percent of NLST participants in the LDCT arm during the screening period. Incidental findings led to downstream evaluation including consultations, additional imaging, and invasive procedures with associated costs and burdens. The benefits of incidental detection of nonlung cancer conditions are uncertain.

#### Detailed Results

##### Evidence From Uncontrolled Studies

Most of the current evidence regarding incidental findings comes from uncontrolled studies because incidental findings are not easily defined for an unscreened (control) population. We found six fair-quality uncontrolled studies (n=27,237 total participants) that described rates of “significant” incidental findings in LDCT-screened populations.^38,^ ^117,^ ^137,^ ^166–168^ Two of these used data from trials (NLST and UKLS).^117,^ ^166^ The other four were U.S.-based cohort studies. Some of these studies reported additional data regarding followup evaluations and findings.

A study of NLST participants assigned to the LDCT screening arm (three rounds) who were enrolled at American College of Radiology Imaging Network centers (n=17,309) found that 58.7 percent of participants had one or more extrapulmonary findings, including 19.6 percent with findings categorized by radiologists as “potentially significant.”^166^ The frequency of these “potentially significant” abnormalities was highest for cardiovascular findings (e.g., atherosclerotic calcifications and aortic aneurysms) (8.5%), followed by renal (2.4%), hepatobiliary (2.1%), adrenal (1.2%), and thyroid (0.6%). These findings led to additional specialty consultations, imaging, invasive testing, and surgery. Extra-thoracic cancers, including kidney, thyroid, and liver cancers, were diagnosed in 67 (0.39%) participants during the screening period. By organ type, the ratio of malignancy to incidental LDCT lesion was highest for the thyroid (1 cancer per 14 findings) followed by kidneys (1 cancer per 37 findings).

In the United Kingdom Lung Cancer Screening Trial, among 1,994 participants screened with a single round of LDCT, the rate of significant incidental findings not related to thoracic malignancy that were referred back to the participant’s general practitioner was 6.4 percent.^117^

The Veterans Health Administration Lung Cancer Screening Demonstration Project reported incidental findings at eight demonstration sites after a single round of screening. They found that 40.7 percent of participants (n=2,452) had one or more incidental findings deemed likely to require followup or further evaluation.^38^ The most common findings included coronary artery calcification, emphysema, abdominal abnormalities and masses (14%), aortic dilation (8.3%), inflammatory or interstitial processes (25.4%), and thyroid nodules (2.4%). The rate of incidental findings deemed likely to need followup varied widely across the eight demonstration sites from 20.0 to 63.4 percent.

A study of 320 patients undergoing one round of LDCT screening at a tertiary U.S. lung cancer screening program reported the frequency and types of incidental findings along with additional data on subsequent evaluation that was driven by prespecified care paths.^167^ If using a broad definition of incidental findings, the vast majority (94%) of the 320 patients had some type of incidental abnormality noted by radiologists in the LDCT report. These types of incidental abnormalities included calcification of coronary arteries (56%) or the aorta (21%), emphysema (50.6%), aortic dilation (8.1%), adrenal nodules (3.8%), renal cysts (2.5%), and thyroid nodules (4.7%). Using a narrower definition, we see that 15 percent of participants had incidental findings categorized as “concerning” and underwent further evaluation that included a variety of nonpulmonary subspecialty consultations, lab tests, imaging studies, and invasive procedures. Five fine-needle aspirations of thyroid nodules were performed. One patient had a total thyroidectomy that revealed a (benign) hyperplastic nodule and multinodular goiter. Evaluation of two suspicious renal masses led to diagnosis of two renal cell carcinomas (grade 3).

Another U.S. cohort study found that 14 percent of 1,520 patients assigned to three rounds of annual screening had incidental nonpulmonary findings of significance that required further evaluation.^168^ The most common nonpulmonary findings (with frequency >1%) were abdominal aortic aneurysm (3.4%), adrenal masses (2.3%), indeterminate renal masses (2.2%), renal calculi (1.6%), and breast nodules (1.1%). Several nonlung cancers were eventually diagnosed including two carcinoid tumors, four renal cell cancers, three breast cancers, two lymphomas, two gastric tumors, and one pheochromocytoma.

PLuSS enrolled 3,642 participants assigned to two rounds of annual LDCT screening and followup. A total of 4.4 percent had “significant” incidental findings, which were not otherwise characterized.^137^

##### Evidence From RCTs

We identified one eligible controlled trial.^169^ Because of concerns that LDCT could lead to overdiagnosis of thyroid cancer through increased incidental detection, the study used data from the NLST (n=53,248) to examine the association of LDCT screening and thyroid cancer risk.^169^ It reported a total of 60 thyroid cancers (37 in the LDCT group vs. 23 in the CXR group), finding a significant increase in thyroid cancer incidence in the LDCT arm compared with the CXR arm during the 3 years of active screening (HR, 2.19 [95% CI, 1.07 to 4.47]) but not during subsequent years of nonimaging observation (HR, 1.08 [95% CI, 0.49 to 2.37]).

Subgroup differences. We identified one study that examined age differences in incidental findings. In this study of 26,722 participants in the LDCT screening arm of the NLST, negative screening results with “clinically significant abnormalities” were more common in the screened cohort over age 65 years compared with those under age 65 (9.2% vs. 6.9%, p< 0.0001).^64^

### Key Question 6a How Effective is Surgical Resection or SBRT for the Treatment of Early (Stage I) NSCLC?

### Key Question 6b Does Effectiveness Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, or Presence of Comorbid Conditions?

#### Summary

No RCTs comparing surgical resection or SBRT with no treatment for stage I NSCLC were identified. Twenty-seven uncontrolled studies evaluating surgical resection (n=147,837 patients with stage I NSCLC),^170–196^ including 6 from the prior review,^190–195^ (Appendix E Tables 4 and 5) and 13 uncontrolled studies evaluating SBRT (n=8,697 patients with stage I NSCLC)^185,^ ^196–207^ (Appendix E Tables 4 and 6) for the treatment of stage I NSCLC were included for KQ 6 for presentation to the USPSTF; additional studies were subsequently identified in update searches and literature surveillance and are described below in the Update Search Summary sections. Results of those studies were similar to what was identified by the original search yield. The studies from the original search yield were uncontrolled analyses of prospectively collected data from registries or databases (e.g., National Cancer Database) or primary studies conducted at one or more institutions. Five surgical resection studies^177,^ ^179,^ ^181,^ ^185,^ ^194^ and one SBRT study^185^ were rated as good quality; the remaining studies were rated fair quality (Appendix D Table 1). Seven surgery studies^172,^ ^181,^ ^184,^ ^186,^ ^187,^ ^191,^ ^192^ and 1 SBRT^204^ study reported survival outcomes among subgroups.

The strength of evidence for the effectiveness of surgical resection and SBRT for the treatment of stage I NSCLC is moderate and low for benefit, respectively, downgrading primarily because the evidence came from uncontrolled cohort studies and for imprecision. Clinical characteristics of the NSCLC diagnoses and operability of tumors, surgical approaches, and SBRT treatment characteristics among studies and over time resulted in imprecise results, despite an overall substantial sample size for the question related to surgical resection.

#### Surgical Resection

##### Description of Included Studies

Twenty-seven studies evaluated the effectiveness of surgical resection for the treatment of stage I NSCLC. Sample sizes ranged from 540^177^ to 54,350.^178^ Of the 27 studies, 14 were primary studies conducted between 1983 and 2012 in the United States,^170,^ ^172,^ ^174,^ ^176,^ ^181,^ ^182^ Japan,^173,^ ^179,^ ^184,^ ^191,^ ^193,^ ^195^ the United Kingdom,^177,^ ^181^ and Italy^171^ (n=16,671 stage I NSCLC patients). The remaining 13 studies were analyses of 131,166 stage I NSCLC patients in the Surveillance, Epidemiology, and End Results (SEER) database between 1988 and 2012 (k=5 studies);^175,^ ^180,^ ^183,^ ^188,^ ^192^ the National Cancer Database (NCDB) between 2003 and 2012 (k=5 studies);^178,^ ^185–187,^ ^189^ the Veteran’s Affairs Informatic and Computing Infrastructure (VINCI) database between 2006 and 2015; and cancer registries in Norway (1993 to 2002),^194^ and Japan (2004).^190^ The SEER program and database, initiated in 1973 by the National Cancer Institute, includes data from a network of cancer registries that represent approximately one-third of the U.S. population,^208^ and the NCDB is a nationwide oncology outcomes database for more than 1,500 Commission on Cancer–accredited cancer programs in the United States and Puerto Rico. The NCDB is a joint effort by the American College of Surgeons and the American Cancer Society, captures approximately 70 percent of all newly diagnosed cases of cancer in the United States, and includes over 34 million records.^209^ Six of the studies^190–195^ were included in the prior review.^47^

Most studies included patients with mean or median ages between 63 and 69. Exceptions included two studies of SEER data focused on patients with stage IA NSCLC who were 75 years or older^180^ or who received sublobar resection (SLR),^188^ and a study of patients from the United Kingdom who received wedge resection;^177^ limited resections, rather than lobectomy, are often indicated for elderly patients with comorbidities or poor pulmonary reserve. The percentage of male patients in most studies ranged from 36 percent^186^ to 72 percent.^171^ Ninety-six percent of the patients in the analysis of VINCI data (i.e., veterans) were male.^196^ Four studies had mean or median followup times of less than 3 years,^177,^ ^185,^ ^188,^ ^210^ five had more than 5 years of followup on average,^174,^ ^176,^ ^181,^ ^187,^ ^193^ and 11 did not report mean or median length of followup.^170,^ ^175,^ ^178,^ ^180,^ ^182,^ ^186,^ ^189,^ ^191,^ ^192,^ ^194,^ ^195^ The other 7 studies had median followup between three and five years.

Patients were enrolled based on both clinical (k=12 studies) and pathologic (k=11 studies) stage. Study populations were restricted to patients with stage I NSCLC, or they presented results for subgroups of patients defined by stage. One study did not specify type of staging,^192^ two studies did not specify staging at enrollment but provided results for both clinical and pathologic staging,^190,^ ^195^ and one study categorized patients by pathologic stage when available (clinical stage, otherwise).^178^ Eight of the 27 studies included only patients with stage IA NSCLC.^179,^ ^180,^ ^183,^ ^184,^ ^187–189,^ ^192^ Most studies included multiple histologic subtypes of stage I NSCLC. Four studies included only patients with adenocarcinoma, the most common subtype; three of the four studies were further restricted to stage IA adenocarcinoma NSCLC,^179,^ ^183,^ ^184^ and the fourth was restricted to adenocarcinoma NSCLCs with lepidic features (i.e., well-differentiated, noninvasive tumor growth).^186^ Three studies included only patients who received a lobectomy,^173,^ ^175,^ ^185^ one included only patients who received SLR,^188^ and one included only patients who received wedge resection.^177^ All other studies included multiple surgical approaches. In one study, patients were categorized by whether they received video-assisted thoracoscopic (VATS) or open lobectomy.^182^

##### Detailed Results

Long-term survival rates varied across study populations, overall and among subgroups defined by various surgical approaches and tumor characteristics in 27 studies. One fair quality study was conducted among a highly selected population of patients 75 years of age or older with stage IA NSCLC^180^ and a good quality study only presented results for patients with pathologic stage I NSCLC by cardiac risk score category^181^; both are described in the subgroups section below. Of the remaining 25 studies, 14 report results for stage I NSCLC (n=139,562),^170–172,^ ^174–178,^ ^182,^ ^185,^ ^186,^ ^191,^ ^194,^ ^196^ 12 report results for stage IA NSCLC (n=49,741),^173,^ ^179,^ ^183,^ ^184,^ ^187–190,^ ^192–195^ and 4 report results for pathologic stage IB NSCLC (n=4,852).^173,^ ^190,^ ^194,^ ^195^

Across all surgical approaches in 14 studies of stage I NSCLC, the 5-year overall survival (OS) ranged from 51 percent in a good quality Norwegian database study of 1,375 patients from 1993 to 2002^194^ to 86 percent in a fair quality Japanese study of 713 patients from 1994 to 2003;^191^ both studies evaluated surgical resection as the intervention (rather than specific surgical approaches). Among 54,350 patients in the NCDB from 2003 to 2006, the 5-year OS for surgical resection was 61 percent for pathologic and 57 percent for clinical stage I NSCLC.^178^ In a fair quality analysis of SEER data from 2004 to 2010, the 5-year OS ranged from 53 percent to 75 percent among 16,315 stage I NSCLC patients who received lobectomy, depending on tumor size and visceral pleural invasion (VPI) status;^175^ three other studies reported 5-year OS for lobectomy of 59 percent in 1,781 healthy patients matched to healthy patients who received SBRT^185^ and 70 percent in both the NCDB (2003–2006; n=1,991)^186^ and VA (2006–2015; n=3,620)^196^ databases. Except for one analysis of SEER data from 1988 to 1997, where the 5-year OS was 58 percent among 10,761 patients, all other studies that evaluated surgical resection for stage IA NSCLC were conducted in Japan^179,^ ^184,^ ^190,^ ^195^ or Norway^194^ where the 5-year OS rates ranged from 65 percent^194^ to 86 percent.^190^ The 5-year OS rates for lobectomy among 11,990 patients in the NCDB (2003–2006) and 7,989 patients in SEER (2004–2012) with stage IA NSCLC were 66 percent^187^ and 71 percent,^183^ respectively. All of the studies that evaluated surgical resection for pathologic stage IB NSCLC were conducted in Japan^173,^ ^190,^ ^195^ and Norway;^194^ the 5-year OS rates ranged from 42 percent among 816 Norwegian patients (1993–2002)^194^ to 69 percent among 2,398 Japanese patients in 2004.^190^

Ten studies reported survival rates for different types of or approaches to surgical resection. In one US study of lobectomy for clinical stage I NSCLC (n=963) in 2002–2011, the 5-year OS rate was significantly higher among patients who received VATS (78%) than patients who received open lobectomy (68%), but the difference decreased in a propensity score–matched analysis of the data.^182^ In five studies, 5-year OS rates were statistically similar between surgical approaches, although rates were generally numerically higher for lobectomy compared with SLR approaches.^176,^ ^179,^ ^183,^ ^186,^ ^193^ In one of the studies (n=614), there was also no difference between lobectomy and segmentectomy with respect to 5-year recurrence-free survival rates (71% [95% CI, 64% to 78%] and 70% [95% CI, 63% to 78%], respectively).^176^ The 5-year lung cancer-specific survival (LCSS) was 84 and 81 percent for lobectomy and segmentectomy, respectively, in a SEER study of 7,989 pathologic stage IA patients in 2004–2012.^183^ Lobectomy outperformed SLR in two studies; the 5-year OS rates were 66 percent^187^ and 70^196^ percent for lobectomy and 51 percent^187^ and 56^196^ percent for SLR. In one of those studies (n=3,620 VA patients), the 5-year incidence of cancer death was 23 percent for patients who received lobectomy and 32 percent for patients who received SLR.^196^ Lobectomy resulted in significantly higher 5-year OS rates than specific types of SLR in two additional studies. In one study among patients 75 years and older, the 5-year OS was 50 percent for lobectomy compared with 44 percent and 39 percent for segmentectomy and wedge resection, respectively; the 5-year cancer-specific survival (CSS) was also different by surgical approach (65%, 59%, and 53%, respectively).^180^ In the other study of 7,034 patients in the NCDB (2003–2011), the 5-year OS rates were 70 percent, 60 percent, and 55 percent for lobectomy, segmentectomy, and wedge resection, respectively.^189^

The 5-year OS rates were higher among stage IA than stage IB NSCLC patients in four studies,^173,^ ^190,^ ^194,^ ^195^ regardless of whether the tumor staging was clinical or pathologic, and ranged from 64 percent^194^ to 86 percent^190^ for stage IA and 42 percent^194^ to 69 percent^190^ for stage IB. Three studies reported 5-year survival rates by tumor size, but each study used different categories (<2 vs. 2–3 vs. 3–5 cm;^175^ ≤1 vs. 1–2 cm;^189^ and ≤3 vs. 3–5 vs. >5 cm^194^), making it difficult to compare them directly. However, survival rates decreased as tumor size increased in all three studies. In one of the studies (which used SEER data from 16,315 patients from 2004 to 2010), investigators further stratified by VPI status.^175^ Both the 5-year OS and LCSS rates were higher among patients without VPI than patients with VPI. Among patients with tumors <2 cm, the 5-year OS and LCSS rates were 75 percent and 88 percent, respectively, for patients without VPI; the rates were lower (70 percent and 84 percent, respectively) for patients with VPI. Similarly, among patients with tumors 3–5 cm, the 5-year OS and LCSS rates were 60 percent and 72 percent, respectively, for patients without VPI; the rates were lower (53% and 66%, respectively) for patients with VPI.^175^ Finally, in a multisite study of 618 patients in Japan, 5-year OS was higher among patients who met node negative criteria post-surgery (96%) than patients who did not (83%), as was 5-year recurrence-free survival (97% and 76%, respectively).^179^

##### Subgroups

Seven studies evaluated the effectiveness of surgical resection among subgroups of patients with stage I NSCLC; one additional study included a highly selected population based on age 75 years or older.^180^ Overall survival was higher among females,^184,^ ^186,^ ^187,^ ^191,^ ^192^ younger patients,^184,^ ^186,^ ^187,^ ^191,^ ^192^ white patients,^186^ patients without comorbidities,^172,^ ^181,^ ^186,^ ^187^ and non- or light smokers^184,^ ^191^ than among males, older patients, black patients, patients with comorbidities, and smokers or heavy smokers, respectively.

Five-year OS rates were higher among females than males in three studies (91% vs. 83%,^191^ 85% vs.74%,^184^ and 63% vs. 53%,^192^ respectively); 10-year overall survival was also higher among females (85%) than males (77%) in one Japanese study between 1994 and 2003.^191^ In the NCDB from 2003 to 2006, the multivariable-adjusted HRs for females compared with males were 0.78 (95% CI, 0.67 to 0.90) among 1,991 patients with lepidic adenocarcinoma^186^ and 0.76 (95% CI, 0.72 to 0.80) among 11,990 patients with clinical stage IA.^187^ Five- and 10-year OS rates were higher among younger patients (i.e., <67 years of age) than older patients in both Japan^184,^ ^191^ and the United States and Europe.^181,^ ^192^ In a study restricted to 1,640 patients 75 years or older with stage IA NSCLC, the 5-year OS was 50 percent for lobectomy, 44 percent for segmentectomy, and 39 percent for wedge resection.^180^ In the NCDB from 2003 to 2006, there was a 46 percent increased risk of death for every 10 years of age (adjusted HR, 1.46; 95% CI, 1.35 to 1.59).^186^ In the NDCB study of 1,991 patients with lepidic adenocarcinoma (2003–2006), black patients had a 45 percent increased risk of death compared with white patients (adjusted HR, 1.45; 95% CI, 1.07 to 1.96); risk of death was nonsignificantly lower among other nonwhite patients (adjusted HR, 0.90; 95% CI, 0.60 to 1.35) than white patients.^186^

The Charleson-Deyo Comorbidity Index is a validated method of predicting mortality by weighting comorbid conditions.^211^ In an analysis of 11,990 clinical stage IA patients in the NCDB diagnosed between 2003 and 2006, the multivariable-adjusted HRs for patients with Charleson-Deyo Comorbidity Index scores of 1 and ≥2 were 1.21 (95% CI, 1.14 to 1.29) and 1.56 (95% CI, 1.44 to 1.68), respectively, when compared with patients with a score of 0.^187^ Adjusted HRs were similar in the 2003–2006 analysis of patients with lepidic adenocarcinoma who had Charleson-Deyo Comorbidity Index scores of 1 and 2 (compared with 0).^186^ Five-year OS among patients with and without COPD was similar (73% and 74%, respectively) in a U.S. study of 724 patients conducted from 1992 to 2010.^172^ As another proxy for comorbidity, the Thoracic Revised Cardiac Risk Index (ThRCRI) is a prognostic tool that aims to identify patients at increased risk of major cardiac events after surgical resection for lung cancer.^181,^ ^212,^ ^213^ A study of 1,370 patients with pathologic stage I NSCLC who underwent surgical resection in three U.S. and European thoracic surgery units from 2000 to 2011 were evaluated according to their ThRCRI class (A: score 0 to 1; B: score 1.5 to 2.5; and C: score > 2.5).^181^ Five-year OS and CSS rates decreased as ThRCRI scores increased (class A: 66% and 77%, respectively; class B: 53% and 75%, respectively; class C: 35% and 55%, respectively). Likewise, median survival decreased with ThRCRI scores (98, 68, and 60 months for classes A, B, and C, respectively).^181^

Finally, 5- and 10-year OS rates were higher among nonsmokers (5-year OS: 91%; 10-year OS: 86%)^191^ and patients reporting 0 to 20 pack-years of smoking (5-year OS: 86%)^184^ than among smokers (5-year OS: 83%; 10-year OS: 76%)^191^ and patients reporting more than 20 pack-years of smoking (5-year OS: 71%)^184^ in two Japanese studies, one of which was restricted to patients with stage 1 adenocarcinoma NSCLC.^184^

##### Update Search Summary: Surgery Results

Nine fair-quality studies^214–222^ identified through the update search evaluated the effectiveness of surgical resection for the treatment of stage I NSCLC (Appendix E Tables 7 and 8). Four studies analyzed 40,288 patients from the SEER database between 2000 and 2014, ensuring at least some overlap of patients among analyses;^214,^ ^215,^ ^219,^ ^221^ one study analyzed 14,545 patients from the California Cancer Registry between 2007 and 2013;^216^ and one study analyzed 6,905 patients from the Polish National Lung Cancer Registry between 2007 and 2013.^217^ Long-term survival rates varied substantially across study populations (5-year OS: 33% to 84.6%) but were similar to what was reported by the original search yield (5-year OS: 51% to 86%). Limited evidence based on a single study^222^ also supported findings from the original search yield that sicker patients (i.e., those with clinically relevant comorbidities) generally did not fare as well in terms of survival as patients without comorbidities.

#### SBRT

##### Description of Included Studies

Thirteen studies evaluated the effectiveness of SBRT, also known as stereotactic ablative radiotherapy (SABR), for the treatment of stage I NSCLC (Appendix E Tables 4 and 6);^185,^ ^196–207^ all studies, except one good quality study,^185^ were rated as fair quality. Sample sizes ranged from 39 to 4,454. Of the 13 studies, four studies analyzed data from the NCDB for patients diagnosed and treated with SBRT from 2003 through 2014.^185,^ ^196,^ ^199,^ ^200,^ ^202^ In the largest NCDB analysis, 4,454 patients were treated with SBRT. The median followup time was 50 months (95% CI, 49 to 52 months) in the entire cohort, which also included 335 radiofrequency ablation patients; 46 percent of the cohort was male and the mean age was 74 years.^202^ The three other NCDB analyses were among 1,781 otherwise healthy patients with operable tumors (i.e., surgery was not contraindicated because of patient risk factors),^185^ 498 patients with inoperable tumors,^200^ and 127 patients who were nonagenarians (i.e., ≥90 years old) at diagnosis.^199^ The mean age of the healthy patients was 76 years, and the proportion of males ranged from 43 to 46 percent in the three analyses. One additional database study included 449 patients diagnosed between 2006 and 2015 from VINCI. A majority of patients were age 60 to 79 years at diagnosis, a majority were diagnosed between 2011 and 2015, and 97 percent were male.^196^ In addition to the database studies, eight primary studies were conducted between 2003 and 2014 in the United States,^197,^ ^204^ Denmark,^203^ Japan,^198,^ ^201,^ ^205^ The Netherlands,^206^ and Scandinavia.^207^ Sample sizes ranged from 39^206^ to 772,^204^ and the reported percentage of male patients ranged from 45 in Denmark^203^ to 72 in Japan.^198^ The mean age of patients ranged from age 72 to 79 years; one study grouped patients by age at diagnosis (<75 years, ≥75 years) where the mean ages were age 67 and 81 years, respectively and is further described in the subgroups section below.^204^ One study each included patients with only operable^201^ or only inoperable^207^ tumors; the operability of tumors was mixed (range of percent inoperable: 62% to 85%) or not described^198,^ ^204^ in the remaining studies.

##### Detailed Results

The 5-year OS was 33 percent among more than 4,000 patients in the NCDB^202^ but was lower among patients with inoperable tumors (n=498) (30%)^200^ or who were 90 years of age or older at diagnosis (n=127) (20%).^199^ In a propensity score–matched analysis of otherwise healthy patients with operable tumors receiving lobectomy or SBRT in the NCDB that was rated as good quality, the 5-year OS was 29 percent among 1,781 patients receiving SBRT. In the same study, 235 SBRT patients who refused surgery were propensity score matched to lobectomy patients, and the 5-year OS was 40 percent.^185^ Among 449 veterans in the VINCI database who received SBRT, the 5-year OS was 44 percent and the 5-year unadjusted cumulative incidence of cancer death was 45 percent.^196^

The median followup time among eight primary studies evaluating SBRT for stage I NSCLC ranged from 3 years (reported as 38 months^206^) in a Dutch study of 39 patients to 7 years in a U.S. study of 65 patients.^197^ Among 57 patients in Scandinavia and 100 patients in Japan with inoperable tumors, the 5-year OS ranged from 30 percent (95% CI, 18% to 42%)^207^ to 42 percent (95% CI, 33% to 52%),^205^ respectively. Among Japanese patients with operable tumors, the 5-year OS ranged from 54 percent (95% CI, 41% to 65%) among 65 patients^205^ to 67 percent (95% CI, 50% to 79%) among 40 patients.^201^ From studies with mixed or unknown patient populations in terms of operability, the 5-yr OS ranged from 35 percent among 136 patients in Denmark^203^ to 66 percent among 65 patients in the United States.^197^ In the U.S. study with median followup of 7 years and a mixed patient population, the 7-year OS was 47.5 percent and the 5- and 7-year progression-free survival rates were 49.5 percent and 38.2 percent, respectively.^197^ The 5-year progression-free survival was similar in a Scandinavian study (52% [95% CI, 33% to 70%]).^207^

##### Subgroups

One study of 772 patients treated with SABR between 2004 and 2014 at The University of Texas MD Anderson Cancer Center compared survival between patients less than 75 years of age with patients 75 years or older.^204^ The median overall survival was significantly higher among younger patients (61.2 months [95% CI, 53.2 to 69.2 months]) than among older patients (47.7 months [95% CI, 39.6 to 55.9 months]). Five-year OS rates decreased with increasing age in two separate analyses; among patients with mean ages in the 70s, 80s,^204^ and 90s,^199^ the 5-year OS rates were 52, 40, and 20 percent, respectively.

##### Update Search Summary: SBRT Results

Fourteen studies (13 fair-quality studies^223–235^ and 1 good-quality study^236^) identified through the update search evaluated the effectiveness of SBRT for the treatment of Stage I NSCLC (Appendix E Tables 7 and 9). Two studies analyzed 27,795 patients from the NCDB between 2004 and 2014;^228,^ ^232^ and one study analyzed 378 patients from the Netherlands Cancer Registry.^231^ Long-term survival rates varied substantially across study populations (5-year OS: 26% to 80%) but were similar to what was reported by the original search yield (5-year OS: 20% to 67%). Although survival varied by subgroups defined by clinical and patient characteristics, differences between subgroups based on sex, age, or NSCLC T-stage were not statistically significant.

### Key Question 7a What Are the Harms Associated With Surgical Resection or SBRT for the Treatment of Early (Stage I) NSCLC?

### Key Question 7b Do the Harms Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, or Presence of Comorbid Conditions?

#### Summary

No RCTs comparing surgical resection or SBRT with no treatment for stage I NSCLC were identified. Twenty-five uncontrolled studies evaluating surgical resection (n=737,775 patients with stage I NSCLC)^170,^ ^173,^ ^176,^ ^177,^ ^179,^ ^182,^ ^185,^ ^189,^ ^196,^ ^237–252^ for the treatment of stage I NSCLC were included for KQ 7 (Appendix E Tables 4 and 5) for presentation to the USPSTF; additional studies were subsequently identified in update searches and literature surveillance and are described below in the Update Search Summary sections. Results of those studies were similar to what was identified by the original search yield. Nine of the studies from the original search yield were previously included for KQ 6,^170,^ ^173,^ ^177,^ ^179,^ ^182,^ ^185,^ ^189,^ ^196,^ ^253^ three were rated good quality,^177,^ ^179,^ ^185^ and 22 were rated fair quality (Appendix D Table 1).^170,^ ^173,^ ^176,^ ^182,^ ^189,^ ^196,^ ^237–252^ Nine of the studies were uncontrolled analyses of prospectively collected data from the NCDB from 1998 to 2010, ensuring at least some overlap of patients among analyses.^189,^ ^239,^ ^240,^ ^243–245,^ ^250–252^ Likewise, there were three analyses of SEER data from 1992 to 2009 that likely included some overlap of patients.^237,^ ^241,^ ^247^ The remaining studies were from other registries or databases (e.g., VINCI) or primary studies conducted at one or more institutions. Five surgery studies reported harms outcomes among subgroups of patients defined by age, sex, and comorbidities.^189,^ ^239,^ ^242,^ ^248,^ ^251^

An additional 31 studies (32 articles) evaluating SBRT (n=17,353 patients with stage I NSCLC)^196–198,^ ^202–207,^ ^237,^ ^241,^ ^246,^ ^251,^ ^254–272^ were also included for KQ 7 (Appendix E Tables 4 and 6) for presentation to the USPSTF; additional studies were subsequently identified in update searches and literature surveillance and are described below in the Update Search Summary sections; results of those studies were similar to what was identified by the original search yield. One of the studies was an RCT comparing two dosing regimens of SBRT (34 Gy in 1 fraction vs. 48 Gy in four consecutive daily fractions);^263^ the remaining studies were uncontrolled. All 31 studies were rated fair quality (Appendix D Tables 1–4). Two studies analyzed data from the NCDB from 2004 to 2014,^202,^ ^251^ and two studies analyzed data from SEER from 2001 to 2009,^237,^ ^241^ likely resulting in some patient overlap in analyses. Four SBRT studies reported harms outcomes among subgroups defined by age, sex, and comorbidities.^204,^ ^251,^ ^255,^ ^261^

The strength of evidence for harms from treatment of stage I NSCLC is moderate for surgical resection and low for SBRT/SABR. Estimates of low 30- and 90-day mortality rates are reasonably consistent and precise for surgical resection, as are the estimates for specific adverse effects. For SBRT/SABR, estimates for 30- and 90-day mortality are reasonably consistently low and for specific adverse events are consistently mild to moderate. However, a majority of the SBRT/SABR studies enrolled fewer than 200 patients (i.e., are imprecise) and are clinically heterogeneous in terms of patients and treatment details. Both bodies of evidence are primarily uncontrolled studies of fair quality and may be affected by selective reporting of specific adverse events.

#### Harms From Surgical Resection

##### Description of Included Studies

Twenty-five uncontrolled studies of mostly fair quality evaluated the harms of surgical resection for the treatment of stage I NSCLC between 1983 and 2015 and were included in KQ 7 (Appendix E Tables 4 and 5).^170,^ ^173,^ ^176,^ ^177,^ ^179,^ ^182,^ ^185,^ ^189,^ ^196,^ ^237–252^ Sample sizes ranged from 540 patients in a good-quality study conducted in the United Kingdom from 2011 to 2012^177^ to 146,908 patients in an analysis of the NCDB from 2004 to 2013.^245^ Most of the studies were conducted in the United States with the exceptions of one study from Denmark,^249^ one from the United Kingdom,^177^ and two from Japan.^173,^ ^179^ A total of 737,775 patients with stage I NSCLC were included in the 25 studies, but there is likely overlap of indeterminant extent of patients among studies that used data from the NCDB (k=9 studies)^189,^ ^239,^ ^240,^ ^243–245,^ ^250–252^ and SEER databases (k=3).^237,^ ^241,^ ^247^ The mean or median age ranged from 65 to 69 years in most studies. One good quality study, which enrolled only patients who received wedge resection, was conducted among patients with a median age of 72 years (interquartile ratio [IQR]: 64 to 77 years).^177^ Two studies of SEER data reported median ages of 75 years, but the entire patient population also included patients receiving SBRT (who tend to be older; see below).^237,^ ^241^ Ninety-six percent of the patients in the analysis of VINCI data (i.e., veterans) were male;^196^ the remaining studies were relatively balanced between males and females (range of % male: 43% to 56%). While some studies focused solely on patients who received lobectomy,^173,^ ^182,^ ^185,^ ^238,^ ^247,^ ^249,^ ^250^ most studies included multiple types of surgical resection including lobectomy, segmentectomy, wedge resection, and pneumonectomy.

##### Detailed Results

The 30-day mortality rates ranged from zero in a good-quality Japanese study of 618 clinical stage IA patients^179^ to 3.6 percent (95% CI, 3.06% to 4.1%) in an analysis of almost 5,000 patients in the SEER database from 1992 to 2002 who were 65 years of age or older.^247^ The 30-day mortality rate for 1,386 patients receiving a pneumonectomy (i.e., surgical removal of one lung) in the NCDB from 2004 to 2013 was an outlier at 7.8 percent compared with rates of 2 percent and 1.8 percent for lobectomy (i.e., removal of a single lobe) and SLR (i.e., removal of less than a full lobe, such as wedge resection or segmentectomy), respectively.^251^ The 30-day mortality rate among patients in the NCDB who delayed surgery 8 or more weeks after diagnosis was higher (2.9%) than patients who did not delay surgery (2.4%, p=0.01).^240^ One study in Denmark reported a higher 30-day mortality rate among lobectomy patients who received a thoracotomy (2.9%) than patients who received VATS (1.1%, p=0.02).^249^ There were no significant differences among various surgical approaches in other studies.^176,^ ^196,^ ^237,^ ^238,^ ^248,^ ^250^ Ninety-day mortality rates ranged from 2 percent in a study of VATS vs. open lobectomy^182^ to 4.8 percent (95% CI, 2.7% to 7.8%) among lobectomy patients in another study of lobectomy and segmentectomy.^176^ The 90-day mortality rate for 1,386 patients receiving a pneumonectomy in the NCDB from 2004 to 2013 was another outlier at 11.9 percent compared with rates of 3.5 percent and 3.3 percent for lobectomy and SLR, respectively.^251^ In an analysis of over 145,000 patients in the NCDB from 2004 to 2013, the 30- and 90-day mortality rates were significantly higher (but still <4%) among patients who did not meet quality measures that included anatomical resection, surgery within 8 weeks of diagnosis, resection for cure or complete remission, or sampling of 10 or more lymph nodes.^245^

The overall perioperative morbidity (categorized as pulmonary, cardiac, neurological, and renal, but not otherwise defined) in one study comparing VATS to open lobectomy among 963 patients was 19 percent and 34 percent, respectively (p=0.0001)^182^ and in another study was 46 percent and 36 percent for patients (n=899) receiving lobectomy and segmentectomy, respectively (p=0.01) (Appendix E Table 5).^248^ Less than 30 percent of patients experienced any perioperative morbidity in a study of 800 patients (28%)^170^ or acute toxicity within 60 days of surgery in 1,183 patients in a National Comprehensive Cancer Network analysis (23%).^246^ Rates of specific adverse events attributed to surgical resection were generally low. The percentage of patients experiencing infection or pneumonia ranged from 3.3 percent^238^ to 7 percent;^182^ patients with delayed surgery experienced significantly higher rates of infection (11%) than patients without delayed surgery (6%, p=0.006).^240^ Patients undergoing delayed surgery,^240^ VATS lobectomy (compared with robotic lobectomy^238^ or segmentectomy^248^), or who were pathologic stage IB (compared with pathologic stage IA^173^) experienced higher blood loss (sometimes defined by need for transfusion or a return to the operating room). Three studies reported rates of bronchopleural fistulas of less than 0.5 percent.^170,^ ^182,^ ^238^ Greater than 10 percent of patients in some studies reported cardiac arrhythmias^170,^ ^182,^ ^238,^ ^240,^ ^242^ or pulmonary morbidities,^182,^ ^238,^ ^240,^ ^247,^ ^248^ including air leaks.^238,^ ^240^

##### Subgroups

Five studies evaluated harms of surgical resection among subgroups of patients.^189,^ ^239,^ ^242,^ ^248,^ ^251^ Thirty-day mortality rates increased with increasing age in four studies. Compared with patients under 75 years, patients 75 years or older were 165 percent more likely to die within 30 days of surgery (OR, 2.65, 95% CI, 2.38 to 2.95) in a multivariable analysis of NCDB data from 2003 to 2011.^239^ In another NCDB analysis, the 30- and 90-day unadjusted mortality rates for patients 55 years or younger were 0.97 percent and 1.55 percent, respectively, compared with patients 80 years or older (3.94% and 7.30%, respectively).^251^ Mortality rates were higher among males than females in two studies.^189,^ ^239^ Finally, the risk of death within 30 days of surgery increased as the Charleson-Deyo Comorbidity Score increased in two studies.^189,^ ^239^ One study found no difference in mortality between “normal”- and “high”-risk patients;^242^ high-risk patients were primarily identified as having predicted forced expiratory volume in 1 second and predicted diffusion capacity of the lung for carbon monoxide of 50 percent or less.

##### Update Search Summary: Surgery Results

Four fair-quality studies^217,^ ^220,^ ^273,^ ^274^ identified through the update search evaluated harms of surgical resection for the treatment of stage I NSCLC between 2017 and 2018 and were included for KQ7 (Appendix E Tables 7 and 8). One study analyzed 6,905 patients from the Polish National Lung Cancer Registry from 2007 to 2013,^217^ and another analyzed 9,508 patients from the SEER database from 2000 to 2009.^273^ Estimates of 30- and 90-day mortality and perioperative morbidity (when reported) were reasonably consistent and precise, and they were similar to the original search yield’s findings for surgical resection.

#### Harms From SBRT

##### Description of Included Studies

Thirty-one fair quality studies described in 32 articles evaluated SBRT/SABR (n=17,353 patients with stage I NSCLC)^196–198,^ ^202–207,^ ^237,^ ^241,^ ^246,^ ^251,^ ^254–272^ for the treatment of stage I NSCLC between 1998 and 2015 and were included for KQ 7 (Appendix E Tables 4 and 6). Sample sizes ranged from 30 patients in a single institution study in Italy^262^ to 8,216 in an analysis of the NCDB from 2004 to 2013;^275^ most studies enrolled fewer than 200 patients. One of the studies was a fair-quality RCT comparing two dosing regimens of SBRT (34 Gy in one fraction vs. 48 Gy in four consecutive daily fractions);^263^ the remaining studies were uncontrolled. While most studies were conducted in North America, there were a few conducted in Europe^203,^ ^206,^ ^207,^ ^254,^ ^256,^ ^262,^ ^267,^ ^270^ and Asia.^198,^ ^205,^ ^255,^ ^268^ The mean or median age of patients receiving SBRT/SABR was between 70 and 79, and the percentage of male patients ranged from 37 percent to 97 percent. Treatment-related toxicity and adverse events were evaluated using the Common Toxicity Criteria for Adverse Events version 3 or 4 in 18 studies. Adverse events were graded according to severity (grade 1: mild; grade 2: moderate; grade 3: severe or medically significant; grade 4: life-threatening consequences; grade 5: death related to adverse event).^276^ Clinical toxicities were also graded using Radiation Therapy Oncology Group (RTOG) criteria^277^ in two studies.^262,^ ^263^

##### Detailed Results

Nine studies reported 30-day mortality rates of 0 to 2 percent;^196,^ ^198,^ ^203,^ ^237,^ ^246,^ ^251,^ ^258,^ ^265,^ ^266^ 90-day mortality rates were similar (range: 0% to 3%) in nine studies.^196,^ ^198,^ ^203,^ ^237,^ ^241,^ ^251,^ ^258,^ ^265,^ ^266^ The most commonly reported adverse events were radiological toxicity, pulmonary toxicity and respiratory disorders, fatigue, pain, and dermatologic adverse events. The RCT comparing two SBRT dosing regimens reported that a majority of reported adverse events were grade 2 (i.e., moderate);^263^ the incidence of grade 2 toxicities ranged from 9 percent^271^ to 31 percent^206^ in the other studies, and the common toxicities were dyspnea, esophageal pain, chest wall pain, and coughing. The range of grade 3 (i.e., severe) toxicities was 0 percent to 13 percent in 13 studies; the most common grade 3 toxicities reported were pulmonary toxicities, fatigue, chest wall pain, and dermatitis.^197,^ ^203,^ ^205,^ ^206,^ ^255,^ ^260,^ ^262–264,^ ^268,^ ^269,^ ^271,^ ^272^ Seven studies reported no grade 4 (i.e., life threatening) adverse events.^197,^ ^206,^ ^207,^ ^255,^ ^264,^ ^267,^ ^269,^ ^271^ Among six studies that reported patients who experienced a grade 4 adverse event,^205,^ ^207,^ ^262,^ ^263,^ ^265,^ ^268,^ ^272^ the highest incidence rate was 5 percent (dyspnea among patients with medically inoperable tumors)^268^ and the most commonly reported toxicity was pulmonary in nature. One study reported a death due to hemoptysis in a patient older than 75 years of age,^204^ and two studies each reported a single death due radiation pneumonitis.^256,^ ^260^

Thirteen studies reported data related to rib fractures;^197,^ ^204,^ ^207,^ ^254,^ ^256,^ ^258,^ ^260,^ ^261,^ ^263,^ ^264,^ ^267,^ ^268,^ ^271^ most were grade 1 (i.e., mild) or 2 (i.e., moderate) according to the Common Toxicity Criteria for Adverse Events or RTOG criteria. The overall incidence of any rib fracture ranged from 0^271^ to 37 percent.^261^ In the study reporting the highest overall incidence, 17 of 46 patients reported 41 fractured ribs and the median time to a fractured rib after SBRT was 21 months (range: 7 to 40 months).^261^ In the RCT comparing dosing regimens, 18 percent of patients receiving 34 Gy in one fraction and only 2 percent of patients receiving 48 Gy in four fractions at 12 Gy per fraction experienced an “injury” that included fracture.^263^ Nineteen studies reported data related to radiation pneumonitis.^197,^ ^204,^ ^205,^ ^207,^ ^237,^ ^246,^ ^254–256,^ ^258–260,^ ^263,^ ^264,^ ^266,^ ^267,^ ^270–272^ As many as 75% of patients experienced grade 1 radiation pneumonitis^197^ and as described above, only two patients experienced grade 5 (i.e., fatal) radiation pneumonitis.^256,^ ^260^ The rate of grade 2, 3, or 4 (i.e., moderate severity to life-threatening) radiation pneumonitis in all of the studies was less than 12 percent.

##### Subgroups

Four SBRT studies reported harms outcomes among subgroups defined by age, sex, and comorbidities.^204,^ ^251,^ ^255,^ ^261^ Thirty- and 90-day unadjusted mortality rates did not substantially differ by age in one study of over 8,000 patients in the NCDB,^251^ and rates of grade 2 or 3 (i.e., moderate or severe) adverse events did not differ by age (<75 years, ≥75 years) in a study of 772 U.S.-based patients.^204^ In one Japanese study, females experienced numerically higher rates of grade 2 or higher radiation pneumonitis than males (16% vs. 13%, respectively; adjusted OR 1.30 [95% CI, 0.53 to 3.10]).^255^ In a small study of 46 patients, females were significantly more likely to experience rib fractures (adjusted OR 4.43), but the CI was very wide (1.68 to 11.69).^261^ In that same study, patients with diabetes or COPD were less likely to experience rib fractures (OR 0.51 [95% CI, 0.09 to 2.88) for diabetes and OR 0.97 [95% CI, 0.28 to 3.39] for COPD) but not significantly so.^261^

##### Update Search Summary: SBRT Results

Twenty-nine studies (28 fair-quality studies^224–230,^ ^232–234,^ ^236,^ ^278–295^ and 1 good-quality study^236^) identified through the update search evaluated the effectiveness of SBRT for the treatment of stage I NSCLC between 2006 and 2019 (Appendix E Tables 7 and 9). Two studies analyzed 27,795 patients from the NCDB from 2004 to 2014,^228,^ ^232^ one analyzed 99 patients from the Amsterdam Cancer Registry from 2002 to 2007,^289^ one study analyzed 55 patients from the RTOG 0236 uncontrolled clinical trial,^279^ and one RCT (the CHISEL trial) analyzed 66 patients.^293^ Estimates of 30- and 90-day mortality from the update search yield were reasonably consistently low and for specific adverse events were consistently mild to moderate. The most commonly reported adverse events were radiological toxicity, pulmonary toxicity and respiratory disorders, fatigue, chest wall pain, and dermatologic adverse events. These findings matched those of the original search yield, and studies from the update search yield were subject to the same limitations. Studies identified in the update search did not report enough information to determine whether most included patients experienced adverse events.

### Key Question 8 What Is the Magnitude of Change in All-Cause and Lung Cancer Mortality That Results From a Specified Change in Lung Cancer Incidence (and Change in Distribution of Lung Cancer Stages [i.e., Stage Shift]) After Screening?

The NLST results indicate that an absolute increase in lung cancer incidence of 0.5 percent (4.1% vs. 3.6% of participants) and the associated absolute increase in Stage I lung cancers of 19 percent (50% vs. 31% of incident lung cancers) and absolute decrease in Stage IV lung cancers of 14 percent (22% vs. 36% of incident lung cancers) after three annual rounds of screening with LDCT (compared with CXR) were associated with 52 fewer lung cancer deaths and 84 fewer all-cause deaths per 100,000 person-years.^32,^ ^63^ Attributing the changes in lung cancer and all-cause mortality to this particular change in lung cancer incidence assumes the approach to workup of lung cancers and subsequent treatments (surgical interventions) used in the NLST.

The NELSON results indicate that an absolute increase in lung cancer incidence of 0.6 percent (5.2% vs. 4.6% of participants) and the associated absolute increase in Stage I lung cancers of 27 percent (41% vs. 14% of incident lung cancers) and absolute decrease in Stage IV lung cancers of 19 percent (27% vs. 46% of incident lung cancers) after four rounds of screening with LDCT using a volumetric method (compared with no screening) were associated with 83 fewer lung cancer deaths per 100,000 person-years, but not fewer all-cause deaths.^76^ Attributing the changes in lung cancer to this particular change in lung cancer incidence assumes the approach to workup of lung cancers and subsequent treatments (surgical interventions) used in NELSON.