# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Eight KQs were developed for this review:

1. a. Does screening for lung cancer with LDCT change the incidence of lung cancer and the distribution of lung cancer types and stages (i.e., stage shift)?
  b. Does screening for lung cancer with LDCT change all-cause mortality, lung cancer mortality, or quality of life?
  c. Does the effectiveness of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
  d. Does the effectiveness of screening for lung cancer with LDCT differ by the number or frequency of LDCT scans (e.g., annual screening for 3 years, the protocol used in the NLST vs. other approaches)?
2. Does the use of risk prediction models for identifying adults at higher risk of lung cancer mortality improve the balance of benefits and harms of screening compared with the use of trial eligibility criteria (e.g., NLST criteria) or the 2013 USPSTF recommendations?
3. a. What is the accuracy of screening for lung cancer with LDCT?
  b. Does the accuracy of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
  c. Does the accuracy of screening for lung cancer with LDCT differ for various approaches to nodule classification (i.e., those based on nodule size and characteristics)?
4. a. What are the harms associated with screening for lung cancer with LDCT?
  b. Do the harms of screening for lung cancer with LDCT differ with the use of Lung-RADS, International Early Lung Cancer Action Program (I-ELCAP), or similar approaches (e.g., to reduce false-positive results)?
  c. Do the harms of screening for lung cancer with LDCT differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
5. a. What are the harms associated with workup or surveillance of nodules?
  b. Do the harms of workup or surveillance of nodules differ with the use of Lung-RADS, I-ELCAP, or similar approaches (e.g., to reduce false-positive results)?
  c. Do the harms of workup or surveillance of nodules differ for subgroups defined by age, sex, race/ethnicity, presence of comorbid conditions, or other lung cancer risk factors?
6. a. What is the effectiveness of surgical resection or SBRT for the treatment of early (Stage I) non-small cell lung cancer?
  b. Does the effectiveness of surgical resection or SBRT differ for subgroups defined by age, sex, race/ethnicity, or presence of comorbid conditions?
7. a. What are the harms associated with surgical resection or SBRT for the treatment of early (Stage I) non-small cell lung cancer?
  b. Do the harms of surgical resection or SBRT differ for subgroups defined by age, sex, race/ethnicity, or presence of comorbid conditions?
8. What is the magnitude of change in all-cause and lung cancer mortality that results from a specified change in lung cancer incidence (and change in distribution of lung cancer stages [i.e., stage shift]) after screening?

Figure 1 Analytic Framework

* The evaluation of evidence on treatment was limited to studies of surgical resection or stereotactic body radiotherapy for stage I NSCLC.

Abbreviations: NSCLC=non-small cell lung cancer.

Figure 1 depicts the key questions (KQs) within the context of the eligible populations, screening tools/interventions, comparisons, outcomes, and settings. The figure first illustrates the overarching question, how does screening for lung cancer with low-dose computed tomography (LDCT) change the incidence of lung cancer and distribution of lung cancer types and stages (KQ1), and what are the harms associated with screening (KQ 4)? On the left, the population of interest is specified as adults at increased risk of lung cancer. Beneath the population of interest, KQ 2 posits: does the use of risk prediction models for identifying adults at higher risk of lung cancer mortality improve the balance of benefits and harms of screening compared with trial eligibility criteria? The figure then depicts the pathway from screening to the detection of nodules, asking: what is the accuracy of LDCT screening for lung cancer (KQ 3) and what are the associated harms of screening (KQ 4)? Following the detection of nodules, the figure addresses the pathway of workup or surveillance to diagnosis of lung cancer, asking: what are the harms associated with workup or surveillance of nodules (KQ 5)? Following diagnosis of lung cancer, the figure outlines the pathway of treatment to advanced disease, and then to health outcomes of interest, asking: how effective is surgical resection for the treatment of early (stage I) non-small cell lung cancer (KQ 6), and what are the associated harms of treatment (KQ 7)? Alongside the aforementioned pathway, the figure follows the pathway from diagnosis of lung cancer to health outcomes, asking: what is the magnitude of change in all-cause mortality that results from a specified change in lung cancer incidence and change in distribution of lung cancer stages after screening (KQ 8)?

In addition to addressing the KQs, this review also looked for evidence related to four contextual questions (CQs) that focused on barriers to implementing lung cancer screening and surveillance in clinical practice in the United States; the representativeness of participants, settings, and providers in randomized, controlled trials (RCTs) of lung cancer screening to corresponding individuals and institutions in the United States.; the comparability of 5-year survival rates and life expectancy of screening-eligible adults (based on NSLT criteria or USPSTF recommendations) to those of NLST participants; unintended benefits of LDCT screening for lung cancer from detecting incidental findings; and the effectiveness of smoking cessation interventions among patients receiving LDCT screening. These CQs were not a part of this systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendix A.

## Data Sources and Searches

PubMed/MEDLINE and the Cochrane Library were searched for English-language articles published from January 1, 2012, through May 28, 2019. A predefined list of search terms and Medical Subject Headings (MeSH) focused on terms that describe relevant populations, tests, interventions, outcomes, and study designs was used when applicable. The search relied primarily on the previous systematic review for the USPSTF to identify potentially relevant studies published before 2012 (we reassessed all articles included in that systematic review using the eligibility criteria).^46,^ ^47^ Complete search terms and limits are listed in Appendix B. ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform (WHO ICTRP) were searched for unpublished literature. To supplement electronic searches, reference lists of relevant articles, systematic reviews, and studies meeting the inclusion criteria were reviewed. Studies suggested by peer reviewers or public comment respondents were reviewed and, if appropriate, incorporated into the final review. Since May 28, 2019, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on November 20, 2020, and we identified two potentially relevant articles. One study used the LCDRAT risk prediction model using the NHIS 2013–2015. Findings were similar to those reported by other studies assessing the LCDRAT that are included in this review.^48^ The study also estimated life-years gained by screening by developing another model for risk prediction of mortality; however, the model was not externally validated in a non-NHIS cohort and was therefore not eligible for this review. The second article (also mentioned by a public commenter) was by the same authors and evaluated the LCDRAT model using NHIS 2005, 2010, and 2015.^49^ It similarly estimated a greater percentage of screen-prevented lung cancer deaths across a range of risk thresholds (1.5% to 2.5%) compared with USPSTF criteria. The results of these studies would not change conclusions or the strength of evidence. All literature search results were managed using EndNote™ version 7.4 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs were developed with input from the USPSTF (Appendix B2). English-language studies of adults age 18 years or older conducted in countries categorized as “very high” on the 2016 Human Development Index^50^ and published in or after 2001 were included. For KQs 1 through 5 and 8 (screening and risk prediction), studies of asymptomatic adults with at least 1,000 participants were included. For KQs 6 and 7 (benefits and harms of treatment), studies among adults with Stage I NSCLC treated with surgery or SBRT (sometimes referred to as stereotactic ablative radiation, or SABR) were included. For all KQs, controlled clinical trials were eligible. Prospective cohort studies (i.e., cohort studies based on prospectively collected data that were intended to be used for evaluations relevant to this review) were also eligible for KQs on harms of screening or workup (KQs 4 and 5) and treatment (KQs 6 and 7); case-control studies were eligible for KQs on harms (KQs 4, 5, and 7).

For KQ 1 (direct evidence for health outcomes), studies that compared LDCT with CXR, no screening, or usual care were eligible. For KQ 2 (on risk prediction), externally validated models aimed at identifying persons at increased risk of lung cancer using multiple variables, including at least age and smoking history, were included. Eligible risk prediction models had to be compared to either the 2013 USPSTF recommendations or criteria used by trials showing benefit (e.g., NLST). Eligible outcomes included estimated screen-preventable lung cancer deaths or all-cause mortality, estimated screening effectiveness (e.g., number needed to screen [NNS]), and estimated screening harms. For KQ 3 (on accuracy), eligible outcomes included sensitivity, specificity, and predictive value. Because there is no single gold standard for assessing accuracy of LDCT for the diagnosis of lung cancer, comparators of subsequent diagnosis of lung cancer within 1 year (likely from repeat imagining and biopsy), biopsy, or subsequent imaging were eligible. For KQs on the harms of screening (KQ 4) or workup and surveillance (KQ 5), studies that evaluated LDCT (KQ 4) or other tests used after screening (KQ 5) were eligible; a comparison group was not required. For KQs on benefits (KQ 6) and harms (KQ 7) of treatment, studies that reported survival over at least 5 years of followup or harms were eligible. Titles and abstracts were independently reviewed by two investigators; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

Quality assessments were conducted using instruments devised for each of the included study designs and adapted for this topic. Criteria developed by the USPSTF^51^ were used to evaluate randomized studies, while Cochrane’s ROBINS-I tool^52^ was used for nonrandomized studies, the QUADAS-2 instrument^53^ was used to assess studies of diagnostic accuracy (KQ 3), and the CHARMS checklist^54^ was used to assess risk prediction models (KQ 2) (Appendix B). Each study was evaluated by two independent reviewers using the instrument(s) described above. Risk-of-bias ratings were translated into overall quality ratings of good, fair, or poor, using USPSTF criteria.^51^ Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized in tabular and narrative format. For KQs 4 and 5, it was often unclear whether harms were directly from LDCT screening or were part of the downstream workup that follows screening. Therefore, this review reports the harms of screening and the cascade of events that follows within a combined section for KQs 4 and 5 that was stratified by outcome (e.g., radiation, overdiagnosis), specifying, when possible, if harms were directly from a particular part of the cascade. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF (and the EPC program).^51^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

To determine whether meta-analyses were appropriate, the clinical and methodological heterogeneity of the studies was assessed according to established guidance.^55^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. The authors of this review did not conduct meta-analyses because of substantial clinical and methodological heterogeneity. For example, the trials of lung cancer screening differed in eligibility criteria (e.g., age, pack-years of smoking, years since quitting), number of screening rounds (from 2 to 5), screening intervals (e.g., annual, biennial, or escalating), thresholds for a positive screen (e.g., 4 mm, 5 mm, or based on volume), and comparators (CXR or no screening). For KQ 1, the authors of this review created forest plots to display the findings of each study by calculating incidence rate ratios (IRR), using number of events and person-years, for lung cancer incidence, lung cancer mortality, and all-cause mortality. Quantitative analyses were conducted using Stata version 14 (Stata Corp).

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft reports, but the authors are solely responsible for the content.

## Expert Review and Public Comment

A draft Research Plan was posted for public comment on the USPSTF Web site from May 3, 2018 to May 30, 2018. In response to public comments, the USPSTF expanded the eligibility criteria to include SBRT and clarified terminology related to screening tests, comparators, and outcomes in the Research Plan. A final Research Plan was posted on the USPSTF’s Web site on August 16, 2018. A draft report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. The draft report was posted for public comment. Revisions were made based on comments received, and references suggested by expert or public reviewers were evaluated for inclusion/exclusion. Revisions included the addition of a study addressing variation in accuracy by different approaches to nodule classification, clarifying that I-ELCAP changed their threshold for a positive nodule over time (from 5 mm to 6 mm), clarifying the nonlung cancers diagnosed in NLST participants, and updating the risk factors section of the introduction.