# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform an update of its recommendation on the topic of lung cancer screening. In 2013, the USPSTF recommended annual screening for lung cancer with low-dose computed tomography (LDCT) in adults ages 55 to 80 years who have a 30 pack-year smoking history and currently smoke or have quit within the past 15 years (B recommendation).^1^ The USPSTF recommended that screening should be discontinued once a person has not smoked for 15 years or develops a health problem that substantially limits life expectancy or the ability or willingness to have curative lung surgery. This report systematically evaluates the current evidence on screening for lung cancer with LDCT for populations and settings relevant to primary care in the United States. This report also summarizes the main benefits and harms of surgical resection or stereotactic body radiotherapy (SBRT) for the treatment of early (Stage I) non-small cell lung cancer (NSCLC).

## Condition Definition

Lung cancer is an abnormal proliferation of cells that originate in the lung tissues. Lung cancer has traditionally been classified into two major categories based on cell type and incorporation of immunohistochemical and molecular characteristics: (1) NSCLC, which collectively comprises adenocarcinoma, squamous cell carcinoma, and large cell carcinoma, and (2) small-cell lung cancer (SCLC), which is more aggressive and has worse survival rates.^2^ The Tumor Node Metastasis staging system is used to characterize the extent of disease and determine lung cancer stage, treatment, and prognosis. Table 1 shows an overview of staging for NSCLC. Persons with Stage I disease have lung tumors less than or equal to 4 cm, no lymph node or metastatic involvement, and the best prognosis for survival.^3^ For SCLC, a simpler staging designating limited and extensive disease is used.

Table 1 NSCLC Staging Overview, Typical 5-Year Survival, and Treatment Approaches^28,^ ^257–261^

Stage | Description | TNM Classifications | 5-Year Survival | Treatment Approach
I | Tumor ≤4 cm with no involvement of lymph nodes or distant metastasis | T1-2a N0 M0 | 77–92% for Stage 1a; 68% for Stage 1b | Surgical resection, including lobectomy; SBRT (mainly for nonsurgical candidates)
II | Tumor >4 cm and ≤7 cm with no involvement of lymph nodes or distant metastasis; OR tumor ≤5 cm with metastases in ipsilateral pulmonary/hilar lymph nodes and no distant metastasis | T2b-3 N0 M0; T1-2 N1 M0 | 53–60% | Lobectomy + adjuvant chemotherapy
III | Heterogeneous group of disease, includes tumors ≥7 cm with or without ipsilateral lymph node involvement and smaller tumors with metastasis to the ipsilateral mediastinal/subcarinal nodes, contralateral mediastinal/hilar nodes, or supraclavicular nodes | T1-4 N0-3 M0 | 13–36% | Combined modality approach (chemotherapy, radiation therapy, +/− surgery, and/or immunotherapy)^*^
IV | Presence of distant metastasis: single or multiple extra-thoracic metastasis, malignant pleural or pericardial effusion | Any T or N; M1a-c | 1–10% | Combined modality approach (chemotherapy, radiation therapy, targeted molecular therapy and/or immunotherapy and +/− surgery)^*^

* Tailored to patient disease and performance status.

Abbreviations: a=separate tumor nodule[s] in contralateral lobe, tumor with pleural or pericardial nodule(s) or malignant pleural or pericardial effusions; b=single extrapulmonary metastasis; c=multiple extrapulmonary metastases in one or more organs; M=distant metastasis; N=regional lymph nodes; NSCLC=non-small cell lung cancer; SBRT=stereotactic body radiation therapy; T=primary tumor; TNM=Tumor Node Metastasis.

## Etiology and Natural History

Smoking is the number one cause of lung cancer, but secondhand smoke and environmental exposures also increase risk.^4^ Trends in lung cancer incidence and mortality rates have closely reflected historical patterns of smoking (but with a delay of decades).^4^ In general, the prognosis for persons with lung cancer is poor; the 5-year survival rate for all stages combined was about 16 percent from 1995 to 2001, with rates varying significantly by stage at diagnosis.^5^ From 2008 to 2014, reported 5-year survival rates were better, 18.6 percent for all stages combined.^3^ Most patients (79%) diagnosed with lung cancer present with distant or metastatic disease; only 16 percent are diagnosed with localized (i.e., Stage 1) disease.^3^

## Risk Factors

The risk of developing lung cancer is largely driven by age and smoking status. The incidence of lung cancer increases with every additional decade of life; the median age of lung cancer diagnosis is 70 years.^6,^ ^7^ Smoking is estimated to account for nearly 90 percent of all lung cancers.^8^ The relative risk of lung cancer in smokers is approximately 20-fold that of nonsmokers, and risk increases with cumulative quantity and duration of smoking.^9^ Secondhand smoke, which exposes nonsmokers to the components of tobacco smoke at lower concentrations, is also an established cause of lung cancer.^10,^ ^11^

Other risk factors for lung cancer include environmental exposures, radiation therapy, other (noncancer) lung diseases, race/ethnicity,^12^ and family history. Environmental exposures account for a proportionately smaller burden of lung cancer compared with tobacco (approximately 10%) and include the carcinogens radon, asbestos, polycyclic aromatic hydrocarbons (i.e., tar, soot), arsenic, and metals (e.g., beryllium, cadmium, chromium, nickel).^13,^ ^14^ Patients treated with radiation therapy are also at an increased risk of developing a primary lung cancer. In a systematic review that included 21 studies of patients with Hodgkin’s lymphoma, radiation therapy was associated with an approximately five-fold increase in secondary lung cancer; the percentage of patients who received radiation therapy ranged from 48 to 100 percent in the included studies.^15^ Similarly, in a meta-analysis of breast cancer patients (N=631,021), those treated with radiation therapy had a higher risk of a second lung cancer (relative risk [RR], 1.23; 95% confidence interval [CI], 1.07 to 1.43), which increased with duration of time following diagnosis.^16^ Lung diseases, such as chronic obstructive pulmonary disease (COPD) and pulmonary fibrosis, are associated with an increased risk of lung cancer, independent of age and smoking history.^17^ In a subcohort analysis of the National Lung Screening Trial (NLST), lung cancer incidence increased linearly with increasing severity of COPD.^18^ Cigarette smoking potentiates the risk of lung cancer in persons with other risk factors like environmental exposures, radiation therapy, and lung disease.^18–20^ Finally, a family history of lung cancer is associated with a 1.7-fold increased risk of developing lung cancer (95% CI, 1.6 to 1.9), an association that is greater with two or more relatives with lung cancer and weaker in nonsmokers (odds ratio [OR], 3.6 [95% CI, 1.6 to 83] and OR, 1.4 [95% CI, 1.2 to 1.7], respectively).^21^

## Prevalence and Burden

Lung cancer is the second most common cancer and the leading cause of cancer-related death in both men and women in the United States.^22^ In 2017 (the most recent year with complete data) 222,500 persons in the United States were diagnosed with lung cancer, and 155,870 persons died from lung cancer, of which 84,590 were men and 71,280 were women.^22^ A large majority (approximately 85%) of lung cancers are NSCLC, about 10 to 15 percent of lung cancers are SCLC, and fewer than 5 percent are lung carcinoid tumors.^23^ Lung cancer incidence increases with age, and the risk is greater in men than in women. Among men, black men have the highest incidence rate of getting lung cancer, followed by white, Asian/Pacific Islander, American Indian/Alaska Native, and Hispanic men.^3^ Among women, the rate is highest among white women, followed by black, American Indian/Alaska Native, Asian/Pacific Islander, and Hispanic women.^3^ Lung cancer incidence and death rates have decreased since the 1990s in both men and women because of lower rates of smoking.^3,^ ^22^

Regarding the preventable burden of disease, a 2013 study using National Health and Nutrition Examination Survey and National Health Interview Survey (NHIS) data estimated that approximately 8.6 million Americans were eligible for lung cancer screening in 2010 according to NLST eligibility criteria (ages 55 to 74 years with at least a 30 pack-year smoking history who currently smoke or used to smoke). The study stated that if the NLST were fully implemented among this screening-eligible population, a total of 12,250 lung cancer deaths would be averted each year.^24^ Others have estimated fewer lung cancer deaths would be averted. A study using data from the 2012 Health and Retirement Study evaluated comorbidities, life expectancy, smoking history, and other characteristics in the screening-eligible population and in NLST participants; it reported a lower 5-year survival rate and life expectancy in the screening-eligible persons compared with NLST participants. The authors concluded that the general U.S. population eligible for lung cancer screening is probably less likely to benefit from early detection compared with NLST participants because they face a high risk of death from competing causes, such as heart disease, diabetes, or stroke.^25^

## Rationale for Screening and Screening Strategies

Lung cancer has a high prevalence, high morbidity and mortality, and better survival rates if diagnosed at an earlier stage.^3^ The main rationale for screening is that it could lead to earlier detection of lung cancer when treatment is more likely to be effective. Screening is aimed at early detection of NSCLC rather than SCLC because the latter is much less common and typically spreads too quickly to be reliably detected by intermittent screening. The screening modality used in current clinical practice is LDCT. Other screening modalities that have been studied, but have not found to be beneficial, include sputum cytology, chest X-ray (CXR), and biomarkers.^26,^ ^27^

Findings from LDCT can range from incidental pulmonary nodules to lesions suspicious for lung cancer. Multiple approaches to nodule classification that guide additional testing or surveillance are available. For example, in an effort to standardize LDCT screening results reporting, the American College of Radiology developed and endorses the Lung-RADS™ classification system (Appendix A Table 1 and Appendix A Table 2).^28^ Lung-RADS provides guidance to clinicians on which findings are suspicious for cancer and suggested management. Briefly, lesions in Lung-RADS categories 1 and 2 are considered benign, whereas category 3 lesions (probably benign) warrant more frequent surveillance, and category 4 lesions (suspicious) require more aggressive evaluation.

For patients with suspected lung cancer, diagnosis by the least invasive method is recommended.^29^ Choosing a method to establish a diagnosis of lung cancer depends on the location of the primary lesion and potential metastatic lesions. Diagnostic techniques and procedures include sputum cytology; flexible bronchoscopy, preferred for central lesions; endobronchial ultrasound, preferred for peripheral lesions; trans-thoracic tissue needle aspiration for lesions not accessible by bronchoscopy; pleural fluid cytology or biopsy for pleural lesions; and surgery. If results from any method are negative and clinical suspicion is high, more invasive testing is recommended.

## Treatment Approaches

Lung cancer can be treated with surgery, chemotherapy, radiation therapy, newer targeted immunotherapies, and combinations of these treatments.^30^ Management is determined by the presenting stage of disease and the patient’s functional status, pulmonary function, medical comorbidities, and values (Table 1 for NSCLC; Appendix A Table 3 for SCLC). Surgical resection, lobectomy, is the treatment of choice for eligible patients with Stage I or II NSCLC and can be performed via open thoracotomy or video-assisted thoracoscopic surgery (VATS).^31^ For nonsurgical candidates, SBRT is a treatment option. In the NLST and NELSON trials, 50 to 62 percent of diagnosed cancers in the LDCT screening group were Stage I and 6 to 7 percent were Stage II (Appendix A Table 4).^32,^ ^33^

## Clinical Practice in the United States

Several recent studies have described the uptake of lung cancer screening in the United States since the USPSTF B recommendation was issued. An analysis of data from the Cancer Control Module of the NHIS data from 2010 (before the most recent USPSTF guidelines were issued) and 2015 (after the guidelines were issued) gives some idea of screening uptake.^34^ The NHIS survey used the following item as a proxy for lung cancer screening with chest computed tomography (CT): “Were any of the CAT scans of your chest area done to check for lung cancer, rather than for some other reason?” Overall, the percentage of U.S. adults older than age 40 who received CT scans for lung cancer screening was very low, although it increased from 2010 to 2015 (1.3% vs. 2.1%). Among respondents who met USPSTF-recommended age and smoking criteria, screening increased from 2.1 to 6.0 percent (p<0.001). The survey also found a temporal increase in screening from 2.1 to 3.8 percent among 55- to 74-year-olds who were at lower risk for lung cancer because they did not meet the eligibility criteria for smoking (p<0.001). Overall, the findings suggest an increase, which was large in relative terms but small in absolute terms, in use of CT screening in the U.S. population meeting eligibility criteria for lung cancer screening as well as some “unintended spillover” of screening to lower risk populations. An analysis using a 20 percent national sample of Medicare enrollees ages 55 to 77 years from January 2010 through December 2016 estimated even lower rates of LDCT screening than those estimated from NHIS.^35^ More recently, however, a study using data for 10 states from the 2017 Behavioral Risk Factor Surveillance System survey found that uptake of LDCT was up to 14.4 percent, with variation across the 10 states (from 6.5% to 18.1%) and higher rates for those with insurance or COPD.^36^

A recent survey of medical directors of Federally Qualified Health Centers that serve low-income populations found that 43 percent of clinics had implemented lung cancer screening, although most reported low volume. Respondents noted that substantial implementation challenges include lack of staff time, lack of resources to systematically collect tobacco use data and track screened populations, and substantial patient financial barriers to initial screening (for those uninsured) and followup procedures.^37^

A description of implementation of lung cancer screening in the Veterans Health Administration found that 2,106 patients underwent screening over 2 years.^38^ The authors noted that screening registry data collection was labor intensive and required manual abstraction of medical record information. Of all patients screened, 56 percent had nodules that required tracking; 2 percent required further evaluation, but the findings were not cancer; and 1.5 percent had lung cancer. Incidental findings (e.g., emphysema, coronary artery calcification) were noted on LDCT scans of 40.7 percent of patients.^38,^ ^39^

The Centers for Medicare & Medicaid Services (CMS) covers lung cancer screening, albeit with several stipulations.^40^ Among these stipulations is a requirement for a written order from a provider during a lung cancer screening counseling and shared decision making (SDM) visit. Specific required elements of this visit included the use of one or more decision aids, to include benefits, harms, followup diagnostic testing, overdiagnosis, false positive rate, and total radiation exposure. Another stipulation was that CMS would cover screening only by radiologists and imaging facilities that meet certain quality standards and that collect and submit required data elements to a CMS-approved national registry for each LDCT lung cancer screening performed. Virtually all guidelines that recommend lung cancer screening, including those issued by the USPSTF, recommend that providers conduct a rigorous process of informed and SDM about the benefits and harms of lung cancer screening before initiating screening. However, given the complex nature of benefits and harms associated with screening, there is some concern that robust SDM is impractical to implement in actual practice.^37,^ ^41,^ ^42^ Contextual Question 1 (Appendix A) further describes the barriers to implementing lung cancer screening and surveillance in clinical practice in the United States.

## Recommendations of Other Organizations

Most guidelines on lung cancer screening now recommend screening in high-risk persons. The American Cancer Society, along with several specialty societies including the American Thoracic Society, the American College of Chest Physicians, and the American Lung Association, have issued recommendations that are similar to those of the USPSTF (Appendix A Table 5). The definition of high risk varies somewhat in terms of age range, smoking history, and other factors but is generally overlapping across guidelines. The National Comprehensive Cancer Network (NCCN) recommends expansion of the screening-eligible population beyond the USPSTF criteria by beginning at age 50 in those with 20 or more pack-years if they also have an additional risk factor, including a cancer history, family history, chronic lung disease (including COPD), or occupational/environmental exposures (e.g., asbestos, radon, silica). The NCCN also notes that it is reasonable to consider using the PLCOm2012 lung cancer risk calculator to assist in quantifying risk, considering a 1.3 percent threshold of lung cancer risk (over 6 years).^43^ Of note, the American Academy of Family Physicians (AAFP) reviewed the USPSTF recommendation and concluded that evidence was insufficient^44^ to recommend for or against screening.^45^ They determined that screening cannot be recommended on the basis of a single study conducted in major medical centers.