# Appendix E Additional Tables and Results

Appendix E Table 1 Screening Details of Included Trials, KQ 1

Appendix E Table 2 Types and Stages of Incident Lung Cancer, KQ 1

Appendix E Table 3 Incidental Findings From KQ 4 Studies

Appendix E Table 4 KQs 6 and 7: Study and Patient Characteristics Table

Appendix E Table 5 KQs 6 and 7: Surgery Results

Appendix E Table 6 KQs 6 and 7: SBRT Results

Appendix E Table 7 KQs 6 and 7 Update Search Results: Study and Patient Characteristics

Appendix E Table 8 KQs 6 and 7 Update Search Results: Surgery Study Outcomes

Appendix E Table 9 KQs 6 and 7 Update Search Results: SBRT Study Outcomes

Appendix E Figure 1 Sensitivity Analysis for Trial Results for Lung Cancer Incidence (KQ 1), Including Studies Rated as Poor Quality

Note: G1=LDCT; G2=Control; The MILD trial randomized participants to annual screening, biennial screening, or a control group. For the 10-year followup, the annual and biennial screening groups were combined. At the 10-year followup, the median duration of screening for those in the screening groups was 6.2 years.

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; MILD=Multicentric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Appendix E Figure 1 displays a forest plot reporting the sensitivity analysis for trial results for lung cancer incidence (KQ1), including studies rated as poor quality. The figure includes trials that compared LDCT screening to control. For the NLST trial the figure displays the data for 6.5 years and 11.3 years of follow up. At 6.5 years, the NLST trial reported a higher lung cancer incidence in the intervention group compared to control (1,089 vs. 969 events; RR, 1.12 [95% CI, 1.02 to 1.22]). At 11.3 years of follow up, the NLST trial reported a higher lung cancer incidence in the intervention group compared to control (1,701 vs. 1,681 events; RR, 1.01 [95% CI, 0.95 to 1.08]). For the DANTE trial, a higher lung cancer incidence was reported in the intervention group compared to control (106 vs. 73 events; RR, 1.35 [95% CI, 1.00 to 1.81]). For the DLCST trial, a higher lung cancer incidence was reported in the intervention group compared to control (100 vs. 53 events; RR, 1.89 [95% CI, 1.36 to 2.64]). For the ITALUNG trial, a higher lung cancer incidence was reported in the control group compared to the intervention group (71 vs. 67 events; RR, 0.92 [95% CI, 0.66 to 1.28]). For the MILD trial, the figure reports on 3 screening arms including multiple interval screening, annual screening, and biannual screening. The multiple screening interval group within the MILD trial reported a higher lung cancer incidence compared to control (98 vs. 60 events; RR, 1.16 [95% CI, 0.84 to 1.59]). The annual screening interval group within the MILD trial reported a higher lung cancer incidence compared to control (34 vs. 20 events; RR, 1.97 [95% CI, 1.13 to 3.41]). The biannual screening interval group within the MILD trial reported a higher lung cancer incidence compared to control (25 vs. 20 events; RR, 1.46 [95% CI, 0.81 to 2.62]). For the NELSON trial, a higher lung cancer incidence was reported in the intervention group compared to control (341 vs. 304 events; RR, 1.14 [95% CI, 0.97 to 1.33]).

Appendix E Figure 2 Sensitivity Analysis for Early-Stage Lung Cancer Incidence (KQ 1), Including Studies Rated as Poor Quality

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; MILD=Multicentric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Appendix E Figure 2 displays a forest plot reporting the sensitivity analysis for early (I-II) stage lung cancer incidence (KQ 1), including studies rated as poor quality. The figure includes six trials that compare LDCT screening to control. All six trials reported increases in early stage lung cancer incidence for the intervention group compared to control. The NLST trial reported 818 events of early stage lung cancer in the intervention group compared to 615 events in the control group (RR, 1.33 [95% CI, 1.20 to 1.48]). The DANTE trial reported 54 events of early stage lung cancer in the intervention group compared to 21 events in the control group (RR, 2.38 [95% CI, 1.44 to 3.94]). The DLCST trial reported 54 events of early stage lung cancer in the intervention group compared to 10 events in the control group (RR, 5.42 [95% CI, 2.76 to 10.63]). The ITALUNG trial reported 29 events of early stage lung cancer in the intervention group compared to 13 events in the control group (RR, 2.17 [95% CI, 1.13 to 4.16]). The NELSON trial reported 168 events of early stage lung cancer in the intervention group compared to 71 events in the control group (RR, 2.39 [95% CI, 1.81 to 3.16]). The MILD trial reported 53 events of early stage lung cancer in the intervention group compared to 18 events in the control group (RR, 2.08 [95% CI, 1.22 to 3.56]).

Appendix E Figure 3 Sensitivity Analysis for Late-Stage Lung Cancer Incidence (KQ 1), Including Studies Rated as Poor Quality

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; MILD=Multicentric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Appendix E Figure 3 displays a forest plot reporting the sensitivity analysis for trial results for late (III-IV) stage lung cancer incidence. The figure includes six trials that compare LDCT screening to control. Five of the six trials reported decreases in late stage lung cancer incidence in the intervention group compared to control. The NLST trial reported 766 events of late stage lung cancer in the intervention group compared to 918 events in the control group (RR, 0.84 [95% CI, 0.76 to 0.92]). The DANTE trial reported 43 events of late stage lung cancer in the intervention group compared to 45 in the control groups (RR, 0.89 [95% CI, 0.59 to 1.35]). The DLCST trial reported 46 events of late stage lung cancer in the intervention group compared to 41 in the control groups (RR, 1.13 [95% CI, 0.74 to 1.72]). The ITALUNG trial reported 33 events of late stage lung cancer in the intervention group compared to 43 in the control group (RR, 0.75 [95% CI, 0.47 to 1.17]). The NELSON trial reported 153 events of late stage lung cancer in the intervention group compared to 216 events in the control group (RR, 0.72 [95% CI, 0.58 to 0.88]. The MILD trial reported 45 events of late stage lung cancer in the intervention group compared to 42 events in the control group (RR, 0.76 [95% CI, 0.50 to 1.16].

Appendix E Figure 4 Sensitivity Analysis for Trial Results for Lung Cancer Mortality (KQ 1), Including Studies Rated as Poor Quality

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LSS=Lung Screening Study; MILD=Multicentric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Appendix E Figure 4 displays a forest plot reporting the sensitivity analysis for trial results for lung cancer mortality (KQ1), including studies rated as poor quality. The figure includes seven trials that compared LDCT screening to control. For the NLST trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (280 vs. 332 deaths per 100,000 person-years; RR, 0.85 [95% CI, 0.75 to 0.96]. For the DANTE trial, a similar number of lung cancer deaths were reported in the intervention and control groups (543 vs. 544 deaths per 100,000 person-years; RR, 1.00 [95% CI, 0.69 to 1.44]. For the DLCST trial, fewer lung cancer deaths were reported in the control group compared to the intervention group (194 vs. 201 deaths per 100,000 person-years; RR, 1.03 [95% CI, 0.66 to 1.61]). For the ITALUNG trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (293 vs. 421 deaths per 100,000 person-years; RR, 0.70 [95% CI, 0.47 to 1.03]). For the MILD trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (173 vs. 247 deaths per 100,000 person-years; RR, 0.70 [95% CI, 0.45 to 1.09]). For the LSS trial, fewer lung cancer deaths were reported in the control group compared to the intervention group (310 vs. 383 deaths per 100,000 person-years; RR, 1.24 [95% CI, 0.74 to 2.07]. For the NELSON trial, fewer lung cancer deaths were reported in the intervention group compared to the control group (241 vs. 324 deaths per 100,000 person-years; RR, 0.75 [95% CI, 0.61 to 0.90]).

Appendix E Figure 5 Sensitivity Analysis for Trial Results for All-Cause Mortality (KQ 1), Including Studies Rated as Poor Quality

Abbreviations: DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology and Molecular Essays; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=Italian Lung Cancer Screening Trial; LSS=Lung Screening Study; MILD=Multicentric Italian Lung Detection; NELSON=Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST=National Lung Screening Trial.

Appendix E Figure 5 displays a forest plot reporting the sensitivity analysis for trial results for all-cause mortality (KQ 1), including studies rated as poor quality. The figure includes trials that compared LDCT screening to control. For the NLST trial, fewer deaths were reported in the intervention group compared to the control group (1,141 vs. 1,225 deaths per 100,000 person-years; RR, 0.93 [95% CI 0.88 to 0.99]). For the DANTE trial, fewer deaths were reported in the intervention group compared to the control group (1,655 vs. 1,742 deaths per 100,000 person-years; RR, 0.95 [95% CI, 0.77 to 1.17]). For the DLCST trial, fewer deaths were reported in the control group compared to the intervention group (834 vs. 849 deaths per 100,000 person-years; RR, 1.02 [95% CI, 0.82 to 1.26]). For the ITALUNG trial, fewer deaths were reported in the intervention group compared to the control group (1,051 vs. 1,270 deaths per 100,000 person-years; RR, 0.83 [95% CI, 0.67 to 1.03]. For the MILD trial, the figure reports on 3 screening arms including multiple interval screening, biannual screening, and annual screening. Multiple screening intervals within the MILD trial reported fewer deaths in the intervention group compared to the control group (594 vs. 654 deaths per 100,000 person-years; RR, 0.91 [95% CI, 0.71 to 1.17]. Biannual screening intervals within the MILD trial reported more deaths in the intervention group compared to the control group (558 vs. 310 deaths per 100,000 person-years; RR, 1.79 [95% CI, 1.02 to 3.14]. Annual screening intervals within the MILD trial reported more deaths in the intervention group compared to the control group (363 vs. 310 deaths per 100,000 person-years; RR, 1.17 [95% CI, 0.63 to 2.17]. For the LSS trial, fewer deaths were reported in the control group compared to the intervention group (1,384 vs. 1,667 deaths per 100,000 person-years; RR, 1.20 [95% CI, 0.94 to 1.53]). For the NELSON trial, fewer deaths were reported in the control group compared to the intervention group (1,376 vs. 1,393 deaths per 100,000 person-years; RR, 1.01 [95% CI, 0.92 to 1.11]).