# Appendix D Quality Assessments

Appendix D Table 1 Risk of Bias and Overall Quality Assessment Ratings for Nonrandomized Studies

First Author, Year; Study Name; Quality Rating | Confounding^*^ | Participant Selection | Intervention Classification | Intervention Deviation | Missing Data | Outcome Measurement | Reporting | Comments for Fair- or Poor-Quality Studies
Ackerson, 2018^295^; N/A; Fair | NA | Medium | Low | Low | NI | Medium | Low | Nearly a quarter (24%) of SBRT patients lacked pathologic confirmation of NSCLC; ROB stemming from this small study with some data collected retrospectively (70 SBRT patients).
Allibhai, 2013^259^; NA; Fair | NA | Low | Low | NI | NI | Low | High | There was no information on deviations from the intended SBRT therapy or on missing data reported in the article. Additionally, the only adverse event reported was radiation pneumonitis.
Anderson, 2009^150^; ELCAP; Fair | NA | Medium | Low | Low | Low | Medium | Low | Risk of selection bias and self-reported outcome
Arnold, 2017^199^; NCDB: 2003–2012; Fair | NA | Medium | Low | NI | Low | Low | Low | Risk of selection bias, as reported by the authors, and lack of information on deviations from treatment before entry into the study.
Badellino, 2017^270^; NA; Fair | NA | Low | Low | Low | NI | Medium | Medium | Risk for information and reporting bias related to the outcomes and no information on missing data.
Baine, 2019^232^; NCDB: 2004–2014; Fair | NA | Low | Low | NI | Low | Medium | Low | Risk of outcome measurement bias; lack of detail about systems for outcome ascertainment.
Ball, 2019^293^; CHISEL; Fair | NA | Medium | Low | Low | Low | Low | Medium | Risk of selection bias because nearly half (43%) of the SBRT sample had a history of previous cancer, and also risk of reporting bias because the trial protocol did not require the recording of toxicities occurring after local treatment failure
Barriger, 2012^290^; N/A; Fair | NA | Medium | Medium | NI | Medium | Medium | Low | Risk of selection bias; unclear how many patients had histologically confirmed NSCLC; ROB due to intervention classification because different treatment planning systems were used depending on the year of treatment; potential missing data bias because of the exclusion of patients with incomplete dosimetry data.
Baumann, 2006^227^; N/A; Fair | NA | Low | Low | NI | Low | Medium | Low | Risk of outcome measurement bias because of ascertainment methods used.
Berry, 2018^216^; California Cancer Registry: 2013–2014; Fair | NA | Medium | Low | NI | Low | Low | Low | Risk of selection bias; no detail was given about how patients’ cancers were staged; no information about potential deviation from intended surgeries.
Bibault, 2015^254^; NA; Fair | NA | Medium | Low | NI | NI | Low | Low | No information for multiple domains and risk of selection bias due to inclusion of patients with previous treatment of lung cancer (surgery and SBRT).
Bongers, 2011^286^; N/A; Fair | NA | Medium | Low | Low | Low | Medium | Low | Risk of outcome measurement bias; a “high proportion” of patients returned to their pulmonology outpatient clinics (number not reported) for longer-term followup; unclear how many patients or how their referring institutions collected data about chest wall toxicity that could be used in this analysis.
Brooks, 2017^204^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | Sparse information was reported for multiple domains; it is unclear what the data source was for survival outcomes.
Brunelli, 2015^181^; NA; Good | NA | Low | Low | NI | Low | Low | Low | NA
Bryant, 2018^196^; VINCI: 2006–2015; Fair | NA | Low | Medium | NI | Medium | Low | Low | Potential misclassification of surgical approach subtype or bias related to missing data.
Byrne, 2008^161^; PLuSS; Fair | NA | Medium | Low | Low | Medium | Medium | Low | Risk of selection bias, missing data, and outcome measurement
Chang, 2007^192^; SEER: 1988–1997; Fair | NA | Low | Low | NI | NI | Low | Low | No information from multiple domains.
Chang, 2012^282^; N/A; Fair | NA | Low | Low | Medium | NI | Low | Low | Deviation from the SBRT protocol for patients with centrally located tumors close to critical structures; no information about whether any patients were excluded during sample selection.
Chung, 2017^132^; NLST; Good | Low | Medium | Low | Low | Low | Low | Low | NA
Cox, 2003^154^; Mayo Lung Project; Fair | NA | Medium | Low | Low | Low | Medium | Low | Risk of selection and outcome measurement bias
Cox, 2017^186^; NCDB: 2003–2006; Fair | NA | Low | Low | NI | NI | NI | Low | No information reported for several ROB domains.
Crabtree/Timmeran, 2013,^265^ 2010^272^; RTOG 0236; Good | NA | Low | Low | Low | NI | Low | Low | NA
Crucitti, 2015^111^; “Un repiro per la vita”; Good | NA | Low | Low | Low | NI | Low | Low | NA
Cummings, 2018^233^; N/A; Fair | NA | Low | Low | NI | NI | Medium | Medium | Risk of outcome measurement bias due to ascertainment methods and a short followup period in the single-fraction SBRT arm; risk of selective outcome reporting bias in that Grade 1–2 toxicities were not recorded or reported.
Detillon, 2019^231^; Netherlands Cancer Registry; Fair | NA | Medium | Medium | NI | NI | Low | Low | Risk of selection bias in that nearly half of the sample (48%) lacked histological confirmation of NSCLC; no information reported about SBRT dosing used to treat the sample.
Dhanasopon, 2017^386^; NCDB, 2004–2013; Poor | Medium | High | Low | Low | High | Low | Low | Risk of selection bias due to confounding by indication, and bias due to missing data, in that some patients were excluded from the analysis for missing data, but the authors did not report how many.
Dunn, 2017^163^; UKLS; Fair | Medium | Medium | Low | Low | Low | Low | Low | Risk of confounding and selection bias.
Dziedzic, 2017^217^; Polish National Lung Cancer Registry; Fair | NA | Medium | Low | NI | Medium | Low | Low | Risk of selection bias in that a “significant number of patients” did not receive PET staging of their tumors; ROB due to exclusion of patients with missing or “inconsistent” data without details about the criteria for that process.
Eba, 2016^201^; NA; Fair | NA | Low | Low | NI | Low | NI | Medium | Lack of information on multiple domains; risk of reporting bias due to the identification of 3-yr OS as the primary endpoint but the reporting of results for 5-yr OS.
Ezer, 2018^273^; SEER: 2000–2009; Fair | NA | Low | Low | NI | NI | Low | Low | No information from multiple domains, including deviation from intended intervention and missing data.
Fair | NA | Low | Low | NI | NI | Medium | Low | Risk of outcome measurement bias that may have led to an underestimation of toxicity events due to the study’s short median followup time, reliance on retrospective review of hospital medical records for some ascertainment, and small sample (N=74 patients with 78 tumors).
Fernandez, 2012^188^; SEER-Medicare: 1998–2005; Fair | NA | Low | Low | NI | NI | Low | Low | No information on multiple domains.
Ferrero, 2015^262^; NA; Fair | NA | NI | Low | Low | Medium | Low | Low | Medium ROB due to missing data over the course of followup and no information on potential sources of selection bias.
Fischer-Valuck, 2013^281^; N/A; Fair | NA | Low | Low | Low | NI | NI | Low | No or minimal information on multiple domains.
Gareen, 2014^156^; NLST; Fair | NA | Medium | Medium | Low | Low | Low | Medium | Risk of selection bias because selection was related to outcome, but with adjustment. Potential for selective reporting bias in that results are inconsistent with a priori plan.
Goya, 2005^195^; Japanese Joint Committee of Lung Cancer Registry; Fair | NA | Medium | Low | NI | Low | NI | Low | Potential selection bias as the type of hospital may be related to survival outcomes; little information reported about the source(s) of the data from individual hospitals.
Grills, 2012^256^; NA; Fair | NA | Medium | Medium | Low | NI | Low | Low | Risk of selection and intervention classification bias across multiple institutions; lack of information on missing data; unclear how harms were included or excluded in the reporting
Guckenberger, 2013^280^; N/A; Fair | NA | Medium | Low | NI | Medium | Medium | Low | Risk of selection bias because the study may have included patients with secondary tumors; exclusion of one of 13 centers from the toxicity analysis may have introduced bias related to missing data; risk of measurement bias because not all participating centers had in-house databases for managing the data of SBRT patients; no information about adherence to SBRT protocols.
Guerrera, 2015^171^; NA; Fair | NA | Low | Low | Low | NI | NI | Low | Lack of information for several domains.
Haasbeek, 2010^291^; N/A; Fair | NA | Medium | Low | Low | NI | Medium | Low | Risk of selection bias in that majority of sample (61%) lacked histological confirmation of NSCLC; risk of outcome measurement bias due to a short median followup period and some reliance on referring lung physicians or GPs for the toxicity data of patients opting out of followup at the study center.
Haidar, 2014^257^; NA; Fair | NA | Low | Low | Low | Medium | Low | Low | Some missing data related to pathologic confirmation of disease.
Handa, 2018^218^; N/A; Fair | NA | Low | Low | NI | NI | Medium | Low | Risk of outcome measurement bias because of reliance on a single hospital’s existing data; no information from multiple domains.
Henschke, 2006^128^; I-ELCAP; Fair | NA | Medium | Low | Low | Medium | Low | Low | Patient selection, decreased patients in annual screening
Henschke, 2006^129^; I-ELCAP; Fair | NA | Medium | Low | Low | Low | Low | Low | Risk of selection bias
Henschke, 2006^131^; I-ELCAP; Fair | NA | Medium | Low | Low | Low | Low | Low | Risk of selection bias
Henschke, 2013^107^; I-ELCAP; Good | NA | Low | Low | Low | Low | Low | NI | NA
Heuvelmans, 2015^325^; NELSON; Fair | NA | Low | Low | Low | Low | Medium | Medium | Risk of outcome measurement bias; unclear if assessments were done with knowledge of patient’s position in study; risk for selective reporting bias.
Husain, 2015^239^; NCDB: 2003–2011; Fair | NA | Low | Low | Low | NI | Low | Medium | No information on missing data and potential for reporting bias with limited harms data reported.
Infante, 2011^140^; DANTE; Fair | NA | Medium | Low | Low | Low | Low | Medium | Risk of selection bias because enrollment was related to outcome; risk of outcome measurement bias because unclear if assessment done with knowledge of patient’s position in study; risk of selective reporting bias in that outcomes were inconsistent with a priori plan.
Inoue, 2013^224^; N/A; Fair | NA | Low | Low | Low | NI | Medium | Low | Risk of outcome measurement bias with short followup period for survival outcomes; no information about missing data.
Jeon, 2018^268^; NA; Fair | NA | Low | Low | Low | NI | Low | Low | No information related to missing data. Authors retrospectively analyzed data that seemed to have been collected prospectively, but there is minimal description of the data ascertainment methods employed.
Jeppesen, 2013^223^; N/A; Fair | NA | Medium | Low | NI | NI | Low | Low | Missing information about multiple domains. Risk for selection bias in that some patients may have had Stage II cancer, depending on which classification system the investigators applied to the sample.
Jeppesen, 2018^203^; NA; Fair | NA | Low | Low | Low | NI | Medium | Medium | No information on missing data and potential for information bias related to outcomes, which were ascertained from medical records and only selectively reported.
Kaerlev, 2012^157^; DLCST; Good | NA | Low | Low | Low | Low | Low | Low | NA
Karasawa, 2018^229^; N/A; Fair | NA | Low | Low | Low | Medium | Medium | Low | Risk of bias from exclusion of 33% of eligible SBRT patients because of a dose difference due to a difference in calculation method; risk of outcome measurement bias.
Katoh, 2017^255^; NA; Fair | NA | Low | Low | Low | NI | Low | Medium | No information on missing data and very little information was provided on harms, except radiation pneumonitis, other than reporting that 1 grade 2 dermatitis and 10 grade 2 thoracic wall pain cases, no other toxicities were reported; data were not presented for Stage 1 patients only.
Khullar, 2015^178^; NCDB: 2003–2006; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information for multiple domains.
Khullar, 2015^189^; NCDB: 2003–2011; Fair | NA | Low | Low | NI | Medium | NI | Low | No information for several ROB domains. Patient characteristics are presented for the entire cohort of patients but not the subcohort that contributed to the long-term survival analyses.
Kinsinger, 2017^38^; VA Population (LCSDP); Fair | NA | Medium | NI | NI | Low | NI | Low | Risk of selection bias because not all eligible patients (veterans) participated
Koshy, 2015^200^; NCDB: 2003–2006; Fair | NA | Medium | Low | Low | NI | Low | Low | Risk of selection bias (only 64% of patients receiving SBRT were included) and lack of information related to missing data.
Lagerwaard, 2008^292^; N/A; Fair | NA | Medium | Low | Low | NI | Medium | Low | Risk of selection bias because most patients lacked histopathological confirmation of NSCLC; unclear how many of the 18% of patients with a prior lung cancer were actually experiencing a secondary tumor or recurrence (vs. a primary tumor); risk of outcome measurement bias due to short median followup period and at least some reliance on referring lung physicians or GPs for toxicity data of patients opting out of followup at the study center.
Lagerwaard, 2012^283^; N/A; Fair | NA | Low | Low | Low | Medium | Medium | Low | Risk of bias due to missing data that may have affected toxicity results; HRQOL data were missing for a large percentage of patients at 18- and 24-month time points; unclear how many patients were missing toxicity data, but the reasons for attrition, such as patients returning to their local hospitals, likely also reduced the availability of toxicity data.
Lagerwaard, 2012^225^; N/A; Fair | NA | Medium | Low | Low | NI | Medium | Low | Risk of selection bias in that probable operability of patients for selection into study was determined post hoc; risk of outcome measurement bias because investigators relied on referring physicians for toxicity data for an unknown number of patients opting out of followup at the study center.
Lakha, 2014^175^; SEER: 2004–2010; Fair | NA | Low | Low | NI | NI | Low | Low | No information on multiple domains.
Lam, 2018^202^; NCDB: 2004–2014; Fair | NA | Low | Low | NI | NI | NI | Low | No information provided related to several domains.
Landreneau, 2014^176^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information related to intervention deviation and missing data. The analysis was among propensity-score matched groups defined by surgical approach; this isn’t a selection bias but might impact generalizability (e.g., unmatched had surgery earlier than matched, were less likely to have COPD, and had larger tumors).
Lee, 2015^387^; RegulomeDB; Poor | NA (KQs 6 & 7) | NI | NI | NI | NI | NI | NI | Uncontrolled study with very little information reported that was relevant to ROB assessment.
Lee, 2018^234^; N/A; Fair | NA | Low | Low | NI | Medium | Medium | Low | ROB due to exclusion of patients not followed up at the study’s hospital, and also potential outcome measurement bias due to the post hoc nature of the analysis.
Licht, 2013^249^; DLCR: 2007–2011; Fair | NA | Medium | Low | Low | Low | Low | Low | Risk of selection bias because authors only included standard lobectomies in the study in an “attempt to make VATS and thoracotomy groups more comparable.” Authors did not provide their definition of a nonstandard lobectomy.
Lindberg, 2015^207^; NA; Fair | NA | Low | Low | Low | NI | Low | Low | Lack of information on missing data.
Liu, 2018^219^; SEER: 2000–2013; Fair | NA | Low | Low | NI | Medium | Low | Low | ROB due to missing data because patients were excluded for missing examinable lymph node counts and clinical features.
Louie, 2016^238^; STS-GTS: 2009–2013; Fair | NA | Medium | Low | Low | NI | NI | Low | No information for multiple domains and potential selection bias resulting from exclusion of cases from low-volume centers.
Lutz, 2019^220^; N/A; Fair | NA | Low | Low | NI | Low | Medium | Low | No information on intervention deviation; risk of outcome measurement bias because no statistical methods or adjustments were used to explore the impact of including 140 patients (22.5% of the 621 in the study sample) who were upstaged in the analysis.
Lv, 2018^221^; SEER: 2004–2014; Fair | NA | Low | Low | NI | NI | Low | Medium | No information from multiple domains; risk of reporting bias because the study’s only eligible survival data, 5-year OS, were reported for the total sample, not the lobectomy or SLR arms, for which overall survival curves were compared.
Ma, 2017^269^; NA; Fair | NA | Low | Low | NI | NI | Low | Medium | Medium risk of reporting bias due to certain data points not being collected and no information on multiple other domains.
Maeda, 2010^191^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | No information on multiple domains.
Maeda, 2012^184^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | No information on multiple domains.
Manyam, 2019^230^; N/A; Fair | NA | Low | Low | Low | NI | Medium | Low | Risk of outcome measurement bias for 5-year OS due to a short followup period (median 23.8 months).
Mascalchi, 2006^136^; ITALUNG; Fair | NA | Medium | Low | Low | Low | Low | Low | Risk of selection bias
Mathieu, 2014^260^; NA; Fair | NA | Low | Low | Low | Medium | Low | Medium | ROB related to exclusion of patients with disease recurrence from analysis and reporting of only some toxicities.
Matsuo, 2012^285^; N/A; Fair | NA | Low | Low | Low | NI | Medium | Low | No information on missing data; risk of outcome measurement bias in that the analysis was based on post hoc ascertainment.
Matsuo, 2014^198^; NA; Fair | NA | Medium | Low | NI | NI | Low | Low | No information for multiple domains and some concern over selection of patients given that the original trial was stopped early due to slow patient enrollment.
Mediratta, 2014^177^; NA; Good | NA | Low | Low | NI | Low | Low | Low | NA
Melvan, 2015^243^; NCDB: 2003–2011; Fair | NA | Low | Low | NI | Medium | Low | Low | Medium ROB related missing data and no information on intervention deviation.
Menezes, 2010^121^; NA; Fair | NA | Medium | Low | Low | Medium | Low | Low | Unclear selection, poor followup after 1st annual screening
Miura, 2015^388^; NA; Poor | NA | High | Low | Low | NI | Low | Low | Restricting the study sample to patients with at least 12 months of followup CT scans after SBRT (i.e., a minimum of 4 followup scans) introduces a high risk of selection bias; unclear why this criterion was applied since all radiation-induced rib fractures after the first day of SBRT were included; unclear how many cases of rib fractures were missed as a result of the exclusion. Additionally, more than half of the patients had multiple cancers (some lung, some other sites).
Moon, 2018^214^; SEER: 2000–2014; Fair | NA | Low | Medium | NI | NI | Low | Low | ROB due to intervention classification in that it was unclear how many segmentectomy patients received “intentional” vs. “compromised” procedures based on their comorbidities, and potential bias due to lack of information about missing data.
Morgan, 2017^167^; NA; Fair | NA | Medium | NI | Low | Low | Low | Low | Risk of selection bias.
Mutter, 2012^287^; N/A; Fair | NA | Low | Low | Low | NI | Medium | Low | Risk of outcome measurement bias in that median followup time (16 months) was shorter than the median time to rib fracture diagnosis (27 months).
Nagata, 2015^205^; JCOG0403; Fair | NA | Low | Low | NI | NI | Medium | Medium | Long-term followup methods unclear, lack of information on missingness of data, and potential reporting bias related to grade 1–2 harms.
Nakamura, 2015^173^; NA; Fair | NA | Low | Low | NI | NI | NI | Medium | Post hoc analysis focused on intraoperative blood loss and lack of information on multiple domains.
Nguyen, 2016^166^; NLST; Fair | NA | Low | Low | Low | Low | NI | Low | Medium risk of selection bias due to possible healthy-volunteer bias, and potential outcome measurement bias because definition of “potentially significant” extrapulmonary findings was left up to radiologists interpreting CT scans to decide.
Nyman, 2016^267^; SPACE^†^; Fair | NA | Low | Low | Medium | Medium | Low | Low | A small percentage of patients did not receive SBRT as intended, data sources are unclear, and there is some missing data, though it is not thoroughly described.
Okada, 2006^193^; NA; Fair | NA | Low | Low | Medium | NI | Low | Low | ROB related to deviations from intended surgical approach and unknown attrition/missing data.
Olsen, 2011^288^; N/A; Fair | NA | Low | Low | Low | NI | Medium | Low | Risk of outcome measurement bias in that median followup time (range of 11 to 16 months) was short and may not have been enough time for some toxicity events to occur.
Onishi, 2007^226^; N/A; Fair | NA | Low | Low | NI | NI | Medium | Low | Potential risk of outcome measurement bias due to post hoc use data from 14 different hospitals. Missing information on multiple domains.
Palma, 2010^289^; Amsterdam Cancer Registry; Fair | NA | Medium | Medium | NI | NI | Medium | Low | Risk of selection bias due to lack of histologic confirmation of NSCLC among 33% of RT patients (and unknown proportion of those receiving SBRT). At least some risk of intervention misclassification because no dosing information was available for RT treatments given. Post hoc analysis of data from population-based registry. No information for several domains.
Pegna, 2013^99^; ITALUNG; Good | NA | Low | Low | Low | Low | Low | Low | NA
Pinsky, 2014^64^; NLST; Fair | NA | Low | Low | Low | Low | Low | Medium | Post hoc analysis
Pinsky, 2015^100^; NLST; Fair | NA | Medium | Low | NI | NI | Medium | Low | Medium risk of outcome measurement bias because of difference in how radiologists were instructed to assess nodule growth using Lung-RADS criteria vs. NLST criteria. They applied Lung-RADS criteria in a post-hoc fashion to patients previously screened using NLST criteria, which created the potential for discrepancy in terms of how nodes discovered at baseline were later classified as having growth during post-baseline scans. A sensitivity analysis was done assuming that all nodules reported with growth in NLST met Lung-RADS criteria for growth, but that assumption may have been incorrect in at least some cases.
Puri, 2014^242^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information for multiple domains. This is a post hoc analysis of two trial datasets that prospectively collected data.
Puri, 2015^252^; NCDB: 1998–2010; Fair | NA | Medium | Low | Medium | NI | Low | Medium | Risk of selection bias in terms of the patients that completed followup; authors were unable to explain the large difference in median survival between the surgical and SBRT groups. No information provided on missingness of data. Author utilized propensity-score matching to compare surgery to SBRT, but results were only presented for surgery overall and SLR.
Pinsky, 2018^139^; NLST; Fair | Medium | Low | Low | Low | Low | Medium | Low | Post hoc analysis of NLST RCT, looking at intervention arm of study.
Rampinelli, 2017^134^; COSMOS; Fair | Yes | Low | Low | Low | NI | NI | NI | Bias due to the source of harms data; data on the harm of radiation-induced cancer from LDCT program were estimated (not measured) based on an assumed relationship (which in turn is based on data from other studies of radiation therapy) that appears to be controversial.
Razi, 2016^180^; SEER: 1998–2007; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information for multiple domains.
Robinson, 2013^266^; NA; Fair | NA | Low | Low | NI | NI | NI | Low | There was no information for several domains.
Rosen, 2014^244^; NCDB: 2004–2009; Fair | NA | Low | Low | NI | Medium | Low | Low | Medium ROB related to missing data (both in terms of how missingness of some variables resulted in exclusion from study and in unknown stage data) and lack of information on intervention deviation.
Rosen, 2014^258^; NA; Fair | NA | Low | Low | Low | NI | Low | Medium | Risk of reporting bias and lack of information on missing data.
Rosen, 2016^185^; NCDB: 2008–2012; Good | NA | Low | Low | Low | NI | Low | Low | NA
Samson, 2015^240^; NCDB: 1998–2010; Washington SOM 2000–2012; Fair | NA | Low | Low | NI | NI | NI | Low | Lack of information for several domains.
Samson, 2017^245^; NCDB: 2004–2013; Fair | NA | Medium | Low | NI | NI | Low | Low | Medium risk of selection bias and lack of information on several additional domains.
Sawabata, 2011^190^; Japanese Joint Committee of Lung Cancer Registry; Fair | NA | Low | Low | NI | Low | NI | Low | No information for multiple domains and few details provided by the authors, except as they related to tumor characteristics.
Scheel, 2015^170^; NA; Fair | NA | Low | Low | Low | NI | Medium | Low | No information on extent of missing data and potential for outcome misclassification.
Schuchert, 2012^248^; NA; Fair | NA | Medium | Low | NI | NI | Low | Low | Patients were identified from multiple databases, including billing records. Authors report that patients who received incomplete resections were not included; if incomplete resection is associated with poorer outcomes, there could be selection bias present. Lack of information related to several other domains.
Sekihara, 2018^222^; N/A; Fair | NA | Low | Low | NI | NI | Medium | Low | Risk of outcome measurement bias in that the study relied on a post hoc analysis of a single hospital’s data, and no information from multiple domains.
Shapiro, 2012^247^; SEER: 1992–2002; Fair | NA | Low | Low | NI | Medium | Low | Low | Medium ROB related to missing data.
Shibamoto, 2012^236^; N/A; Good | NA | Low | Low | Low | Low | Low | Low | NA
Shirvani, 2012^237^; SEER: 2001–2007; Fair | NA | Low | Low | NI | NI | Low | Low | No information on multiple domains.
Shirvani, 2014^241^; SEER: 2003–2009; Fair | NA | Medium | Low | Low | NI | Low | Low | Risk of selection bias resulting from exclusion of patients with incomplete Medicare records. Lack of information on missing outcomes data.
Speicher, 2016^187^; NCDB: 2003–2006; Fair | NA | Low | Low | NI | Medium | NI | Low | No information for several ROB domains. Patient characteristics are presented for the entire cohort of patients but not the subcohort that contributed to the long-term survival analyses.
Stanic, 2014^279^; RTOG 0236; Fair | NA | Medium | Low | NI | Medium | Medium | Low | Risk of self-selection bias indicated by fact that most of the sample was female when majority of NSCLC patients in the population are male. Potential bias from missing data for PFT outcomes due to test noncompliance at each timepoint of interest. Potential bias from outcome measurement for PFT outcomes in that large variation occurred in the timing of assessments.
Stephens, 2014^182^; NA; Fair | NA | Low | Low | Medium | NI | Low | Low | ROB related to patients who crossed over from one surgical approach to another and lack of information related to missing data.
Stokes, 2018^251^; NCDB: 2004–2013; Fair | NA | Medium | NI | NI | Low | NI | Low | No information provided related to several domains. Missing data informed selection of patients into the analysis (i.e., complete case analysis).
Strand, 2006^194^; Cancer Registry of Norway; Good | NA | Low | Low | Low | Low | Low | Low | NA
Styn, 2009^151^; PLuSS; Fair | NA | Medium | Low | Low | Low | Medium | Low | Potential bias from outcomes and patient selection.
Su, 2014^174^; ACOSOG Z0030 (Alliance); Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information on several domains.
Sun, 2017^197^; NA; Fair | NA | Medium | Low | Low | Low | NI | Low | Risk of selection bias with respect to inclusion of patients with a prior history of lung or other cancers. Additionally, 5% of the enrolled patients had no followup imaging or records and were not included in the analysis.
Swensen, 2002^168^; NA; Fair | NA | Medium | Low | Low | Low | Low | Low | Potential bias from patient selection.
Swensen, 2005^130^; NA; Fair | NA | Medium | Low | Low | Medium | Low | Low | Potential bias from patient selection and missing data.
Taremi, 2012^261^; NA; Fair | NA | Medium | Low | NI | NI | Low | Low | Medium risk of selection bias related to short followup periods and lack of information related to missing data.
Taremi, 2012^264^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information for multiple domains.
Thalanayar, 2015^143^; PLuSS; Fair | NA | Medium | Low | Low | Low | Medium | Low | Potential bias due to patient selection and outcome.
Townsend, 2005^152^; Mayo Lung Project; Fair | NA | Medium | Low | Low | Medium | Medium | Low | Possible selection, outcome and missing data bias as listed.
Toyoda, 2008^126^; NA; Fair | NA | Medium | Low | Low | Low | Low | Low | Potential bias due to patient selection.
Tsushima, 2008^123^; NA; Fair | NA | Medium | Low | Low | Low | Low | Low | Potential bias due to patient selection.
Tsutani, 2014^179^; NA; Good | NA | Low | Low | NI | Low | Low | Low | NA
Ubels, 2015^206^; NA; Fair | NA | Medium | Low | NI | NI | Low | Low | Lack of information for multiple domains. The study included a small number of patients; almost 10% of them were excluded after enrollment for reasons that may be associated with poorer outcomes.
Ueda, 2018^274^; N/A; Fair | NA | Low | Low | NI | NI | Medium | Low | No information in multiple domains; risk of outcome measurement bias because ECG was inconsistently used to identify POAF, the study’s primary outcome of interest, and more broadly, this was a small post hoc analysis of a single hospital’s data.
Uhlig, 2018^228^; NCDB: 2004–2013; Fair | NA | Low | Low | NI | Low | Medium | Low | Risk of outcome measurement bias due to the post hoc nature of the analysis and lack of detail about systems for outcome ascertainment.
Valle, 2016^246^; NCCN: 2007–2011; Fair | NA | Medium | Low | NI | Medium | NI | Low | Risk of selection bias and bias due to missing data; no information provided for additional domains.
Veronesi, 2008^124^; COSMOS; Fair | NA | Medium | Low | Low | Low | Low | Low | Risk of patient selection bias.
Veronesi, 2008^127^; COSMOS; Fair | NA | Medium | Low | Low | Low | Low | Low | Risk of selection bias.
Veronesi, 2012^135^; COSMOS; Fair | Medium | Low | Low | Low | Medium | Medium | Medium | ROB likely affects the size of effects this study demonstrates: namely, that (for scenario A) greater VDT is associated with lower LC mortality (and likely overdiagnosis), as well as for scenario B) that LDCT screening finds indolent lesions, i.e., those with long VDT. Sources of bias include confounding, missing data, outcomes measurement, and selective reporting.
Videtic, 2014^271^; NA; Fair | NA | Medium | Low | Low | NI | Low | Low | Risk of selection bias and lack of information on missingness of data.
Wagnetz, 2012^118^; NA; Fair | NA | Medium | Low | Low | NI | Low | Low | Risk of selection bias and no information on missing data.
Walker, 2015^133^; NA; Fair | NA | Medium | Low | Low | Low | Low | Low | ROB due to patient selection.
Walter, 2016^78^; NELSON; Good | NA | Low | Low | Low | Low | Low | Low | NA
Westover, 2012^284^; N/A; Fair | NA | Low | Low | Low | Low | Medium | Low | Medium risk of outcome measurement bias; study relied on a database and drew data from a very small sample of 15 patients.
Wilson, 2008^137^; PLuSS; Fair | NA | Medium | Low | Low | Low | Low | Low | ROB due to patient selection.
Wink, 2019^235^; N/A; Fair | NA | Medium | Medium | NI | NI | Medium | Low | Missing information for multiple domains; post hoc analysis with short followup period for 5-year OS (median 48.1 months for surviving patients); risk of outcome measurement bias; OS data were retrieved from national databases, and unclear how comprehensively they captured mortality; risk of selection bias because majority (68%) of sample did not have histologic confirmation of NSCLC; variation in how SBRT was planned across the study’s treating institutions.
Yang, 2016^250^; NCDB: 2010–2012; Fair | NA | Low | Low | NI | NI | NI | Low | No information on multiple domains. Authors report that outcomes of surgical approach were evaluated with intent-to-treat analysis but provide no additional information.
Ye, 2018^294^; N/A; Fair | NA | Medium | Low | Low | NI | Low | Low | Risk of selection bias in that nearly a fifth (19%) of SBRT patients lacked pathologic confirmation of NSCLC.
Yousaf-Khan, 2017^389^; NELSON; Poor | Low | Medium | Low | Low | Medium | Low | Low | High risk of self-selection bias for the fourth round of screening, the focus of this substudy. Enrollment of 78% of eligible patients from 3rd round of screening (about 70% of initial sample) and confirmation in the article that the fourth round’s patients differed significantly from the initial sample in several ways (e.g., more current smokers in the fourth round).
Zhai, 2014^172^; NA; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information for several domains.
Zhao, 2014^109^; NELSON; Fair | NA | Low | Low | Medium | Low | Low | NI | This longitudinal study did not apply the same imaging followup protocol to all patients in terms of the intervals between scans.
Zhao, 2017^183^; SEER: 2004–2012; Fair | NA | Low | Low | NI | NI | Low | Low | Lack of information related to several domains.
Zhou, 2015^390^; Mass General Hospital Database; Poor | NA | High | Low | NI | Medium | NI | Medium | High risk of selection bias, medium ROB related to missing data/patient attrition and reporting of harms (i.e., ‘complications’), and lack of information on additional domains.
Zhou, 2018^215^; SEER: 2004–2013; Fair | NA | Medium | Low | NI | Low | Low | Low | Risk of selection bias because no detail was given about how patients’ cancers were staged, and no information about potential deviation from intended interventions.

* Bias due to confounding did not apply to KQ6/7 studies.

† Only the SBRT arm of the study was eligible for this review.

Abbreviations: ACOSOG=American College of Surgeons Oncology Group; CHISEL=A Randomised Phase III Trial of Highly Conformal Hypofractionated Image Guided (“Stereotactic”) Radiotherapy (HypoRT) Versus Conventionally Fractionated Radiotherapy (ConRT) for Inoperable Early Stage I Non-small Cell Lung Cancer; COPD=chronic obstructive pulmonary disease; COSMOS=Continuous Observation of Smoking Subjects study; CT=computed tomography; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology trial; DLCR=Danish Lung Cancer Registry; ECG=electrocardiogram; GP=general practitioner; HRQOL=health-related quality of life; I-ELCAP=International Early Lung Cancer Action Project; ITALUNG=The Italian Lung Study; JCOG=Japan Clinical Oncology Group; KQ=Key Question; LC=lung cancer; LDCT=low-dose computed tomography; LCSDP=Lung Cancer Screening Demonstration Project; Lung-RADS=ACR Lung Imaging Reporting and Data System; NA=not applicable; NCCN=National Comprehensive Cancer Network; NCDB=National Cancer Database; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NI=no information; NLST=National Lung Screening Trial; OS=overall surgery; PFT=pulmonary function test; POAF=postoperative atrial fibrillation; RCT=randomized, controlled trial; ROB=risk of bias; RT=radiotherapy; RTOG=Radiation Therapy Oncology Group; SBRT=stereotactic body radiation therapy; SEER=Surveillance, Epidemiology, and End Results; SLR=sublobar resection; SOM=School of Medicine; SPACE=Stereotactic Precision And Conventional Radiotherapy Evaluation; STS-GTS=Society of Thoracic Surgeons General Thoracic Surgery Database; VATS=video-assisted thoracoscopic surgery; VDT=volume doubling time; VINCI=Veteran’s Affairs Informatics and Computing Infrastructure; vs.=versus.

Appendix D Table 2 Risk of Bias and Overall Quality Assessment Ratings for Randomized Studies: Part 1

First Author, Year; Study Name; Quality Rating | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | Eligibility criteria specified? | Were outcome measurements equal, reliable and valid? | Were outcome accessors masked? | Were care providers masked? | Were Patients masked?
Aberle, 2011^32^; NLST; Good | Yes | Yes | Yes | Yes | Yes | LC mortality: Yes; LC incidence: unclear (but likely) | Unclear (but unlikely) | No
Aberle, 2013^58^; NLST; Good | Yes | Yes | Yes | Yes | Yes | LC mortality: Yes; LC incidence: Unclear (but likely) | Unclear (but unlikely) | No
Aggestrup, 2012^160^; DLCST; Fair | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Ashraf, 2009^145^; DLCST; Fair | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Ashraf, 2014^147^; DLCST; Good | Yes | Unclear | Yes | Yes | Yes | Unclear (but unlikely to bias smoking cessation) | Unclear (but unlikely to bias smoking cessation) | No
Becker, 2012^60^; LUSI; Good | Yes | Unclear | Yes | Yes | Yes | NR | No (but unlikely to bias baseline screening results) | No
Becker, 2015^59^, 2019^73^; LUSI; Fair | Yes | Unclear | Yes | Yes | Yes | NR | No | No
Brain, 2016^391^; UKLS; Poor | Yes | Yes | Yes | Yes | Yes | NR | No | No
Brain, 2017^392^; UKLS; Poor | Yes | Yes | Yes | Yes | Unclear | Not reported | No | No
Church, 2013^57^; NLST; Good | Yes | Yes | Yes | Yes | Yes | LC mortality: Yes; LC incidence: Unclear (but likely) | Unclear (but unlikely) | No
Clark, 2016^149^; NLST; Fair | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear (but unlikely) | No
Croswell, 2010^119^; NA; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
De Koning, 2020^76^ | Yes^*^ | Yes^*^ | Yes | Yes | Unclear | Yes | Unclear | No
Field, 2016^97^; UKLS; Fair | Yes | Unclear | Yes | Yes | No | Unclear | Unclear | No
Field, 2016^117^; UKLS; Fair | Yes | Yes | Yes | Yes | Yes | NR | No | No
Gohagan, 2004^70^; LSS; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
Gohagan, 2005^69^; LSS; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
Heleno, 2018^141^; DLCST; Fair | Yes | NR | Mostly (slightly higher risk) | Yes | Yes | NR | No | No
Horeweg, 2013^98^; NELSON; Poor | Yes | Unclear | Yes | Yes | Yes | Unclear | Unclear | No
Horeweg, 2014^33^; NELSON; Poor | Yes | Unclear | Yes | Yes | Yes | Unclear | Unclear | No
Infante, 2008^72^; DANTE; Fair | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Infante, 2009^71^; DANTE; Fair | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Infante, 2015^61^; DANTE; Fair | Yes | No | Yes | Yes | Yes | Unclear | Unclear | No
Lopes Penga, 2009^125^; ITALUNG; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
National Lung Screening Trial Research Team, 2019^74^; NLST; Fair | Yes | Yes | Yes | Yes | Unclear; ascertainment methods differed for trial years (when outcome verification committee was involved) and post-trial years | Unclear | Unclear (but unlikely) | No
O’Grady, 2014^169^; PLCO, NLST; Good | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Paci, 2017^62^; ITALUNG; Fair | Yes | Yes | Yes | Yes | Yes | Yes | No | No
Pastorino, 2012^80^ and 2019^75,^ ^81^; MILD; Poor | No | Unclear | No | Yes | Unclear | Unclear | No | No
Patz, 2014^142^; NLST; Fair | Yes | Yes | Yes | Yes | Yes | Yes | No | No
Pedersen, 2009^122^; DLCST; Good | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Pinsky, 2005^393^, Doroudi, 2018^75^; LSS; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
Pinsky, 2013^63^; NLST; Fair | Yes | Yes | Yes | Yes | Yes | Yes | No | No
Rasmussen, 2014^158^; DLCST; Fair | Yes | Yes | Yes | Yes | Yes | Yes | No | No
Saghir, 2012^65^; DLCST; Fair | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Sverzellati, 2016^82^; MILD; Fair | Yes (for annual vs. Biennial) | Unclear | Yes | Yes | Yes | Unclear | No | No
Tanner, 2015^66^; NLST; Fair | Yes | Yes | Yes | Yes | Yes | Yes | No | No
Taylor, 2007^155^; NLST/LSS; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
van den Bergh, 2010^162^; NELSON; Fair | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
van den Bergh, 2011^159^; NELSON; Fair | Yes | Yes | Yes | Yes | Unclear | Yes | No | No
van der Aalst, 2010^148^; NELSON; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
van der Aalst, 2011^153^; NELSON; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
van Klaveren, 2009^120^; NELSON; Good | Yes | Yes | Yes | Yes | Yes | No | No | No
van’t Westeinde, 2012^138^; NELSON; Fair | Yes | Yes | Yes | Yes | Yes | No | No | No
Videtic, 2015^263^; RTOG 0915; Fair | Unclear | Unclear | Unclear | Yes | Yes | Unclear | No | No
Wille, 2016^67^; DLCST; Good | Yes | Yes | Yes | Yes | Yes | Unclear | No | No
Young, 2015^144^; NLST; Fair | Yes | Yes | Yes | Yes | Yes | Yes | No | No

* Details of randomization and allocation concealment were not published but were obtained by written personal communication from the first author. In short, all invited persons were given an 8-character random number by an external consultant. For persons responding with informed consent, these personal identification numbers were shifted by 1–8 positions (blindly, randomly computer generated), and then sorted again (ascending numbers) to be randomized. No investigator had control nor insight into this random process, and it also ensured that the consultant could not influence this process.

Abbreviations: CT=computed tomography; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology trial; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=The Italian Lung Study; LC=lung cancer; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multicentric Italian Lung Detection trial; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NLST=National Lung Screening Trial; NR=Not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; RTOG=Radiation Therapy Oncology Group; UKLS=UK Lung Cancer Screening trial; vs.=versus

Appendix D Table 3 Risk of Bias and Overall Quality Assessment Ratings for Randomized Studies: Part 2

First Author, Year; Study Name; Quality Rating | What was the reported adherence to the intervention? | Did the study have crossovers or contamination? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition >10% or overall high attrition, raising concerns for bias?
Aberle, 2011^32^; NLST; Good | CT: 95%; CXR: 93% | Minimal (average annual rate of CT in CXR group: 4.3%) | Average over three screening rounds: 6.1% | Average over three screening rounds:; LDCT: 5%; CXR: 7%; T0:; LDCT: 1.5%; CXR: 2.6%; T1:; LDCT: 6.0%; CXR: 8.8%; T2:; LDCT: 7.1%; CXR: 10.6% | No
Aberle, 2013^58^; NLST; Good | T1:; LDCT: 94%; CXR: 91.2%; T2:; LDCT: 92.9%; CXR: 89.4% | NR for T1 and T2 screens; over three rounds, 4.3% (per Aberle 75) | Overall:; T1: 7.4%; T2: 8.8% | T1:; LDCT: 6.0%; CXR: 8.8%; T2:; LDCT: 7.1%; CXR: 10.6% | No
Aggestrup, 2012^160^; DLCST; Fair | 94.3% | NR | 5.6% | CT: 2.9%; Control: 8.2% | No
Ashraf, 2009^145^; DLCST; Fair | NR | NR | 8.3% | CT: 5.3%; Control: 11.6% | 11.6% of the control group had missing data
Ashraf, 2014^147^; DLCST; Good | Year 5: 89%; CT: 90%; Control: 89%; (Higher for years 1–4) | Yes | Year 5: 14.6% | CT: 6%; Control: 12% | No; Sensitivity analysis complete case vs. imputation LOCF same results
Becker, 2012^60^; LUSI; Good | CT: 99.9%; Control: 99.9% | No (baseline screen) | 0% (baseline screen) | None | No
Becker, 2015^59^, 2019^73^; LUSI; Fair | Year 3:; CT: 93.4%; Control: 94.5%; Year 2:; CT: 94.6%; Control: 91.5%; Year 1:; CT: 99.9%; Control: 99.9% | NR | Over five years: 0.1% - 6.9% | Year 3:; CT: 6.6%; Control: 5.5%; Year 2:; CT: 5.4%; Control: 8.5%; Year 1:; CT: 0.1%; Control: 0.1% | No
Brain, 2016^391^; UKLS; Poor | For psychosocial outcomes, adherence to followup surveys:; T0: 99.9%; T1:; CT: 84%; Control: 78%; T2:; CT: 82%; Control: 65% | NR | For psychosocial outcomes:; T0: 0.01%; T1:; CT: 16%; Control: 22%; T2:; CT: 18%; Control: 35% | Psychosocial outcomes:; T0: 0.01%; T1:; CT: 16%; Control: 22%; T2:; CT: 18%; Control: 35% | Yes
Brain, 2017^392^; UKLS; Poor | For smoking cessation outcomes, adherence to followup surveys:; T1: 65%; T2: 57% | NR | T1: 35%; T2: 43% | T1:; CT: 31%; Control: 39%; T2:; CT: 35%; Control: 51% | Yes
Church, 2013^57^; NLST; Good | 98% | NR for baseline scree, over three rounds, 4.3% (per Aberle 75) | 2% | LDCT: 1.5%; CXR: 2.6% | No
Clark, 2016^149^; NLST; Fair | NR for this subset of ACRIN centers; likely >90% given overall study adherence | NR for ACRIN centers subset; but for overall study 4.3% | NR for ACRIN center subset; likely similar to overall study | NR | No
Croswell, 2010^119^; NA; Fair | 84.2% | NR | 15.8% | CT: 15.8% | Yes
De Koning, 2020^76^ | 90% among men for all rounds (95.8% for round 1 of screening); NR for women | Unclear | Missing data <2% for the primary outcome from linkages with national registries | <2% | No
Field, 2016^97^; UKLS; Fair | 98.30% | NR | 1.70% | Unclear | Unclear
Field, 2016^117^; UKLS; Fair | 98% | NR | For psychosocial outcomes:; T0: 0.01%; T1:; CT: 16%; Control: 22%; T2:; CT: 18%; Control: 35% | For psychosocial outcomes:; Baseline: 0%; T1 (2 weeks after LDCT or control notification): 6%; T2 (10–27 months): 17% | T1: No; T2: Yes
Gohagan, 2004^70^; LSS; Fair | 95.5% | 0.90% | 4.5% | CT: 4.5% | No
Gohagan, 2005^69^; LSS; Fair | 85.8% | NR | 14.2% | CT: 14.2% | Yes
Heleno, 2018^141^; DLCST; Fair | NR | Yes | NR | NR | No
Horeweg, 2013^98^; NELSON; Poor | For all three waves: ~90–95% | Unclear | 3.80% | Unclear | Unclear
Horeweg, 2014^33^; NELSON; Poor | 90% | NR | 3.80% | Unclear | Unclear
Infante, 2008^72^; DANTE; Fair | Baseline only: 100% | No | 0% | 0% | No
Infante, 2009^71^; DANTE; Fair | 90.9% | <10% (presented as combined arms needing CT) | 9.1% | CT: 9.1% | No
Infante, 2015^61^; DANTE; Fair | 94% | Yes | 6% | Unclear | NA
Lopes Penga, 2009^125^; ITALUNG; Fair | 87.2% | NR | 12.7% | CT: 12.7% | Yes
National Lung Screening Trial Research Team, 2019^74^; NLST; Fair | NR in this article, and post-trial screening was unclear, but original NLST reported; CT: 95%; CXR: 93% | Unclear; post-trial screening was not ascertained | 11/33 centers (representing 12.4% of trial participants) did not have a home state cancer registry for linkage for lung cancer incidence; for mortality, linkage to national death index was available for all but 2.2% | NR | Unclear for lung cancer incidence; no for lung cancer mortality and all-cause mortality
O’Grady, 2014^169^; PLCO, NLST; Good | High | Some | Unclear | Unclear | Unclear
Paci, 2017^62^; ITALUNG; Fair | Across 4 rounds of LDCT screening: 81% | Yes (but minimal) | Low (conducted ITT analysis) | Low | No
Pastorino, 2012^80^ and 2019^81^; MILD; Poor | >95% | Unclear for 5-year followup; by 10-year followup, 1.2% of control group had LDCT | Low (conducted ITT analysis) for loss to followup, but many people in control group had shorter followup duration. | Unclear for loss to followup, but less followup among control group (e.g., 44.9 vs. 56 months in 5-year followup study); percentage of subjects with available data at 10 years: 46.2% (805/1723) controls vs. 81.4% (1934/2376) LDCT | Yes, when considering differential followup, 35.2% fewer people from the control group had 10-year followup than in the LDCT group
Patz, 2014^142^; NLST; Fair | NR in this paper | NR | Low | No | No
Pedersen, 2009^122^; DLCST; Good | Unclear but appears to be 100% for baseline CT | NR | Number of CTs obtained NR | NR | It was NR whether any of the 2,052 patients did not have a CT
Pinsky, 2005^393^ Doroudi, 2018^75^; LSS; Fair | 85.8% | NR | 14.2% | CT: 14.2% | Yes
Pinsky, 2013^63^; NLST; Fair | NR in this paper | NR | Low | No | No
Rasmussen, 2014^158^; DLCST; Fair | Unclear | Not much | Moderate for COS-LC | None at baseline, somewhat lower for COS-LC survey completion in control arm in subsequent rounds | Depends on which round of screening you are referring to
Saghir, 2012^65^; DLCST; Fair | High, mean annual participation 95.5% | Minimal | Low | Low | No
Sverzellati, 2016^82^; MILD; Fair | High, until years T5 and T6 | NR | Low in early years, then moderate | Unclear | In later years, yes
Tanner, 2015^66^; NLST; Fair | High in NLST | NR | Low | Low | No
Taylor, 2007^155^; NLST/LSS; Fair | 79.7% | NR | 20.3% | For entire survey group: 20.3% | Yes
van den Bergh, 2010^162^; NELSON; Fair | For all, 86.7%; CT at; T0: 91.0% (630/692); T1: 93.6% (641/685); T2: 93.0% (620/667); T3: 87.7% (600/684) | NR | 13.3% | 13.3% | Yes, at third annual screen
van den Bergh, 2011^159^; NELSON; Fair | NR in this paper | No | T0, All: 87.9%; LDCT: 89.8%; Control: 85.9%; T1 Screen: 87.7%; T2, All: 78.9%; LDCT: 89.3%,; Control 64.7% | LDCT: 89% vs.; Control: 65% | Yes
van der Aalst, 2010^148^; NELSON; Fair | 92.1% | No | NA | NA | NA
van der Aalst, 2011^153^; NELSON; Fair | 92.1% | No | NA | NA | NA
van Klaveren, 2009^120^; NELSON; Good | 96.4% | NR | 3.5% | CT: 3.5% | No
van’t Westeinde, 2012^138^; NELSON; Fair | NR in this publication (but >90% in other NELSON publications) | NR | NR | NR | NR
Videtic, 2015^263^; RTOG 0915; Fair | 100% of analyzable patients | No | 10/94 (11%) patients were excluded post-randomization due to withdrawal of consent, protocol violations, or RT dosing not met | 34Gy group: 8/47 (17%); 48Gy group: 2/47 (4%) | Yes
Wille, 2016^67^; DLCST; Good | NR in this paper | No | Low | Low (LDCT: 20; Control: 14) | No
Young, 2015^144^; NLST; Fair | High in NLST | NR | Low | Low | No

Abbreviations: ACRIN=American College of Radiology Imaging Network; COS-LC=consequences of screening-lung cancer; CT=computed tomography; CXR=chest X-ray; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology trial; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=The Italian Lung Study; ITT=intention-to-treat; LDCT=low-dose computed tomography; LOCF: last observation carried forward; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multicentric Italian Lung Detection trial; NA=not applicable; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NLST=National Lung Screening Trial; NR=not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; RTOG=Radiation Therapy Oncology Group; T=timepoint; UKLS=UK Lung Cancer Screening trial; vs.=versus.

Appendix D Table 4 Risk of Bias and Overall Quality Assessment Ratings for Randomized Studies: Part 3

First Author, Year; Study Name; Quality Rating | What was the method used to handle missing data? | Did the study use intention to screen analysis or ITT (e.g., rather than per protocol)? | Were ascertainment techniques for outcomes adequately described? | Were ascertainment techniques equal, valid, and reliable? | Overall Rating | Comments for Poor-Quality Studies
Aberle, 2011^32^; NLST; Good | NR, (small amount of missing data from baseline questionnaires); Missing data from Aberle 2010: 0.4%, similar each arm | Yes | Yes | Yes | Good | NA
Aberle, 2013^58^; NLST; Good | Missing data excluded from screening accuracy calculations | Yes | Yes | Yes | Good | NA
Aggestrup, 2012^160^; DLCST; Fair | NR | ITT | NR | NA | Fair | NA
Ashraf, 2009^145^; DLCST; Fair | Functioned under the assumption that they were still smokers | ITT | No | NA | Fair | NA
Ashraf, 2014^147^; DLCST; Good | Complete case and LOCF imputation | Yes | Yes | Yes | Good | NA
Becker, 2012^60^; LUSI; Good | Missing data NR, but baseline data appears complete | Yes | Yes | Yes | Good | NA
Becker, 2015^59^, 2019^73^; LUSI; Fair | NR, but less than 10 participants each round were lost to followup, so complete case analysis would likely not bias results | Yes | Yes | Yes | Fair | NA
Brain, 2016^391^; UKLS; Poor | For individual instruments: mean replacement imputation within domain if <35% missing data If > 35% missing data within domain, dropped from analysis. For participants lost to followup - complete case analysis. Sensitivity analysis performed where inverse probability weighting used to adjust for missing data | Yes | Yes | Yes | Poor | Poor quality rating is due to high attrition for psychosocial outcomes and greater loss to followup, as well as lack of reporting contamination and cross-overs in the control group.
Brain, 2017^392^; UKLS; Poor | Imputed all missing followup as smokers; sensitivity analysis of complete case with unclear use of inverse probability weighting to account for nonresponse | Yes | Yes | Yes | Poor | Poor quality rating due to high attrition for smoking cessation outcomes, single imputation conducted under the assumption that smoking status was positive, and unclear use of IPW
Church, 2013^57^; NLST; Good | Missing data excluded from screening accuracy calculations | Yes | Yes | Yes | Good | NA
Clark, 2016^149^; NLST; Fair | Complete case for smoking status data (5.8% missing followup forms) | Yes | Yes | Unclear | Fair | NA
Croswell, 2010^119^; NA; Fair | NR | No | NR | NA | Fair | NA
De Koning, 2020^76^ | None (but missing data very low) | Yes | Mostly, but some details NR | Unclear | Fair | NA
Field, 2016^97^; UKLS; Poor | Unclear | No | No | NA | Poor | Poor quality rating due to numerous unclear domains, including allocation concealment and accessor and provider masking, differential attrition, and methods used to handle missing data.; No reporting on crossovers or contamination. This study did not report on the control arm
Field, 2016^117^; UKLS; Fair | Mean replacement strategy was used when participants were missing data for psychosocial variables | Yes | Yes | Yes | Fair | NA
Gohagan, 2004^70^; LSS; Fair | NR | No | NR | NA | Fair | NA
Gohagan, 2005^69^; LSS; Fair | NR | No | NR | NA | Fair | NA
Heleno, 2018^141^; DLCST; Fair | NR | Yes | Elsewhere | Presumably | Fair | NA
Horeweg, 2013^98^; NELSON; Poor | Did not include patients without a CT | No | No | NA | Poor | Poor quality rating due to numerous unclear domains, including allocation concealment, masking, crossover and contamination. No data from the control arm is reported in this study.
Horeweg, 2014^33^; NELSON; Poor | Excluded from analysis | No | No | NA | Poor | Poor quality rating due to lack of control arm inclusion, and because several groups were not reported due to unavailable data.
Infante, 2008^72^; DANTE; Fair | NR | Yes | NR | NA | Fair | NA
Infante, 2009^71^; DANTE; Fair | NI | No | NR | NA | Fair | NA
Infante, 2015^61^; DANTE; Fair | Unclear | Yes | No | NA | Fair | NA
Lopes Penga, 2009^125^; ITALUNG; Fair | NR | No | NR | NA | Fair | NA
National Lung Screening Trial Research Team, 2019^74^; NLST; Fair | NR | Yes | Yes | Unclear for lung cancer incidence; yes for lung cancer mortality and all-cause mortality | Fair | NA
O’Grady, 2014^169^; PLCO, NLST; Good | Use of missing indicator variable | Yes | Yes | Yes | Good | NA
Paci, 2017^62^; ITALUNG; Fair | NA | Yes | Yes | Unclear (31 deaths of 335 in the trial underwent cause-of-death review; the other deaths did not undergo the same rigorous evaluation based on an algorithm with uncertain validity) | Fair | NA
Pastorino, 2012^80^ and 2019^81^; MILD; Poor | Unclear | Yes | No | Unclear | Poor | Poor-quality rating due to high risk of selection bias, unclear methods of randomization and allocation concealment, changing protocol and addition of a control arm later in the trial, lack of similar groups at baseline for important variables (e.g., proportion of current smokers), differential followup between groups, and high risk of measurement bias.
Patz, 2014^142^; NLST; Fair | NR in this paper | Yes | Yes | Yes | Fair | NA
Pedersen, 2009^122^; DLCST; Good | NR | Appears all had a CT in intervention arm | NR | NA | Good | NA
Pinsky, 2005^393^ Doroudi, 2018^75^; LSS; Fair | NR | NR | NR | Unclear | Fair | NA
Pinsky, 2013^63^; NLST; Fair | NR in this paper | Yes | Yes | Yes | Fair | NA
Rasmussen, 2014^158^; DLCST; Fair | Imputation | Yes | Yes | Yes | Fair | NA
Saghir, 2012^65^; DLCST; Fair | NR | Yes | Yes | Yes | Fair | NA
Sverzellati, 2016^82^; MILD; Fair | NR in this paper | Unclear | Yes | Unclear | Fair | NA
Tanner, 2015^66^; NLST; Fair | NR | Yes | Yes (in other publications) | Yes | Fair | NA
Taylor, 2007^155^; NLST/LSS; Fair | NR | No | NR | NA | Fair | NA
van den Bergh, 2010^162^; NELSON; Fair | Not used for each round | No | NR | NA | Fair | NA
van den Bergh, 2011^159^; NELSON; Fair | NR | Yes | Yes (in other publications) | Yes | Fair | NA
van der Aalst, 2010^148^; NELSON; Fair | NI | No | NR | NA | Fair | NA
van der Aalst, 2011^153^; NELSON; Fair | NI | No | NR | NA | Fair | NA
van Klaveren, 2009^120^; NELSON; Good | NI | No | NR | NA | Good | NA
van’t Westeinde, 2012^138^; NELSON; Fair | Took only positive results from NELSON, thus missing data NR | No | NR | NA | Fair | NA
Videtic, 2015^263^; RTOG 0915; Fair | Unclear | Yes | Yes | Yes | Fair | NA
Wille, 2016^67^; DLCST; Good | NA | Yes | Yes | Yes | Good | NA
Young, 2015^144^; NLST; Fair | NR in this paper | Yes | Yes (in other publications) | Yes | Fair | NA

Abbreviations: ACRIN=American College of Radiology Imaging Network; COPD=chronic obstructive pulmonary disease; CT=computed tomography; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology trial; DLCST=Danish Lung Cancer Screening Trial; ITALUNG=The Italian Lung Study; IPW=inverse probability weighting; ITT=Intention-to-treat; KQ=Key Question; LDCT=low-dose computed tomography; LOCF: Last observation carried forward; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multicentric Italian Lung Detection trial; NA=Not applicable; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NI=Not included; NLST=National Lung Screening Trial; NR=Not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; RTOG=Radiation Therapy Oncology Group; UKLS=UK Lung Cancer Screening trial.

Appendix D Table 5 Risk of Bias and Overall Quality Assessment Ratings for Risk Prediction Model (KQ 2) Studies: Part 1

First Author, Year; Model Name; Quality Rating | Does study sample adequately capture the population of interest? | Was there selective inclusion of participants in the model based on data availability? | Enrolled consecutive patients or a random sample? | Selection criteria clearly described? | Was followup duration for the cohort the same as the time horizon of the prediction reported? | Is a valid and reliable definition and method for measurement of the outcomes reported? | Was the same outcome definition (and method for measurement) used in all patients?
De-Torres, 2015^88^; COPD-LUCSS; Fair | Maybe | Some | Yes | Yes | Yes | Yes | Somewhat
Katki, 2016^84^; PLCO, NLST, NHIS; Good | Yes | Some | Yes | Yes | Somewhat | Yes | Yes
Kovalckik, 2013^56^; NLST; Good | Yes | No | Yes | Yes | Yes | Yes | Yes
Landy, 2019^89^; NHIS; Fair | Yes (NHIS) | NR | No, complex sampling survey design | Yes, based on model development papers^84,^ ^85^ | NA – modeling study | NR/NA - modeling study | NA – modeling study
Li, 2015^394^; EPIC Cohort; Poor | No | Yes | No | Yes | No (only for 1 of the models) | Yes | Yes
Markaki, 2018^95^; HUNT2 Cohort; Fair | Yes | No | No. Entire county was sampled. 70% response rate | Yes | Yes, max followup 16 yrs. Two models estimated – 6 year and 16 year. | Yes, probably (although some uncertainty about validity and reliability of registry and ICD codes) | Yes
Tammemagi, 2013^85^; PLCOm2012; Good | Yes | No | Yes | Yes | Yes | Yes | Yes
Tammemagi, 2014^87^; NLST, PLCO; Good | Yes | No | Yes | Yes | Yes | Yes | Yes
ten Haaf, 2017^83^; NA; Good | Yes | No | Yes | Yes | Yes | Yes | Yes
Weber, 2017^86^; PLCOm2012; Good | Yes | Some | Yes | Yes | Yes | Yes | Yes

Abbreviations: COPD=Chronic Obstructive Pulmonary Disease; COPD-LUCSS=COPD-Lung Cancer Screening Score; EPIC=European Prospective Investigation of Cancer and Nutrition; KQ=key question; NA=not applicable; NHIS=National Health Interview Survey; NLST=National Lung Screening Trial; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial

Appendix D Table 6 Risk of Bias and Overall Quality Assessment Ratings for Risk Prediction Model (KQ 2) Studies: Part 2

First Author, Year; Model Name; Quality Rating | Were the outcomes assessed without knowledge of the candidate predictors? | Are valid and reliable definitions and methods for measurement and classification of candidate predictor(s) reported? | Was the same predictor definition and method of measurement used in all patients? | Were all relevant predictors included? | Were predictors assessed blinded for the outcome, and for each other (if relevant)? | How were the predictors handled in the modelling?
De-Torres, 2015^88^; COPD-LUCSS; Fair | Yes | Yes | Yes | Yes | Yes | Categorized/dichotomized
Katki, 2016^84^; PLCO, NLST, NHIS; Good | Yes | Yes | Yes | Yes | Yes | Depends on predictor
Kovalckik, 2013^56^; NLST; Good | Yes | Yes for most (all historical/questionnaire) Unclear how NLST defined COPD/emphysema | Yes | Yes | Yes | Continuous for age, categorical for race/ethnicity, count for years since smoking cessation, first degree relatives with lung cancer, binary for sex, emphysema, and nonlinear for BMI
Landy, 2019^89^; NHIS; Fair | NA – modeling study | NR | NR | Yes, based on development papers^84,^ ^85^ | NA – modeling study | Refer to development papers^84,^ ^85^
Li, 2015^394^; EPIC Cohort; Poor | NR | Yes | Yes | No (in this external validation, only for the Bach model were all predictors included) | Yes | Varies by model and predictor
Markaki, 2018^95^; HUNT2 Cohort; Fair | Probably yes (linkage to registry data on outcomes) | Probably yes (survey questions, although uncertain validity of that approach for hours of daily indoor exposure to smoke, which was in their final model) | Yes | Yes | Yes – prospective | Multiple ways (continuous cigarettes/day; log transformation – pack-years, years since quit, BMI, smoke exposure; p-spline transformation – age)
Tammemagi, 2013^85^; PLCOm2012; Good | Yes | Yes/No; Self-reported demo, smoking | Yes/Unclear; - most predictors are self-reported.; - Unclear how COPD defined for NLST and PLCO (primary papers reviewed and no information - Oken and Aberle) | Yes | Yes | Continuous for age, BMI, education, duration smoking, smoking quit time, categorized for race/ethnicity, COPD, cancer history, family history cancer, smoking status, nonlinear transformation for smoking intensity
Tammemagi, 2014^87^; NLST, PLCO; Good | Yes | Yes | Yes | Yes | Yes | Continuous for age, BMI, education, duration smoking, smoking quit time, categorized for race/ethnicity, COPD, cancer history, family history cancer, smoking status, nonlinear transformation for smoking intensity
ten Haaf, 2017^83^; NA; Good | Yes | Yes | Probably- “data on predictor variables in each trial were collected through epidemiologic questionnaires administered at study entry and harmonized across both trials” | Yes | Yes | Nine models were considered. Refer to primary papers. (pull refs)
Weber, 2017^86^; PLCOm2012; Good | Yes | Yes | Yes | Yes | Yes | Varies

Abbreviations: BMI=Body Mass Index; COPD=chronic obstructive pulmonary disease; COPD-LUCSS=COPD-Lung Cancer Screening Score; EPIC=European Prospective Investigation of Cancer and Nutrition; KQ=key question; NA=not applicable; NHIS=National Health Interview Survey; NLST=National Lung Screening Trial; NR=Not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial

Appendix D Table 7 Risk of Bias and Overall Quality Assessment Ratings for Risk Prediction Model (KQ 2) Studies: Part 3

First Author, Year; Model Name; Quality Rating | Number (%) participants with missing data | Did the study have high attrition (>10%), raising concerns for bias? | How was missing data handled? | Modeling assumptions satisfied? | Describe the method for selection of predictors for inclusion in multivariable modelling | Describe the method for selection of predictors during multivariable modelling and criteria used
De-Torres, 2015^88^; COPD-LUCSS; Fair | Low | No | Imputation or assumption | NR | All | Significance in multivariable model, backwards selection
Katki, 2016^84^; PLCO, NLST, NHIS; Good | Less than 2% | No | Imputation or assumption | Yes | Previous models | Akaike and other
Kovalckik, 2013^56^; NLST; Good | From NLST parent paper < 1% | No | NR | Not reported | Based on prior studies | Lasso regression
Landy, 2019^89^; NHIS; Fair | 1.8% for race/ethnicity, 0.4% for education, 2.9% for body mass index, 0.4% for number of years since quitting, 7.3% for number of cigarettes smoked per day, 0.3% for number of years of smoking, 0.2% for presence of emphysema, and 12.1% for family history of lung cancer | NA – modeling study | Multiple imputation | NR | Refer to development papers^84,^ ^85^ | Refer to development papers^84,^ ^85^
Li, 2015^394^; EPIC Cohort; Poor | NR, although less than half of the EPIC cohort were included (20,700/53,088) | NR | Not reported for the outcomes; for predictors, they only included people with data for predictors and for the predictors that they had no data for in their cohort (e.g., COPD, pneumonia, emphysema, dust exposure, family history of lung cancer) they assumed that risk factors were absent | Not applicable - external validation only | Not applicable - external validation only (although see entry for missing data regarding how they didn’t include all predictors from the original models) | Not applicable - external validation only
Markaki, 2018^95^; HUNT2 Cohort; Fair | 9.35% total for all predictors | NR | Multiple imputation | NR | Authors selected risk factors for lung cancer and other smoking-related behaviors | Backwards selection; criteria not reported
Tammemagi, 2013^85^; PLCOm2012; Good | PLCO < 5% for all predictors NLST < 1% for all predictors | No | NR; presumably complete case | Yes | Predictor selection guided by predictive performance, not based on univariate association p value | Predictor selection guided by predictive performance, not based on univariate association p value
Tammemagi, 2014^87^; NLST, PLCO; Good | < 5% missing per Oken 2011 and Kovalchik supplement (32) | Not reported, but per Oken 2011, overall adherence was high 91.2% of participants had undergone at least 1 CXR screen, | NR | Yes | Predictor selection guided by predictive performance, not based on univariate association p value | Predictor selection guided by predictive performance, not based on univariate association p value
ten Haaf, 2017^83^; NA; Good | <7% across all predictors | Probably No; Reviewing primary studies: Aberle and Oken; NLST <10% both arm; PLCO intervention arm 16.5%; PLCO control arm 8.8% | Multiple imputation | NR | NA - Model validation only | NA - Model validation only
Weber, 2017^86^; PLCOm2012; Good | Low | No | Imputation or assumption | Yes | NA – Model validation only | NA – Model validation only

Abbreviations: COPD=chronic obstructive pulmonary disease; COPD-LUCSS=COPD-Lung Cancer Screening Score; CXR=chest X-ray; EPIC=European Prospective Investigation of Cancer and Nutrition; KQ=key question; NA=not applicable; NHIS=National Health Interview Survey; NLST=National Lung Screening Trial; NR=not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial.

Appendix D Table 8 Risk of Bias and Overall Quality Assessment Ratings for Risk Prediction Model (KQ 2) Studies: Part 4

First Author, Year; Study Name; Quality Rating | Were a priori cut points used for classification measures? | Method used for testing model performance: development dataset only or separate external validation? | Were coefficients of final model published? | In case of poor validation, was the model adjusted or updated? | Was there comparison of the distribution of predictors for development and validation datasets? | Overall Rating | Comments for Poor Quality Studies
De-Torres, 2015^88^; NLST; Fair | Some | Separate, external | Yes | NA | Unclear | Fair | NA
Katki, 2016^84^; PLCO, NLST, NHIS; Good | Yes | Separate, external | Yes | NA | Yes | Good | NA
Kovalckik, 2013^56^; NLST; Good | NA | Development cohort: NLST CXR arm; Validation cohort: PLCO CXR arm | No | NA | No | Good | NA
Landy, 2019^89^; NHIS; Fair | Yes | NA | Refer to development papers^84,^ ^85^ | NA | NA | Fair | NA
Li, 2015^394^; EPIC Cohort; Poor | No | Separate external validation | No | NA | NA | Poor | Concerns with missing data, missing predictor variables, selection of the sample, and changing the original models for analyses. Limited to ever smokers from among the larger cohort, introducing risk for bias.
Markaki, 2018^95^; HUNT2 Cohort; Fair | Yes | External validation | Yes | NA | NR | Fair | NA
Tammemagi, 2013^85^; PLCOm2012; Good | No | External Validation | Yes | NA | Yes | Good | NA
Tammemagi, 2014^87^; NLST, PLCO; Good | No | External Validation | Yes | NA | Yes | Good | NA
ten Haaf, 2017^83^; NA; Good | No | External Validation | Review primary studies. PLCOm2012 has published coefficients | NA | Yes | Good | NA
Weber, 2017^86^; PLCO, 2012; Good | Yes | Separate, external | Yes | NA | Unclear | Good | NA

Abbreviations: COPD=chronic obstructive pulmonary disease; COPD-LUCSS=COPD-Lung Cancer Screening Score; CXR=chest X-ray; EPIC=European Prospective Investigation of Cancer and Nutrition; KQ=key question; NA=not applicable; LC=lung cancer; LLP=Liverpool Lung Project; NHIS=National Health Interview Survey; NLST=National Lung Screening Trial; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; USPSTF=United States Preventive Services Task Force.

Appendix D Table 9 Risk of Bias and Overall Quality Assessment Ratings for Accuracy (KQ 3) Studies: Part 1

First Author, Year; Study Name; Quality Rating | Was a consecutive or random sample of patients used? | Was a case control design avoided? | Did the study avoid inappropriate exclusions? | Bias due to patient selection? | Were the test and reference standard results interpreted independently (blinded)? | If a threshold was used, was it pre-specified? | Were the tests adequately described (or referenced)? | Were methods for calculating accuracy clearly reported and valid? | Bias due to index test (LDCT)?
Aberle, 2011^32^; NLST; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | NA | Low
Aberle, 2011^58^; NLST; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Becker, 2012^60^; LUSI; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | NA | Low
Becker, 2015^59^; LUSI; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | NA | Low
Chung, 2017^132^; NLST; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Church, 2013^57^; NLST; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Croswell, 2010^119^; NA; Fair | Yes | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Crucitti, 2015^111^; “Un repiro per la vita”; Fair/Poor | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes for false-positive screens | Low
De Koning, 2020^76^ | Yes | Yes | Yes | Low | Yes | Yes | Yes | No | High
Field, 2016^97^; UKLS; Fair | Random | Yes | Yes | High | Unclear | Yes | Yes | Yes | Low
Field, 2016^117^; UKLS; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Gierada, 2017^110^; NLST; Fair | Yes (in parent trial) | No | Yes | Low | Not completely | Yes | Yes | Yes | Low
Gohagan, 2004^70^; LSS; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Henschke, 2004^131^; I-ELCAP; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Henschke, 2006^128^; I-ELCAP; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Henschke, 2006^129^; I-ELCAP; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Henschke, 2013^107^; I-ELCAP; Fair | Yes | Yes | Unclear | Low | Unclear | Multiple thresholds used | Yes | Yes | Low
Henschke, 2016^106^; I-ELCAP; Fair | Probably | Yes | Yes | Low | Yes | Yes | Yes | NA | Low
Heuvelmans, 2015^325^; NELSON; Poor | Random | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Unclear
Heuvelmans, 2013^114^; NELSON; Fair | Yes | Yes | Yes | Low | Yes | No | Yes | Yes | Low
Horeweg, 2013^98^; NELSON; Fair | Random | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Horeweg, 2014^33^; NELSON; Fair | Random | Yes | No | Low | Unclear | Yes | No | Yes | High
Infante, 2009^71^; DANTE; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Infante, 2015^61^; DANTE; Fair | Random | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Kinsinger, 2017^38^; LCSDP; Fair | No | Yes | NA | Unclear | NR | NR | Yes | Yes | Low
Lopes Penga, 2009^125^; ITALUNG; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
McKee, 2015^395^; NA; Poor | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
McWilliams, 2013^116^; PanCan, BCCA; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Menezes, 2010^121^; NA; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Paci, 2017^62^; ITALUNG; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Pedersen, 2009^122^; DLCST; Good | Yes | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Pinsky, 2015^100^; NLST; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Pinsky, 2015^64^; NLST; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Pinsky, 2015^101^; NLST; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Pinsky, 2015^102^; NLST; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Scholten, 2013^103^; NA; Good | Yes | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Sverzellati, 2016^82^; MILD; Fair | Yes | Yes | Yes | Low | NR | Yes | Yes | No | Unclear
Swensen, 2005^130^; NA; Fair | Yes | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Tammemagi, 2017^115^; PanCan; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Toyoda, 2008^126^; NA; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | NR | Yes | Unclear
Tsushima, 2008^123^; NA; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
van Klaveren, 2009^120^; NELSON; Good | Yes | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Van Riel, 2015^113^; NELSON; Good | Yes | NA | NA | Unclear | Yes | NA | Yes | Yes | Low
Veronesi, 2008^124^; COSMOS; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Veronesi, 2008^127^; COSMOS; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Wagnetz, 2012^118^; NA; Fair | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Low
Walter, 2016^78^; NELSON; Good | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Wang, 2012^112^; NELSON; Fair | Yes | Yes | No | High | Yes | Yes | Yes | Yes | Low
Wille, 2014^108^; DLCST; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | NA | Low
Xu, 2006^79^; NELSON; Fair | Yes | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Yankelevitz, 2015^105^; I-ELCAP; Fair | Unknown | Yes | Yes | Unclear | Yes | Yes | Yes | NA | Low
Yip, 2014^104^; NLST, I-ELCAP; Fair | Yes | Yes | No | Unclear | Yes | Yes | Yes | NA | Low
Yousaf-Khan, 2017^389^; NELSON; Poor | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear
Zhao, 2011^77^; NELSON; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Zhao, 2014^109^; NELSON; Fair | Yes | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low

Abbreviations: BCCA=British Columbia Cancer Agency; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology Trial; DLCST=Danish Lung Cancer Screening Trial; I-ELCAP=International Early Lung Cancer Action Project; ITALUNG=The Italian Lung Study; KQ=Key Question; LCSDP=Lung Cancer Screening Demonstration Project; LDCT=Low-Dose Computed Tomography; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multicentric Italian Lung Detection Trial; NA=not applicable; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NLST=National Lung Screening Trial; NR=Not reported; PanCan=Pan-Canadian Early Detection of Lung Cancer Study; UKLS=UK Lung Cancer Screening Trial.

Appendix D Table 10 Risk of Bias and Overall Quality Assessment Ratings for Accuracy (KQ 3) Studies: Part 2

First Author, Year; Study Name; Quality Rating | Reference Standard Used | Comments about Reference Standard | Is the reference standard likely to correctly classify the target condition? | Were the reference standard results interpreted without knowledge of the results of the index test (blinded)? | Did patients receive the reference test regardless of screening test results? | Bias due to reference standard?
Aberle, 2011^32^; NLST; Good | Subsequent diagnosis of LC within 1 yr | Lung cancer diagnosis was ascertained from patient questionnaires, certified by medical record abstraction, augmented by search from the NDI | Yes | Yes | Yes | Low
Aberle, 2011^58^; NLST; Good | Subsequent diagnosis of LC within 1 yr | Lung cancer diagnosis was ascertained from patient questionnaires, certified by medical record abstraction, augmented by search from the NDI | Yes | Yes | No | Low
Becker, 2012^60^; LUSI; Good | Subsequent diagnosis of LC within 1 yr | No comments | Yes | NR | Yes | Low
Becker, 2015^59^; LUSI; Good | Subsequent diagnosis of LC within 1 yr | No comments | Yes | NR | Yes | Low
Chung, 2017^132^; NLST; Good | Subsequent diagnosis of LC within 1 yr | Lung cancer diagnosis was ascertained from patient questionnaires, certified by medical record abstraction, augmented by search from the NDI | Yes | Yes | Yes | Low
Church, 2013^57^; NLST; Good | Subsequent diagnosis of LC within 1 yr | Lung cancer diagnosis was ascertained from patient questionnaires, certified by medical record abstraction, augmented by search from the NDI | Yes | Yes | No | Low
Croswell, 2010^119^; NA; Fair | Multiple | Biopsy/surgical | Yes | Unclear | No | Low
Crucitti, 2015^111^; “Un repiro per la vita”; Fair/Poor | Multiple | Multiple; they had protocol for workup of initial positive screen (most went on to additional imaging, some had biopsies). For sensitivity (false negatives), the reference standard is unclear and they were not really aiming to determine sensitivity | Yes, for false-positive screens/specificity; Unclear, for sensitivity | No | No | Low for false-positive screens; High for sensitivity/false-negative screens
De Koning, 2020^76^ | Multiple | Subsequent imaging and evaluation, diagnosis of lung cancer, registry determined lung cancer death | Yes | Yes | No | Low
Field, 2016^97^; UKLS; Fair | Biopsy | Diagnosis appeared to be made by lung resection or biopsy, 1 was made radiographically | Yes | Unclear | No | Low
Field, 2016^117^; UKLS; Fair | Other | Lung cancer diagnosis ascertained from biopsy and search of the following databases: the Office for National Statistics the Hospital Episode Statistics database and the National Cancer Registration Service. However, timing of followup to determine lung cancer is unclear and authors are clear that lung cancer incidence will only be studied after data is pooled with other European studies. | Yes | Yes | Yes | Low
Gierada, 2017^110^; NLST; Fair | Subsequent diagnosis of LC within 1 yr | Prior reading of same LDCT scan along with clinical knowledge of progression to lung cancer | Yes | Yes | Yes | Unclear
Gohagan, 2004^70^; LSS; Fair | Multiple | No algorithm for this protocol; abstracted histology | Yes | Unclear | No | Low
Henschke, 2004^131^; I-ELCAP; Fair | Biopsy | No comments | Yes | Unclear | No | Low
Henschke, 2006^128^; I-ELCAP; Fair | Biopsy | No comments | Yes | Unclear | No | Low
Henschke, 2006^129^; I-ELCAP; Fair | Multiple | Biopsy/surgical resection | Yes | Unclear | No | Low
Henschke, 2013^107^; I-ELCAP; Fair | Subsequent diagnosis of LC within 1 yr | No comments | Yes | Unclear | Unclear | Unclear
Henschke, 2016^106^; I-ELCAP; Fair | Biopsy | Diagnosis defined on cytology from nonsurgical biopsy and path from resection | Unclear | No | Yes | Unclear
Heuvelmans, 2015^325^; NELSON; Poor | Other | Histology was the reference | Yes | Unclear | No | High
Heuvelmans, 2013^114^; NELSON; Fair | Biopsy | Median followup was 4.4 yrs | Yes | Yes | No | Low
Horeweg, 2013^98^; NELSON; Fair | Other | Histology | Yes | Unclear | No | Unclear
Horeweg, 2014^33^; NELSON; Fair | Biopsy | No comments | Yes | Unclear | No | High
Infante, 2009^71^; DANTE; Fair | Biopsy | No comments | Yes | Unclear | No | Low
Infante, 2015^61^; DANTE; Fair | Other | Reference standard was histology | Yes | Unclear | No | Unclear
Kinsinger, 2017^38^; LCSDP; Fair | Multiple | Reference standard is LC diagnosis made by clinical teams, date are extracted from VA system central data system and probably other sources since these screened patients were tracked in a registry | Yes | No | Yes | Low
Lopes Penga, 2009^125^; ITALUNG; Fair | Biopsy | No comments | Yes | Unclear | No | Low
McKee, 2015^395^; NA; Poor | Subsequent diagnosis of LC within 1 yr | 1) Diagnosed lung cancer=biopsy proven + positive PET for patients that could not undergo biopsy; 2) Biopsy-prove lung cancer | Yes | No | No | Unclear
McWilliams, 2013^116^; PanCan, BCCA; Fair | Biopsy | 1) Histopathological exam of resected surgical specimens; 2) Cytopathology from needle-aspiration biopsy samples | Yes | No | No | Unclear
Menezes, 2010^121^; NA; Fair | Biopsy | No comments | Yes | Unclear | No | Low
Paci, 2017^62^; ITALUNG; Good | Multiple | Biopsy reports, telephone followup, death registry | Yes | Yes | Yes | Low
Pedersen, 2009^122^; DLCST; Good | Biopsy | No comments | Yes | Unclear | No | Low
Pinsky, 2015^100^; NLST; Fair | Subsequent diagnosis of LC within 1 yr | No comments | Yes | Yes | Yes | Low
Pinsky, 2015^64^; NLST; Good | Subsequent diagnosis of LC within 1 yr | No comments | Yes | Yes | Yes | Low
Pinsky, 2015^101^; NLST; Fair | Subsequent diagnosis of LC within 1 yr | No comments | Yes | Unclear | Yes | Low
Pinsky, 2015^102^; NLST; Fair | Subsequent diagnosis of LC within 1 yr | No comments | Yes | Unclear | Yes | Low
Scholten, 2013^103^; NA; Good | Biopsy | No comments | Yes | Unclear | No | Low
Sverzellati, 2016^82^; MILD; Fair | Subsequent diagnosis of LC within 1 yr | No comments | Yes | Unclear | Unclear | Unclear
Swensen, 2005^130^; NA; Fair | Multiple | Determined by an individual’s provider | Unclear | Unclear | No | High
Tammemagi, 2017^115^; PanCan; Fair | Subsequent diagnosis of LC within 2 yrs | Any of the following; 1) histopathological exam of resected surgical specimens; 2) cytopathology from FNA; 3) nodules stable, nodules not visible, benign calcification developed | Yes | No | No | Low
Toyoda, 2008^126^; NA; Fair | Other | Histology used, but procedures unclear | Yes | Unclear | No | Low
Tsushima, 2008^123^; NA; Fair | Multiple | Biopsy/surgical | Yes | Unclear | No | Low
van Klaveren, 2009^120^; NELSON; Good | Biopsy | No comments | Yes | Unclear | No | Low
Van Riel, 2015^113^; NELSON; Good | Other | This is study only looked at inter observer agreement, and its potential effect on subsequent testing. As such there was no clear reference standard in sensitivity and specificity were not calculated. In other words, this was the study of reliability. | NA | NA | NA | Unclear
Veronesi, 2008^124^; COSMOS; Fair | Biopsy | No comments | Yes | Unclear | No | Low
Veronesi, 2008^127^; COSMOS; Fair | Biopsy | No comments | Yes | Unclear | No | Low
Wagnetz, 2012^118^; NA; Fair | Multiple | Biopsy/VATS | Yes | Unclear | No | Low
Walter, 2016^78^; NELSON; Good | Multiple | LC diagnosis based on histology; benignity based on histology or stable size for at least 2 yrs | Yes | Unclear | Yes | Low
Wang, 2012^112^; NELSON; Fair | Multiple | Pathology or no cancers diagnosed in 2 yr followup | Yes | No | No | Unclear
Wille, 2014^108^; DLCST; Fair | Subsequent imaging | Last annual CT scan | Unclear | Yes | Yes | Unclear
Xu, 2006^79^; NELSON; Fair | Multiple | Brushings, biopsy, VATS, resection | Yes | Unclear | Not planned | Low
Yankelevitz, 2015^105^; I-ELCAP; Fair | Biopsy | Diagnosis defined on cytology from nonsurgical biopsy and path from resection -- for nonsolid nodules, FNAs can be operator dependent and not useful (according to authors in introduction) | Yes | No | No | High
Yip, 2014^104^; NLST, I-ELCAP; Fair | Biopsy | Outcome is lung cancer incidence, relies on biopsy. | Yes | No | No | High
Yousaf-Khan, 2017^389^; NELSON; Poor | Multiple | LC diagnosis based on histology; benignity based on histology or stable size for at least 2 yrs | Yes | Yes | Yes | Low
Zhao, 2011^77^; NELSON; Fair | Subsequent diagnosis of LC within 1 yr | Subsequent diagnosis of LC within various time intervals, according to NELSON management protocol. Intervals could be 3 mos, 1 yr, or 2 yrs. | Yes | Yes | Unclear | Low
Zhao, 2014^109^; NELSON; Fair | Multiple | Nodules were classified as benign or malignant based on histologic examination or as benign based on stable volume for more than 2 yrs after baseline. | Yes | Unclear | No, but they were subject to the same multicomponent reference standard | Unclear

Abbreviations: BCCA=British Columbia Cancer Agency; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology Trial; DLCST=Danish Lung Cancer Screening Trial; I-ELCAP=International Early Lung Cancer Action Project; ITALUNG=The Italian Lung Study; KQ=Key Question; LC=lung cancer; LCSDP=Lung Cancer Screening Demonstration Project; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multicentric Italian Lung Detection Trial; NA=not applicable; NDI=National Death Index; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NLST=National Lung Screening Trial; NR=Not reported; PanCan=Pan-Canadian Early Detection of Lung Cancer Study; UKLS=UK Lung Cancer Screening Trial.

Appendix D Table 11 Risk of Bias and Overall Quality Assessment Ratings for Accuracy (KQ 3) Studies: Part 3

First Author, Year; Study Name; Quality Rating | Is the time period between the test and reference test short enough? | Did the whole or a random selection of the patients receive the reference test? | Did patients receive the same reference standard for the outcome specified? | Did the study have high attrition raising concern for bias? | Was an appropriate method used to handle missing data? | Bias due to flow and timing? | Quality Rating | Comments any Study With Poor Quality
Aberle, 2011^32^; NLST; Good | Yes | Only patients with positive screen underwent diagnostic evaluation, but all received questionnaire and NDI search | Yes | No | Yes | Low | Good | NA
Aberle, 2011^58^; NLST; Good | Yes | Only patients with positive screen underwent diagnostic evaluation, but all received questionnaire and NDI Search | Yes | No | Yes | Low | Good | NA
Becker, 2012^60^; LUSI; Good | Yes | Whole sample - LC diagnosis by biopsy or followup | Yes | No | NR | Low | Good | NA
Becker, 2015^59^; LUSI; Good | Yes | Whole sample - LC diagnosis by biopsy or followup | Yes | No | Yes | Low | Good | NA
Chung, 2017^132^; NLST; Good | Yes | Only patients with positive screen underwent diagnostic evaluation, but all received questionnaire and NDI Search | Yes | No | Yes | Low | Good | NA
Church, 2013^57^; NLST; Good | Yes | Only patients with positive screen underwent diagnostic evaluation, but all received questionnaire and NDI Search | Yes | No | Yes | Low | Good | NA
Croswell, 2010^119^; NA; Fair | Yes | No | Yes | Yes | NR | High | Fair | NA
Crucitti, 2015^111^; “Un repiro per la vita”; Fair/Poor | Yes, for specificity and false-positive screens;; Unclear, for sensitivity | No | No | No | NR | Low for false-positive screens; High for sensitivity/false-negative screens | Fair for false-positive screens; Poor for sensitivity and false-negative screens | Poor quality rating for sensitivity and false- negative outcomes is due to high risk of ascertainment bias; unreported length of followup or ascertainment approach (e.g., medical record review or endpoint verification); number of patients lost to followup; and methods of handling missing data
De Koning, 2020^76^ | Yes | Yes | Yes | No | Yes | Low | Fair | NA
Field, 2016^97^; UKLS; Fair | Unclear how long after LDCT patients had biopsy | No | No | No | Unclear | Unclear | Fair | NA
Field, 2016^117^; UKLS; Fair | Unclear | Yes, if composite reference test of biopsy/imaging | Yes | No | NR (but unlikely) | Low | Fair | NA
Gierada, 2017^110^; NLST; Fair | No - it is possible that interval cancer developed | Yes | No | No | NA | Low | Fair | NA
Gohagan, 2004^70^; LSS; Fair | Unclear | No | Unclear | No | NR | Low | Fair | NA
Henschke, 2004^131^; I-ELCAP; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Henschke, 2006^128^; I-ELCAP; Fair | Yes | No | Yes | Yes (>10%) | NR | Low | Fair | NA
Henschke, 2006^129^; I-ELCAP; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Henschke, 2013^107^; I-ELCAP; Fair | Yes | Unclear | No | Unclear | Unclear | Unclear | Fair | NA
Henschke, 2016^106^; I-ELCAP; Fair | Yes | Selection | Yes | NR | NR | Unclear | Fair | NA
Heuvelmans, 2015^325^; NELSON; Poor | Unclear | No | Yes | No | Unclear | High | Poor | Poor quality rating is due to several unclear and high categories, including unclear independence of test and reference standard interpretation, unclear bias due to index test
Heuvelmans, 2013^114^; NELSON; Fair | NA | No | Yes | No | NA | Low | Fair | NA
Horeweg, 2013^98^; NELSON; Fair | Unclear | No | Yes | No | Yes | Low | Fair | NA
Horeweg, 2014^33^; NELSON; Fair | Unclear | No | Yes | No | Yes | Low | Fair | NA
Infante, 2009^71^; DANTE; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Infante, 2015^61^; DANTE; Fair | Unclear | No | Yes | No | Unclear | Unclear | Fair | NA
Kinsinger, 2017^38^; LCSDP; Fair | NR | Yes | Yes | NR | NR | Unclear | Fair | NA
Lopes Penga, 2009^125^; ITALUNG; Fair | Yes | No | Yes | Yes | NR | Low | Fair | NA
McKee, 2015^395^; NA; Poor | Yes | Yes | Yes | Yes | Unclear | High | Poor | Poor rating is due to the lack of clinical followup and inclusion of 26% of the sample in analysis. Given the small number of cases reclassified, results could change if data from missing participants had been available.
McWilliams, 2013^116^; PanCan, BCCA; Fair | Unclear | Biopsy | Yes | No | Yes | Unclear | Fair | NA
Menezes, 2010^121^; NA; Fair | Yes | No | Yes | Yes | NR | Unclear | Fair | NA
Paci, 2017^62^; ITALUNG; Good | Yes | All received the same outcome assessment process | Not all received biopsy | No | Yes | Low | Good | NA
Pedersen, 2009^122^; DLCST; Good | Yes | No | Yes | No | NR | Low | Good | NA
Pinsky, 2015^100^; NLST; Fair | Yes | All received the same outcome assessment process | Not all received biopsy | No | Yes | Low | Fair | NA
Pinsky, 2015^64^; NLST; Good | Yes | All received the same outcome assessment process | Not all received biopsy | No | Yes | Low | Good | NA
Pinsky, 2015^101^; NLST; Fair | Yes | All received the same outcome assessment process | Not all received biopsy | No | Yes | Low | Fair | NA
Pinsky, 2015^102^; NLST; Fair | Yes | All received the same outcome assessment process | Not all received biopsy | No | Yes | Low | Fair | NA
Scholten, 2013^103^; NA; Good | Yes | No | Yes | No | NR | Low | Good | NA
Sverzellati, 2016^82^; MILD; Fair | Yes | Unclear | Not all received biopsy | Unclear | Unclear | Unclear | Fair | NA
Swensen, 2005^130^; NA; Fair | Yes | No | Yes | Yes, for fourth annual (20%) | NR | High | Fair | NA
Tammemagi, 2017^115^; PanCan; Fair | Yes | Yes - if composite reference test of biopsy/imaging. | Yes | Yes | Unclear | High | Fair | NA
Toyoda, 2008^126^; NA; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Tsushima, 2008^123^; NA; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
van Klaveren, 2009^120^; NELSON; Good | Yes | No | Yes | No | NR | Low | Good | NA
Van Riel, 2015^113^; NELSON; Good | NA | NA | NA | NA | NA | Low | Good | NA
Veronesi, 2008^124^; COSMOS; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Veronesi, 2008^127^; COSMOS; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Wagnetz, 2012^118^; NA; Fair | Yes | No | Yes | No | NR | Low | Fair | NA
Walter, 2016^78^; NELSON; Good | Yes | Yes | Same protocol for all | No | NA | Low | Good | NA
Wang, 2012^112^; NELSON; Fair | Yes | All | Yes | NR | NR | Unclear | Fair | NA
Wille, 2014^108^; DLCST; Fair | Yes | Intervention arm | Yes | No | NR | Low | Fair | NA
Xu, 2006^79^; NELSON; Fair | NR | Not planned | Likely planned, but unclear | No data | No data | Unclear | Fair | NA
Yankelevitz, 2015^105^; I-ELCAP; Fair | Yes | Selection | Yes | For the sample of nonsolid lesions, none. | NR | Unclear | Fair | NA
Yip, 2014^104^; NLST, I-ELCAP; Fair | Yes | Selection | Yes | No | Yes | Low | Fair | NA
Yousaf-Khan, 2017^389^; NELSON; Poor | Yes | Yes | Same protocol for all | Yes | None | High | Poor | Poor quality assessment is due to a number of unclear bias ratings, including the length of time (2 yrs) between index and reference test, and the participation rate (which was optional in the fourth round of screening).
Zhao, 2011^77^; NELSON; Fair | Yes | All received the same outcome assessment process | Not all received biopsy | Unclear based on this paper | Unclear | Unclear | Fair | NA
Zhao, 2014^109^; NELSON; Fair | Unclear | No | No | Unclear | Unclear | Unclear | Fair | NA

Abbreviations: BCCA=British Columbia Cancer Agency; DANTE=Detection and Screening of Early Lung Cancer with Novel Imaging Technology Trial; DLCST=Danish Lung Cancer Screening Trial; I-ELCAP=International Early Lung Cancer Action Project; ITALUNG=The Italian Lung Study; KQ=key question; LC=lung cancer; LCSDP=Lung Cancer Screening Demonstration Project; LUSI=German Lung Cancer Screening Intervention Trial; MILD=Multicentric Italian Lung Detection Trial; NA=not applicable; NDI=National Death Index; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial; NLST=National Lung Screening Trial; NR=not reported; PanCan=Pan-Canadian Early Detection of Lung Cancer Study; UKLS=UK Lung Cancer Screening Trial.