# Appendix C Excluded Studies

X1 Non-English
X2 Abstract only
X3 Ineligible population
X4 Ineligible risk prediction model
X5 Ineligible screening modality
X6 Ineligible intervention
X7 Ineligible comparator
X8 Ineligible outcome(s)
X9 Ineligible study design
X10 Ineligible study design
X11 Ineligible sample size
X12 Ineligible duration for KQ 6 (surgery studies)
X13 Ineligible duration for KQ 6 (SBRT/SABR studies)
X14 Eligible, except for country setting
X15 Eligible, except published prior to 2001
X16 Irretrievable
X17 Poor quality

1 How big is too big for lung nodules on screening scans? BMJ. 2013 Feb 20;346:f1070. doi: 10.1136/bmj.f1070. PMID: 23427128. E^73^xclusion Code: X2.23427128
2 Who to screen for lung cancer. BMJ. 2013 Jul 23;347:f4686. doi: 10.1136/bmj.f4686. PMID: 23882010. Exclusion Code: X10.23882010
3 Quality of life following stereotactic ablative radiation therapy versus surgery for early-stage lung cancer: results from the rosel randomized controlled trial and a systematic review. International journal of radiation oncology. 2016;Conference: 58th Annual Meeting of the American Society for Radiation Oncology, ASTRO 2016. United States. 96(2 Supplement 1):S10–S1. doi: 10.1016/j.ijrobp.2016.06.039. PMID: CN-01448175. Exclusion Code: X2.
4 Abdelsattar ZM, Allen MS, Shen KR, . Variation in hospital adoption rates of video-assisted thoracoscopic lobectomy for lung cancer and the effect on outcomes. Ann Thorac Surg. 2017 Feb;103(2):454–60. doi: 10.1016/j.athoracsur.2016.08.091. PMID: 27825690. Exclusion Code: X3.27825690
5 Abdelsattar ZM, Shen KR, Yendamuri S, . Outcomes after sleeve lung resections versus pneumonectomy in the United States. Ann Thorac Surg. 2017 Nov;104(5):1656–64. doi: 10.1016/j.athoracsur.2017.05.086. PMID: 28935348. Exclusion Code: X3.28935348
6 Abdul Rahim M, North J, Costello S. Stereotactic ablative radiotherapy for inoperable early stage non-small cell lung cancer-Dunedin experience. J Med Imaging Radiat Oncol. 2013;57:120-. doi: 10.1111/1754-9485.12121. PMID: CN-01011012. Exclusion Code: X2.
7 Abdulla S, Salavati A, Saboury B, . Quantitative assessment of global lung inflammation following radiation therapy using FDG PET/CT: a pilot study. Eur J Nucl Med Mol Imaging. 2014 Feb;41(2):350–6. doi: 10.1007/s00259-013-2579-4. PMID: 24085504. Exclusion Code: X3.24085504
8 Abe J, Okazaki T, Kikuchi N, . Preoperative bronchoscopic cancer confirmation does not increase risk of recurrence in stage1A non-small cell lung cancer. Gen Thorac Cardiovasc Surg. 2018 May;66(5):284–90. doi: 10.1007/s11748-018-0909-y. PMID: 29564776. Exclusion Code: X8.29564776
9 Abe T, Shirai K, Saitoh J, . Incidence, risk factors, and dose-volume relationship of radiation-induced rib fracture after carbon ion radiotherapy for lung cancer. Acta Oncol. 2016;55(2):163–6. doi: 10.3109/0284186x.2015.1088169. PMID: 26399488. Exclusion Code: X6.26399488
10 Aberle DR, Adams AM, Berg CD, . Baseline characteristics of participants in the randomized national lung screening trial. J Natl Cancer Inst. 2010 Dec 1;102(23):1771–9. doi: 10.1093/jnci/djq434. PMID: 21119104. Exclusion Code: X8.21119104
11 Abramyuk A, Appold S, Zophel K, . Quantitative modifications of TNM staging, clinical staging and therapeutic intent by FDG-PET/CT in patients with non small cell lung cancer scheduled for radiotherapy--a retrospective study. Lung Cancer. 2012 Nov;78(2):148–52. doi: 10.1016/j.lungcan.2012.08.001. PMID: 22922126. Exclusion Code: X3.22922126
12 Accordino MK, Wright JD, Buono D, . Trends in use and safety of image-guided transthoracic needle biopsies in patients with cancer. J Oncol Pract. 2015 May;11(3):e351–9. doi: 10.1200/jop.2014.001891. PMID: 25604594. Exclusion Code: X3.25604594
13 Adebahr S, Collette S, Shash E, . LungTech, an EORTC Phase II trial of stereotactic body radiotherapy for centrally located lung tumours: a clinical perspective. Br J Radiol. 2015 Jul;88(1051):20150036. doi: 10.1259/bjr.20150036. PMID: 25873481. Exclusion Code: X10.25873481
14 Advani M, Purohit G, Vyas S, . Comparison of Diagnostic Potential of Narrow Band Imaging Bronchoscopy Over White Light Bronchoscopy in Lung Cancer. J Bronchology Interv Pulmonol. 2018 Apr;25(2):132–6. doi: 10.1097/lbr.0000000000000469. PMID: 29346246. Exclusion Code: X3.29346246
15 Agostini P, Lugg ST, Adams K, . Postoperative pulmonary complications and rehabilitation requirements following lobectomy: a propensity score matched study of patients undergoing video-assisted thoracoscopic surgery versus thoracotomydagger. Interact Cardiovasc Thorac Surg. 2017 Jun 1;24(6):931–7. doi: 10.1093/icvts/ivx002. PMID: 28329213. Exclusion Code: X3.28329213
16 Agostini PJ, Lugg ST, Adams K, . Risk factors and short-term outcomes of postoperative pulmonary complications after VATS lobectomy. J Cardiothorac Surg. 2018 Apr 12;13(1):28. doi: 10.1186/s13019-018-0717-6. PMID: 29673386. Exclusion Code: X11.29673386
17 Agzarian J, Hanna WC, Schneider L, . Postdischarge venous thromboembolic complications following pulmonary oncologic resection: An underdetected problem. J Thorac Cardiovasc Surg. 2016 Apr;151(4):992–9. doi: 10.1016/j.jtcvs.2015.11.038. PMID: 26707765. Exclusion Code: X3.26707765
18 Ahmed N, Hasan S, Schumacher L, . Stereotactic body radiotherapy for central lung tumors: Finding the balance between safety and efficacy in the “no fly” zone. Thorac Cancer. 2018 Oct;9(10):1211–4. doi: 10.1111/1759-7714.12764. PMID: 30095228. Exclusion Code: X3.30095228
19 Ahn H, Lee KW, Lee KH, . Effect of computed tomography window settings and reconstruction plane on 8th edition T-stage classification in patients with lung adenocarcinoma manifesting as a subsolid nodule. Eur J Radiol. 2018 Jan;98:130–5. doi: 10.1016/j.ejrad.2017.11.015. PMID: 29279151. Exclusion Code: X3.29279151
20 Ahn SY, Yoon SH, Yang BR, . Risk of pleural recurrence after percutaneous transthoracic needle biopsy in stage I non-small-cell lung cancer. Eur Radiol. 2019 Jan;29(1):270–8. doi: 10.1007/s00330-018-5561-5. PMID: 29948086. Exclusion Code: X11.29948086
21 Ai D, Xu G, Feng L, . Dexmedetomidine does not reduce atrial fibrillation after lung cancer surgery. J Cardiothorac Vasc Anesth. 2015 Apr;29(2):396–401. doi: 10.1053/j.jvca.2014.05.013. PMID: 25440618. Exclusion Code: X3.25440618
22 Akashita S, Tachibana Y, Sakamaki K, . Detection of pure ground-glass nodules in the lung by low-dose multi-detector computed tomography, with use of an iterative reconstruction method: a comparison with conventional image reconstruction by the filtered back-projection method. Jpn J Radiol. 2015 Mar;33(3):113–21. doi: 10.1007/s11604-014-0384-z. PMID: 25552203. Exclusion Code: X3.25552203
23 Akin H, Olcmen A, Isgorucu O, . Approach to patients with chylothorax complicating pulmonary resection. Thorac Cardiovasc Surg. 2012 Mar;60(2):135–9. doi: 10.1055/s-0030-1270990. PMID: 21557161. Exclusion Code: X3.21557161
24 Akthar AS, Ferguson MK, Koshy M, . Limitations of PET/CT in the detection of occult N1 metastasis in clinical stage I(T1-2aN0) non-small cell lung cancer for staging prior to stereotactic body radiotherapy. Technol Cancer Res Treat. 2017 Feb;16(1):15–21. doi: 10.1177/1533034615624045. PMID: 26792491. Exclusion Code: X6.26792491
25 Akthar AS, Koshy M, Ferguson MK, . Effect of endoscopic bronchial ultrasound on outcomes for stage i non-small-cell lung cancer patients receiving hypofractionated radiotherapy. Clin Lung Cancer. 2018 Mar;19(2):e227–e33. doi: 10.1016/j.cllc.2017.08.003. PMID: 28939097. Exclusion Code: X10.28939097
26 Al-Alao BS, O’Callaghan DS, Gately K, . Surgical resection for non-small cell lung cancer: clinical features and outcomes for a consecutive series at an Irish tertiary referral centre. Ir J Med Sci. 2013 Jun;182(2):217–25. doi: 10.1007/s11845-012-0863-0. PMID: 23139062. Exclusion Code: X11.23139062
27 Al-Ameri A, Malhotra P, Thygesen H, . Risk of malignancy in pulmonary nodules: a validation study of four prediction models. Lung Cancer. 2015 Jul;89(1):27–30. doi: 10.1016/j.lungcan.2015.03.018. PMID: 25864782. Exclusion Code: X4.25864782
28 Al-Ameri M, Bergman P, Franco-Cereceda A, . Video-assisted thoracoscopic versus open thoracotomy lobectomy: a Swedish nationwide cohort study. J Thorac Dis. 2018 Jun;10(6):3499–506. doi: 10.21037/jtd.2018.05.177. PMID: 30069346. Exclusion Code: X3.30069346
29 Albano D, Borghesi A, Bosio G, . Pulmonary mucosa-associated lymphoid tissue lymphoma: (18)F-FDG PET/CT and CT findings in 28 patients. Br J Radiol. 2017 Nov;90(1079):20170311. doi: 10.1259/bjr.20170311. PMID: 28830222. Exclusion Code: X3.28830222
30 Albers J, Parker W, Kildea J, . Chest wall pain following lung stereotactic body radiation therapy using 48Gy in three fractions: A search for predictors. Cancer Radiother. 2019 Apr;23(2):98–103. doi: 10.1016/j.canrad.2018.07.140. PMID: 30952561. Exclusion Code: X3.30952561
31 Alberti N, Ferretti G, Buy X, . Diaphragmatic hernia after lung percutaneous radiofrequency ablation: incidence and risk factors. Cardiovasc Intervent Radiol. 2014 Dec;37(6):1516–22. doi: 10.1007/s00270-014-0854-9. PMID: 24519640. Exclusion Code: X6.24519640
32 Alberts L, El Sharouni SY, Hofman FN, . Changes in pulmonary function after stereotactic body radiotherapy and after surgery for stage I and II non-small cell lung cancer, a description of two cohorts. Anticancer Res. 2015 Dec;35(12):6773–9. PMID: 26637895. Exclusion Code: X3.26637895
33 Aldrich MC, Mercaldo SF, Sandler KL, . Evaluation of USPSTF Lung Cancer Screening Guidelines among African American adult smokers. JAMA Oncol. 2019 Jun 27doi: 10.1001/jamaoncol.2019.1402. PMID: 31246249. Exclusion Code: X4.31246249
34 Alexander ES, Machan JT, Ng T, . Cost and effectiveness of radiofrequency ablation versus limited surgical resection for stage I non-small-cell lung cancer in elderly patients: is less more? J Vasc Interv Radiol. 2013 Apr;24(4):476–82. doi: 10.1016/j.jvir.2012.12.016. PMID: 23462066. Exclusion Code: X11.23462066
35 Alexander M, Evans SM, Stirling RG, . The influence of comorbidity and the simplified comorbidity score on overall survival in non-small cell lung cancer-a prospective cohort study. J Thorac Oncol. 2016 May;11(5):748–57. doi: 10.1016/j.jtho.2016.01.016. PMID: 26851495. Exclusion Code: X3.26851495
36 Algan O, Confer M, Algan S, . Quantitative evaluation of correlation of dose and FDG-PET uptake value with clinical chest wall complications in patients with lung cancer treated with stereotactic body radiation therapy. J Xray Sci Technol. 2015;23(6):727–36. doi: 10.3233/xst-150523. PMID: 26756408. Exclusion Code: X3.26756408
37 Ali N, Lifford KJ, Carter B, . Barriers to uptake among high-risk individuals declining participation in lung cancer screening: a mixed methods analysis of the UK Lung Cancer Screening (UKLS) trial. BMJ Open. 2015 Jul 14;5(7):e008254. doi: 10.1136/bmjopen-2015-008254. PMID: 26173719. Exclusion Code: X8.26173719
38 Alite F, Balasubramanian N, Adams W, . Decreased Risk of Radiation Pneumonitis With Coincident Concurrent Use of Angiotensin-converting Enzyme Inhibitors in Patients Receiving Lung Stereotactic Body Radiation Therapy. Am J Clin Oncol. 2018 Jun;41(6):576–80. doi: 10.1097/coc.0000000000000324. PMID: 27560156. Exclusion Code: X3.27560156
39 Al-Jaghbeer M, Marcus M, Durkin M, . Diagnostic yield of electromagnetic navigational bronchoscopy. Ther Adv Respir Dis. 2016 Aug;10(4):295–9. doi: 10.1177/1753465816637053. PMID: 26944363. Exclusion Code: X3.26944363
40 Alshora S, McKee BJ, Regis SM, . Adherence to Radiology Recommendations in a Clinical CT Lung Screening Program. J Am Coll Radiol. 2018 Feb;15(2):282–6. doi: 10.1016/j.jacr.2017.10.014. PMID: 29289507. Exclusion Code: X8.29289507
41 Altorki NK, Yip R, Hanaoka T, . Sublobar resection is equivalent to lobectomy for clinical stage 1A lung cancer in solid nodules. J Thorac Cardiovasc Surg. 2014 Feb;147(2):754–62; Discussion 62-4. doi: 10.1016/j.jtcvs.2013.09.065. PMID: 24280722. Exclusion Code: X11.24280722
42 Ambrogi MC, Fanucchi O, Dini P, . Wedge resection and radiofrequency ablation for stage I nonsmall cell lung cancer. Eur Respir J. 2015 Apr;45(4):1089–97. doi: 10.1183/09031936.00188014. PMID: 25700387. Exclusion Code: X11.25700387
43 Amini A, Yang J, Williamson R, . Dose constraints to prevent radiation-induced brachial plexopathy in patients treated for lung cancer. Int J Radiat Oncol Biol Phys. 2012 Mar 1;82(3):e391–8. doi: 10.1016/j.ijrobp.2011.06.1961. PMID: 22284035. Exclusion Code: X3.22284035
44 Amir GJ, Lehmann HP. After detection: the improved accuracy of lung cancer assessment using radiologic computer-aided diagnosis. Acad Radiol. 2016 Feb;23(2):186–91. doi: 10.1016/j.acra.2015.10.014. PMID: 26616209. Exclusion Code: X9.26616209
45 Amit G, Purdie TG, Levinshtein A, . Automatic learning-based beam angle selection for thoracic IMRT. Med Phys. 2015 Apr;42(4):1992–2005. doi: 10.1118/1.4908000. PMID: 25832090. Exclusion Code: X3.25832090
46 Anami K, Yamashita S, Yamamoto S, . Contralateral mediastinal lymph node micrometastases assessed by video-assisted thoracoscopic surgery in stage I non-small cell left lung cancer. Eur J Cardiothorac Surg. 2013 Apr;43(4):778–82. doi: 10.1093/ejcts/ezs415. PMID: 22822105. Exclusion Code: X11.22822105
47 Anand AK, Punnakal AU, Chaudhoory AR, . Stereotactic body radiation therapy (SBRT) for lung and liver tumours. J Indian Med Assoc. 2012 Jul;110(7):462–4. PMID: 23520671. Exclusion Code: X9.23520671
48 Andersen MB, Harders SW, Ganeshan B, . CT texture analysis can help differentiate between malignant and benign lymph nodes in the mediastinum in patients suspected for lung cancer. Acta Radiol. 2016 Jun;57(6):669–76. doi: 10.1177/0284185115598808. PMID: 26271125. Exclusion Code: X3.26271125
49 Andratschke N, Zimmermann F, Boehm E, . Stereotactic radiotherapy of histologically proven inoperable stage I non-small cell lung cancer: patterns of failure. Radiother Oncol. 2011 Nov;101(2):245–9. doi: 10.1016/j.radonc.2011.06.009. PMID: 21724287. Exclusion Code: X11.21724287
50 Andriole GL. Update of the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Recent Results Cancer Res. 2014;202:53–7. doi: 10.1007/978-3-642-45195-9_6. PMID: 24531777. Exclusion Code: X3.24531777
51 Antonoff MB, Hofstetter WL, Correa AM, . Clinical prediction of pathologic complete response in superior sulcus non-small cell lung cancer. Ann Thorac Surg. 2016 Jan;101(1):211–7. doi: 10.1016/j.athoracsur.2015.06.019. PMID: 26279367. Exclusion Code: X3.26279367
52 Aokage K, Miyoshi T, Ishii G, . Clinical and Pathological Staging Validation in the Eighth Edition of the TNM Classification for Lung Cancer: Correlation between Solid Size on Thin-Section Computed Tomography and Invasive Size in Pathological Findings in the New T Classification. J Thorac Oncol. 2017 Sep;12(9):1403–12. doi: 10.1016/j.jtho.2017.06.003. PMID: 28627462. Exclusion Code: X3.28627462
53 Aokage K, Okada M, Suzuki K, . Is cancer history really an exclusion criterion for clinical trial of lung cancer? Influence of gastrointestinal tract cancer history on the outcomes of lung cancer surgery. Jpn J Clin Oncol. 2017 Feb 15;47(2):145–56. doi: 10.1093/jjco/hyw157. PMID: 28173108. Exclusion Code: X11.28173108
54 Aokage K, Yoshida J, Ishii G, . Identification of early t1b lung adenocarcinoma based on thin-section computed tomography findings. J Thorac Oncol. 2013 Oct;8(10):1289–94. doi: 10.1097/JTO.0b013e31829f6d3b. PMID: 24457240. Exclusion Code: X6.24457240
55 Aoki M, Sato M, Hirose K, . Radiation-induced rib fracture after stereotactic body radiotherapy with a total dose of 54-56 Gy given in 9-7 fractions for patients with peripheral lung tumor: impact of maximum dose and fraction size. Radiat Oncol. 2015 Apr 22;10:99. doi: 10.1186/s13014-015-0406-8. PMID: 25897487. Exclusion Code: X3.25897487
56 Apostolova I, Rogasch J, Buchert R, . Quantitative assessment of the asphericity of pretherapeutic FDG uptake as an independent predictor of outcome in NSCLC. BMC Cancer. 2014 Dec 1;14:896. doi: 10.1186/1471-2407-14-896. PMID: 25444154. Exclusion Code: X3.25444154
57 Appel S, Lawrence YR, Goldstein J, . Stereotactic ablative body radiation for stage I lung cancer in Israel: a retrospective single-center report. Isr Med Assoc J. 2017 Jan;19(1):39–43. PMID: 28457113. Exclusion Code: X10.28457113
58 Aprile V, Bertoglio P, Dini P, . Is left upper lobectomy always worthwhile for early stage lung cancer? A comparison between left upper lobectomy, trisegmentectomy, and lingulectomy. J Surg Oncol. 2018 Mar;117(4):618–24. doi: 10.1002/jso.24884. PMID: 29049856. Exclusion Code: X11.29049856
59 Arcangeli S, Falcinelli L, Bracci S, . Treatment outcomes and patterns of radiologic appearance after hypofractionated image-guided radiotherapy delivered with helical tomotherapy (HHT) for lung tumours. Br J Radiol. 2017 Mar;90(1071):20160853. doi: 10.1259/bjr.20160853. PMID: 28256158. Exclusion Code: X6.28256158
60 Argon A, Nart D, Veral A. The value of cytokeratin 5/6, p63 and thyroid transcription factor-1 in adenocarcinoma, squamous cell carcinoma and non-small-cell lung cancer of the lung. Turk Patoloji Derg. 2015;31(2):81–8. doi: 10.5146/tjpath.2015.01302. PMID: 25944390. Exclusion Code: X5.25944390
61 Armato SG, 3rd, McNitt-Gray MF, Reeves AP, . The Lung Image Database Consortium (LIDC): an evaluation of radiologist variability in the identification of lung nodules on CT scans. Acad Radiol. 2007 Nov;14(11):1409–21. doi: 10.1016/j.acra.2007.07.008. PMID: 17964464. Exclusion Code: X3.17964464
62 Armato SG, 3rd, Roberts RY, Kocherginsky M, . Assessment of radiologist performance in the detection of lung nodules: dependence on the definition of “truth”. Acad Radiol. 2009 Jan;16(1):28–38. doi: 10.1016/j.acra.2008.05.022. PMID: 19064209. Exclusion Code: X3.19064209
63 Armato SG, 3rd, Roberts RY, McNitt-Gray MF, . The Lung Image Database Consortium (LIDC): ensuring the integrity of expert-defined “truth”. Acad Radiol. 2007 Dec;14(12):1455–63. doi: 10.1016/j.acra.2007.08.006. PMID: 18035275. Exclusion Code: X3.18035275
64 Arrieta O, Vega-Gonzalez MT, Lopez-Macias D, . Randomized, open-label trial evaluating the preventive effect of tetracycline on afatinib induced-skin toxicities in non-small cell lung cancer patients. Lung Cancer. 2015 Jun;88(3):282–8. doi: 10.1016/j.lungcan.2015.03.019. PMID: 25882778. Exclusion Code: X3.25882778
65 Arslan S, Yilmaz A, Bayramgurler B, . CT- guided transthoracic fine needle aspiration of pulmonary lesions: accuracy and complications in 294 patients. Med Sci Monit. 2002 Jul;8(7):Cr493–7. PMID: 12118196. Exclusion Code: X3.12118196
66 Asakura K, Izumi Y, Yamauchi Y, . Incidence of pleural recurrence after computed tomography-guided needle biopsy in stage I lung cancer. PLoS One. 2012;7(8):e42043. doi: 10.1371/journal.pone.0042043. PMID: 22876299. Exclusion Code: X11.22876299
67 Asakura K, Mitsuboshi S, Tsuji M, . Pulmonary arterial enlargement predicts cardiopulmonary complications after pulmonary resection for lung cancer: a retrospective cohort study. J Cardiothorac Surg. 2015 Sep 9;10:113. doi: 10.1186/s13019-015-0315-9. PMID: 26353804. Exclusion Code: X11.26353804
68 Ashraf H, de Hoop B, Shaker SB, . Lung nodule volumetry: segmentation algorithms within the same software package cannot be used interchangeably. Eur Radiol. 2010 Aug;20(8):1878–85. doi: 10.1007/s00330-010-1749-z. PMID: 20306082. Exclusion Code: X3.20306082
69 Asplund SA, Johnsson AA, Vikgren J, . Effect of radiation dose level on the detectability of pulmonary nodules in chest tomosynthesis. Eur Radiol. 2014 Jul;24(7):1529–36. doi: 10.1007/s00330-014-3182-1. PMID: 24792590. Exclusion Code: X3.24792590
70 Atallah S, Cho BC, Allibhai Z, . Impact of pretreatment tumor growth rate on outcome of early-stage lung cancer treated with stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 2014 Jul 1;89(3):532–8. doi: 10.1016/j.ijrobp.2014.03.003. PMID: 24929163. Exclusion Code: X13.24929163
71 Attili F, Petrone G, Abdulkader I, . Accuracy and inter-observer agreement of the Procore 25 gauge needle for endoscopic ultrasound-guided tissue core biopsy. Dig Liver Dis. 2015 Nov;47(11):943–9. doi: 10.1016/j.dld.2015.07.003. PMID: 26216067. Exclusion Code: X3.26216067
72 Avanzo M, Barbiero S, Trovo M, . Voxel-by-voxel correlation between radiologically radiation induced lung injury and dose after image-guided, intensity modulated radiotherapy for lung tumors. Phys Med. 2017 Oct;42:150–6. doi: 10.1016/j.ejmp.2017.09.127. PMID: 29173909. Exclusion Code: X3.29173909
73 Awais O, Reidy MR, Mehta K, . Electromagnetic Navigation Bronchoscopy-Guided Dye Marking for Thoracoscopic Resection of Pulmonary Nodules. Ann Thorac Surg. 2016 Jul;102(1):223–9. doi: 10.1016/j.athoracsur.2016.02.040. PMID: 27157054. Exclusion Code: X3.27157054
74 Awano N, Ikushima S, Izumo T, . Efficacy and safety of stereotactic body radiotherapy using CyberKnife in Stage I primary lung tumor. Jpn J Clin Oncol. 2017 Oct 1;47(10):969–75. doi: 10.1093/jjco/hyx100. PMID: 28981731. Exclusion Code: X10.28981731
75 Axelsson R, Herlin G, Baath M, . Role of scintigraphy with technetium-99m depreotide in the diagnosis and management of patients with suspected lung cancer. Acta Radiol. 2008 Apr;49(3):295–302. doi: 10.1080/02841850701793777. PMID: 18365818. Exclusion Code: X3.18365818
76 Bach PB, Kattan MW, Thornquist MD, . Variations in lung cancer risk among smokers. J Natl Cancer Inst. 2003 Mar 19;95(6):470–8. PMID: 12644540. Exclusion Code: X7.12644540
77 Backhus LM, Farjah F, Liang CK, . Imaging surveillance and survival for surgically resected non-small-cell lung cancer. J Surg Res. 2016 Jan;200(1):171–6. doi: 10.1016/j.jss.2015.06.048. PMID: 26231974. Exclusion Code: X3.26231974
78 Backhus LM, Farjah F, Zeliadt SB, . Predictors of imaging surveillance for surgically treated early-stage lung cancer. Ann Thorac Surg. 2014 Dec;98(6):1944–51; discussion 51-2. doi: 10.1016/j.athoracsur.2014.06.067. PMID: 25282167. Exclusion Code: X8.25282167
79 Bade M, Bahr V, Brandt U, . Effect of smoking cessation counseling within a randomised study on early detection of lung cancer in Germany. J Cancer Res Clin Oncol. 2016 May;142(5):959–68. doi: 10.1007/s00432-015-2105-0. PMID: 26814889. Exclusion Code: X8.26814889
80 Bagan P, De Dominicis F, Hernigou J, . Complete thoracoscopic lobectomy for cancer: comparative study of three-dimensional high-definition with two-dimensional high-definition video systems dagger. Interact Cardiovasc Thorac Surg. 2015 Jun;20(6):820–3. doi: 10.1093/icvts/ivv031. PMID: 25736286. Exclusion Code: X11.25736286
81 Baglietto L, Ponzi E, Haycock P, . DNA methylation changes measured in pre-diagnostic peripheral blood samples are associated with smoking and lung cancer risk. Int J Cancer. 2017 Jan 1;140(1):50–61. doi: 10.1002/ijc.30431. PMID: 27632354. Exclusion Code: X10.27632354
82 Bahig H, Filion E, Vu T, . Severe radiation pneumonitis after lung stereotactic ablative radiation therapy in patients with interstitial lung disease. Pract Radiat Oncol. 2016 Sep-Oct;6(5):367–74. doi: 10.1016/j.prro.2016.01.009. PMID: 27068780. Exclusion Code: X10.27068780
83 Bahig H, Filion E, Vu T, . Excellent Cancer Outcomes Following Patient-adapted Robotic Lung SBRT But a Case for Caution in Idiopathic Pulmonary Fibrosis. Technol Cancer Res Treat. 2015 Dec;14(6):667–76. doi: 10.7785/tcrt.2012.500445. PMID: 24988054. Exclusion Code: X10.24988054
84 Baimatova I, Smith C, Beckert L, . Treatment of octogenarians with lung cancer: A single centre audit of treatments and outcomes. N Z Med J. 2015 Aug 7;128(1419):29–34. PMID: 26365843. Exclusion Code: X3.26365843
85 Baine MJ, Verma V, Schonewolf CA, . Histology significantly affects recurrence and survival following SBRT for early stage non-small cell lung cancer. Lung Cancer. 2018 Apr;118:20–6. doi: 10.1016/j.lungcan.2018.01.021. PMID: 29571997. Exclusion Code: X3.29571997
86 Bak SH, Lee HY, Kim JH, . Quantitative CT Scanning Analysis of Pure Ground-Glass Opacity Nodules Predicts Further CT Scanning Change. Chest. 2016 Jan;149(1):180–91. doi: 10.1378/chest.15-0034. PMID: 26313232. Exclusion Code: X3.26313232
87 Baker RR, Tockman MS, Marsh BR, . Screening for bronchogenic carcinoma: the surgical experience. J Thorac Cardiovasc Surg. 1979 Dec;78(6):876–82. PMID: 502570. Exclusion Code: X5.502570
88 Baldvinsson K, Oskarsdottir GN, Orrason AW, . Resection rate and operability of elderly patients with non-small cell lung cancer: Nationwide study from 1991 to 2014. Interact Cardiovasc Thorac Surg. 2017 May 1;24(5):733–9. doi: 10.1093/icvts/ivw415. PMID: 28329255. Exclusion Code: X3.28329255
89 Baldwin DR, Duffy SW, Wald NJ, . UK Lung Screen (UKLS) nodule management protocol: modelling of a single screen randomised controlled trial of low-dose CT screening for lung cancer. Thorax. 2011 Apr;66(4):308–13. doi: 10.1136/thx.2010.152066. PMID: 21317179. Exclusion Code: X8.21317179
90 Balekian AA, Tanner NT, Fisher JM, . Factors Associated with a Positive Baseline Screening Exam Result in the National Lung Screening Trial. Ann Am Thorac Soc. 2016 Sep;13(9):1568–74. doi: 10.1513/AnnalsATS.201602-091OC. PMID: 27387658. Exclusion Code: X8.27387658
91 Baliga S, Bennion N, Richardson KM, . Stereotactic Body Radiation Therapy in Unbiopsied PET+ Pulmonary Tumors. Oncology. 2014;28(1S)PMID: CN-01010573. Exclusion Code: X2.
92 Bandoh S, Fujita J, Tojo Y, . Diagnostic accuracy and safety of flexible bronchoscopy with multiplanar reconstruction images and ultrafast Papanicolaou stain: evaluating solitary pulmonary nodules. Chest. 2003 Nov;124(5):1985–92. PMID: 14605077. Exclusion Code: X3.14605077
93 Bang DH, Lim D, Hwang WS, . Lateral topography for reducing effective dose in low-dose chest CT. AJR Am J Roentgenol. 2013 Jun;200(6):1294–7. doi: 10.2214/ajr.12.9001. PMID: 23701067. Exclusion Code: X3.23701067
94 Banik A, Schwarzer R, Pawlowska I, . Women with family cancer history are at risk for poorer physical quality of life and lower self-efficacy: a longitudinal study among men and women with non-small cell lung cancer. Health Qual Life Outcomes. 2017 Apr 4;15(1):62. doi: 10.1186/s12955-017-0645-5. PMID: 28376887. Exclusion Code: X8.28376887
95 Barta JA, Henschke CI, Flores RM, . Lung cancer diagnosis by fine needle aspiration is associated with reduction in resection of nonmalignant lung nodules. Ann Thorac Surg. 2017 Jun;103(6):1795–801. doi: 10.1016/j.athoracsur.2016.11.055. PMID: 28274517. Exclusion Code: X3.28274517
96 Baumann JL, Li M, Poulsen A, . Analysis of microsatellite mutations in buccal cells from a case-control study for lung cancer. Cancer Epidemiol. 2012 Feb;36(1):e33–9. doi: 10.1016/j.canep.2011.06.003. PMID: 22056752. Exclusion Code: X5.22056752
97 Baumann P, Nyman J, Hoyer M, . Outcome in a prospective phase II trial of medically inoperable stage I non-small-cell lung cancer patients treated with stereotactic body radiotherapy. J Clin Oncol. 2009 Jul 10;27(20):3290–6. doi: 10.1200/jco.2008.21.5681. PMID: 19414667. Exclusion Code: X11.19414667
98 Baxa J, Matouskova T, Ludvik J, . Single-source Dual-energy CT as a Part of (18)F-FDG PET/CT: Direct Comparison of Iodine-related and Metabolic Parameters in Non-small Cell Lung Cancer. Anticancer Res. 2018 Jul;38(7):4131–7. doi: 10.21873/anticanres.12704. PMID: 29970540. Exclusion Code: X3.29970540
99 Bayanati H, R ET, Souza CA, . Quantitative CT texture and shape analysis: can it differentiate benign and malignant mediastinal lymph nodes in patients with primary lung cancer? Eur Radiol. 2015 Feb;25(2):480–7. doi: 10.1007/s00330-014-3420-6. PMID: 25216770. Exclusion Code: X3.25216770
100 Bedetti B, Bertolaccini L, Rocco R, . Segmentectomy versus lobectomy for stage I non-small cell lung cancer: a systematic review and meta-analysis. J Thorac Dis. 2017 Jun;9(6):1615–23. doi: 10.21037/jtd.2017.05.79. PMID: 28740676. Exclusion Code: X9.28740676
101 Belfiore G, Ronza F, Belfiore MP, . Patients’ survival in lung malignancies treated by microwave ablation: our experience on 56 patients. Eur J Radiol. 2013 Jan;82(1):177–81. doi: 10.1016/j.ejrad.2012.08.024. PMID: 23099201. Exclusion Code: X6.23099201
102 Bellezza G, Vannucci J, Bianconi F, . Prognostic implication of aquaporin 1 overexpression in resected lung adenocarcinoma. Interact Cardiovasc Thorac Surg. 2017 Dec 1;25(6):856–61. doi: 10.1093/icvts/ivx202. PMID: 29106595. Exclusion Code: X3.29106595
103 Bellinger CR, Khan I, Chatterjee AB, . Bronchoscopy Safety in Patients With Chronic Obstructive Lung Disease. J Bronchology Interv Pulmonol. 2017 Apr;24(2):98–103. doi: 10.1097/lbr.0000000000000333. PMID: 28005831. Exclusion Code: X3.28005831
104 Bendixen M, Jorgensen OD, Kronborg C, . Postoperative pain and quality of life after lobectomy via video-assisted thoracoscopic surgery or anterolateral thoracotomy for early stage lung cancer: a randomised controlled trial. Lancet Oncol. 2016 Jun;17(6):836–44. doi: 10.1016/s1470-2045(16)00173-x. PMID: 27160473. Exclusion Code: X11.27160473
105 Bergamo C, Sigel K, Mhango G, . Inequalities in lung cancer care of elderly patients with schizophrenia: an observational cohort study. Psychosom Med. 2014 Apr;76(3):215–20. doi: 10.1097/psy.0000000000000050. PMID: 24677164. Exclusion Code: X3.24677164
106 Bernatowicz K, Keall P, Mishra P, . Quantifying the impact of respiratory-gated 4D CT acquisition on thoracic image quality: a digital phantom study. Med Phys. 2015 Jan;42(1):324–34. doi: 10.1118/1.4903936. PMID: 25563272. Exclusion Code: X3.25563272
107 Berrington de Gonzalez A, Kim KP, Berg CD. Low-dose lung computed tomography screening before age 55: estimates of the mortality reduction required to outweigh the radiation-induced cancer risk. J Med Screen. 2008;15(3):153–8. doi: 10.1258/jms.2008.008052. PMID: 18927099. Exclusion Code: X4.18927099
108 Berry MF, D’Amico TA, Onaitis MW, . Thoracoscopic approach to lobectomy for lung cancer does not compromise oncologic efficacy. Ann Thorac Surg. 2014 Jul;98(1):197–202. doi: 10.1016/j.athoracsur.2014.03.018. PMID: 24820392. Exclusion Code: X10.24820392
109 Berry MF, Onaitis MW, Tong BC, . Feasibility of hybrid thoracoscopic lobectomy and en-bloc chest wall resection. Eur J Cardiothorac Surg. 2012 Apr;41(4):888–92. doi: 10.1093/ejcts/ezr150. PMID: 22219441. Exclusion Code: X3.22219441
110 Berry MF, Yang CJ, Hartwig MG, . Impact of Pulmonary Function Measurements on Long-Term Survival After Lobectomy for Stage I Non-Small Cell Lung Cancer. Ann Thorac Surg. 2015 Jul;100(1):271–6. doi: 10.1016/j.athoracsur.2015.02.076. PMID: 25986099. Exclusion Code: X3.25986099
111 Berthet JP, Paradela M, Jimenez MJ, . Extended sleeve lobectomy: one more step toward avoiding pneumonectomy in centrally located lung cancer. Ann Thorac Surg. 2013 Dec;96(6):1988–97. doi: 10.1016/j.athoracsur.2013.07.011. PMID: 24035301. Exclusion Code: X3.24035301
112 Bertolaccini L, Davoli F, Pardolesi A, . Conversion due to vascular injury during video-assisted thoracic surgery lobectomy: A multicentre retrospective analysis from the Italian video-assisted thoracic surgery group registry. Eur J Surg Oncol. 2019 May;45(5):857–62. doi: 10.1016/j.ejso.2018.12.023. PMID: 30661924. Exclusion Code: X10.30661924
113 Bhandari RP, Stanford JD, Packianathan S, . Stereotactic Body Radiation Therapy for Stage I Non-Small Cell Lung Cancer: A Retrospective, Single-Center Study of 55 Patients. Oncology. 2016;91(4):194–204. doi: 10.1159/000447540. PMID: 27427761. Exclusion Code: X10.27427761
114 Bhatt AD, El-Ghamry MN, Dunlap NE, . Tumor volume change with stereotactic body radiotherapy (SBRT) for early-stage lung cancer: evaluating the potential for adaptive SBRT. Am J Clin Oncol. 2015 Feb;38(1):41–6. doi: 10.1097/COC.0b013e318287bd7f. PMID: 24513663. Exclusion Code: X8.24513663
115 Bhatt KM, Tandon YK, Graham R, . Electromagnetic Navigational Bronchoscopy versus CT-guided Percutaneous Sampling of Peripheral Indeterminate Pulmonary Nodules: A Cohort Study. Radiology. 2018 Mar;286(3):1052–61. doi: 10.1148/radiol.2017170893. PMID: 29156147. Exclusion Code: X3.29156147
116 Biederer J, Ohno Y, Hatabu H, . Screening for lung cancer: Does MRI have a role? Eur J Radiol. 2017 Jan;86:353–60. doi: 10.1016/j.ejrad.2016.09.016. PMID: 27665148. Exclusion Code: X9.27665148
117 Bilgin Buyukkarabacak Y, Taslak Sengul A, Meydan BC, . The risk of tumor cell dissemination in mediastinoscopy: a cytological study. Turk J Med Sci. 2015;45(4):872–6. PMID: 26422860. Exclusion Code: X3.26422860
118 Bille A, Ahmad U, Woo KM, . Detection of Recurrence Patterns After Wedge Resection for Early Stage Lung Cancer: Rationale for Radiologic Follow-Up. Ann Thorac Surg. 2016 Oct;102(4):1067–73. doi: 10.1016/j.athoracsur.2016.04.056. PMID: 27345095. Exclusion Code: X11.27345095
119 Bille A, Okiror L, Skanjeti A, . Evaluation of integrated positron emission tomography and computed tomography accuracy in detecting lymph node metastasis in patients with adenocarcinoma vs squamous cell carcinoma. Eur J Cardiothorac Surg. 2013 Mar;43(3):574–9. doi: 10.1093/ejcts/ezs366. PMID: 22689182. Exclusion Code: X10.22689182
120 Bille A, Pelosi E, Skanjeti A, . Preoperative intrathoracic lymph node staging in patients with non-small-cell lung cancer: accuracy of integrated positron emission tomography and computed tomography. Eur J Cardiothorac Surg. 2009 Sep;36(3):440–5. doi: 10.1016/j.ejcts.2009.04.003. PMID: 19464906. Exclusion Code: X3.19464906
121 Bille A, Woo KM, Ahmad U, . Incidence of occult pN2 disease following resection and mediastinal lymph node dissection in clinical stage I lung cancer patients. Eur J Cardiothorac Surg. 2017 Apr 1;51(4):674–9. doi: 10.1093/ejcts/ezw400. PMID: 28200091. Exclusion Code: X3.28200091
122 Billmeier SE, Ayanian JZ, He Y, . Predictors of nursing home admission, severe functional impairment, or death one year after surgery for non-small cell lung cancer. Ann Surg. 2013 Mar;257(3):555–63. doi: 10.1097/SLA.0b013e31828353af. PMID: 23386241. Exclusion Code: X3.23386241
123 Binkley MS, King MT, Shrager JB, . Pulmonary function after lung tumor stereotactic ablative radiotherapy depends on regional ventilation within irradiated lung. Radiother Oncol. 2017 May;123(2):270–5. doi: 10.1016/j.radonc.2017.03.021. PMID: 28460826. Exclusion Code: X10.28460826
124 Binkley MS, Shrager JB, Chaudhuri A, . Time course and predictive factors for lung volume reduction following stereotactic ablative radiotherapy (SABR) of lung tumors. Radiat Oncol. 2016 Mar 15;11:40. doi: 10.1186/s13014-016-0616-8. PMID: 26975700. Exclusion Code: X10.26975700
125 Bishawi M, Kim B, Moore WH, . Pulmonary function testing after stereotactic body radiotherapy to the lung. Int J Radiat Oncol Biol Phys. 2012 Jan 1;82(1):e107–10. doi: 10.1016/j.ijrobp.2011.01.037. PMID: 21470798. Exclusion Code: X8.21470798
126 Biswas T, Walker P, Podder T, . Effect of race and insurance on the outcome of stage I non-small cell lung cancer. Anticancer Res. 2015 Jul;35(7):4243–9. PMID: 26124385. Exclusion Code: X12.26124385
127 Black WC. Overdiagnosis: An underrecognized cause of confusion and harm in cancer screening. J Natl Cancer Inst. 2000 Aug 16;92(16):1280–2. PMID: 10944539. Exclusion Code: X10.10944539
128 Black WC, Gareen IF, Soneji SS, . Cost-effectiveness of CT screening in the National Lung Screening Trial. N Engl J Med. 2014 Nov 06;371(19):1793–802. doi: 10.1056/NEJMoa1312547. PMID: 25372087. Exclusion Code: X8.25372087
129 Blanchon T, Brechot JM, Grenier PA, . Baseline results of the Depiscan study: a French randomized pilot trial of lung cancer screening comparing low dose CT scan (LDCT) and chest X-ray (CXR). Lung Cancer. 2007 Oct;58(1):50–8. doi: 10.1016/j.lungcan.2007.05.009. PMID: 17624475. Exclusion Code: X11.17624475
130 Bogoni L, Ko JP, Alpert J, . Impact of a computer-aided detection (CAD) system integrated into a picture archiving and communication system (PACS) on reader sensitivity and efficiency for the detection of lung nodules in thoracic CT exams. J Digit Imaging. 2012 Dec;25(6):771–81. doi: 10.1007/s10278-012-9496-0. PMID: 22710985. Exclusion Code: X11.22710985
131 Bogot NR, Kazerooni EA, Kelly AM, . Interobserver and intraobserver variability in the assessment of pulmonary nodule size on CT using film and computer display methods. Acad Radiol. 2005 Aug;12(8):948–56. doi: 10.1016/j.acra.2005.04.009. PMID: 16087090. Exclusion Code: X3.16087090
132 Boiselle PM, White CS, Ravenel JG. Computed tomographic screening for lung cancer: current practice patterns at leading academic medical centers. JAMA Intern Med. 2014 Feb 1;174(2):286–7. doi: 10.1001/jamainternmed.2013.12693. PMID: 24322527. Exclusion Code: X10.24322527
133 Bollen EC, Goei R, van ’t Hof-Grootenboer BE, . Interobserver variability and accuracy of computed tomographic assessment of nodal status in lung cancer. Ann Thorac Surg. 1994 Jul;58(1):158–62. PMID: 8037515. Exclusion Code: X3.8037515
134 Booth K, Hanna GG, McGonigle N, . The mediastinal staging accuracy of 18F-Fluorodeoxyglycose positron emission tomography/computed tomography in non-small cell lung cancer with variable time intervals to surgery. Ulster Med J. 2013 May;82(2):75–81. PMID: 24082283. Exclusion Code: X3.24082283
135 Borghesi A, Farina D, Michelini S, . Pulmonary adenocarcinomas presenting as ground-glass opacities on multidetector CT: three-dimensional computer-assisted analysis of growth pattern and doubling time. Diagn Interv Radiol. 2016 Nov-Dec;22(6):525–33. doi: 10.5152/dir.2016.16110. PMID: 27682741. Exclusion Code: X8.27682741
136 Borst GR, Ishikawa M, Nijkamp J, . Radiation pneumonitis in patients treated for malignant pulmonary lesions with hypofractionated radiation therapy. Radiother Oncol. 2009 Jun;91(3):307–13. doi: 10.1016/j.radonc.2009.02.003. PMID: 19321217. Exclusion Code: X3.19321217
137 Bosinceanu M, Sandu C, Ionescu LR, . Clinical-epidemiological study on the incidence of postoperative complications after pulmonary resection for lung cancer. Rev Med Chir Soc Med Nat Iasi. 2014 Oct-Dec;118(4):1040–6. PMID: 25581967. Exclusion Code: X3.25581967
138 Botling J, Edlund K, Lohr M, . Biomarker discovery in non-small cell lung cancer: integrating gene expression profiling, meta-analysis, and tissue microarray validation. Clin Cancer Res. 2013 Jan 1;19(1):194–204. doi: 10.1158/1078-0432.ccr-12-1139. PMID: 23032747. Exclusion Code: X3.23032747
139 Bott MJ, Patel AP, Crabtree TD, . Pathologic Upstaging in Patients Undergoing Resection for Stage I Non-Small Cell Lung Cancer: Are There Modifiable Predictors? Ann Thorac Surg. 2015 Dec;100(6):2048–53. doi: 10.1016/j.athoracsur.2015.05.100. PMID: 26277562. Exclusion Code: X8.26277562
140 Bousamra M, 2nd, Schumer E, Li M, . Quantitative analysis of exhaled carbonyl compounds distinguishes benign from malignant pulmonary disease. J Thorac Cardiovasc Surg. 2014 Sep;148(3):1074–80; discussion 80-1. doi: 10.1016/j.jtcvs.2014.06.006. PMID: 25129599. Exclusion Code: X3.25129599
141 Bousema JE, Dijkgraaf MGW, Papen-Botterhuis NE, . MEDIASTinal staging of non-small cell lung cancer by endobronchial and endoscopic ultrasonography with or without additional surgical mediastinoscopy (MEDIASTrial): study protocol of a multicenter randomised controlled trial. BMC Surg. 2018 May 18;18(1):27. doi: 10.1186/s12893-018-0359-6. PMID: 29776444. Exclusion Code: X3.29776444
142 Braak SJ, Herder GJ, van Heesewijk JP, . Pulmonary masses: initial results of cone-beam CT guidance with needle planning software for percutaneous lung biopsy. Cardiovasc Intervent Radiol. 2012 Dec;35(6):1414–21. doi: 10.1007/s00270-011-0302-z. PMID: 22146973. Exclusion Code: X3.22146973
143 Bradley JD, El Naqa I, Drzymala RE, . Stereotactic body radiation therapy for early-stage non-small-cell lung cancer: the pattern of failure is distant. Int J Radiat Oncol Biol Phys. 2010 Jul 15;77(4):1146–50. doi: 10.1016/j.ijrobp.2009.06.017. PMID: 19800181. Exclusion Code: X11.19800181
144 Brain K, Carter B, Lifford KJ, . Impact of low-dose CT screening on smoking cessation among high-risk participants in the UK Lung Cancer Screening Trial. Thorax. 2017 Oct;72(10):912–8. doi: 10.1136/thoraxjnl-2016-209690. PMID: 28710339. Exclusion Code: X17.28710339
145 Brain K, Lifford KJ, Carter B, . Long-term psychosocial outcomes of low-dose CT screening: results of the UK Lung Cancer Screening randomised controlled trial. Thorax. 2016 Nov;71(11):996–1005. doi: 10.1136/thoraxjnl-2016-208283. PMID: 27471048. Exclusion Code: X17.27471048
146 Bral S, Gevaert T, Linthout N, . Prospective, risk-adapted strategy of stereotactic body radiotherapy for early-stage non-small-cell lung cancer: results of a Phase II trial. Int J Radiat Oncol Biol Phys. 2011 Aug 1;80(5):1343–9. doi: 10.1016/j.ijrobp.2010.04.056. PMID: 20708849. Exclusion Code: X11.20708849
147 Braun FM, Holzner V, Meinel FG, . Improved assessment of mediastinal and pulmonary pathologies in combined staging CT examinations using a fast-speed acquisition dual-source CT protocol. Eur Radiol. 2017 Dec;27(12):4931–40. doi: 10.1007/s00330-017-4888-7. PMID: 28677055. Exclusion Code: X3.28677055
148 Brenner A, James S, Malo TL, . Analysis of patient-provider conversations to assess quality of shared decision making about lung cancer screening. SciAbstracts: Lineberger Comprehensive Cancer Center, University of North Carolina at Chapel Hill; 2018. Exclusion Code: X5.
149 Brenner DJ. Radiation risks potentially associated with low-dose CT screening of adult smokers for lung cancer. Radiology. 2004 May;231(2):440–5. doi: 10.1148/radiol.2312030880. PMID: 15128988. Exclusion Code: X4.15128988
150 Brochu B, Beigelman-Aubry C, Goldmard J, . Computer-aided detection of lung nodules on thin collimation MDCT: impact on radiologists’ performance. J Radiol. 2007;88(4):573–8. PMID: CN-00588342. Exclusion Code: X7.17464256
151 Brocken P, van der Heijden HF, Dekhuijzen PN, . High performance of F-fluorodeoxyglucose positron emission tomography and contrast-enhanced CT in a rapid outpatient diagnostic program for patients with suspected lung cancer. Respiration. 2014;87(1):32–7. doi: 10.1159/000347096. PMID: 23595051. Exclusion Code: X11.23595051
152 Brodersen J, Dirksen A, Pedersen JH. Screening for lung cancer with low-dose computed tomography. Ann Intern Med. 2014 Feb 04;160(3):212. doi: 10.7326/l14-5003-2. PMID: 24658700. Exclusion Code: X9.24658700
153 Broekhuizen H, Groothuis-Oudshoorn CGM, Vliegenthart R, . Assessing Lung Cancer Screening Programs under Uncertainty in a Heterogeneous Population. Value Health. 2018 Nov;21(11):1269–77. doi: 10.1016/j.jval.2018.01.021. PMID: 30442273. Exclusion Code: X3.30442273
154 Broodman I, VanDuijn MM, Stingl C, . Survivin Autoantibodies Are Not Elevated in Lung Cancer When Assayed Controlling for Specificity and Smoking Status. Cancer Immunol Res. 2016 Feb;4(2):165–72. doi: 10.1158/2326-6066.cir-14-0176. PMID: 26659304. Exclusion Code: X4.26659304
155 Brooks ED, Sun B, Feng L. Association of Long-term Outcomes and Survival With Multidisciplinary Salvage Treatment for Local and Regional Recurrence After Stereotactic Ablative Radiotherapy for Early-Stage Lung Cancer. JAMA Network Open. 2018;1(4):e181390. doi: doi:10.1001/jamanetworkopen.2018.1390. Exclusion Code: X3.30646121
156 Brown LM, Cooke DT, Jett JR, . Extent of Resection and Lymph Node Assessment for Clinical Stage T1aN0M0 Typical Carcinoid Tumors. Ann Thorac Surg. 2018 Jan;105(1):207–13. doi: 10.1016/j.athoracsur.2017.07.049. PMID: 29132704. Exclusion Code: X3.29132704
157 Brunelli A, Dinesh P, Woodcock-Shaw J, . Ninety-Day Mortality After Video-Assisted Thoracoscopic Lobectomy: Incidence and Risk Factors. Ann Thorac Surg. 2017 Sep;104(3):1020–6. doi: 10.1016/j.athoracsur.2017.02.083. PMID: 28577845. Exclusion Code: X3.28577845
158 Brunelli A, Pompili C, Salati M, . Preoperative maximum oxygen consumption is associated with prognosis after pulmonary resection in stage I non-small cell lung cancer. Ann Thorac Surg. 2014 Jul;98(1):238–42. doi: 10.1016/j.athoracsur.2014.04.029. PMID: 24874414. Exclusion Code: X11.24874414
159 Brunelli A, Salati M, Rocco G, . European risk models for morbidity (EuroLung1) and mortality (EuroLung2) to predict outcome following anatomic lung resections: an analysis from the European Society of Thoracic Surgeons database. Eur J Cardiothorac Surg. 2017 Mar 1;51(3):490–7. doi: 10.1093/ejcts/ezw319. PMID: 27744321. Exclusion Code: X3.27744321
160 Bryant AK, Mundt R, Sandhu APS, . Stereotactic body radiation therapy versus surgery for early non-small-cell lung cancer in the veterans affairs system. International journal of radiation oncology biology physics. 2017;99(2):S7-. doi: 10.1016/j.ijrobp.2017.06.1661. PMID: CN-01422912. Exclusion Code: X2.
161 Bugge A, Lund MB, Brunborg C, . Survival After Surgical Resection for Lung Cancer in Patients With Chronic Obstructive Pulmonary Disease. Ann Thorac Surg. 2016 Jun;101(6):2125–31. doi: 10.1016/j.athoracsur.2015.12.057. PMID: 27016839. Exclusion Code: X3.27016839
162 Bugge AS, Lund MB, Valberg M, . Cause-specific death after surgical resection for early-stage non-small-cell lung cancer. Eur J Cardiothorac Surg. 2018 Jan 1;53(1):221–7. doi: 10.1093/ejcts/ezx274. PMID: 28950311. Exclusion Code: X10.28950311
163 Bui NC, Lee YY, Suh M, . Beliefs and Intentions to Undergo Lung Cancer Screening among Korean Males. Cancer Res Treat. 2018 Oct;50(4):1096–105. doi: 10.4143/crt.2017.393. PMID: 29141395. Exclusion Code: X6.29141395
164 Burt BM, Kosinski AS, Shrager JB, . Thoracoscopic lobectomy is associated with acceptable morbidity and mortality in patients with predicted postoperative forced expiratory volume in 1 second or diffusing capacity for carbon monoxide less than 40% of normal. J Thorac Cardiovasc Surg. 2014 Jul;148(1):19–28, dicussion -9.e1. doi: 10.1016/j.jtcvs.2014.03.007. PMID: 24766848. Exclusion Code: X3.24766848
165 Butof R, Simon M, Lock S, . PORTAF - postoperative radiotherapy of non-small cell lung cancer: accelerated versus conventional fractionation - study protocol for a randomized controlled trial. Trials. 2017;18(1)doi: 10.1186/s13063-017-2346-0. PMID: CN-01441318. Exclusion Code: X6.
166 Calcagni ML, Taralli S, Cardillo G, . Diagnostic performance of (18)F-Fluorodeoxyglucose in 162 small pulmonary nodules incidentally detected in subjects without a history of malignancy. Ann Thorac Surg. 2016 Apr;101(4):1303–9. doi: 10.1016/j.athoracsur.2015.10.072. PMID: 26822348. Exclusion Code: X3.26822348
167 Calderon-Santiago M, Priego-Capote F, Turck N, . Human sweat metabolomics for lung cancer screening. Anal Bioanal Chem. 2015 Jul;407(18):5381–92. doi: 10.1007/s00216-015-8700-8. PMID: 25935675. Exclusion Code: X5.25935675
168 Call S, Obiols C, Rami-Porta R, . Video-Assisted Mediastinoscopic Lymphadenectomy for Staging Non-Small Cell Lung Cancer. Ann Thorac Surg. 2016 Apr;101(4):1326–33. doi: 10.1016/j.athoracsur.2015.10.073. PMID: 26806169. Exclusion Code: X3.26806169
169 Callahan J, Kron T, Schneider ME, . A prospective investigation into the clinical impact of 4D-PET/CT in the characterisation of solitary pulmonary nodules. Cancer Imaging. 2014 Jun 5;14:24. doi: 10.1186/1470-7330-14-24. PMID: 25608679. Exclusion Code: X8.25608679
170 Callahan J, Kron T, Siva S, . Geographic miss of lung tumours due to respiratory motion: a comparison of 3D vs 4D PET/CT defined target volumes. Radiat Oncol. 2014 Dec 16;9:291. doi: 10.1186/s13014-014-0291-6. PMID: 25511904. Exclusion Code: X3.25511904
171 Cannon DM, Mehta MP, Adkison JB, . Dose-limiting toxicity after hypofractionated dose-escalated radiotherapy in non-small-cell lung cancer. J Clin Oncol. 2013 Dec 1;31(34):4343–8. doi: 10.1200/jco.2013.51.5353. PMID: 24145340. Exclusion Code: X6.24145340
172 Cannon NA, Meyer J, Iyengar P, . Neutrophil-lymphocyte and platelet-lymphocyte ratios as prognostic factors after stereotactic radiation therapy for early-stage non-small-cell lung cancer. J Thorac Oncol. 2015 Feb;10(2):280–5. doi: 10.1097/jto.0000000000000399. PMID: 25299234. Exclusion Code: X10.25299234
173 Cao C, Wang D, Chung C, . A systematic review and meta-analysis of stereotactic body radiation therapy versus surgery for patients with non-small cell lung cancer. J Thorac Cardiovasc Surg. 2019 Jan;157(1):362–73.e8. doi: 10.1016/j.jtcvs.2018.08.075. PMID: 30482524. Exclusion Code: X3.30482524
174 Capalbo E, Peli M, Lovisatti M, . Trans-thoracic biopsy of lung lesions: FNAB or CNB? Our experience and review of the literature. Radiol Med. 2014 Aug;119(8):572–94. doi: 10.1007/s11547-013-0360-1. PMID: 24297594. Exclusion Code: X11.24297594
175 Capasso R, Nizzoli R, Tiseo M, . Extra-pleuric coaxial system for CT-guided percutaneous fine-needle aspiration biopsy (FNAB) of small (</=20 mm) lung nodules: a novel technique using multiplanar reconstruction (MPR) images. Med Oncol. 2017 Feb;34(2):17. doi: 10.1007/s12032-016-0871-4. PMID: 28035579. Exclusion Code: X3.28035579
176 Carlsson A, Nair VS, Luttgen MS, . Circulating tumor microemboli diagnostics for patients with non-small-cell lung cancer. J Thorac Oncol. 2014 Aug;9(8):1111–9. doi: 10.1097/jto.0000000000000235. PMID: 25157764. Exclusion Code: X3.25157764
177 Caronia FP, Fiorelli A, Ruffini E, . A comparative analysis of Pancoast tumour resection performed via video-assisted thoracic surgery versus standard open approaches. Interact Cardiovasc Thorac Surg. 2014 Sep;19(3):426–35. doi: 10.1093/icvts/ivu115. PMID: 25052071. Exclusion Code: X3.25052071
178 Carozzi FM, Bisanzi S, Carrozzi L, . Multimodal lung cancer screening using the ITALUNG biomarker panel and low dose computed tomography. Results of the ITALUNG biomarker study. Int J Cancer. 2017 Jul 01;141(1):94–101. doi: 10.1002/ijc.30727. PMID: 28387927. Exclusion Code: X7.28387927
179 Carrafiello G, Mangini M, Fontana F, . Microwave ablation of lung tumours: single-centre preliminary experience. Radiol Med. 2014 Jan;119(1):75–82. doi: 10.1007/s11547-013-0301-z. PMID: 24234180. Exclusion Code: X6.24234180
180 Carrillo SA, Daniel VC, Hall N, . Fusion positron emission/computed tomography underestimates the presence of hilar nodal metastases in patients with resected non-small cell lung cancer. Ann Thorac Surg. 2012 May;93(5):1621–4. doi: 10.1016/j.athoracsur.2012.01.006. PMID: 22429676. Exclusion Code: X3.22429676
181 Carter G, Barrett A, Kaye J, . A comprehensive review of nongenetic prognostic and predictive factors influencing the heterogeneity of outcomes in advanced non-small-cell lung cancer (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):437–49. PMID: DARE-12014067536. Exclusion Code: X3.
182 Cassidy A, Myles JP, van Tongeren M, . The LLP risk model: an individual risk prediction model for lung cancer. Br J Cancer. 2008 Jan 29;98(2):270–6. doi: 10.1038/sj.bjc.6604158. PMID: 18087271. Exclusion Code: X7.18087271
183 Cassidy RJ, Patel PR, Zhang X, . Stereotactic Body Radiotherapy for Early-stage Non-small-cell Lung Cancer in Patients 80 Years and Older: A Multi-center Analysis. Clin Lung Cancer. 2017 Sep;18(5):551–8.e6. doi: 10.1016/j.cllc.2017.03.006. PMID: 28373068. Exclusion Code: X3.28373068
184 Casutt A, Bouchaab H, Beigelman-Aubry C, . Stereotactic body radiotherapy with helical TomoTherapy for medically inoperable early stage primary and second-primary non-small-cell lung neoplasm: 1-year outcome and toxicity analysis. Br J Radiol. 2015 May;88(1049):20140687. doi: 10.1259/bjr.20140687. PMID: 25735428. Exclusion Code: X3.25735428
185 Casutt A, Prella M, Beigelman-Aubry C, . Fluoroscopic-Guided Radial Endobronchial Ultrasound Without Guide Sheath For Peripheral Pulmonary Lesions: A Safe And Efficient Combination. Arch Bronconeumol. 2015 Jul;51(7):338–43. doi: 10.1016/j.arbres.2014.09.017. PMID: 25769444. Exclusion Code: X3.25769444
186 Cataldo JK. High-risk older smokers’ perceptions, attitudes, and beliefs about lung cancer screening. Cancer Med. 2016 Apr;5(4):753–9. doi: 10.1002/cam4.617. PMID: 26822940. Exclusion Code: X8.26822940
187 Cattoni M, Vallieres E, Brown LM, . External Validation of a Prognostic Model of Survival for Resected Typical Bronchial Carcinoids. Ann Thorac Surg. 2017 Oct;104(4):1215–20. doi: 10.1016/j.athoracsur.2017.05.019. PMID: 28821334. Exclusion Code: X3.28821334
188 Cavic M, Spasic J, Krivokuca A, . TP53 and DNA-repair gene polymorphisms genotyping as a low-cost lung adenocarcinoma screening tool. J Clin Pathol. 2019 Jan;72(1):75–80. doi: 10.1136/jclinpath-2018-205553. PMID: 30467244. Exclusion Code: X3.30467244
189 Cazzoli R, Buttitta F, Di Nicola M, . microRNAs derived from circulating exosomes as noninvasive biomarkers for screening and diagnosing lung cancer. J Thorac Oncol. 2013 Sep;8(9):1156–62. doi: 10.1097/JTO.0b013e318299ac32. PMID: 23945385. Exclusion Code: X5.23945385
190 Cengiz A, Aydin F, Sipahi M, . The role of F-18 FDG PET/CT in differentiating benign from malignant pulmonary masses and accompanying lymph nodes. Tuberk Toraks. 2018 Jun;66(2):130–5. doi: 10.5578/tt.10809. PMID: 30246656. Exclusion Code: X3.30246656
191 Centers for Medicare & Medicaid Services. Proposed decision memo for screening for lung cancer with low dose computed tomography (LDCT) (CAG-00439N). Baltimore, MD: U.S. Centers for Medicare & Medicaid Services; 2014. https://www.cms.gov/medicare-coverage-database/details/nca-proposed-decision-memo.aspx?NCAId=274 Accessed Nov 20, 2017. Exclusion Code: X10.
192 Ceppi M, Munnia A, Cellai F, . Linking the generation of DNA adducts to lung cancer. Toxicology. 2017 Sep 1;390:160–6. doi: 10.1016/j.tox.2017.09.011. PMID: 28928033. Exclusion Code: X3.28928033
193 Cerfolio RJ, Ojha B, Bryant AS, . The accuracy of integrated PET-CT compared with dedicated PET alone for the staging of patients with nonsmall cell lung cancer. Ann Thorac Surg. 2004 Sep;78(3):1017–23; discussion -23. doi: 10.1016/j.athoracsur.2004.02.067. PMID: 15337041. Exclusion Code: X3.15337041
194 Cerfolio RJ, Watson C, Minnich DJ, . One Hundred Planned Robotic Segmentectomies: Early Results, Technical Details, and Preferred Port Placement. Ann Thorac Surg. 2016 Mar;101(3):1089–95; Discussion 95-6. doi: 10.1016/j.athoracsur.2015.08.092. PMID: 26846343. Exclusion Code: X3.26846343
195 Cerra-Franco A, Liu S, Azar M, . Predictors of Nodal and Metastatic Failure in Early Stage Non-small-cell Lung Cancer After Stereotactic Body Radiation Therapy. Clin Lung Cancer. 2019 May;20(3):186–93.e3. doi: 10.1016/j.cllc.2018.12.016. PMID: 30711394. Exclusion Code: X13.30711394
196 Cha N, Lv M, Zhao YJ, . Diagnostic utility of VEGF mRNA and SP1 mRNA expression in bronchial cells of patients with lung cancer. Respirology. 2014 May;19(4):544–8. doi: 10.1111/resp.12272. PMID: 24661424. Exclusion Code: X3.24661424
197 Chabowski M, Szymanska-Chabowska A, Skotarczak J, . The role of mediastinoscopy in the diagnosis of thoracic disease: one-year single center experience. Adv Exp Med Biol. 2015;852:1–4. doi: 10.1007/5584_2014_101. PMID: 25416070. Exclusion Code: X11.25416070
198 Chambers SK, Baade P, Youl P, . Psychological distress and quality of life in lung cancer: the role of health-related stigma, illness appraisals and social constraints. Psychooncology. 2015 Nov;24(11):1569–77. doi: 10.1002/pon.3829. PMID: 25920906. Exclusion Code: X6.25920906
199 Chan A, Devanand A, Low SY, . Radial endobronchial ultrasound in diagnosing peripheral lung lesions in a high tuberculosis setting. BMC Pulm Med. 2015 Aug 19;15:90. doi: 10.1186/s12890-015-0089-9. PMID: 26285821. Exclusion Code: X3.26285821
200 Chan EG, Landreneau JR, Schuchert MJ, . Preoperative (3-dimensional) computed tomography lung reconstruction before anatomic segmentectomy or lobectomy for stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2015 Sep;150(3):523–8. doi: 10.1016/j.jtcvs.2015.06.051. PMID: 26319461. Exclusion Code: X6.26319461
201 Chandarana H, Heacock L, Rakheja R, . Pulmonary nodules in patients with primary malignancy: comparison of hybrid PET/MR and PET/CT imaging. Radiology. 2013 Sep;268(3):874–81. doi: 10.1148/radiol.13130620. PMID: 23737537. Exclusion Code: X3.23737537
202 Chandler PD, Song Y, Lin J, . Lipid biomarkers and long-term risk of cancer in the Women’s Health Study. Am J Clin Nutr. 2016 Jun;103(6):1397–407. doi: 10.3945/ajcn.115.124321. PMID: 27099252. Exclusion Code: X3.27099252
203 Chang B, Hwang JH, Choi YH, . Natural history of pure ground-glass opacity lung nodules detected by low-dose CT scan. Chest. 2013 Jan;143(1):172–8. doi: 10.1378/chest.11-2501. PMID: 22797081. Exclusion Code: X3.22797081
204 Chang DH, Hiss S, Mueller D, . Radiation Dose Reduction in Computed Tomography-Guided Lung Interventions using an Iterative Reconstruction Technique. Rofo. 2015 Oct;187(10):906–14. doi: 10.1055/s-0035-1553125. PMID: 26085175. Exclusion Code: X5.26085175
205 Chang JM, Kam KH, Yen YT, . From biportal to uniportal video-assisted thoracoscopic anatomical lung resection: A single-institute experience. Medicine (Baltimore). 2016 Oct;95(40):e5097. doi: 10.1097/md.0000000000005097. PMID: 27749589. Exclusion Code: X3.27749589
206 Chang JY, Komaki R, Wen HY, . Toxicity and patterns of failure of adaptive/ablative proton therapy for early-stage, medically inoperable non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2011 Aug 1;80(5):1350–7. doi: 10.1016/j.ijrobp.2010.04.049. PMID: 21251767. Exclusion Code: X6.21251767
207 Chang JY, Li QQ, Xu QY, . Stereotactic ablative radiation therapy for centrally located early stage or isolated parenchymal recurrences of non-small cell lung cancer: how to fly in a “no fly zone”. Int J Radiat Oncol Biol Phys. 2014 Apr 1;88(5):1120–8. doi: 10.1016/j.ijrobp.2014.01.022. PMID: 24661665. Exclusion Code: X3.24661665
208 Chang JY, Senan S, Paul MA, . Stereotactic ablative radiotherapy versus lobectomy for operable stage I non-small-cell lung cancer: a pooled analysis of two randomised trials. Lancet Oncol. 2015 Jun;16(6):630–7. doi: 10.1016/s1470-2045(15)70168-3. PMID: 25981812. Exclusion Code: X9.25981812
209 Chang JY, Zhang W, Komaki R, . Long-term outcome of phase I/II prospective study of dose-escalated proton therapy for early-stage non-small cell lung cancer. Radiother Oncol. 2017 Feb;122(2):274–80. doi: 10.1016/j.radonc.2016.10.022. PMID: 28139305. Exclusion Code: X6.28139305
210 Chang WP, Lin CC. Changes in the sleep-wake rhythm, sleep quality, mood, and quality of life of patients receiving treatment for lung cancer: A longitudinal study. Chronobiol Int. 2017;34(4):451–61. doi: 10.1080/07420528.2017.1293678. PMID: 28282238. Exclusion Code: X3.28282238
211 Chang YY, Chen CK, Yeh YC, . Diagnostic feasibility and safety of CT-guided core biopsy for lung nodules less than or equal to 8 mm: A single-institution experience. Eur Radiol. 2018 Feb;28(2):796–806. doi: 10.1007/s00330-017-5027-1. PMID: 28884222. Exclusion Code: X3.28884222
212 Charvat H, Sasazuki S, Shimazu T, . Development of a risk prediction model for lung cancer: The Japan Public Health Center-based Prospective Study. Cancer Sci. 2018 Mar;109(3):854–62. doi: 10.1111/cas.13509. PMID: 29345859. Exclusion Code: X7.29345859
213 Chellapandian D, Lehrnbecher T, Phillips B, . Bronchoalveolar lavage and lung biopsy in patients with cancer and hematopoietic stem-cell transplantation recipients: a systematic review and meta-analysis. J Clin Oncol. 2015 Feb 10;33(5):501–9. doi: 10.1200/jco.2014.58.0480. PMID: 25559816. Exclusion Code: X3.25559816
214 Chen C, Mu CY, Su MQ, . Endobronchial Ultrasound-guided Transbronchial Needle Aspiration Increases the Yield of Transbronchial Lung Biopsy for the Evaluation of Peribronchial Lesions. Chin Med J (Engl). 2017 5th Jan 2017;130(1):11–4. doi: 10.4103/0366-6999.196567. PMID: 28051017. Exclusion Code: X3.28051017
215 Chen C, Zhu WD, Zhang XH, . Value of Ki-67 and computed tomography in the assessment of peripheral lung adenocarcinoma. Br J Biomed Sci. 2016;73(1):32–7. doi: 10.1080/09674845.2016.1146434. PMID: 27182675. Exclusion Code: X8.27182675
216 Chen CY, Chen CH, Shen TC, . Lung cancer screening with low-dose computed tomography: Experiences from a tertiary hospital in Taiwan. J Formos Med Assoc. 2016 Mar;115(3):163–70. doi: 10.1016/j.jfma.2015.11.007. PMID: 26714425. Exclusion Code: X7.26714425
217 Chen FF, Zhang D, Wang YL, . Video-assisted thoracoscopic surgery lobectomy versus open lobectomy in patients with clinical stage non-small cell lung cancer: a meta-analysis. Eur J Surg Oncol. 2013 Sep;39(9):957–63. doi: 10.1016/j.ejso.2013.06.016. PMID: 23845704. Exclusion Code: X9.23845704
218 Chen HH, Chiu NT, Su WC, . Prognostic value of whole-body total lesion glycolysis at pretreatment FDG PET/CT in non-small cell lung cancer. Radiology. 2012 Aug;264(2):559–66. doi: 10.1148/radiol.12111148. PMID: 22692034. Exclusion Code: X3.22692034
219 Chen K, Chen H, Yang F, . Validation of the Eighth Edition of the TNM Staging System for Lung Cancer in 2043 Surgically Treated Patients With Non-small-cell Lung Cancer. Clin Lung Cancer. 2017 Nov;18(6):e457–e66. doi: 10.1016/j.cllc.2017.04.001. PMID: 28539214. Exclusion Code: X3.28539214
220 Chen S, Li X, Chen M, . Limited diagnostic value of Dual-Time-Point (18)F-FDG PET/CT imaging for classifying solitary pulmonary nodules in granuloma-endemic regions both at visual and quantitative analyses. Eur J Radiol. 2016 Oct;85(10):1744–9. doi: 10.1016/j.ejrad.2016.07.016. PMID: 27666611. Exclusion Code: X3.27666611
221 Chen T, Luo J, Gu H, . Impact of Solid Minor Histologic Subtype in Postsurgical Prognosis of Stage I Lung Adenocarcinoma. Ann Thorac Surg. 2018 Jan;105(1):302–8. doi: 10.1016/j.athoracsur.2017.08.018. PMID: 29162222. Exclusion Code: X10.29162222
222 Chen X, Gorlov IP, Ying J, . Initial medical attention on patients with early-stage non-small cell lung cancer. PLoS One. 2012;7(3):e32644. doi: 10.1371/journal.pone.0032644. PMID: 22412901. Exclusion Code: X3.22412901
223 Chen X, Wu J, Zhang F, . Prognostic Significance of Pre-Operative Monocyte-to-Lymphocyte Ratio in Lung Cancer Patients Undergoing Radical Surgery. Lab Med. 2018 Mar 21;49(2):e29–e39. doi: 10.1093/labmed/lmx069. PMID: 29361036. Exclusion Code: X3.29361036
224 Chen XR, Dong JN, Zhang F, . Efficacy and safety of image-guidance radiotherapy by helical tomotherapy in patients with lung cancer. Medicine (Baltimore). 2018 Jan;97(1):e9243. doi: 10.1097/md.0000000000009243. PMID: 29505510. Exclusion Code: X14.29505510
225 Chen Y, Li J, Zhang Y, . Early versus late prophylactic cranial irradiation in patients with extensive small cell lung cancer. Strahlenther Onkol. 2018 Oct;194(10):876–85. doi: 10.1007/s00066-018-1307-1. PMID: 29774395. Exclusion Code: X3.29774395
226 Chen Z, Xu Z, Sun S, . TGF-beta1, IL-6, and TNF-alpha in bronchoalveolar lavage fluid: useful markers for lung cancer? Sci Rep. 2014 Jul 7;4:5595. doi: 10.1038/srep05595. PMID: 24999009. Exclusion Code: X11.24999009
227 Cheng M, Liu L, Yang HS, . Circulating tumor cells are associated with bone metastasis of lung cancer. Asian Pac J Cancer Prev. 2014;15(15):6369–74. PMID: 25124627. Exclusion Code: X3.25124627
228 Cheng YD, Duan CJ, Dong S, . Clinical controlled comparison between lobectomy and segmental resection for patients over 70 years of age with clinical stage I non-small cell lung cancer. Eur J Surg Oncol. 2012 Dec;38(12):1149–55. doi: 10.1016/j.ejso.2012.08.001. PMID: 22901959. Exclusion Code: X11.22901959
229 Chesterfield-Thomas G, Goldsmith I. Impact of preoperative pulmonary rehabilitation on the Thoracoscore of patients undergoing lung resection. Interact Cardiovasc Thorac Surg. 2016 Nov;23(5):729–32. doi: 10.1093/icvts/ivw238. PMID: 27430554. Exclusion Code: X3.27430554
230 Cheung P, Faria S, Ahmed S, . Phase II study of accelerated hypofractionated three-dimensional conformal radiotherapy for stage T1-3 N0 M0 non-small cell lung cancer: NCIC CTG BR.25. J Natl Cancer Inst. 2014 Aug;106(8)doi: 10.1093/jnci/dju164. PMID: 25074417. Exclusion Code: X6.25074417
231 Chi A, Wen S, Liao Z, . What would be the most appropriate alpha/beta ratio in the setting of stereotactic body radiation therapy for early stage non-small cell lung cancer. Biomed Res Int. 2013;2013:391021. doi: 10.1155/2013/391021. PMID: 24350266. Exclusion Code: X10.24350266
232 Chi CT. A multicenter randomized controlled trial on video-assisted thoracoscopic surgery and axillary thoracotomy for resection of early-stage non-small cell lung cancer. Http://www.who.int/trialsearch/trial2.aspx?Trialid=chictr-trc-10000750. 2010 PMID: CN-01833643. Exclusion Code: X16.
233 Chiang A, Thibault I, Warner A, . A comparison between accelerated hypofractionation and stereotactic ablative radiotherapy (SABR) for early-stage non-small cell lung cancer (NSCLC): Results of a propensity score-matched analysis. Radiother Oncol. 2016 Mar;118(3):478–84. doi: 10.1016/j.radonc.2015.12.026. PMID: 26795773. Exclusion Code: X3.26795773
234 Chiappetta M, Rosella F, Dall’armi V, . CT-guided fine-needle ago-biopsy of pulmonary nodules: predictive factors for diagnosis and pneumothorax occurrence. Radiol Med. 2016 Aug;121(8):635–43. doi: 10.1007/s11547-016-0639-0. PMID: 27132130. Exclusion Code: X3.27132130
235 Chiles C, Duan F, Gladish GW, . Association of Coronary Artery Calcification and Mortality in the National Lung Screening Trial: A Comparison of Three Scoring Methods. Radiology. 2015 Jul;276(1):82–90. doi: 10.1148/radiol.15142062. PMID: 25759972. Exclusion Code: X5.25759972
236 Chlebowski RT, Wakelee H, Pettinger M, . Estrogen Plus Progestin and Lung Cancer: Follow-up of the Women’s Health Initiative Randomized Trial. Clin Lung Cancer. 2016 Jan;17(1):10–7.e1. doi: 10.1016/j.cllc.2015.09.004. PMID: 26577506. Exclusion Code: X6.26577506
237 Cho H, Lee HY, Kim J, . Pure ground glass nodular adenocarcinomas: Are preoperative positron emission tomography/computed tomography and brain magnetic resonance imaging useful or necessary? J Thorac Cardiovasc Surg. 2015 Sep;150(3):514–20. doi: 10.1016/j.jtcvs.2015.06.024. PMID: 26189165. Exclusion Code: X3.26189165
238 Cho HJ, Yun HJ, Yang HC, . Prognostic significance of nuclear factor of activated T-cells 5 expression in non-small cell lung cancer patients who underwent surgical resection. J Surg Res. 2018 Jun;226:40–7. doi: 10.1016/j.jss.2017.12.036. PMID: 29661287. Exclusion Code: X3.29661287
239 Cho J, Kim ES, Kim SJ, . Long-Term Follow-up of Small Pulmonary Ground-Glass Nodules Stable for 3 Years: Implications of the Proper Follow-up Period and Risk Factors for Subsequent Growth. J Thorac Oncol. 2016 Sep;11(9):1453–9. doi: 10.1016/j.jtho.2016.05.026. PMID: 27287413. Exclusion Code: X3.27287413
240 Cho J, Ko SJ, Kim SJ, . Surgical resection of nodular ground-glass opacities without percutaneous needle aspiration or biopsy. BMC Cancer. 2014 Nov 18;14:838. doi: 10.1186/1471-2407-14-838. PMID: 25406492. Exclusion Code: X3.25406492
241 Cho JH, Choi YS, Kim J, . Long-term outcomes of wedge resection for pulmonary ground-glass opacity nodules. Ann Thorac Surg. 2015 Jan;99(1):218–22. doi: 10.1016/j.athoracsur.2014.07.068. PMID: 25440277. Exclusion Code: X11.25440277
242 Choe J, Lee SM, Do KH, . Prognostic value of radiomic analysis of iodine overlay maps from dual-energy computed tomography in patients with resectable lung cancer. Eur Radiol. 2019 Feb;29(2):915–23. doi: 10.1007/s00330-018-5639-0. PMID: 30054795. Exclusion Code: X11.30054795
243 Choi JW, Park CM, Goo JM, . C-arm cone-beam CT-guided percutaneous transthoracic needle biopsy of small (</= 20 mm) lung nodules: diagnostic accuracy and complications in 161 patients. AJR Am J Roentgenol. 2012 Sep;199(3):W322–30. doi: 10.2214/ajr.11.7576. PMID: 22915422. Exclusion Code: X3.22915422
244 Choi MJ, Kim Y, Hong YS, . Transthoracic needle biopsy using a C-arm cone-beam CT system: diagnostic accuracy and safety. Br J Radiol. 2012 Jun;85(1014):e182–7. doi: 10.1259/bjr/95413532. PMID: 21791505. Exclusion Code: X10.21791505
245 Choi SH, Chae EJ, Shin SY, . Comparisons of clinical outcomes in patients with and without a preoperative tissue diagnosis in the persistent malignant-looking, ground-glass-opacity nodules. Medicine (Baltimore). 2016 Aug;95(34):e4359. doi: 10.1097/md.0000000000004359. PMID: 27559945. Exclusion Code: X3.27559945
246 Choi SM, Heo EY, Lee J, . Characteristics of benign solitary pulmonary nodules confirmed by diagnostic video-assisted thoracoscopic surgery. Clin Respir J. 2016 Mar;10(2):181–8. doi: 10.1111/crj.12200. PMID: 25103572. Exclusion Code: X3.25103572
247 Choi YR, An JY, Kim MK, . The diagnostic efficacy and safety of endobronchial ultrasound-guided transbronchial needle aspiration as an initial diagnostic tool. Korean J Intern Med. 2013 Nov;28(6):660–7. doi: 10.3904/kjim.2013.28.6.660. PMID: 24307841. Exclusion Code: X3.24307841
248 Choi YY, Lee SY, Lee WK, . RACK1 is a candidate gene associated with the prognosis of patients with early stage non-small cell lung cancer. Oncotarget. 2015 Feb 28;6(6):4451–66. doi: 10.18632/oncotarget.2865. PMID: 25686824. Exclusion Code: X6.25686824
249 Chopra A, Ford A, De Noronha R, . Incidental findings on positron emission tomography/CT scans performed in the investigation of lung cancer. Br J Radiol. 2012 Jul;85(1015):e229–37. doi: 10.1259/bjr/60606623. PMID: 22745208. Exclusion Code: X3.22745208
250 Chou HP, Chen CK, Shen SH, . Percutaneous cryoablation for inoperable malignant lung tumors: midterm results. Cryobiology. 2015 Feb;70(1):60–5. doi: 10.1016/j.cryobiol.2014.12.004. PMID: 25541142. Exclusion Code: X6.25541142
251 Christe A, Ebner L, Steiger P, . Impact of image quality, radiologists, lung segments, and Gunnar eyewear on detectability of lung nodules in chest CT. Acta Radiol. 2013 Jul;54(6):646–51. doi: 10.1177/0284185113483677. PMID: 23612429. Exclusion Code: X3.23612429
252 Christe A, Leidolt L, Huber A, . Lung cancer screening with CT: evaluation of radiologists and different computer assisted detection software (CAD) as first and second readers for lung nodule detection at different dose levels. Eur J Radiol. 2013 Dec;82(12):e873–8. doi: 10.1016/j.ejrad.2013.08.026. PMID: 24074648. Exclusion Code: X3.24074648
253 Christensen TD, Vad H, Pedersen S, . Coagulation profile in open and video-assisted thoracoscopic lobectomies: a cohort study. Interact Cardiovasc Thorac Surg. 2018 Mar 1;26(3):382–8. doi: 10.1093/icvts/ivx328. PMID: 29049684. Exclusion Code: X3.29049684
254 Christian C, Erica S, Morandi U. The prognostic impact of tumor size in resected stage I non-small cell lung cancer: evidence for a two thresholds tumor diameters classification. Lung Cancer. 2006 Nov;54(2):185–91. doi: 10.1016/j.lungcan.2006.08.003. PMID: 16996167. Exclusion Code: X10.16996167
255 Chua KLM, Sin I, Fong KW, . Stereotactic body radiotherapy for early stage lung cancer-historical developments and future strategies. Chin Clin Oncol. 2017 Sep;6:(Suppl 2):S20. doi: 10.21037/cco.2017.08.02. PMID: 28917258. Exclusion Code: X10.28917258
256 Chubachi S, Takahashi S, Tsutsumi A, . Radiologic features of precancerous areas of the lungs in chronic obstructive pulmonary disease. Int J Chron Obstruct Pulmon Dis. 2017;12:1613–24. doi: 10.2147/copd.s132709. PMID: 28615934. Exclusion Code: X3.28615934
257 Chung K, Mets OM, Gerke PK, . Brock malignancy risk calculator for pulmonary nodules: validation outside a lung cancer screening population. Thorax. 2018 Sep;73(9):857–63. doi: 10.1136/thoraxjnl-2017-211372. PMID: 29777062. Exclusion Code: X3.29777062
258 Cieszanowski A, Lisowska A, Dabrowska M, . MR Imaging of Pulmonary Nodules: Detection Rate and Accuracy of Size Estimation in Comparison to Computed Tomography. PLoS One. 2016;11(6):e0156272. doi: 10.1371/journal.pone.0156272. PMID: 27258047. Exclusion Code: X3.27258047
259 Citak N, Buyukkale S, Kok A, . Does video-assisted mediastinoscopy offer lower false-negative rates for subcarinal lymph nodes compared with standard cervical mediastinoscopy? Thorac Cardiovasc Surg. 2014 Oct;62(7):624–30. doi: 10.1055/s-0033-1358656. PMID: 24297632. Exclusion Code: X3.24297632
260 Clausen E, Wittman C, Gingo M, . Chest computed tomography findings in HIV-infected individuals in the era of antiretroviral therapy. PLoS One. 2014;9(11):e112237. doi: 10.1371/journal.pone.0112237. PMID: 25409510. Exclusion Code: X8.25409510
261 Cole AM, Pflugeisen B, Schwartz MR, . Cross sectional study to assess the accuracy of electronic health record data to identify patients in need of lung cancer screening. BMC Res Notes. 2018 Jan 10;11(1):14. doi: 10.1186/s13104-018-3124-0. PMID: 29321038. Exclusion Code: X5.29321038
262 Coley SM, Crapanzano JP, Saqi A. FNA, core biopsy, or both for the diagnosis of lung carcinoma: Obtaining sufficient tissue for a specific diagnosis and molecular testing. Cancer Cytopathol. 2015 May;123(5):318–26. doi: 10.1002/cncy.21527. PMID: 25711901. Exclusion Code: X3.25711901
263 Cornwell LD, Bakaeen FG, Lan CK, . Endobronchial ultrasonography-guided transbronchial needle aspiration biopsy for preoperative nodal staging of lung cancer in a veteran population. JAMA Surg. 2013 Nov;148(11):1024–9. doi: 10.1001/jamasurg.2013.3776. PMID: 24048268. Exclusion Code: X3.24048268
264 Cornwell LD, Echeverria AE, Samuelian J, . Video-assisted thoracoscopic lobectomy is associated with greater recurrence-free survival than stereotactic body radiotherapy for clinical stage I lung cancer. J Thorac Cardiovasc Surg. 2018 Jan;155(1):395–402. doi: 10.1016/j.jtcvs.2017.07.065. PMID: 28888379. Exclusion Code: X10.28888379
265 Coroller TP, Mak RH, Lewis JH, . Low incidence of chest wall pain with a risk-adapted lung stereotactic body radiation therapy approach using three or five fractions based on chest wall dosimetry. PLoS One. 2014;9(4):e94859. doi: 10.1371/journal.pone.0094859. PMID: 24728448. Exclusion Code: X3.24728448
266 Corradetti MN, Haas AR, Rengan R. Central-airway necrosis after stereotactic body-radiation therapy. N Engl J Med. 2012 Jun 14;366(24):2327–9. doi: 10.1056/NEJMc1203770. PMID: 22694017. Exclusion Code: X10.22694017
267 Corradi M, Poli D, Banda I, . Exhaled breath analysis in suspected cases of non-small-cell lung cancer: a cross-sectional study. J Breath Res. 2015 Jan 29;9(2):027101. doi: 10.1088/1752-7155/9/2/027101. PMID: 25634546. Exclusion Code: X7.25634546
268 Corso CD, Park HS, Kim AW, . Racial disparities in the use of SBRT for treating early-stage lung cancer. Lung Cancer. 2015 Aug;89(2):133–8. doi: 10.1016/j.lungcan.2015.05.002. PMID: 26051446. Exclusion Code: X8.26051446
269 Corso CD, Park HS, Moreno AC, . Stage I Lung SBRT Clinical Practice Patterns. Am J Clin Oncol. 2017 Aug;40(4):358–61. doi: 10.1097/coc.0000000000000162. PMID: 25503436. Exclusion Code: X8.25503436
270 Coverley D, Higgins G, West D, . A quantitative immunoassay for lung cancer biomarker CIZ1b in patient plasma. Clin Biochem. 2017 Apr;50(6):336–43. doi: 10.1016/j.clinbiochem.2016.11.015. PMID: 27867087. Exclusion Code: X3.27867087
271 Crabtree TD, Denlinger CE, Meyers BF, . Stereotactic body radiation therapy versus surgical resection for stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2010 Aug;140(2):377–86. doi: 10.1016/j.jtcvs.2009.12.054. PMID: 20400121. Exclusion Code: X11.20400121
272 Crabtree TD, Puri V, Chen SB, . Does the method of radiologic surveillance affect survival after resection of stage I non-small cell lung cancer? J Thorac Cardiovasc Surg. 2015 Jan;149(1):45–52, 3.e1–3. doi: 10.1016/j.jtcvs.2014.07.095. PMID: 25218540. Exclusion Code: X12.25218540
273 Crabtree TD, Puri V, Robinson C, . Analysis of first recurrence and survival in patients with stage I non-small cell lung cancer treated with surgical resection or stereotactic radiation therapy. J Thorac Cardiovasc Surg. 2014 Apr;147(4):1183–91; discussion 91-2. doi: 10.1016/j.jtcvs.2013.11.057. PMID: 24507980. Exclusion Code: X10.24507980
274 Criss SD, Sheehan DF, Palazzo L, . Population impact of lung cancer screening in the United States: Projections from a microsimulation model. PLoS Med. 2018 Feb;15(2):e1002506. doi: 10.1371/journal.pmed.1002506. PMID: 29415013. Exclusion Code: X3.29415013
275 Cronin KA, Gail MH, Zou Z, . Validation of a model of lung cancer risk prediction among smokers. J Natl Cancer Inst. 2006 May 03;98(9):637–40. doi: 10.1093/jnci/djj163. PMID: 16670389. Exclusion Code: X7.16670389
276 Cruz C, Afonso M, Oliveiros B, . Recurrence and Risk Factors for Relapse in Patients with Non-Small Cell Lung Cancer Treated by Surgery with Curative Intent. Oncology. 2017;92(6):347–52. doi: 10.1159/000458533. PMID: 28278499. Exclusion Code: X11.28278499
277 Currow DC, You H, Aranda S, . What factors are predictive of surgical resection and survival from localised non-small cell lung cancer? Med J Aust. 2014 Oct 20;201(8):475–80. PMID: 25332036. Exclusion Code: X11.25332036
278 Cusumano G, Fournel L, Strano S, . Surgical Resection for Pulmonary Carcinoid: Long-Term Results of Multicentric Study-The Importance of Pathological N Status, More Than We Thought. Lung. 2017 Dec;195(6):789–98. doi: 10.1007/s00408-017-0056-8. PMID: 29022070. Exclusion Code: X3.29022070
279 Cykert S, Walker PR, Edwards LJ, . Weighing projections of physical decline in lung cancer surgery decisions. Am J Med Sci. 2015 Jan;349(1):61–6. doi: 10.1097/maj.0000000000000354. PMID: 25285513. Exclusion Code: X3.25285513
280 Dabrowska M, Krenke R, Korczynski P, . Diagnostic accuracy of contrast-enhanced computed tomography and positron emission tomography with 18-FDG in identifying malignant solitary pulmonary nodules. Medicine (Baltimore). 2015 Apr;94(15):e666. doi: 10.1097/md.0000000000000666. PMID: 25881842. Exclusion Code: X3.25881842
281 Dabrowska M, Przybylo Z, Zukowska M, . Should we be concerned about the doses of ionizing radiation related to diagnostic and follow-up imaging in patients with solitary pulmonary nodules? Radiat Prot Dosimetry. 2018 Jan 1;178(2):201–7. doi: 10.1093/rpd/ncx099. PMID: 28981871. Exclusion Code: X3.28981871
282 Dai C, Shen J, Ren Y, . Choice of Surgical Procedure for Patients With Non-Small-Cell Lung Cancer </= 1 cm or > 1 to 2 cm Among Lobectomy, Segmentectomy, and Wedge Resection: A Population-Based Study. J Clin Oncol. 2016 Sep 10;34(26):3175–82. doi: 10.1200/jco.2015.64.6729. PMID: 27382092. Exclusion Code: X8.27382092
283 Dai H, Liu J, Liang L, . Increased lung cancer risk in patients with interstitial lung disease and elevated CEA and CA125 serum tumour markers. Respirology. 2014 Jul;19(5):707–13. doi: 10.1111/resp.12317. PMID: 24903079. Exclusion Code: X3.24903079
284 Dai J, Liu M, Swensen SJ, . Regional Emphysema Score Predicting Overall Survival, Quality of Life, and Pulmonary Function Recovery in Early-Stage Lung Cancer Patients. J Thorac Oncol. 2017 May;12(5):824–32. doi: 10.1016/j.jtho.2017.01.016. PMID: 28126539. Exclusion Code: X10.28126539
285 Dai L, Tsay JC, Li J, . Autoantibodies against tumor-associated antigens in the early detection of lung cancer. Lung Cancer. 2016 Sep;99:172–9. doi: 10.1016/j.lungcan.2016.07.018. PMID: 27565936. Exclusion Code: X3.27565936
286 Dale CR, Madtes DK, Fan VS, . Navigational bronchoscopy with biopsy versus computed tomography-guided biopsy for the diagnosis of a solitary pulmonary nodule: a cost-consequences analysis. J Bronchology Interv Pulmonol. 2012 Oct;19(4):294–303. doi: 10.1097/LBR.0b013e318272157d. PMID: 23207529. Exclusion Code: X10.23207529
287 Dalwadi SM, Szeja SS, Bernicker EH, . Practice Patterns and Outcomes in Elderly Stage I Non-Small-cell Lung Cancer: A 2004 to 2012 SEER Analysis. Clin Lung Cancer. 2018 Mar;19(2):e269–e76. doi: 10.1016/j.cllc.2017.11.004. PMID: 29208356. Exclusion Code: X13.29208356
288 Dama E, Melocchi V, Dezi F, . An Aggressive Subtype of Stage I Lung Adenocarcinoma with Molecular and Prognostic Characteristics Typical of Advanced Lung Cancers. Clin Cancer Res. 2017 Jan 1;23(1):62–72. doi: 10.1158/1078-0432.ccr-15-3005. PMID: 27358486. Exclusion Code: X6.27358486
289 D’Amelio AM, Jr., Cassidy A, Asomaning K, . Comparison of discriminatory power and accuracy of three lung cancer risk models. Br J Cancer. 2010 Jul 27;103(3):423–9. doi: 10.1038/sj.bjc.6605759. PMID: 20588271. Exclusion Code: X7.20588271
290 Dandachi N, Tiran V, Lindenmann J, . Frequency and clinical impact of preoperative circulating tumor cells in resectable non-metastatic lung adenocarcinomas. Lung Cancer. 2017 Nov;113:152–7. doi: 10.1016/j.lungcan.2017.10.003. PMID: 29110843. Exclusion Code: X8.29110843
291 D’Andrilli A, Maurizi G, Andreetti C, . Sleeve Lobectomy Versus Standard Lobectomy for Lung Cancer: Functional and Oncologic Evaluation. Ann Thorac Surg. 2016 May;101(5):1936–42. doi: 10.1016/j.athoracsur.2015.11.057. PMID: 26912305. Exclusion Code: X3.26912305
292 D’Andrilli A, Natoli G, Scarpino S, . Stage I non-small cell lung cancer: the presence of the lymphocyte-specific protein tyrosin kinase in the tumour infiltrate is associated with a better long-term prognosis. Interact Cardiovasc Thorac Surg. 2012 Jul;15(1):148–51. doi: 10.1093/icvts/ivr128. PMID: 22457183. Exclusion Code: X11.22457183
293 Dang H, Siewerdsen JH, Stayman JW. Prospective regularization design in prior-image-based reconstruction. Phys Med Biol. 2015 Dec 21;60(24):9515–36. doi: 10.1088/0031-9155/60/24/9515. PMID: 26606653. Exclusion Code: X5.26606653
294 David EA, Cooke DT, Chen Y, . Surgery in high-volume hospitals not commission on cancer accreditation leads to increased cancer-specific survival for early-stage lung cancer. Am J Surg. 2015 Oct;210(4):643–7. doi: 10.1016/j.amjsurg.2015.05.002. PMID: 26193801. Exclusion Code: X8.26193801
295 Davis JN, Medbery C, Sharma S, . Stereotactic body radiotherapy for centrally located early-stage non-small cell lung cancer or lung metastases from the RSSearch((R)) patient registry. Radiat Oncol. 2015 May 15;10:113. doi: 10.1186/s13014-015-0417-5. PMID: 25975848. Exclusion Code: X3.25975848
296 Davis JN, Medbery C, 3rd, Sharma S, . Stereotactic body radiotherapy for early-stage non-small cell lung cancer: clinical outcomes from a National Patient Registry. J Radiat Oncol. 2015;4(1):55–63. doi: 10.1007/s13566-014-0177-0. PMID: 25774243. Exclusion Code: X13.25774243
297 Dawe DE, Pond GR, Ellis PM. Assessment of Referral and Chemotherapy Treatment Patterns for Elderly Patients With Non-small-Cell Lung Cancer. Clin Lung Cancer. 2016 Nov;17(6):563–72.e2. doi: 10.1016/j.cllc.2016.05.012. PMID: 27374398. Exclusion Code: X8.27374398
298 de Baere T, Tselikas L, Catena V, . Percutaneous thermal ablation of primary lung cancer. Diagn Interv Imaging. 2016 Oct;97(10):1019–24. doi: 10.1016/j.diii.2016.08.016. PMID: 27692673. Exclusion Code: X6.27692673
299 de Dios NR, Sanz X, Foro P, . Accelerated hypofractionated radiation therapy (AHRT) for non-small-cell lung cancer: can we leave standard fractionation? Clin Transl Oncol. 2017 Apr;19(4):440–7. doi: 10.1007/s12094-016-1544-7. PMID: 27553602. Exclusion Code: X6.27553602
300 de Hoop B, van Ginneken B, Gietema H, . Pulmonary perifissural nodules on CT scans: rapid growth is not a predictor of malignancy. Radiology. 2012 Nov;265(2):611–6. doi: 10.1148/radiol.12112351. PMID: 22929331. Exclusion Code: X8.22929331
301 de Koning HJ, Meza R, Plevritis SK, . Benefits and harms of computed tomography lung cancer screening strategies: a comparative modeling study for the U.S. Preventive Services Task Force. Ann Intern Med. 2014 Mar 04;160(5):311–20. doi: 10.7326/m13-2316. PMID: 24379002. Exclusion Code: X4.24379002
302 De Roza MA, Quah KH, Tay CK, . Diagnosis of Peripheral Lung Lesions via Conventional Flexible Bronchoscopy with Multiplanar CT Planning. Pulm Med. 2016;2016:5048961. doi: 10.1155/2016/5048961. PMID: 27957340. Exclusion Code: X3.27957340
303 De Ruysscher D, Sharifi H, Defraene G, . Quantification of radiation-induced lung damage with CT scans: the possible benefit for radiogenomics. Acta Oncol. 2013 Oct;52(7):1405–10. doi: 10.3109/0284186x.2013.813074. PMID: 23957564. Exclusion Code: X3.23957564
304 De Wever W, Bruyeer E, Demaerel P, . Staging of lung cancer. Do we need a diagnostic CT of the brain after an integrated PET/CT for the detection of brain metastases? Jbr-btr. 2010 Mar-Apr;93(2):71–6. PMID: 20524514. Exclusion Code: X3.20524514
305 Debieuvre D, Fraboulet G, Duvert B, . Impact of distance from surgery department on the outcome of patients followed for non-small-cell lung cancer in the respiratory department of nonacademic hospitals: Results of the KBP-2010-study. Bull Cancer. 2017 Oct;104(10):840–9. doi: 10.1016/j.bulcan.2017.07.008. PMID: 28965729. Exclusion Code: X3.28965729
306 Decaluwe H, Moons J, Fieuws S, . Is central lung tumour location really predictive for occult mediastinal nodal disease in (suspected) non-small-cell lung cancer staged cN0 on 18F-fluorodeoxyglucose positron emission tomography-computed tomography? Eur J Cardiothorac Surg. 2018 Jul 1;54(1):134–40. doi: 10.1093/ejcts/ezy018. PMID: 29447330. Exclusion Code: X6.29447330
307 Decaluwe H, Petersen RH, Hansen H, . Major intraoperative complications during video-assisted thoracoscopic anatomical lung resections: an intention-to-treat analysis. Eur J Cardiothorac Surg. 2015 Oct;48(4):588–98; discussion 99. doi: 10.1093/ejcts/ezv287. PMID: 26385060. Exclusion Code: X3.26385060
308 Decaluwe H, Stanzi A, Dooms C, . Central tumour location should be considered when comparing N1 upstaging between thoracoscopic and open surgery for clinical stage I non-small-cell lung cancer. Eur J Cardiothorac Surg. 2016 Jul;50(1):110–7. doi: 10.1093/ejcts/ezv489. PMID: 26819286. Exclusion Code: X8.26819286
309 Deepak JA, Ng X, Feliciano J, . Pulmonologist involvement, stage-specific treatment, and survival in adults with non-small cell lung cancer and chronic obstructive pulmonary disease. Ann Am Thorac Soc. 2015 May;12(5):742–51. doi: 10.1513/AnnalsATS.201406-230OC. PMID: 25760983. Exclusion Code: X6.25760983
310 Dell’Amore A, Monteverde M, Martucci N, . Early and long-term results of pulmonary resection for non-small-cell lung cancer in patients over 75 years of age: a multi-institutional study. Interact Cardiovasc Thorac Surg. 2013 Mar;16(3):250–6. doi: 10.1093/icvts/ivs473. PMID: 23178392. Exclusion Code: X3.23178392
311 Dembitzer FR, Flores RM, Parides MK, . Impact of histologic subtyping on outcome in lobar vs sublobar resections for lung cancer: a pilot study. Chest. 2014 Jul;146(1):175–81. doi: 10.1378/chest.13-2506. PMID: 24556743. Exclusion Code: X11.24556743
312 Demir Y, Polack BD, Karaman C, . The diagnostic role of dual-phase (18)F-FDG PET/CT in the characterization of solitary pulmonary nodules. Nucl Med Commun. 2014 Mar;35(3):260–7. doi: 10.1097/mnm.0000000000000049. PMID: 24468852. Exclusion Code: X3.24468852
313 Deng B, Cassivi SD, de Andrade M, . Clinical outcomes and changes in lung function after segmentectomy versus lobectomy for lung cancer cases. J Thorac Cardiovasc Surg. 2014 Oct;148(4):1186–92.e3. doi: 10.1016/j.jtcvs.2014.03.019. PMID: 24746994. Exclusion Code: X11.24746994
314 Deng C, Cao X, Wu D, . Small lung lesions invisible under fluoroscopy are located accurately by three-dimensional localization technique on chest wall surface and performed bronchoscopy procedures to increase diagnostic yields. BMC Pulm Med. 2016 Nov 29;16(1):166. doi: 10.1186/s12890-016-0328-8. PMID: 27894283. Exclusion Code: X11.27894283
315 Deng CJ, Dai FQ, Qian K, . Clinical updates of approaches for biopsy of pulmonary lesions based on systematic review. BMC Pulm Med. 2018 Sep 3;18(1):146. doi: 10.1186/s12890-018-0713-6. PMID: 30176840. Exclusion Code: X3.30176840
316 Denholm R, Schuz J, Straif K, . Is previous respiratory disease a risk factor for lung cancer? Am J Respir Crit Care Med. 2014 Sep 1;190(5):549–59. doi: 10.1164/rccm.201402-0338OC. PMID: 25054566. Exclusion Code: X3.25054566
317 Deppen SA, Blume JD, Aldrich MC, . Predicting lung cancer prior to surgical resection in patients with lung nodules. J Thorac Oncol. 2014 Oct;9(10):1477–84. doi: 10.1097/jto.0000000000000287. PMID: 25170644. Exclusion Code: X3.25170644
318 Desseroit MC, Visvikis D, Tixier F, . Development of a nomogram combining clinical staging with (18)F-FDG PET/CT image features in non-small-cell lung cancer stage I-III. Eur J Nucl Med Mol Imaging. 2016 Jul;43(8):1477–85. doi: 10.1007/s00259-016-3325-5. PMID: 26896298. Exclusion Code: X3.26896298
319 Detillon D, Veen EJ. Postoperative Outcome After Pulmonary Surgery for Non-Small Cell Lung Cancer in Elderly Patients. Ann Thorac Surg. 2018 Jan;105(1):287–93. doi: 10.1016/j.athoracsur.2017.07.032. PMID: 29132701. Exclusion Code: X3.29132701
320 de-Torres JP, Marin JM, Casanova C, . Identification of COPD Patients at High Risk for Lung Cancer Mortality Using the COPD-LUCSS-DLCO. Chest. 2016 Apr;149(4):936–42. doi: 10.1378/chest.15-1868. PMID: 26513409. Exclusion Code: X4.26513409
321 DeWees TA, Nikitas J, Rehman S, . Defining Optimal Comorbidity Measures for Patients With Early-Stage Non-small cell lung cancer Treated With Stereotactic Body Radiation Therapy. Pract Radiat Oncol. 2019 Jan;9(1):e83–e9. doi: 10.1016/j.prro.2018.09.001. PMID: 30244094. Exclusion Code: X13.30244094
322 Dhanasopon AP, Salazar MC, Hoag JR, . Fate of pneumonectomy patients variably captured by non-small cell lung cancer staging system. Ann Thorac Surg. 2017 Dec;104(6):1829–36. doi: 10.1016/j.athoracsur.2017.06.073. PMID: 29074151. Exclusion Code: X17.29074151
323 Diao K, Chen YH, Catalano PJ, . Radiation toxicity in patients with collagen vascular disease and intrathoracic malignancy treated with modern radiation techniques. Radiother Oncol. 2017 Nov;125(2):301–9. doi: 10.1016/j.radonc.2017.10.002. PMID: 29102264. Exclusion Code: X3.29102264
324 Diaz-Lagares A, Mendez-Gonzalez J, Hervas D, . A Novel Epigenetic Signature for Early Diagnosis in Lung Cancer. Clin Cancer Res. 2016 Jul 1;22(13):3361–71. doi: 10.1158/1078-0432.ccr-15-2346. PMID: 26842235. Exclusion Code: X5.26842235
325 Dickey M, Roa W, Drodge S, . A planning comparison of 3-dimensional conformal multiple static field, conformal arc, and volumetric modulated arc therapy for the delivery of stereotactic body radiotherapy for early stage lung cancer. Med Dosim. 2015 Winter;40(4):347–51. doi: 10.1016/j.meddos.2015.04.006. PMID: 26027510. Exclusion Code: X8.26027510
326 Digumarthy SR, Kovacina B, Otrakji A, . Percutaneous CT guided lung biopsy in patients with pulmonary hypertension: Assessment of complications. Eur J Radiol. 2016 Feb;85(2):466–71. doi: 10.1016/j.ejrad.2015.12.007. PMID: 26781153. Exclusion Code: X3.26781153
327 Ding M, Zollinger W, Ebeling R, . Using max standardized uptake value from positron emission tomography to assess tumor responses after lung stereotactic body radiotherapy for different prescriptions. J Appl Clin Med Phys. 2018 Nov;19(6):226–33. doi: 10.1002/acm2.12453. PMID: 30216639. Exclusion Code: X3.30216639
328 Diot Q, Kavanagh B, Schefter T, . Regional normal lung tissue density changes in patients treated with stereotactic body radiation therapy for lung tumors. Int J Radiat Oncol Biol Phys. 2012 Nov 15;84(4):1024–30. doi: 10.1016/j.ijrobp.2011.11.080. PMID: 22583607. Exclusion Code: X3.22583607
329 Doll C, Duncker-Rohr V, Rucker G, . Influence of experience and qualification on PET-based target volume delineation. When there is no expert--ask your colleague. Strahlenther Onkol. 2014 Jun;190(6):555–62. doi: 10.1007/s00066-014-0644-y. PMID: 24615189. Exclusion Code: X3.24615189
330 Dominioni L, Poli A, Mantovani W, . Assessment of lung cancer mortality reduction after chest X-ray screening in smokers: a population-based cohort study in Varese, Italy. Lung Cancer. 2013 Apr;80(1):50–4. doi: 10.1016/j.lungcan.2012.12.014. PMID: 23294502. Exclusion Code: X5.23294502
331 Dominioni L, Rotolo N, Mantovani W, . A population-based cohort study of chest x-ray screening in smokers: lung cancer detection findings and follow-up. BMC Cancer. 2012 Jan 17;12:18. doi: 10.1186/1471-2407-12-18. PMID: 22251777. Exclusion Code: X5.22251777
332 Dominioni L, Rotolo N, Poli A, . Cost of a population-based programme of chest x-ray screening for lung cancer. Monaldi Arch Chest Dis. 2013 Jun;79(2):67–72. doi: 10.4081/monaldi.2013.94. PMID: 24354094. Exclusion Code: X5.24354094
333 Donahue JM, Morse CR, Wigle DA, . Oncologic efficacy of anatomic segmentectomy in stage IA lung cancer patients with T1a tumors. Ann Thorac Surg. 2012 Feb;93(2):381–7; discussion 7-8. doi: 10.1016/j.athoracsur.2011.10.079. PMID: 22209375. Exclusion Code: X11.22209375
334 Dong S, Roberts SA, Chen S, . Survival after lobectomy versus sub-lobar resection in elderly with stage I NSCLC: a meta-analysis. BMC Surg. 2019 Apr 15;19(1):38. doi: 10.1186/s12893-019-0500-1. PMID: 30987622. Exclusion Code: X10.30987622
335 Doseeva V, Colpitts T, Gao G, . Performance of a multiplexed dual analyte immunoassay for the early detection of non-small cell lung cancer. J Transl Med. 2015 Feb 12;13:55. doi: 10.1186/s12967-015-0419-y. PMID: 25880432. Exclusion Code: X5.25880432
336 Dowling P, Clarke C, Hennessy K, . Analysis of acute-phase proteins, AHSG, C3, CLI, HP and SAA, reveals distinctive expression patterns associated with breast, colorectal and lung cancer. Int J Cancer. 2012 Aug 15;131(4):911–23. doi: 10.1002/ijc.26462. PMID: 21953030. Exclusion Code: X5.21953030
337 Doyen J, Poudenx M, Gal J, . Stereotactic ablative radiotherapy after concomitant chemoradiotherapy in non-small cell lung cancer: A TITE-CRM phase 1 trial. Radiother Oncol. 2018 May;127(2):239–45. doi: 10.1016/j.radonc.2018.03.024. PMID: 29650404. Exclusion Code: X3.29650404
338 Dreyer J, Bremer M, Henkenberens C. Comorbidity indexing for prediction of the clinical outcome after stereotactic body radiation therapy in non-small cell lung cancer. Radiat Oncol. 2018 Nov 3;13(1):213. doi: 10.1186/s13014-018-1156-1. PMID: 30390700. Exclusion Code: X3.30390700
339 Du Q, Li E, Liu Y, . CTAPIII/CXCL7: a novel biomarker for early diagnosis of lung cancer. Cancer Med. 2018 Feb;7(2):325–35. doi: 10.1002/cam4.1292. PMID: 29356357. Exclusion Code: X3.29356357
340 Duann CW, Hung JJ, Hsu PK, . Surgical outcomes in lung cancer presenting as ground-glass opacities of 3 cm or less: a review of 5 years’ experience. J Chin Med Assoc. 2013 Dec;76(12):693–7. doi: 10.1016/j.jcma.2013.08.005. PMID: 24099986. Exclusion Code: X3.24099986
341 Duffy SW, Field JK, Allgood PC, . Translation of research results to simple estimates of the likely effect of a lung cancer screening programme in the United Kingdom. Br J Cancer. 2014 Apr 2;110(7):1834–40. doi: 10.1038/bjc.2014.63. PMID: 24525696. Exclusion Code: X7.24525696
342 Duijm M, Tekatli H, Oomen-de Hoop E, . Esophagus toxicity after stereotactic and hypofractionated radiotherapy for central lung tumors: Normal tissue complication probability modeling. Radiother Oncol. 2018 May;127(2):233–8. doi: 10.1016/j.radonc.2018.02.004. PMID: 29478763. Exclusion Code: X3.29478763
343 Duncker-Rohr V, Nestle U, Momm F, . Stereotactic ablative radiotherapy for small lung tumors with a moderate dose. Favorable results and low toxicity. Strahlenther Onkol. 2013 Jan;189(1):33–40. doi: 10.1007/s00066-012-0224-y. PMID: 23179248. Exclusion Code: X10.23179248
344 Dunlap NE, Yang W, McIntosh A, . Computed tomography-based anatomic assessment overestimates local tumor recurrence in patients with mass-like consolidation after stereotactic body radiotherapy for early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2012 Dec 1;84(5):1071–7. doi: 10.1016/j.ijrobp.2012.01.088. PMID: 22898383. Exclusion Code: X3.22898383
345 Dupont G, Flory L, Morel J, . Postoperative lymphopenia: An independent risk factor for postoperative pneumonia after lung cancer surgery, results of a case-control study. PLoS One. 2018;13(10):e0205237. doi: 10.1371/journal.pone.0205237. PMID: 30321194. Exclusion Code: X3.30321194
346 Ebara K, Takashima S, Jiang B, . Pleural invasion by peripheral lung cancer: prediction with three-dimensional CT. Acad Radiol. 2015 Mar;22(3):310–9. doi: 10.1016/j.acra.2014.10.002. PMID: 25542401. Exclusion Code: X3.25542401
347 Echavarria MF, Cheng AM, Velez-Cubian FO, . Comparison of pulmonary function tests and perioperative outcomes after robotic-assisted pulmonary lobectomy vs segmentectomy. Am J Surg. 2016 Dec;212(6):1175–82. doi: 10.1016/j.amjsurg.2016.09.017. PMID: 27823756. Exclusion Code: X11.27823756
348 Eguchi T, Bains S, Lee MC, . Impact of Increasing Age on Cause-Specific Mortality and Morbidity in Patients With Stage I Non-Small-Cell Lung Cancer: A Competing Risks Analysis. J Clin Oncol. 2017 Jan 20;35(3):281–90. doi: 10.1200/jco.2016.69.0834. PMID: 28095268. Exclusion Code: X3.28095268
349 Elsayad K, Kriz J, Reinartz G, . Cone-beam CT-guided radiotherapy in the management of lung cancer: Diagnostic and therapeutic value. Strahlenther Onkol. 2016 Feb;192(2):83–91. doi: 10.1007/s00066-015-0927-y. PMID: 26630946. Exclusion Code: X3.26630946
350 Elsayad K, Samhouri L, Scobioala S, . Is tumor volume reduction during radiotherapy prognostic relevant in patients with stage III non-small cell lung cancer? J Cancer Res Clin Oncol. 2018 Jun;144(6):1165–71. doi: 10.1007/s00432-018-2640-6. PMID: 29623466. Exclusion Code: X3.29623466
351 Enache I, Noel G, Jeung MY, . Impact of 3D conformal radiotherapy on lung function of patients with lung cancer: a prospective study. Respiration. 2013;86(2):100–8. doi: 10.1159/000342371. PMID: 23154264. Exclusion Code: X3.23154264
352 Endo C, Sakurada A, Notsuda H, . Results of long-term follow-up of patients with completely resected non-small cell lung cancer. Ann Thorac Surg. 2012 Apr;93(4):1061–8. doi: 10.1016/j.athoracsur.2012.01.004. PMID: 22386090. Exclusion Code: X11.22386090
353 Eo JS, Kim HK, Kim S, . Gallium-68 neomannosylated human serum albumin-based PET/CT lymphoscintigraphy for sentinel lymph node mapping in non-small cell lung cancer. Ann Surg Oncol. 2015 Feb;22(2):636–41. doi: 10.1245/s10434-014-3986-x. PMID: 25155392. Exclusion Code: X8.25155392
354 Eom JS, Mok JH, Kim I, . Radial probe endobronchial ultrasound using a guide sheath for peripheral lung lesions in beginners. BMC Pulm Med. 2018 Aug 13;18(1):137. doi: 10.1186/s12890-018-0704-7. PMID: 30103727. Exclusion Code: X3.30103727
355 Erasmus JJ, Gladish GW, Broemeling L, . Interobserver and intraobserver variability in measurement of non-small-cell carcinoma lung lesions: implications for assessment of tumor response. J Clin Oncol. 2003 Jul 1;21(13):2574–82. doi: 10.1200/jco.2003.01.144. PMID: 12829678. Exclusion Code: X3.12829678
356 Eriguchi T, Takeda A, Sanuki N, . Stereotactic body radiotherapy for operable early-stage non-small cell lung cancer. Lung Cancer. 2017 Jul;109:62–7. doi: 10.1016/j.lungcan.2017.04.022. PMID: 28577952. Exclusion Code: X10.28577952
357 Erkmen CP, Mitchell M, Randhawa S, . An Enhanced Shared Decision Making Model to Address Willingness and Ability to Undergo Lung Cancer Screening and Follow-Up Treatment in Minority Underserved Populations. J Community Health. 2018 Feb;43(1):27–32. doi: 10.1007/s10900-017-0383-y. PMID: 28612174. Exclusion Code: X8.28612174
358 Erol Y, Cakan A, Ergonul AG, . Psychiatric assessments in patients operated on due to lung cancer. Asian Cardiovasc Thorac Ann. 2017 Sep-Oct;25(7-8):518–21. doi: 10.1177/0218492317724044. PMID: 28776419. Exclusion Code: X3.28776419
359 Etzel CJ, Kachroo S, Liu M, . Development and validation of a lung cancer risk prediction model for African-Americans. Cancer Prev Res (Phila). 2008 Sep;1(4):255–65. doi: 10.1158/1940-6207.CAPR-08-0082. PMID: 19138969. Exclusion Code: X7.19138969
360 Evangelista L, Cuocolo A, Pace L, . Performance of FDG-PET/CT in solitary pulmonary nodule based on pre-test likelihood of malignancy: results from the ITALIAN retrospective multicenter trial. Eur J Nucl Med Mol Imaging. 2018 Oct;45(11):1898–907. doi: 10.1007/s00259-018-4016-1. PMID: 29736699. Exclusion Code: X3.29736699
361 Everitt S, Ball D, Hicks RJ, . Prospective Study of Serial Imaging Comparing Fluorodeoxyglucose Positron Emission Tomography (PET) and Fluorothymidine PET During Radical Chemoradiation for Non-Small Cell Lung Cancer: Reduction of Detectable Proliferation Associated With Worse Survival. Int J Radiat Oncol Biol Phys. 2017 Nov 15;99(4):947–55. doi: 10.1016/j.ijrobp.2017.07.035. PMID: 29063854. Exclusion Code: X3.29063854
362 Everitt S, Schneider-Kolsky M, Yuen K, . Dose escalation of radical radiation therapy in non-small-cell lung cancer using positron emission tomography/computed tomography-defined target volumes: are class solutions obsolete? J Med Imaging Radiat Oncol. 2008 Apr;52(2):168–77. doi: 10.1111/j.1440-1673.2008.01937.x. PMID: 18373810. Exclusion Code: X3.18373810
363 Evison M, Crosbie PA, Martin J, . EBUS-TBNA in elderly patients with lung cancer: safety and performance outcomes. J Thorac Oncol. 2014 Mar;9(3):370–6. doi: 10.1097/jto.0000000000000085. PMID: 24518088. Exclusion Code: X3.24518088
364 Evison M, Edwards T, Balata H, . Prevalence of nodal metastases in lymph node stations 8 & 9 in a large UK lung cancer surgical centre without routine pre-operative EUS nodal staging. Lung Cancer. 2018 Jan;115:127–30. doi: 10.1016/j.lungcan.2017.11.023. PMID: 29290254. Exclusion Code: X3.29290254
365 Evison M, Morris J, Martin J, . Nodal staging in lung cancer: a risk stratification model for lymph nodes classified as negative by EBUS-TBNA. J Thorac Oncol. 2015 Jan;10(1):126–33. doi: 10.1097/jto.0000000000000348. PMID: 25371076. Exclusion Code: X3.25371076
366 Ezer N, Veluswamy RR, Mhango G, . Outcomes after Stereotactic Body Radiotherapy versus Limited Resection in Older Patients with Early-Stage Lung Cancer. J Thorac Oncol. 2015 Aug;10(8):1201–6. doi: 10.1097/jto.0000000000000600. PMID: 26200275. Exclusion Code: X3.26200275
367 Fagundes CP, Shi Q, Vaporciyan AA, . Symptom recovery after thoracic surgery: Measuring patient-reported outcomes with the MD Anderson Symptom Inventory. J Thorac Cardiovasc Surg. 2015 Sep;150(3):613–9.e2. doi: 10.1016/j.jtcvs.2015.05.057. PMID: 26088408. Exclusion Code: X11.26088408
368 Fakiris AJ, McGarry RC, Yiannoutsos CT, . Stereotactic body radiation therapy for early-stage non-small-cell lung carcinoma: four-year results of a prospective phase II study. Int J Radiat Oncol Biol Phys. 2009 Nov 1;75(3):677–82. doi: 10.1016/j.ijrobp.2008.11.042. PMID: 19251380. Exclusion Code: X11.19251380
369 Fan L, Liu SY, Li QC, . Multidetector CT features of pulmonary focal ground-glass opacity: differences between benign and malignant. Br J Radiol. 2012 Jul;85(1015):897–904. doi: 10.1259/bjr/33150223. PMID: 22128130. Exclusion Code: X3.22128130
370 Fan XL, Liu YX, Tian H. Video-assisted thoracoscopic surgery for treatment of early-stage non-small cell lung cancer. Asian Pac J Cancer Prev. 2013;14(5):2871–7. PMID: 23803046. Exclusion Code: X3.23803046
371 Fang HY, Chen CY, Wang YC, . Consistently lower narcotics consumption after video-assisted thoracoscopic surgery for early stage non-small cell lung cancer when compared to open surgery: a one-year follow-up study. Eur J Cardiothorac Surg. 2013 Apr;43(4):783–6. doi: 10.1093/ejcts/ezs370. PMID: 22864790. Exclusion Code: X11.22864790
372 Fang Z, He J, Fang W, . Long-term Outcomes of Thoracoscopic Anatomic Resections and Systematic Lymphadenectomy for Elderly High-risk Patients with Stage IB Non-small-cell Lung Cancer. Heart Lung Circ. 2016 Apr;25(4):392–7. doi: 10.1016/j.hlc.2015.08.022. PMID: 26546096. Exclusion Code: X11.26546096
373 Fanidi A, Muller DC, Yuan JM, . Circulating Folate, Vitamin B6, and Methionine in Relation to Lung Cancer Risk in the Lung Cancer Cohort Consortium (LC3). J Natl Cancer Inst. 2018 Jan 1;110(1)doi: 10.1093/jnci/djx119. PMID: 28922778. Exclusion Code: X4.28922778
374 Faris NR, Smeltzer MP, Lu F, . Evolution in the Surgical Care of Patients With Non-Small Cell Lung Cancer in the Mid-South Quality of Surgical Resection Cohort. Semin Thorac Cardiovasc Surg. 2017 Spring;29(1):91–101. doi: 10.1053/j.semtcvs.2016.10.001. PMID: 28684006. Exclusion Code: X8.28684006
375 Farjah F, Backhus L, Cheng A, . Failure to rescue and pulmonary resection for lung cancer. J Thorac Cardiovasc Surg. 2015 May;149(5):1365–71; discussion 71-3.e3. doi: 10.1016/j.jtcvs.2015.01.063. PMID: 25791948. Exclusion Code: X3.25791948
376 Farjah F, Wood DE, Zadworny ME, . Resected Lung Cancer Patients Who Would and Would Not Have Met Screening Criteria. Ann Thorac Surg. 2016 Jan;101(1):274–9. doi: 10.1016/j.athoracsur.2015.06.010. PMID: 26298169. Exclusion Code: X3.26298169
377 Farr KP, Kallehauge JF, Moller DS, . Inclusion of functional information from perfusion SPECT improves predictive value of dose-volume parameters in lung toxicity outcome after radiotherapy for non-small cell lung cancer: A prospective study. Radiother Oncol. 2015 Oct;117(1):9–16. doi: 10.1016/j.radonc.2015.08.005. PMID: 26303012. Exclusion Code: X3.26303012
378 Fassina A, Corradin M, Zardo D, . Role and accuracy of rapid on-site evaluation of CT-guided fine needle aspiration cytology of lung nodules. Cytopathology. 2011 Oct;22(5):306–12. doi: 10.1111/j.1365-2303.2010.00802.x. PMID: 20738359. Exclusion Code: X3.20738359
379 Feczko A, McKeown E, Wilson JL, . Assessing Survival and Grading the Severity of Complications in Octogenarians Undergoing Pulmonary Lobectomy. Can Respir J. 2017;2017:6294895. doi: 10.1155/2017/6294895. PMID: 28270738. Exclusion Code: X11.28270738
380 Federman DG, Kravetz JD, Lerz KA, . Implementation of an electronic clinical reminder to improve rates of lung cancer screening. Am J Med. 2014 Sep;127(9):813–6. doi: 10.1016/j.amjmed.2014.04.010. PMID: 24769298. Exclusion Code: X8.24769298
381 Feng M, Yang X, Ma Q, . Retrospective analysis for the false positive diagnosis of PET-CT scan in lung cancer patients. Medicine (Baltimore). 2017 Oct;96(42):e7415. doi: 10.1097/md.0000000000007415. PMID: 29049175. Exclusion Code: X3.29049175
382 Feng M, Zhao J, Wang L, . Upregulated Expression of Serum Exosomal microRNAs as Diagnostic Biomarkers of Lung Adenocarcinoma. Ann Clin Lab Sci. 2018 Nov;48(6):712–8. PMID: 30610040. Exclusion Code: X3.30610040
383 Ferguson JS, Van Wert R, Choi Y, . Impact of a bronchial genomic classifier on clinical decision making in patients undergoing diagnostic evaluation for lung cancer. BMC Pulm Med. 2016 May 17;16(1):66. doi: 10.1186/s12890-016-0217-1. PMID: 27184093. Exclusion Code: X3.27184093
384 Ferguson MK, Watson S, Johnson E, . Predicted postoperative lung function is associated with all-cause long-term mortality after major lung resection for cancer. Eur J Cardiothorac Surg. 2014 Apr;45(4):660–4. doi: 10.1093/ejcts/ezt462. PMID: 24052607. Exclusion Code: X3.24052607
385 Fernandes P, Lareiro S, Vouga L, . Uniportal Video-Assisted Thorascoscopic Surgery - The New Paradigm in the Surgical Treatment of Lung Cancer. Rev Port Cir Cardiotorac Vasc. 2017 Jul-Dec;24(3-4):127. PMID: 29701369. Exclusion Code: X2.29701369
386 Fernandez FG, Kosinski AS, Burfeind W, . The Society of Thoracic Surgeons Lung Cancer Resection Risk Model: Higher Quality Data and Superior Outcomes. Ann Thorac Surg. 2016 Aug;102(2):370–7. doi: 10.1016/j.athoracsur.2016.02.098. PMID: 27209606. Exclusion Code: X3.27209606
387 Fernandez-Bussy S, Labarca G, Canals S, . Diagnostic yield of endobronchial ultrasound-guided transbronchial needle aspiration for mediastinal staging in lung cancer. J Bras Pneumol. 2015 May-Jun;41(3):219–24. doi: 10.1590/s1806-37132015000004466. PMID: 26176519. Exclusion Code: X3.26176519
388 Fernando H, Timmerman R. American College of Surgeons Oncology Group Z4099/Radiation Therapy Oncology Group 1021: a randomized study of sublobar resection compared with stereotactic body radiotherapy for high-risk stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2012;144(3):S35–8. doi: 10.1016/j.jtcvs.2012.06.003. PMID: CN-00968594. Exclusion Code: X10.22795435
389 Fernando HC, Landreneau RJ, Mandrekar SJ, . Analysis of longitudinal quality-of-life data in high-risk operable patients with lung cancer: results from the ACOSOG Z4032 (Alliance) multicenter randomized trial. J Thorac Cardiovasc Surg. 2015 Mar;149(3):718–25; discussion 25-6. doi: 10.1016/j.jtcvs.2014.11.003. PMID: 25500100. Exclusion Code: X11.25500100
390 Fielding DI, Chia C, Nguyen P, . Prospective randomised trial of endobronchial ultrasound-guide sheath versus computed tomography-guided percutaneous core biopsies for peripheral lung lesions. Intern Med J. 2012 Aug;42(8):894–900. doi: 10.1111/j.1445-5994.2011.02707.x. PMID: 22212110. Exclusion Code: X11.22212110
391 Filaire M, Tardy MM, Richard R, . Prophylactic tracheotomy and lung cancer resection in patient with low predictive pulmonary function: a randomized clinical trials. Chin Clin Oncol. 2015 Dec;4(4):40. doi: 10.3978/j.issn.2304-3865.2015.11.05. PMID: 26730752. Exclusion Code: X3.26730752
392 Filippo L, Principe R, Cesario A, . Smoking cessation intervention within the framework of a lung cancer screening program: preliminary results and clinical perspectives from the “Cosmos-II” Trial. Lung. 2015 Feb;193(1):147–9. doi: 10.1007/s00408-014-9661-y. PMID: 25323328. Exclusion Code: X6.25323328
393 Finley RJ, Mayo JR, Grant K, . Preoperative computed tomography-guided microcoil localization of small peripheral pulmonary nodules: a prospective randomized controlled trial. J Thorac Cardiovasc Surg. 2015 Jan;149(1):26–31. doi: 10.1016/j.jtcvs.2014.08.055. PMID: 25293355. Exclusion Code: X6.25293355
394 Fintelmann FJ, Troschel FM, Mario J, . Thoracic Skeletal Muscle Is Associated With Adverse Outcomes After Lobectomy for Lung Cancer. Ann Thorac Surg. 2018 May;105(5):1507–15. doi: 10.1016/j.athoracsur.2018.01.013. PMID: 29408306. Exclusion Code: X3.29408306
395 Fiorelli A, Caronia FP, Daddi N, . Sublobar resection versus lobectomy for stage I non-small cell lung cancer: an appropriate choice in elderly patients? Surg Today. 2016 Dec;46(12):1370–82. doi: 10.1007/s00595-016-1314-8. PMID: 27085869. Exclusion Code: X11.27085869
396 Fiorelli A, Vicidomini G, Mazzella A, . The influence of body mass index and weight loss on outcome of elderly patients undergoing lung cancer resection. Thorac Cardiovasc Surg. 2014 Oct;62(7):578–87. doi: 10.1055/s-0034-1373733. PMID: 24959934. Exclusion Code: X3.24959934
397 Fiorelli A, Vicidomini G, Milione R, . The effects of lung resection on physiological motor activity of the oesophagus. Eur J Cardiothorac Surg. 2013 Aug;44(2):250–6;discussion 7. doi: 10.1093/ejcts/ezs711. PMID: 23355690. Exclusion Code: X3.23355690
398 Fischer-Valuck BW, Boggs H, Katz S, . Comparison of stereotactic body radiation therapy for biopsy-proven versus radiographically diagnosed early-stage non-small lung cancer: a single-institution experience. Tumori. 2015 May-Jun;101(3):287–93. doi: 10.5301/tj.5000279. PMID: 25908031. Exclusion Code: X3.25908031
399 Fitzgerald NR, Flanagan WM, Evans WK, . Eligibility for low-dose computerized tomography screening among asbestos-exposed individuals. Scand J Work Environ Health. 2015 Jul;41(4):407–12. doi: 10.5271/sjweh.3496. PMID: 25837734. Exclusion Code: X8.25837734
400 Flanagan WM, Evans WK, Fitzgerald NR, . Performance of the cancer risk management model lung cancer screening module. Health Rep. 2015 May;26(5):11–8. PMID: 25993046. Exclusion Code: X7.25993046
401 Fleming C, Rimner A, Cohen GN, . High- and low-dose-rate intraoperative radiotherapy for thoracic malignancies resected with close or positive margins. Brachytherapy. 2016 Mar-Apr;15(2):208–15. doi: 10.1016/j.brachy.2015.11.007. PMID: 26825857. Exclusion Code: X3.26825857
402 Fletcher JW, Kymes SM, Gould M, . A comparison of the diagnostic accuracy of 18F-FDG PET and CT in the characterization of solitary pulmonary nodules. J Nucl Med. 2008 Feb;49(2):179–85. doi: 10.2967/jnumed.107.044990. PMID: 18199626. Exclusion Code: X3.18199626
403 Flores J, Moreno-Koehler A, Finkelman M, . Chest X-ray (CXR) screening improves outcomes in Lung Cancer (LC) in the Prostate, Lung, Colon, and Ovary (PLCO) Randomized Controlled Trial (RCT). Chest. 2015;148(4 MEETING ABSTRACT) (no pagination)doi: 10.1378/chest.2247102. PMID: CN-01129112. Exclusion Code: X5.
404 Flores R, Bauer T, Aye R, . Balancing curability and unnecessary surgery in the context of computed tomography screening for lung cancer. J Thorac Cardiovasc Surg. 2014 May;147(5):1619–26. doi: 10.1016/j.jtcvs.2013.11.001. PMID: 24332102. Exclusion Code: X11.24332102
405 Flores R, Taioli E, Yankelevitz DF, . Initiative for Early Lung Cancer Research on Treatment: Development of Study Design and Pilot Implementation. J Thorac Oncol. 2018 Jul;13(7):946–57. doi: 10.1016/j.jtho.2018.03.009. PMID: 29578108. Exclusion Code: X11.29578108
406 Flores RM, Nicastri D, Bauer T, . Computed tomography screening for lung cancer: mediastinal lymph node resection in stage IA nonsmall cell lung cancer manifesting as subsolid and solid Nodules. Ann Surg. 2017 May;265(5):1025–33. doi: 10.1097/sla.0000000000001802. PMID: 27232256. Exclusion Code: X8.27232256
407 Fontaine-Delaruelle C, Souquet PJ, Gamondes D, . Negative predictive value of transthoracic core-needle biopsy: a multicenter study. Chest. 2015 Aug;148(2):472–80. doi: 10.1378/chest.14-1907. PMID: 25569025. Exclusion Code: X3.25569025
408 Foster CC, Rusthoven CG, Sher DJ, . Adjuvant chemotherapy following stereotactic body radiotherapy for early stage non-small-cell lung cancer is associated with lower overall: A National Cancer Database Analysis. Lung Cancer. 2019 Apr;130:162–8. doi: 10.1016/j.lungcan.2019.02.023. PMID: 30885339. Exclusion Code: X3.30885339
409 Fox M, Van Berkel V, Bousamra M, 2nd, . Surgical management of pulmonary carcinoid tumors: sublobar resection versus lobectomy. Am J Surg. 2013 Feb;205(2):200–8. doi: 10.1016/j.amjsurg.2012.05.008. PMID: 23063095. Exclusion Code: X3.23063095
410 Foy M, Spitz MR, Kimmel M, . A smoking-based carcinogenesis model for lung cancer risk prediction. Int J Cancer. 2011 Oct 15;129(8):1907–13. doi: 10.1002/ijc.25834. PMID: 21140453. Exclusion Code: X7.21140453
411 Fraioli F, Catalano C, Almberger M, . Evaluation of effectiveness of a computer system (CAD) in the identification of lung nodules with low-dose MSCT: scanning technique and preliminary results. Radiol Med. 2005 Jan-Feb;109(1-2):40–8. PMID: 15729185. Exclusion Code: X3.15729185
412 Fraioli F, Screaton NJ, Janes SM, . Non-small-cell lung cancer resectability: diagnostic value of PET/MR. Eur J Nucl Med Mol Imaging. 2015 Jan;42(1):49–55. doi: 10.1007/s00259-014-2873-9. PMID: 25120040. Exclusion Code: X6.25120040
413 Franco I, Chen YH, Chipidza F, . Use of frailty to predict survival in elderly patients with early stage non-small-cell lung cancer treated with stereotactic body radiation therapy. J Geriatr Oncol. 2018 Mar;9(2):130–7. doi: 10.1016/j.jgo.2017.09.002. PMID: 28941581. Exclusion Code: X3.28941581
414 Franke KJ, Hein M, Domanski U, . Transbronchial catheter aspiration and transbronchial needle aspiration in the diagnostic workup of peripheral lung lesions. Lung. 2015 Oct;193(5):767–72. doi: 10.1007/s00408-015-9763-1. PMID: 26156311. Exclusion Code: X11.26156311
415 Freeman RK, Dilts JR, Ascioti AJ, . A comparison of quality and cost indicators by surgical specialty for lobectomy of the lung. J Thorac Cardiovasc Surg. 2013 Jan;145(1):68–73; discussion -4. doi: 10.1016/j.jtcvs.2012.09.012. PMID: 23058669. Exclusion Code: X8.23058669
416 Frood R, Prestwich R, Tsoumpas C, . Effectiveness of Respiratory-gated Positron Emission Tomography/Computed Tomography for Radiotherapy Planning in Patients with Lung Carcinoma - A Systematic Review. Clin Oncol (R Coll Radiol). 2018 Apr;30(4):225–32. doi: 10.1016/j.clon.2018.01.005. PMID: 29397271. Exclusion Code: X3.29397271
417 Fu M, Travier N, Martin-Sanchez JC, . Identifying high-risk individuals for lung cancer screening: Going beyond NLST criteria. PLoS One. 2018;13(4):e0195441. doi: 10.1371/journal.pone.0195441. PMID: 29621354. Exclusion Code: X8.29621354
418 Fu SS, Rothman AJ, Vock DM, . Program for lung cancer screening and tobacco cessation: Study protocol of a sequential, multiple assignment, randomized trial. Contemp Clin Trials. 2017 Sep;60:86–95. doi: 10.1016/j.cct.2017.07.002. PMID: 28687349. Exclusion Code: X8.28687349
419 Fu YF, Gao YG, Zhang M, . Computed tomography-guided simultaneous coil localization as a bridge to one-stage surgery for multiple lung nodules: a retrospective study. J Cardiothorac Surg. 2019 Feb 26;14(1):43. doi: 10.1186/s13019-019-0870-6. PMID: 30808426. Exclusion Code: X3.30808426
420 Fuchs FS, Zirlik S, Hildner K, . Confocal laser endomicroscopy for diagnosing lung cancer in vivo. Eur Respir J. 2013 Jun;41(6):1401–8. doi: 10.1183/09031936.00062512. PMID: 22997220. Exclusion Code: X3.22997220
421 Fujii O, Demizu Y, Hashimoto N, . Particle therapy for clinically diagnosed stage I lung cancer: comparison with pathologically proven non-small cell lung cancer. Acta Oncol. 2015 Mar;54(3):315–21. doi: 10.3109/0284186x.2014.974828. PMID: 25383445. Exclusion Code: X6.25383445
422 Fukui M, Suzuki K, Matsunaga T, . Outcomes of lung cancer resection for patients with combined pulmonary fibrosis and emphysema. Surg Today. 2016 Mar;46(3):341–7. doi: 10.1007/s00595-015-1234-z. PMID: 26276308. Exclusion Code: X11.26276308
423 Fukui M, Takamochi K, Matsunaga T, . Risk of the preoperative underestimation of tumour size of lung cancer in patients with idiopathic interstitial pneumonias. Eur J Cardiothorac Surg. 2016 Sep;50(3):428–32. doi: 10.1093/ejcts/ezw065. PMID: 26987880. Exclusion Code: X8.26987880
424 Fukui T, Kato K, Okasaka T, . Predictors for hilar/intrapulmonary lymph node metastasis in discrete type of clinical N1 non-small cell lung cancer. Gen Thorac Cardiovasc Surg. 2017 Nov;65(11):640–5. doi: 10.1007/s11748-017-0827-4. PMID: 28866794. Exclusion Code: X3.28866794
425 Fukushima T, Tateishi K, Hanaoka M, . Clinical outcomes in patients with small cell lung cancer in a single institute: Comparative analysis of radiographic screening with symptom-prompted patients. Lung Cancer. 2015 Apr;88(1):48–51. doi: 10.1016/j.lungcan.2015.01.025. PMID: 25703893. Exclusion Code: X3.25703893
426 Fukushima T, Tateishi K, Yamamoto H, . Clinical characteristics and outcomes of patients with small cell lung cancer detected by CT screening. Med Oncol. 2013;30(3):623. doi: 10.1007/s12032-013-0623-7. PMID: 23740004. Exclusion Code: X3.23740004
427 Fuso L, Varone F, Magnini D, . Role of ultrasound-guided transbronchial biopsy in the diagnosis of peripheral pulmonary lesions. Lung Cancer. 2013 Jul;81(1):60–4. doi: 10.1016/j.lungcan.2013.04.004. PMID: 23639784. Exclusion Code: X8.23639784
428 Fuso L, Varone F, Magnini D, . Influence of the learning effect on the diagnostic yield of endobronchial ultrasound-guided transbronchial needle aspiration of mediastinal and hilar lymph nodes. J Bronchology Interv Pulmonol. 2017 Jul;24(3):193–9. doi: 10.1097/lbr.0000000000000372. PMID: 28696965. Exclusion Code: X3.28696965
429 Gadaleta CD, Solbiati L, Mattioli V, . Unresectable lung malignancy: combination therapy with segmental pulmonary arterial chemoembolization with drug-eluting microspheres and radiofrequency ablation in 17 patients. Radiology. 2013 May;267(2):627–37. doi: 10.1148/radiol.12120198. PMID: 23249572. Exclusion Code: X3.23249572
430 Galetta D, Solli P, Borri A, . Bilobectomy for lung cancer: analysis of indications, postoperative results, and long-term outcomes. Ann Thorac Surg. 2012 Jan;93(1):251–7; discussion 7-8. doi: 10.1016/j.athoracsur.2011.08.086. PMID: 22112798. Exclusion Code: X3.22112798
431 Gallagher SP, Abolhoda A, Kirkpatrick VE, . Learning Curve of Robotic Lobectomy for Early-Stage Non-Small Cell Lung Cancer by a Thoracic Surgeon Adept in Open Lobectomy. Innovations (Phila). 2018 Sep/Oct;13(5):321–7. doi: 10.1097/imi.0000000000000552. PMID: 30407925. Exclusion Code: X3.30407925
432 Gallardo-Estrella L, Pompe E, de Jong PA, . Normalized emphysema scores on low dose CT: Validation as an imaging biomarker for mortality. PLoS One. 2017;12(12):e0188902. doi: 10.1371/journal.pone.0188902. PMID: 29227997. Exclusion Code: X3.29227997
433 Ganti AK, Shostrom V, Alorabi M, . Early stage non-small-cell lung cancer in octogenarian and older patients: A SEER Database analysis. Clin Lung Cancer. 2016 Jul;17(4):285–91. doi: 10.1016/j.cllc.2015.11.014. PMID: 26725852. Exclusion Code: X12.26725852
434 Ganti AK, Williams CD, Gajra A, . Effect of age on the efficacy of adjuvant chemotherapy for resected non-small cell lung cancer. Cancer. 2015 Aug 1;121(15):2578–85. doi: 10.1002/cncr.29360. PMID: 25873330. Exclusion Code: X6.25873330
435 Gao S, Wu H, Li W, . A pilot study imaging integrin alphavbeta3 with RGD PET/CT in suspected lung cancer patients. Eur J Nucl Med Mol Imaging. 2015 Dec;42(13):2029–37. doi: 10.1007/s00259-015-3119-1. PMID: 26153145. Exclusion Code: X3.26153145
436 Gao SJ, Kim AW, Puchalski JT, . Indications for invasive mediastinal staging in patients with early non-small cell lung cancer staged with PET-CT. Lung Cancer. 2017 Jul;109:36–41. doi: 10.1016/j.lungcan.2017.04.018. PMID: 28577947. Exclusion Code: X11.28577947
437 Garcia-Garrigos E, Arenas-Jimenez JJ, Sanchez-Paya J. Best Protocol for Combined Contrast-Enhanced Thoracic and Abdominal CT for Lung Cancer: A Single-Institution Randomized Crossover Clinical Trial. AJR Am J Roentgenol. 2018 Jun;210(6):1226–34. doi: 10.2214/ajr.17.19185. PMID: 29570376. Exclusion Code: X3.29570376
438 Garcia-Ortega A, Briones-Gomez A, Fabregat S, . Benefit of Chest Ultrasonography in the Diagnosis of Peripheral Thoracic Lesions in an Interventional Pulmonology Unit. Arch Bronconeumol. 2016 May;52(5):244–9. doi: 10.1016/j.arbres.2015.07.012. PMID: 26411258. Exclusion Code: X3.26411258
439 Garcia-Velloso MJ, Bastarrika G, de-Torres JP, . Assessment of indeterminate pulmonary nodules detected in lung cancer screening: Diagnostic accuracy of FDG PET/CT. Lung Cancer. 2016 Jul;97:81–6. doi: 10.1016/j.lungcan.2016.04.025. PMID: 27237032. Exclusion Code: X5.27237032
440 Gareen IF, Sicks JD, Jain AA, . Identifying and collecting pertinent medical records for centralized abstraction in a multi-center randomized clinical trial: the model used by the American College of Radiology arm of the National Lung Screening Trial. Contemp Clin Trials. 2013 Jan;34(1):36–44. doi: 10.1016/j.cct.2012.09.002. PMID: 22982342. Exclusion Code: X8.22982342
441 Garg K, Keith RL, Byers T, . Randomized controlled trial with low-dose spiral CT for lung cancer screening: feasibility study and preliminary results. Radiology. 2002 Nov;225(2):506–10. doi: 10.1148/radiol.2252011851. PMID: 12409588. Exclusion Code: X8.12409588
442 Gariani J, Martin SP, Hachulla AL, . Noninvasive pulmonary nodule characterization using transcutaneous bioconductance: Preliminary results of an observational study. Medicine (Baltimore). 2018 Aug;97(34):e11924. doi: 10.1097/md.0000000000011924. PMID: 30142805. Exclusion Code: X3.30142805
443 Garrido P, Vinolas N, Isla D, . Lung cancer in Spanish women: The WORLD07 project. Eur J Cancer Care (Engl). 2019 Jan;28(1):e12941. doi: 10.1111/ecc.12941. PMID: 30277293. Exclusion Code: X3.30277293
444 Ge H, Cai J, Kelsey CR, . Quantification and minimization of uncertainties of internal target volume for stereotactic body radiation therapy of lung cancer. Int J Radiat Oncol Biol Phys. 2013 Feb 1;85(2):438–43. doi: 10.1016/j.ijrobp.2012.04.032. PMID: 22687196. Exclusion Code: X8.22687196
445 Ge X, Gao F, Li M, . Diagnostic value of solid component for lung adenocarcinoma shown as ground-glass nodule on computed tomography. Zhonghua yi xue za zhi. 2014;94(13):1010–3. PMID: CN-01116479. Exclusion Code: X1.24851690
446 Gelbman BD, Cham MD, Kim W, . Radiographic and clinical characterization of false negative results from CT-guided needle biopsies of lung nodules. J Thorac Oncol. 2012 May;7(5):815–20. doi: 10.1097/JTO.0b013e31824abd9c. PMID: 22729035. Exclusion Code: X3.22729035
447 Genestreti G, Bongiovanni A, Burgio MA, . 111In-Pentetreotide (OctreoScan) scintigraphy in the staging of small-cell lung cancer: its accuracy and prognostic significance. Nucl Med Commun. 2015 Feb;36(2):135–42. doi: 10.1097/mnm.0000000000000221. PMID: 25321157. Exclusion Code: X3.25321157
448 Georgiou HD, Taverner J, Irving LB, . Safety and efficacy of radial EBUS for the investigation of peripheral pulmonary lesions in patients with advanced COPD. J Bronchology Interv Pulmonol. 2016 Jul;23(3):192–8. doi: 10.1097/lbr.0000000000000288. PMID: 27454473. Exclusion Code: X11.27454473
449 Geraci T, Baratta V, Young J, . Lobectomy for lung cancer at Veterans Administration Medical Center versus academic medical center. Ann Thorac Surg. 2017 Jun;103(6):1715–22. doi: 10.1016/j.athoracsur.2016.12.040. PMID: 28347532. Exclusion Code: X11.28347532
450 Geraldson CT, Stephenson JE, Lagrew JP, . Use of positron emission tomography in initial staging of nonsmall cell lung carcinoma: a regional teaching hospital experience. Am Surg. 2012 Mar;78(3):305–8. PMID: 22524768. Exclusion Code: X8.22524768
451 Gerber DE, Hamann HA, Santini NO, . Patient navigation for lung cancer screening in an urban safety-net system: Protocol for a pragmatic randomized clinical trial. Contemp Clin Trials. 2017 Sep;60:78–85. doi: 10.1016/j.cct.2017.07.003. PMID: 28689056. Exclusion Code: X8.28689056
452 Ghaly G, Kamel M, Nasar A, . Video-assisted thoracoscopic surgery is a safe and effective alternative to thoracotomy for anatomical segmentectomy in patients with clinical stage I non-small cell lung cancer. Ann Thorac Surg. 2016 Feb;101(2):465–72; discussion 72. doi: 10.1016/j.athoracsur.2015.06.112. PMID: 26391692. Exclusion Code: X11.26391692
453 Ghaly G, Rahouma M, Kamel MK, . Clinical predictors of nodal metastases in peripherally clinical T1a N0 non-small cell lung cancer. Ann Thorac Surg. 2017 Oct;104(4):1153–8. doi: 10.1016/j.athoracsur.2017.02.074. PMID: 28551047. Exclusion Code: X11.28551047
454 Gianella P, Soccal PM, Plojoux J, . Utility of Rapid On-Site Cytologic Evaluation during Endobronchial Ultrasound-Guided Transbronchial Needle Aspiration in Malignant and Nonmalignant Disease. Acta Cytol. 2018;62(5-6):380–5. doi: 10.1159/000493334. PMID: 30244239. Exclusion Code: X3.30244239
455 Gibson G, Kumar AR, Steinke K, . Risk stratification in the investigation of pulmonary nodules in a high-risk cohort: positron emission tomography/computed tomography outperforms clinical risk prediction algorithms. Intern Med J. 2017 Dec;47(12):1385–92. doi: 10.1111/imj.13576. PMID: 28782248. Exclusion Code: X3.28782248
456 Gierada DS, Pilgram TK, Ford M, . Lung cancer: interobserver agreement on interpretation of pulmonary findings at low-dose CT screening. Radiology. 2008 Jan;246(1):265–72. doi: 10.1148/radiol.2461062097. PMID: 18024436. Exclusion Code: X11.18024436
457 Gierada DS, Politte DG, Zheng J, . Quantitative computed tomography classification of lung nodules: initial comparison of 2- and 3-dimensional analysis. J Comput Assist Tomogr. 2016 Jul-Aug;40(4):589–95. doi: 10.1097/rct.0000000000000394. PMID: 27096403. Exclusion Code: X3.27096403
458 Gietema HA, Wang Y, Xu D, . Pulmonary nodules detected at lung cancer screening: interobserver variability of semiautomated volume measurements. Radiology. 2006 Oct;241(1):251–7. doi: 10.1148/radiol.2411050860. PMID: 16908677. Exclusion Code: X3.16908677
459 Gilbert S, Maghera S, Seely AJ, . Identifying patients at higher risk of prolonged air leak after lung resection. Ann Thorac Surg. 2016 Nov;102(5):1674–9. doi: 10.1016/j.athoracsur.2016.05.035. PMID: 27457828. Exclusion Code: X3.27457828
460 Gill RR, Zheng Y, Barlow JS, . Image-guided video assisted thoracoscopic surgery (iVATS) - phase I-II clinical trial. J Surg Oncol. 2015 Jul;112(1):18–25. doi: 10.1002/jso.23941. PMID: 26031893. Exclusion Code: X11.26031893
461 Girard P, Caliandro R, Seguin-Givelet A, . Sensitivity of cytology specimens from bronchial aspirate or washing during bronchoscopy in the diagnosis of lung malignancies: an update. Clin Lung Cancer. 2017 Sep;18(5):512–8. doi: 10.1016/j.cllc.2016.11.009. PMID: 28007409. Exclusion Code: X8.28007409
462 Giti R, Hosseinzadeh M. Efficacy of Bronchial Washing and Brushing Cytology in the Diagnosis of Non-Neoplastic Lung Diseases. Acta Med Iran. 2017 Oct;55(10):636–41. PMID: 29228529. Exclusion Code: X3.29228529
463 Glick D, Lyen S, Kandel S, . Impact of Pretreatment Interstitial Lung Disease on Radiation Pneumonitis and Survival in Patients Treated With Lung Stereotactic Body Radiation Therapy (SBRT). Clin Lung Cancer. 2018 Mar;19(2):e219–e26. doi: 10.1016/j.cllc.2017.06.021. PMID: 29066051. Exclusion Code: X3.29066051
464 Go T, Misaki N, Matsuura N, . Role of surgery in multi-modality treatment for carcinomatous pleuritis in patients with non-small cell lung cancer. Surg Today. 2015 Feb;45(2):197–202. doi: 10.1007/s00595-014-0987-0. PMID: 25034395. Exclusion Code: X3.25034395
465 Gobara H, Arai Y, Kobayashi T, . Percutaneous radiofrequency ablation for patients with malignant lung tumors: a phase II prospective multicenter study (JIVROSG-0702). Jpn J Radiol. 2016 Aug;34(8):556–63. doi: 10.1007/s11604-016-0557-z. PMID: 27260478. Exclusion Code: X6.27260478
466 Gohagan JK, Broski K, Gren LH, . Managing multi-center recruitment in the PLCO Cancer Screening Trial. Rev Recent Clin Trials. 2015;10(3):187–93. PMID: 26435288. Exclusion Code: X11.26435288
467 Goldwasser DL. Estimation of the tumor size at cure threshold among aggressive non-small cell lung cancers (NSCLCs): evidence from the surveillance, epidemiology, and end results (SEER) program and the national lung screening trial (NLST). Int J Cancer. 2017 Mar 15;140(6):1280–92. doi: 10.1002/ijc.30548. PMID: 27925181. Exclusion Code: X10.27925181
468 Goldwasser DL, Kimmel M. Small median tumor diameter at cure threshold (<20 mm) among aggressive non-small cell lung cancers in male smokers predicts both chest X-ray and CT screening outcomes in a novel simulation framework. Int J Cancer. 2013 Jan 1;132(1):189–97. doi: 10.1002/ijc.27599. PMID: 22510979. Exclusion Code: X7.22510979
469 Gomez DR, Gillin M, Liao Z, . Phase 1 study of dose escalation in hypofractionated proton beam therapy for non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2013 Jul 15;86(4):665–70. doi: 10.1016/j.ijrobp.2013.03.035. PMID: 23688815. Exclusion Code: X6.23688815
470 Gomez-Caro A, Boada M, Cabanas M, . False-negative rate after positron emission tomography/computer tomography scan for mediastinal staging in cI stage non-small-cell lung cancer. Eur J Cardiothorac Surg. 2012 Jul;42(1):93–100; discussion doi: 10.1093/ejcts/ezr272. PMID: 22290911. Exclusion Code: X11.22290911
471 Gong J, Liu JY, Jiang YJ, . Fusion of quantitative imaging features and serum biomarkers to improve performance of computer-aided diagnosis scheme for lung cancer: A preliminary study. Med Phys. 2018 Dec;45(12):5472–81. doi: 10.1002/mp.13237. PMID: 30317652. Exclusion Code: X3.30317652
472 Gong J, Liu JY, Sun XW, . Computer-aided diagnosis of lung cancer: the effect of training data sets on classification accuracy of lung nodules. Phys Med Biol. 2018 Feb 5;63(3):035036. doi: 10.1088/1361-6560/aaa610. PMID: 29311420. Exclusion Code: X3.29311420
473 Gonzalez J, de-Torres JP. Lung cancer and emphysema. Arch Bronconeumol. 2017 Feb;53(2):47–8. doi: 10.1016/j.arbres.2016.07.010. PMID: 27566892. Exclusion Code: X2.27566892
474 Gonzalez-Perez V, Arana E, Barrios M, . Differentiation of benign and malignant lung lesions: dual-energy computed tomography findings. Eur J Radiol. 2016 Oct;85(10):1765–72. doi: 10.1016/j.ejrad.2016.07.019. PMID: 27666614. Exclusion Code: X3.27666614
475 Gonzalez-Rivas D, Kuo YC, Wu CY, . Predictive factors of postoperative complications in single-port video-assisted thoracoscopic anatomical resection: Two center experience. Medicine (Baltimore). 2018 Oct;97(40):e12664. doi: 10.1097/md.0000000000012664. PMID: 30290649. Exclusion Code: X3.30290649
476 Gossot D, Lutz JA, Grigoroiu M, . Unplanned procedures during thoracoscopic segmentectomies. Ann Thorac Surg. 2017 Nov;104(5):1710–7. doi: 10.1016/j.athoracsur.2017.05.081. PMID: 28969898. Exclusion Code: X11.28969898
477 Grassberger C, Daartz J, Dowdell S, . Quantification of proton dose calculation accuracy in the lung. Int J Radiat Oncol Biol Phys. 2014 Jun 1;89(2):424–30. doi: 10.1016/j.ijrobp.2014.02.023. PMID: 24726289. Exclusion Code: X3.24726289
478 Grasso RF, Cazzato RL, Luppi G, . Percutaneous lung biopsies: performance of an optical CT-based navigation system with a low-dose protocol. Eur Radiol. 2013 Nov;23(11):3071–6. doi: 10.1007/s00330-013-2932-9. PMID: 23783784. Exclusion Code: X3.23783784
479 Gray SW, Landrum MB, Lamont EB, . Improved outcomes associated with higher surgery rates for older patients with early stage nonsmall cell lung cancer. Cancer. 2012 Mar 1;118(5):1404–11. doi: 10.1002/cncr.26363. PMID: 21800285. Exclusion Code: X12.21800285
480 Green A, Hauge J, Iachina M, . The mortality after surgery in primary lung cancer: results from the Danish Lung Cancer Registry. Eur J Cardiothorac Surg. 2016 Feb;49(2):589–94. doi: 10.1093/ejcts/ezv107. PMID: 25825264. Exclusion Code: X3.25825264
481 Greenberg AK, Lu F, Goldberg JD, . CT scan screening for lung cancer: risk factors for nodules and malignancy in a high-risk urban cohort. PLoS One. 2012;7(7):e39403. doi: 10.1371/journal.pone.0039403. PMID: 22768300. Exclusion Code: X7.22768300
482 Greillier L, Cortot AB, Viguier J, . Perception of Lung Cancer Risk: Impact of Smoking Status and Nicotine Dependence. Curr Oncol Rep. 2018 Mar 5;20(Suppl 1):18. doi: 10.1007/s11912-017-0650-1. PMID: 29508085. Exclusion Code: X3.29508085
483 Grills IS, Mangona VS, Welsh R, . Outcomes after stereotactic lung radiotherapy or wedge resection for stage I non-small-cell lung cancer. J Clin Oncol. 2010 Feb 20;28(6):928–35. doi: 10.1200/jco.2009.25.0928. PMID: 20065181. Exclusion Code: X11.20065181
484 Grinberg M, Djureinovic D, Brunnstrom HR, . Reaching the limits of prognostication in non-small cell lung cancer: an optimized biomarker panel fails to outperform clinical parameters. Mod Pathol. 2017 Jul;30(7):964–77. doi: 10.1038/modpathol.2017.14. PMID: 28281552. Exclusion Code: X3.28281552
485 Grivaux M, Debieuvre D, Herman D, . Early mortality in lung cancer: French prospective multicentre observational study. BMC Pulm Med. 2016 Apr 2;16:45. doi: 10.1186/s12890-016-0205-5. PMID: 27039176. Exclusion Code: X3.27039176
486 Grose D, Morrison DS, Devereux G, . The impact of comorbidity upon determinants of outcome in patients with lung cancer. Lung Cancer. 2015 Feb;87(2):186–92. doi: 10.1016/j.lungcan.2014.11.012. PMID: 25498829. Exclusion Code: X11.25498829
487 Gross DJ, Chang EH, Rosen PL, . Outcomes in video-assisted thoracoscopic surgery lobectomies: challenging preconceived notions. J Surg Res. 2018 Nov;231:161–6. doi: 10.1016/j.jss.2018.05.040. PMID: 30278924. Exclusion Code: X3.30278924
488 Grossi F, Belvedere O, Fasola G, . Tumor measurements on computed tomographic images of non-small cell lung cancer were similar among cancer professionals from different specialties. J Clin Epidemiol. 2004 Aug;57(8):804–8. doi: 10.1016/j.jclinepi.2003.12.020. PMID: 15485732. Exclusion Code: X3.15485732
489 Grosso M, Priotto R, Ghirardo D, . Comparison of digital tomosynthesis and computed tomography for lung nodule detection in SOS screening program. Radiol Med. 2017 Aug;122(8):568–74. doi: 10.1007/s11547-017-0765-3. PMID: 28429205. Exclusion Code: X3.28429205
490 Grove O, Berglund AE, Schabath MB, . Quantitative computed tomographic descriptors associate tumor shape complexity and intratumor heterogeneity with prognosis in lung adenocarcinoma. PLoS One. 2015;10(3):e0118261. doi: 10.1371/journal.pone.0118261. PMID: 25739030. Exclusion Code: X11.25739030
491 Gu B, Burt BM, Merritt RE, . A dominant adenocarcinoma with multifocal ground glass lesions does not behave as advanced disease. Ann Thorac Surg. 2013 Aug;96(2):411–8. doi: 10.1016/j.athoracsur.2013.04.048. PMID: 23806231. Exclusion Code: X11.23806231
492 Gu C, Pan X, Chen Y, . Short-term and mid-term survival in bronchial sleeve resection by robotic system versus thoracotomy for centrally located lung cancer. Eur J Cardiothorac Surg. 2018 Mar 1;53(3):648–55. doi: 10.1093/ejcts/ezx355. PMID: 29029111. Exclusion Code: X10.29029111
493 Gu C, Wang R, Pan X, . Sublobar resection versus lobectomy in patients aged </=35 years with stage IA non-small cell lung cancer: a SEER database analysis. J Cancer Res Clin Oncol. 2017 Nov;143(11):2375–82. doi: 10.1007/s00432-017-2499-y. PMID: 28819775. Exclusion Code: X11.28819775
494 Gu F, Cheung LC, Freedman ND, . Potential Impact of Including Time to First Cigarette in Risk Models for Selecting Ever-Smokers for Lung Cancer Screening. J Thorac Oncol. 2017 Nov;12(11):1646–53. doi: 10.1016/j.jtho.2017.08.001. PMID: 28818607. Exclusion Code: X4.28818607
495 Gu F, Wacholder S, Kovalchik S, . Time to smoke first morning cigarette and lung cancer in a case-control study. J Natl Cancer Inst. 2014 Jun;106(6):dju118. doi: 10.1093/jnci/dju118. PMID: 24948709. Exclusion Code: X4.24948709
496 Guckenberger M, Klement RJ, Kestin LL, . Lack of a dose-effect relationship for pulmonary function changes after stereotactic body radiation therapy for early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2013 Mar 15;85(4):1074–81. doi: 10.1016/j.ijrobp.2012.09.016. PMID: 23154077. Exclusion Code: X8.23154077
497 Guerra L, De Ponti E, Elisei F, . Respiratory gated PET/CT in a European multicentre retrospective study: added diagnostic value in detection and characterization of lung lesions. Eur J Nucl Med Mol Imaging. 2012 Sep;39(9):1381–90. doi: 10.1007/s00259-012-2148-2. PMID: 22588628. Exclusion Code: X3.22588628
498 Guichet PL, Liu BY, Desai B, . Preliminary Results of Lung Cancer Screening in a Socioeconomically Disadvantaged Population. AJR Am J Roentgenol. 2018 Mar;210(3):489–96. doi: 10.2214/ajr.17.18853. PMID: 29166147. Exclusion Code: X10.29166147
499 Gulati CM, Schreiner AM, Libby DM, . Outcomes of unresected ground-glass nodules with cytology suspicious for adenocarcinoma. J Thorac Oncol. 2014 May;9(5):685–91. doi: 10.1097/jto.0000000000000143. PMID: 24722156. Exclusion Code: X3.24722156
500 Guldbrandt LM. The effect of direct referral for fast CT scan in early lung cancer detection in general practice. A clinical, cluster-randomised trial. Dan Med J. 2015 Mar;62(3)PMID: 25748876. Exclusion Code: X6.25748876
501 Guldbrandt LM, Fenger-Gron M, Rasmussen TR, . The effect of direct access to CT scan in early lung cancer detection: an unblinded, cluster-randomised trial. BMC Cancer. 2015 Nov 25;15:934. doi: 10.1186/s12885-015-1941-2. PMID: 26608727. Exclusion Code: X6.26608727
502 Guldbrandt LM, Rasmussen TR, Rasmussen F, . Implementing direct access to low-dose computed tomography in general practice--method, adaption and outcome. PLoS One. 2014;9(11):e112162. doi: 10.1371/journal.pone.0112162. PMID: 25383780. Exclusion Code: X8.25383780
503 Gumireddy K, Li A, Chang DH, . AKAP4 is a circulating biomarker for non-small cell lung cancer. Oncotarget. 2015 Jul 10;6(19):17637–47. doi: 10.18632/oncotarget.3946. PMID: 26160834. Exclusion Code: X5.26160834
504 Gungor G, Demir M, Aydin G, . Improvement of conformal arc plans by using deformable margin delineation method for stereotactic lung radiotherapy. J Appl Clin Med Phys. 2018 Jan;19(1):184–93. doi: 10.1002/acm2.12237. PMID: 29218841. Exclusion Code: X3.29218841
505 Gunluoglu MZ, Kocaturk CI, Demir A, . Bronchial Stump Recurrence after Complete Resection of Lung Cancer: Effect of the Distance between the Tumor and Bronchial Resection Margin. Thorac Cardiovasc Surg. 2018 Mar;66(2):156–63. doi: 10.1055/s-0036-1592192. PMID: 27628445. Exclusion Code: X3.27628445
506 Guo H, Liu S, Guo J, . Rapid on-site evaluation during endobronchial ultrasound-guided transbronchial needle aspiration for the diagnosis of hilar and mediastinal lymphadenopathy in patients with lung cancer. Cancer Lett. 2016 Feb 28;371(2):182–6. doi: 10.1016/j.canlet.2015.11.038. PMID: 26656954. Exclusion Code: X3.26656954
507 Guo NL, Wan YW. Pathway-based identification of a smoking associated 6-gene signature predictive of lung cancer risk and survival. Artif Intell Med. 2012 Jun;55(2):97–105. doi: 10.1016/j.artmed.2012.01.001. PMID: 22326768. Exclusion Code: X3.22326768
508 Guo X, Li D, Wu Y, . Genetic variants in genes of tricarboxylic acid cycle key enzymes are associated with prognosis of patients with non-small cell lung cancer. Lung Cancer. 2015 Feb;87(2):162–8. doi: 10.1016/j.lungcan.2014.12.005. PMID: 25576295. Exclusion Code: X3.25576295
509 Gupta A, Saar T, Martens O, . Automatic detection of multisize pulmonary nodules in CT images: Large-scale validation of the false-positive reduction step. Med Phys. 2018 Mar;45(3):1135–49. doi: 10.1002/mp.12746. PMID: 29359462. Exclusion Code: X3.29359462
510 Guralnik L, Rozenberg R, Frenkel A, . Metabolic PET/CT-guided lung lesion biopsies: impact on diagnostic accuracy and rate of sampling error. J Nucl Med. 2015 Apr;56(4):518–22. doi: 10.2967/jnumed.113.131466. PMID: 25698780. Exclusion Code: X3.25698780
511 Gursoy S, Yazgan S, Ucvet A, . Postpneumonectomy bronchopleural fistula in non-small cell lung cancer patients: incidence, survival, mortality, and treatment analysis. Surg Today. 2018 Jul;48(7):695–702. doi: 10.1007/s00595-018-1648-5. PMID: 29516277. Exclusion Code: X3.29516277
512 Gust L, Toullec A, Benoit C, . Pulmonary Endogenous Fluorescence Allows the Distinction of Primary Lung Cancer from the Perilesional Lung Parenchyma. PLoS One. 2015;10(8):e0134559. doi: 10.1371/journal.pone.0134559. PMID: 26244637. Exclusion Code: X3.26244637
513 Guyatt GH, Lefcoe M, Walter S, . Interobserver variation in the computed tomographic evaluation of mediastinal lymph node size in patients with potentially resectable lung cancer. Canadian Lung Oncology Group. Chest. 1995 Jan;107(1):116–9. PMID: 7813261. Exclusion Code: X3.7813261
514 Gwozdz P, Pasieka-Lis M, Kolodziej K, . Prognosis of Patients With Stages I and II Non-Small Cell Lung Cancer With Nodal Micrometastases. Ann Thorac Surg. 2018 May;105(5):1551–7. doi: 10.1016/j.athoracsur.2017.12.006. PMID: 29305849. Exclusion Code: X11.29305849
515 Ha D, Choi H, Zell K, . Association of impaired heart rate recovery with cardiopulmonary complications after lung cancer resection surgery. J Thorac Cardiovasc Surg. 2015 Apr;149(4):1168–73.e3. doi: 10.1016/j.jtcvs.2014.11.037. PMID: 25583106. Exclusion Code: X3.25583106
516 Haas K, Brillante C, Sharp L, . Lung cancer screening: assessment of health literacy and readability of online educational resources. BMC Public Health. 2018 Dec 7;18(1):1356. doi: 10.1186/s12889-018-6278-8. PMID: 30526544. Exclusion Code: X3.30526544
517 Haasbeek CJ, Lagerwaard FJ, Slotman BJ, . Outcomes of stereotactic ablative radiotherapy for centrally located early-stage lung cancer. J Thorac Oncol. 2011 Dec;6(12):2036–43. doi: 10.1097/JTO.0b013e31822e71d8. PMID: 21892102. Exclusion Code: X11.21892102
518 Halac M, Ozhan M, Yilmaz Aksoy S, . The role of FDG-PET/CT in detecting unsuspected and unknown distant metastasis in the initial staging of NSCLC. Turk J Med Sci. 2014;44(6):1029–40. PMID: 25552157. Exclusion Code: X8.25552157
519 Halpenny DF, Cunningham JD, Long NM, . Patients with a previous history of malignancy undergoing lung cancer screening: clinical characteristics and radiologic findings. J Thorac Oncol. 2016 Sep;11(9):1447–52. doi: 10.1016/j.jtho.2016.05.006. PMID: 27223458. Exclusion Code: X7.27223458
520 Hamada K, Irie M, Fujino Y, . Prognostic value of preoperative exercise capacity in patients undergoing thoracoscopic lobectomy for non-small cell lung cancer. Lung Cancer. 2019 Feb;128:47–52. doi: 10.1016/j.lungcan.2018.12.013. PMID: 30642452. Exclusion Code: X3.30642452
521 Hamaji M, Chen F, Matsuo Y, . Video-assisted thoracoscopic lobectomy versus stereotactic radiotherapy for stage I lung cancer. Ann Thorac Surg. 2015 Apr;99(4):1122–9. doi: 10.1016/j.athoracsur.2014.11.009. PMID: 25661580. Exclusion Code: X10.25661580
522 Hamamoto Y, Kataoka M, Yamashita M, . Lung-cancer related chest events detected by periodical follow-up CT after stereotactic body radiotherapy for stage I primary lung cancer: retrospective analysis of incidence of lung-cancer related chest events and outcomes of salvage treatment. Jpn J Radiol. 2012 Oct;30(8):671–5. doi: 10.1007/s11604-012-0107-2. PMID: 22836906. Exclusion Code: X13.22836906
523 Hamanaka R, Yokose T, Sakuma Y, . Prognostic impact of vascular invasion and standardization of its evaluation in stage I non-small cell lung cancer. Diagn Pathol. 2015 Apr 2;10:17. doi: 10.1186/s13000-015-0249-5. PMID: 25884820. Exclusion Code: X11.25884820
524 Hamatake D, Yoshida Y, Miyahara S, . Surgical outcomes of lung cancer measuring less than 1 cm in diameter. Interact Cardiovasc Thorac Surg. 2012 Nov;15(5):854–8. doi: 10.1093/icvts/ivs337. PMID: 22904166. Exclusion Code: X12.22904166
525 Han C, Schultheiss TE, Wong JYC. Estimation of radiation-induced secondary cancer risks for early-stage non-small cell lung cancer patients after stereotactic body radiation therapy. Pract Radiat Oncol. 2017 May - Jun;7(3):e185–e94. doi: 10.1016/j.prro.2016.10.009. PMID: 28089479. Exclusion Code: X16.28089479
526 Han DH, Goo JM, Chong S, . Are lung imaging reporting and data system categories clear to radiologists? A survey of the Korean Society of Thoracic Radiology members on ten difficult-to-classify scenarios. Korean J Radiol. 2017 Mar-Apr;18(2):402–7. doi: 10.3348/kjr.2017.18.2.402. PMID: 28246521. Exclusion Code: X3.28246521
527 Han KN, Kim HK, Lee HJ, . Single-port video-assisted thoracoscopic pulmonary segmentectomy: a report on 30 casesdagger. Eur J Cardiothorac Surg. 2016 Jan;49: Suppl 1:i42–7. doi: 10.1093/ejcts/ezv406. PMID: 26612717. Exclusion Code: X3.26612717
528 Han SS, Erdogan SA, Toumazis I, . Evaluating the impact of varied compliance to lung cancer screening recommendations using a microsimulation model. Cancer Causes Control. 2017 Sep;28(9):947–58. doi: 10.1007/s10552-017-0907-x. PMID: 28702814. Exclusion Code: X4.28702814
529 Han SS, ten Haaf K, Hazelton WD, . The impact of overdiagnosis on the selection of efficient lung cancer screening strategies. Int J Cancer. 2017 Jun 1;140(11):2436–43. doi: 10.1002/ijc.30602. PMID: 28073150. Exclusion Code: X4.28073150
530 Han X, Yang X, Ye X, . Computed tomography-guided percutaneous microwave ablation of patients 75 years of age and older with early-stage nonsmall cell lung cancer. Indian J Cancer. 2015 Dec;52: Suppl 2:e56–60. doi: 10.4103/0019-509x.172514. PMID: 26728675. Exclusion Code: X6.26728675
531 Hanas JS, Peyton MD, Lerner MR, . Distinguishing patients with stage I lung cancer versus control individuals using serum mass profiling. Cancer Invest. 2014 May;32(4):136–43. doi: 10.3109/07357907.2014.883528. PMID: 24579933. Exclusion Code: X7.24579933
532 Hanauer M, Perentes JY, Krueger T, . Pre-operative localization of solitary pulmonary nodules with computed tomography-guided hook wire: report of 181 patients. J Cardiothorac Surg. 2016 Jan 16;11:5. doi: 10.1186/s13019-016-0404-4. PMID: 26772183. Exclusion Code: X3.26772183
533 Hancock JG, Rosen JE, Antonicelli A, . Impact of adjuvant treatment for microscopic residual disease after non-small cell lung cancer surgery. Ann Thorac Surg. 2015 Feb;99(2):406–13. doi: 10.1016/j.athoracsur.2014.09.033. PMID: 25528723. Exclusion Code: X6.25528723
534 Hanna WC, de Valence M, Atenafu EG, . Is video-assisted lobectomy for non-small-cell lung cancer oncologically equivalent to open lobectomy? Eur J Cardiothorac Surg. 2013 Jun;43(6):1121–5. doi: 10.1093/ejcts/ezs623. PMID: 23299237. Exclusion Code: X3.23299237
535 Harder EM, Chen ZJ, Park HS, . Dose-volume predictors of esophagitis after thoracic stereotactic body radiation therapy. Am J Clin Oncol. 2017 Oct;40(5):477–82. doi: 10.1097/coc.0000000000000195. PMID: 26017483. Exclusion Code: X3.26017483
536 Harder EM, Park HS, Chen ZJ, . Pulmonary dose-volume predictors of radiation pneumonitis following stereotactic body radiation therapy. Pract Radiat Oncol. 2016 Nov - Dec;6(6):e353–e9. doi: 10.1016/j.prro.2016.01.015. PMID: 27156424. Exclusion Code: X3.27156424
537 Harders SW, Madsen HH, Hjorthaug K, . Characterization of pulmonary lesions in patients with suspected lung cancer: computed tomography versus [(1)(8)F] fluorodeoxyglucose-positron emission tomography/computed tomography. Cancer Imaging. 2012 Oct 16;12:437–46. doi: 10.1102/1470-7330.2012.0035. PMID: 23092816. Exclusion Code: X3.23092816
538 Harders SW, Madsen HH, Hjorthaug K, . Mediastinal staging in non-small-cell lung carcinoma: computed tomography versus F-18-fluorodeoxyglucose positron-emission tomography and computed tomography. Cancer Imaging. 2014 Jun 3;14:23. doi: 10.1186/1470-7330-14-23. PMID: 25608616. Exclusion Code: X3.25608616
539 Harders SW, Madsen HH, Hjorthaug K, . Limited value of (9)(9)mTc depreotide single photon emission CT compared with CT for the evaluation of pulmonary lesions. Br J Radiol. 2012 Jul;85(1015):e307–13. doi: 10.1259/bjr/10438644. PMID: 22745210. Exclusion Code: X11.22745210
540 Harkenrider MM, Bertke MH, Dunlap NE. Stereotactic body radiation therapy for unbiopsied early-stage lung cancer: a multi-institutional analysis. Am J Clin Oncol. 2014 Aug;37(4):337–42. doi: 10.1097/COC.0b013e318277d822. PMID: 23660597. Exclusion Code: X10.23660597
541 Hart K, Tofthagen C, Wang HL. Development and evaluation of a lung cancer screening decision aid. Clin J Oncol Nurs. 2016 Oct 1;20(5):557–9. doi: 10.1188/16.cjon.557-559. PMID: 27668377. Exclusion Code: X10.27668377
542 Haruki T, Miwa K, Araki K, . Distribution and prevalence of locoregional recurrence after video-assisted thoracoscopic surgery for primary lung cancer. Thorac Cardiovasc Surg. 2016 Sep;64(6):526–32. doi: 10.1055/s-0035-1550231. PMID: 26258471. Exclusion Code: X3.26258471
543 Harzheim D, Sterman D, Shah PL, . Bronchoscopic transparenchymal nodule access: feasibility and safety in an endoscopic unit. Respiration. 2016;91(4):302–6. doi: 10.1159/000445032. PMID: 27007334. Exclusion Code: X3.27007334
544 Hasan S, Colonias A, Mickus T, . Image-based management of empiric lung stereotactic body radiotherapy (SBRT) without biopsy: Predictors from a 10-year single institution experience. Thorac Cancer. 2018 Jun;9(6):699–706. doi: 10.1111/1759-7714.12635. PMID: 29697204. Exclusion Code: X13.29697204
545 Hasegawa T, Kuroda H, Sato Y, . The Utility of Indigo Carmine and Lipiodol Mixture for Preoperative Pulmonary Nodule Localization before Video-Assisted Thoracic Surgery. J Vasc Interv Radiol. 2019 Mar;30(3):446–52. doi: 10.1016/j.jvir.2018.08.024. PMID: 30819492. Exclusion Code: X11.30819492
546 Hashimoto K, Daddi N, Giuliani M, . The role of endobronchial ultrasound-guided transbronchial needle aspiration in stereotactic body radiation therapy for non-small cell lung cancer. Lung Cancer. 2018 Sep;123:1–6. doi: 10.1016/j.lungcan.2018.06.011. PMID: 30089578. Exclusion Code: X3.30089578
547 Hashimoto N, Iwano S, Kawaguchi K, . Impact of thin-section computed tomography-determined combined pulmonary fibrosis and emphysema on outcomes among patients with resected lung cancer. Ann Thorac Surg. 2016 Aug;102(2):440–7. doi: 10.1016/j.athoracsur.2016.03.014. PMID: 27157056. Exclusion Code: X11.27157056
548 Hata A, Sekine Y, Kota O, . Impact of combined pulmonary fibrosis and emphysema on surgical complications and long-term survival in patients undergoing surgery for non-small-cell lung cancer. Int J Chron Obstruct Pulmon Dis. 2016;11:1261–8. doi: 10.2147/copd.s94119. PMID: 27354784. Exclusion Code: X3.27354784
549 Hata M, Tokuuye K, Kagei K, . Hypofractionated high-dose proton beam therapy for stage I non-small-cell lung cancer: preliminary results of a phase I/II clinical study. Int J Radiat Oncol Biol Phys. 2007 Jul 1;68(3):786–93. doi: 10.1016/j.ijrobp.2006.12.063. PMID: 17379439. Exclusion Code: X6.17379439
550 Hattori A, Matsunaga T, Hayashi T, . Prognostic impact of the findings on thin-section computed tomography in patients with subcentimeter non-small cell lung cancer. J Thorac Oncol. 2017 Jun;12(6):954–62. doi: 10.1016/j.jtho.2017.02.015. PMID: 28257958. Exclusion Code: X11.28257958
551 Hattori A, Matsunaga T, Takamochi K, . Neither maximum tumor size nor solid component size is prognostic in part-solid lung cancer: impact of tumor size should be applied exclusively to solid lung cancer. Ann Thorac Surg. 2016 Aug;102(2):407–15. doi: 10.1016/j.athoracsur.2016.02.074. PMID: 27177840. Exclusion Code: X3.27177840
552 Hattori A, Matsunaga T, Takamochi K, . Oncological characteristics of radiological invasive adenocarcinoma with additional ground-glass nodules on initial thin-section computed tomography: comparison with solitary invasive adenocarcinoma. J Thorac Oncol. 2016 May;11(5):729–36. doi: 10.1016/j.jtho.2016.01.008. PMID: 26802286. Exclusion Code: X10.26802286
553 Hattori A, Matsunaga T, Takamochi K, . The oncological outcomes of segmentectomy in clinical-T1b lung adenocarcinoma with a solid-dominant appearance on thin-section computed tomography. Surg Today. 2016 Aug;46(8):914–21. doi: 10.1007/s00595-015-1256-6. PMID: 26471507. Exclusion Code: X11.26471507
554 Hattori A, Matsunaga T, Takamochi K, . Importance of ground glass opacity component in clinical stage IA radiologic invasive lung cancer. Ann Thorac Surg. 2017 Jul;104(1):313–20. doi: 10.1016/j.athoracsur.2017.01.076. PMID: 28433219. Exclusion Code: X3.28433219
555 Hattori A, Matsunaga T, Takamochi K, . Locoregional recurrence after segmentectomy for clinical-T1aN0M0 radiologically solid non-small-cell lung carcinoma. Eur J Cardiothorac Surg. 2017 Mar 1;51(3):518–25. doi: 10.1093/ejcts/ezw336. PMID: 28082475. Exclusion Code: X11.28082475
556 Hattori A, Matsunaga T, Takamochi K, . Surgical resection for clinical-Stage I radiological pure-solid lung cancer that met the current high risk criteria. Jpn J Clin Oncol. 2017 Jul 1;47(7):630–8. doi: 10.1093/jjco/hyx054. PMID: 28419333. Exclusion Code: X10.28419333
557 Hattori A, Suzuki K, Matsunaga T, . What is the appropriate operative strategy for radiologically solid tumours in subcentimetre lung cancer patients?dagger. Eur J Cardiothorac Surg. 2015 Feb;47(2):244–9. doi: 10.1093/ejcts/ezu250. PMID: 24972722. Exclusion Code: X11.24972722
558 Hattori A, Suzuki K, Takamochi K, . Is bilateral pulmonary lobectomy feasible in patients with bilateral lung cancers? Thorac Cardiovasc Surg. 2015 Oct;63(7):589–96. doi: 10.1055/s-0034-1383816. PMID: 25025891. Exclusion Code: X3.25025891
559 Hattori A, Takamochi K, Kitamura Y, . Risk factor analysis of cerebral infarction and clinicopathological characteristics of left upper pulmonary vein stump thrombus after lobectomy. Gen Thorac Cardiovasc Surg. 2019 Feb;67(2):247–53. doi: 10.1007/s11748-018-1017-8. PMID: 30251002. Exclusion Code: X3.30251002
560 Hattori A, Takamochi K, Matsunaga T, . Oncological outcomes of sublobar resection for clinical-stage IA high-risk non-small cell lung cancer patients with a radiologically solid appearance on computed tomography. Gen Thorac Cardiovasc Surg. 2016 Jan;64(1):18–24. doi: 10.1007/s11748-015-0598-8. PMID: 26486132. Exclusion Code: X11.26486132
561 Hattori K, Matsuda T, Takagi Y, . Preoperative six-minute walk distance is associated with pneumonia after lung resection. Interact Cardiovasc Thorac Surg. 2018 Feb 1;26(2):277–83. doi: 10.1093/icvts/ivx310. PMID: 29049742. Exclusion Code: X3.29049742
562 Hawkins PG, Boonstra PS, Hobson ST, . Radiation-induced lung toxicity in non-small-cell lung cancer: Understanding the interactions of clinical factors and cytokines with the dose-toxicity relationship. Radiother Oncol. 2017 Oct;125(1):66–72. doi: 10.1016/j.radonc.2017.09.005. PMID: 28947099. Exclusion Code: X3.28947099
563 Hayashi S, Tanaka H, Kajiura Y, . Stereotactic body radiotherapy for very elderly patients (age, greater than or equal to 85 years) with stage I non-small cell lung cancer. Radiat Oncol. 2014 Jun 16;9:138. doi: 10.1186/1748-717x-9-138. PMID: 24935216. Exclusion Code: X10.24935216
564 Hayes JT, David EA, Qi L, . Risk of pneumonitis after stereotactic body radiation therapy in patients with previous anatomic lung resection. Clin Lung Cancer. 2015 Sep;16(5):379–84. doi: 10.1016/j.cllc.2015.01.006. PMID: 25737143. Exclusion Code: X3.25737143
565 Hazelton WD, Goodman G, Rom WN, . Longitudinal multistage model for lung cancer incidence, mortality, and CT detected indolent and aggressive cancers. Math Biosci. 2012 Nov;240(1):20–34. doi: 10.1016/j.mbs.2012.05.008. PMID: 22705252. Exclusion Code: X7.22705252
566 Hazelton WD, Jeon J, Meza R, . Chapter 8: the FHCRC lung cancer model. Risk Anal. 2012 Jul;32: Suppl 1:S99–S116. doi: 10.1111/j.1539-6924.2011.01681.x. PMID: 22882896. Exclusion Code: X4.22882896
567 He F, Chen LM, Xiong WM, . A case-control study of the association between self-reported occupational and recreational physical activity and lung cancer. Medicine (Baltimore). 2017 Sep;96(36):e7923. doi: 10.1097/md.0000000000007923. PMID: 28885346. Exclusion Code: X3.28885346
568 Healey TT, March BT, Baird G, . Microwave ablation for lung neoplasms: a retrospective analysis of long-term results. J Vasc Interv Radiol. 2017 Feb;28(2):206–11. doi: 10.1016/j.jvir.2016.10.030. PMID: 27993505. Exclusion Code: X6.27993505
569 Heidinger BH, Anderson KR, Moriarty EM, . Size measurement and T-staging of lung adenocarcinomas manifesting as solid nodules </=30 mm on CT: radiology-pathology correlation. Acad Radiol. 2017 Jul;24(7):851–9. doi: 10.1016/j.acra.2017.01.009. PMID: 28256438. Exclusion Code: X3.28256438
570 Heidinger BH, Nemec U, Anderson KR, . “Rounding” the Size of Pulmonary Nodules: Impact of Rounding Methods on Nodule Management, as Defined by the 2017 Fleischner Society Guidelines. Acad Radiol. 2017 Nov;24(11):1422–7. doi: 10.1016/j.acra.2017.05.013. PMID: 28666724. Exclusion Code: X3.28666724
571 Heineman DJ, Ten Berge MG, Daniels JM, . Clinical staging of stage i non-small cell lung cancer in the Netherlands-need for improvement in an era with expanding nonsurgical treatment options: data from the Dutch Lung Surgery Audit. Ann Thorac Surg. 2016 Nov;102(5):1615–21. doi: 10.1016/j.athoracsur.2016.07.054. PMID: 27665481. Exclusion Code: X8.27665481
572 Hennon MW, Dexter EU, Huang M, . Does thoracoscopic surgery decrease the morbidity of combined lung and chest wall resection? Ann Thorac Surg. 2015 Jun;99(6):1929–34; discussion 34-5. doi: 10.1016/j.athoracsur.2015.02.038. PMID: 25916876. Exclusion Code: X3.25916876
573 Hennon MW, Kumar A, Devisetty H, . Minimally Invasive Approaches Do Not Compromise Outcomes for Pneumonectomy: A Comparison Using the National Cancer Database. J Thorac Oncol. 2019 Jan;14(1):107–14. doi: 10.1016/j.jtho.2018.09.024. PMID: 30292851. Exclusion Code: X3.30292851
574 Henschke CI, Boffetta P, Yankelevitz DF, . Computed tomography screening: the international early lung cancer action program experience. Thorac Surg Clin. 2015 May;25(2):129–43. doi: 10.1016/j.thorsurg.2014.12.001. PMID: 25901557. Exclusion Code: X10.25901557
575 Henschke CI, Salvatore M, Cham M, . Baseline and annual repeat rounds of screening: implications for optimal regimens of screening. Eur Radiol. 2018 Mar;28(3):1085–94. doi: 10.1007/s00330-017-5029-z. PMID: 28983713. Exclusion Code: X10.28983713
576 Herbrik M, Treffert J, Geiger B, . Diagnostic accuracy of virtual 18F-FDG PET/CT bronchoscopy for the detection of lymph node metastases in non-small cell lung cancer patients. J Nucl Med. 2011 Oct;52(10):1520–5. doi: 10.2967/jnumed.111.092593. PMID: 21908390. Exclusion Code: X3.21908390
577 Herde RF, Kokeny KE, Reddy CB, . Primary pulmonary carcinoid tumor: a long-term single institution experience. Am J Clin Oncol. 2018 Jan;41(1):24–9. doi: 10.1097/coc.0000000000000221. PMID: 26270444. Exclusion Code: X3.26270444
578 Hernandez-Arenas LA, Lin L, Yang Y, . Initial experience in uniportal subxiphoid video-assisted thoracoscopic surgery for major lung resections. Eur J Cardiothorac Surg. 2016 Dec;50(6):1060–6. doi: 10.1093/ejcts/ezw189. PMID: 27401700. Exclusion Code: X11.27401700
579 Herth FJ, Eberhardt R, Sterman D, . Bronchoscopic transparenchymal nodule access (BTPNA): first in human trial of a novel procedure for sampling solitary pulmonary nodules. Thorax. 2015 Apr;70(4):326–32. doi: 10.1136/thoraxjnl-2014-206211. PMID: 25746631. Exclusion Code: X5.25746631
580 Heuvelmans MA, Walter JE, Peters RB, . Relationship between nodule count and lung cancer probability in baseline CT lung cancer screening: The NELSON study. Lung Cancer. 2017 Nov;113:45–50. doi: 10.1016/j.lungcan.2017.08.023. PMID: 29110848. Exclusion Code: X7.29110848
581 Heuvelmans MA, Walter JE, Vliegenthart R, . Disagreement of diameter and volume measurements for pulmonary nodule size estimation in CT lung cancer screening. Thorax. 2018;73(8):779–81. doi: 10.1136/thoraxjnl-2017-210770. PMID: CN-01704274. Exclusion Code: X7.29056601
582 Heye T, Ley S, Heussel CP, . Detection and size of pulmonary lesions: how accurate is MRI? A prospective comparison of CT and MRI. Acta Radiol. 2012 Mar 1;53(2):153–60. doi: 10.1258/ar.2011.110445. PMID: 22287146. Exclusion Code: X3.22287146
583 Heye T, Sommer G, Miedinger D, . Ultrafast 3D balanced steady-state free precession MRI of the lung: assessment of anatomic details in comparison to low-dose CT. J Magn Reson Imaging. 2015 Sep;42(3):602–9. doi: 10.1002/jmri.24836. PMID: 25545835. Exclusion Code: X11.25545835
584 Higgins KA, O’Connell K, Liu Y, . National Cancer Database analysis of proton versus photon radiation therapy in non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2017 Jan 1;97(1):128–37. doi: 10.1016/j.ijrobp.2016.10.001. PMID: 27979443. Exclusion Code: X6.27979443
585 Higuchi M, Yaginuma H, Yonechi A, . Long-term outcomes after video-assisted thoracic surgery (VATS) lobectomy versus lobectomy via open thoracotomy for clinical stage IA non-small cell lung cancer. J Cardiothorac Surg. 2014 May 17;9:88. doi: 10.1186/1749-8090-9-88. PMID: 24886655. Exclusion Code: X11.24886655
586 Hino H, Karasaki T, Yoshida Y, . Risk factors for postoperative complications and long-term survival in lung cancer patients older than 80 years. Eur J Cardiothorac Surg. 2018 May 1;53(5):980–6. doi: 10.1093/ejcts/ezx437. PMID: 29272371. Exclusion Code: X3.29272371
587 Hino H, Murakawa T, Ichinose J, . Results of lung cancer surgery for octogenarians. Ann Thorac Cardiovasc Surg. 2015;21(3):209–16. doi: 10.5761/atcs.oa.14-00160. PMID: 25740447. Exclusion Code: X11.25740447
588 Hirai K, Takeuchi S, Usuda J. Single-incision thoracoscopic surgery and conventional video-assisted thoracoscopic surgery: a retrospective comparative study of perioperative clinical outcomesdagger. Eur J Cardiothorac Surg. 2016 Jan;49: Suppl 1:i37–41. doi: 10.1093/ejcts/ezv320. PMID: 26417062. Exclusion Code: X11.26417062
589 Hiraishi Y, Izumo T, Sasada S, . Factors affecting bacterial culture positivity in specimens from bronchoscopy in patients with suspected lung cancer. Respir Investig. 2018 Nov;56(6):457–63. doi: 10.1016/j.resinv.2018.07.006. PMID: 30392535. Exclusion Code: X3.30392535
590 Hishida T, Miyaoka E, Yokoi K, . Lobe-specific nodal dissection for clinical stage I and II NSCLC: Japanese multi-institutional retrospective study using a propensity score analysis. J Thorac Oncol. 2016 Sep;11(9):1529–37. doi: 10.1016/j.jtho.2016.05.014. PMID: 27249959. Exclusion Code: X3.27249959
591 Hjorthaug K, Hojbjerg JA, Knap MM, . Accuracy of 18F-FDG PET-CT in triaging lung cancer patients with suspected brain metastases for MRI. Nucl Med Commun. 2015 Nov;36(11):1084–90. doi: 10.1097/mnm.0000000000000371. PMID: 26302460. Exclusion Code: X3.26302460
592 Hofman MS, Smeeton NC, Rankin SC, . Observer variation in FDG PET-CT for staging of non-small-cell lung carcinoma. Eur J Nucl Med Mol Imaging. 2009 Feb;36(2):194–9. doi: 10.1007/s00259-008-0946-3. PMID: 18828012. Exclusion Code: X3.18828012
593 Hoggart C, Brennan P, Tjonneland A, . A risk model for lung cancer incidence. Cancer Prev Res (Phila). 2012 Jun;5(6):834–46. doi: 10.1158/1940-6207.capr-11-0237. PMID: 22496387. Exclusion Code: X7.22496387
594 Holbek BL, Hansen HJ, Kehlet H, . Thoracoscopic pulmonary wedge resection without post-operative chest drain: an observational study. Gen Thorac Cardiovasc Surg. 2016 Oct;64(10):612–7. doi: 10.1007/s11748-016-0692-6. PMID: 27510705. Exclusion Code: X11.27510705
595 Honda T, Kondo T, Murakami S, . Radiographic and pathological analysis of small lung adenocarcinoma using the new IASLC classification. Clin Radiol. 2013 Jan;68(1):e21–6. doi: 10.1016/j.crad.2012.09.002. PMID: 23146553. Exclusion Code: X3.23146553
596 Hong S, Park EC, Kim TH, . Effect of pre existing respiratory conditions on survival of lung cancer patients: A nationwide population-based cohort study. Asia Pac J Clin Oncol. 2018 Apr;14(2):e71–e80. doi: 10.1111/ajco.12697. PMID: 28762660. Exclusion Code: X3.28762660
597 Hong TH, Cho JH, Shin S, . Extended sleeve lobectomy for centrally located non-small-cell lung cancer: a 20-year single-centre experience. Eur J Cardiothorac Surg. 2018 Jul 1;54(1):142–8. doi: 10.1093/ejcts/ezy011. PMID: 29408983. Exclusion Code: X3.29408983
598 Hoppe BS, Huh S, Flampouri S, . Double-scattered proton-based stereotactic body radiotherapy for stage I lung cancer: a dosimetric comparison with photon-based stereotactic body radiotherapy. Radiother Oncol. 2010 Dec;97(3):425–30. doi: 10.1016/j.radonc.2010.09.006. PMID: 20934768. Exclusion Code: X8.20934768
599 Hoppe BS, Laser B, Kowalski AV, . Acute skin toxicity following stereotactic body radiation therapy for stage I non-small-cell lung cancer: who’s at risk? Int J Radiat Oncol Biol Phys. 2008 Dec 1;72(5):1283–6. doi: 10.1016/j.ijrobp.2008.08.036. PMID: 19028267. Exclusion Code: X11.19028267
600 Horeweg N, van der Aalst CM, Thunnissen E, . Characteristics of lung cancers detected by computer tomography screening in the randomized NELSON trial. Am J Respir Crit Care Med. 2013 Apr 15;187(8):848–54. doi: 10.1164/rccm.201209-1651OC. PMID: 23348977. Exclusion Code: X7.23348977
601 Horeweg N, van Rosmalen J, Heuvelmans MA, . Lung cancer probability in patients with CT-detected pulmonary nodules: a prespecified analysis of data from the NELSON trial of low-dose CT screening. Lancet Oncol. 2014 Nov;15(12):1332–41. doi: 10.1016/s1470-2045(14)70389-4. PMID: 25282285. Exclusion Code: X7.25282285
602 Horne ZD, Clump DA, Vargo JA, . Pretreatment SUVmax predicts progression-free survival in early-stage non-small cell lung cancer treated with stereotactic body radiation therapy. Radiat Oncol. 2014 Jan 30;9:41. doi: 10.1186/1748-717x-9-41. PMID: 24479954. Exclusion Code: X10.24479954
603 Horne ZD, Richman AH, Dohopolski MJ, . Stereotactic body radiation therapy for isolated hilar and mediastinal non-small cell lung cancers. Lung Cancer. 2018 Jan;115:1–4. doi: 10.1016/j.lungcan.2017.10.014. PMID: 29290248. Exclusion Code: X3.29290248
604 Horner-Rieber J, Bernhardt D, Dern J, . Histology of non-small cell lung cancer predicts the response to stereotactic body radiotherapy. Radiother Oncol. 2017 Nov;125(2):317–24. doi: 10.1016/j.radonc.2017.08.029. PMID: 28919006. Exclusion Code: X13.28919006
605 Hosny A, Parmar C, Coroller TP, . Deep learning for lung cancer prognostication: A retrospective multi-cohort radiomics study. PLoS Med. 2018 Nov;15(11):e1002711. doi: 10.1371/journal.pmed.1002711. PMID: 30500819. Exclusion Code: X3.30500819
606 Hostetter JM, Morrison JJ, Morris M, . Personalizing lung cancer risk prediction and imaging follow-up recommendations using the National Lung Screening Trial dataset. J Am Med Inform Assoc. 2017 Nov 1;24(6):1046–51. doi: 10.1093/jamia/ocx012. PMID: 28340104. Exclusion Code: X8.28340104
607 Hou S, Lin X, Wang S, . Combination of positron emission tomography/computed tomography and chest thin-layer high-resolution computed tomography for evaluation of pulmonary nodules: Correlation with imaging features, maximum standardized uptake value, and pathology. Medicine (Baltimore). 2018 Aug;97(31):e11640. doi: 10.1097/md.0000000000011640. PMID: 30075545. Exclusion Code: X3.30075545
608 Hou YL, Chen H, Ge MJ, . Quantification of serum HBXAP DNA in lung cancer patients by quantitative fluorescent polymerase chain reaction. Mol Biol Rep. 2013 Jun;40(6):4091–6. doi: 10.1007/s11033-013-2488-4. PMID: 23456648. Exclusion Code: X3.23456648
609 Howard DH, Richards TB, Bach PB, . Comorbidities, smoking status, and life expectancy among individuals eligible for lung cancer screening. Cancer. 2015 Dec 15;121(24):4341–7. doi: 10.1002/cncr.29677. PMID: 26372542. Exclusion Code: X5.26372542
610 Hoyer M, Roed H, Hansen AT, . Prospective study on stereotactic radiotherapy of limited-stage non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2006;44(4):S128–35. doi: 10.1016/j.ijrobp.2006.01.012. Exclusion Code: X11.
611 Hoyer N, Wille MMW, Thomsen LH, . Interstitial lung abnormalities are associated with increased mortality in smokers. Respir Med. 2018 Mar;136:77–82. doi: 10.1016/j.rmed.2018.02.001. PMID: 29501250. Exclusion Code: X7.29501250
612 Hrbacek J, Lang S, Graydon SN, . Dosimetric comparison of flattened and unflattened beams for stereotactic ablative radiotherapy of stage I non-small cell lung cancer. Med Phys. 2014 Mar;41(3):031709. doi: 10.1118/1.4866231. PMID: 24593713. Exclusion Code: X8.24593713
613 Hristov B, Eguchi T, Bains S, . Minimally Invasive Lobectomy Is Associated With Lower Noncancer-specific Mortality in Elderly Patients: A Propensity Score Matched Competing Risks Analysis. Ann Surg. 2018 Apr 18doi: 10.1097/sla.0000000000002772. PMID: 29672399. Exclusion Code: X3.29672399
614 Hristova R, Pompili C, Begum S, . An aggregate score to predict the risk of large pleural effusion after pulmonary lobectomy. Eur J Cardiothorac Surg. 2015 Jul;48(1):72–6. doi: 10.1093/ejcts/ezu413. PMID: 25352659. Exclusion Code: X4.25352659
615 Hsieh TC, Huang WW, Lai CL, . Diagnostic value of tumor markers in lung adenocarcinoma-associated cytologically negative pleural effusions. Cancer Cytopathol. 2013 Sep;121(9):483–8. doi: 10.1002/cncy.21283. PMID: 23408492. Exclusion Code: X3.23408492
616 Hsu HH, Ko KH, Chou YC, . SUVmax and tumor size predict surgical outcome of synchronous multiple primary lung cancers. Medicine (Baltimore). 2016 Feb;95(6):e2351. doi: 10.1097/md.0000000000002351. PMID: 26871768. Exclusion Code: X11.26871768
617 Hsu HH, Shen CH, Tsai WC, . Localization of nonpalpable pulmonary nodules using CT-guided needle puncture. World J Surg Oncol. 2015 Aug 15;13:248. doi: 10.1186/s12957-015-0664-9. PMID: 26271476. Exclusion Code: X11.26271476
618 Hsu LS, Chen CW, Chang CH, . Influences of cardiac motion on computed tomography-guided biopsy of lung nodules located near the heart. Medicine (Baltimore). 2017 Nov;96(46):e8558. doi: 10.1097/md.0000000000008558. PMID: 29145264. Exclusion Code: X3.29145264
619 Hsu PK, Lin WC, Chang YC, . Multiinstitutional analysis of single-port video-assisted thoracoscopic anatomical resection for primary lung cancer. Ann Thorac Surg. 2015 May;99(5):1739–44. doi: 10.1016/j.athoracsur.2015.01.041. PMID: 25827674. Exclusion Code: X11.25827674
620 Hu Z, Whitney D, Anderson JR, . Analytical performance of a bronchial genomic classifier. BMC Cancer. 2016 Feb 26;16:161. doi: 10.1186/s12885-016-2153-0. PMID: 26920854. Exclusion Code: X3.26920854
621 Huang BT, Lin Z, Lin PX, . Monitor unit optimization in stereotactic body radiotherapy for small peripheral non-small cell lung cancer patients. Sci Rep. 2015 Dec 18;5:18453. doi: 10.1038/srep18453. PMID: 26679747. Exclusion Code: X8.26679747
622 Huang BT, Lu JY, Lin PX, . Radiobiological modeling analysis of the optimal fraction scheme in patients with peripheral non-small cell lung cancer undergoing stereotactic body radiotherapy. Sci Rep. 2015 Dec 11;5:18010. doi: 10.1038/srep18010. PMID: 26657569. Exclusion Code: X3.26657569
623 Huang BY, Zhou JJ, Yu ZQ, . Long-term observation of CT-guided radiofrequency ablation of lung neoplasm in 476 consecutive patients by a thoracic surgical service: a single-institutional experience. Acad Radiol. 2017 Dec;24(12):1517–25. doi: 10.1016/j.acra.2017.06.018. PMID: 28888381. Exclusion Code: X6.28888381
624 Huang K, Senthi S, Palma DA, . High-risk CT features for detection of local recurrence after stereotactic ablative radiotherapy for lung cancer. Radiother Oncol. 2013 Oct;109(1):51–7. doi: 10.1016/j.radonc.2013.06.047. PMID: 23953413. Exclusion Code: X8.23953413
625 Huang L, Wang L, Zhu W, . Area--a consistent method to evaluate pulmonary tumor size on multidetector CT imaging: an intraobserver and interobserver agreement study. Clin Imaging. 2013 Nov-Dec;37(6):1006–10. doi: 10.1016/j.clinimag.2013.06.011. PMID: 23993800. Exclusion Code: X3.23993800
626 Huang P, Park S, Yan R, . Added value of computer-aided CT image features for early lung cancer diagnosis with small pulmonary nodules: a matched case-control study. Radiology. 2018 Jan;286(1):286–95. doi: 10.1148/radiol.2017162725. PMID: 28872442. Exclusion Code: X10.28872442
627 Huang TW, Lin KH, Huang HK, . The role of the ground-glass opacity ratio in resected lung adenocarcinoma. Eur J Cardiothorac Surg. 2018 Aug 1;54(2):229–34. doi: 10.1093/ejcts/ezy040. PMID: 29471517. Exclusion Code: X3.29471517
628 Huang Y, Hu Q, Deng Z, . MicroRNAs in body fluids as biomarkers for non-small cell lung cancer: a systematic review. Technol Cancer Res Treat. 2014 Jun;13(3):277–87. doi: 10.7785/tcrt.2012.500377. PMID: 24066954. Exclusion Code: X5.24066954
629 Huang Y, Zhao Z, Wang T, . A Comparison between Prethoracoscopy Localization of Small Pulmonary Nodules by Means of Medical Adhesive versus Hookwire. J Vasc Interv Radiol. 2018 Nov;29(11):1547–52. doi: 10.1016/j.jvir.2018.05.013. PMID: 30293726. Exclusion Code: X3.30293726
630 Huang YS, Chen JL, Hsu FM, . Response assessment of stereotactic body radiation therapy using dynamic contrast-enhanced integrated MR-PET in non-small cell lung cancer patients. J Magn Reson Imaging. 2018 Jan;47(1):191–9. doi: 10.1002/jmri.25758. PMID: 28480541. Exclusion Code: X8.28480541
631 Hubers AJ, van der Drift MA, Prinsen CF, . Methylation analysis in spontaneous sputum for lung cancer diagnosis. Lung Cancer. 2014 May;84(2):127–33. doi: 10.1016/j.lungcan.2014.01.019. PMID: 24598366. Exclusion Code: X3.24598366
632 Huellner MW, de Galiza Barbosa F, Husmann L, . TNM staging of non-small cell lung cancer: comparison of PET/MR and PET/CT. J Nucl Med. 2016 Jan;57(1):21–6. doi: 10.2967/jnumed.115.162040. PMID: 26471696. Exclusion Code: X3.26471696
633 Hueto Perez De Heredia J, Cebollero Rivas P, Cascante Rodrigo JA, . Evaluation of the use of a rapid diagnostic consultation of lung cancer. Delay time of diagnosis and therapy. Arch Bronconeumol. 2012 Aug;48(8):267–73. doi: 10.1016/j.arbres.2012.03.009. PMID: 22575811. Exclusion Code: X3.22575811
634 Hulbert A, Hooker CM, Keruly JC, . Prospective CT screening for lung cancer in a high-risk population: HIV-positive smokers. J Thorac Oncol. 2014 Jun;9(6):752–9. doi: 10.1097/jto.0000000000000161. PMID: 24828660. Exclusion Code: X7.24828660
635 Hulbert A, Jusue-Torres I, Stark A, . Early detection of lung cancer using DNA promoter hypermethylation in plasma and sputum. Clin Cancer Res. 2017 Apr 15;23(8):1998–2005. doi: 10.1158/1078-0432.ccr-16-1371. PMID: 27729459. Exclusion Code: X7.27729459
636 Hung JJ, Jeng WJ, Hsu WH, . Predictors of death, local recurrence, and distant metastasis in completely resected pathological stage-I non-small-cell lung cancer. J Thorac Oncol. 2012 Jul;7(7):1115–23. doi: 10.1097/JTO.0b013e31824cbad8. PMID: 22592210. Exclusion Code: X10.22592210
637 Hung JJ, Jeng WJ, Hsu WH, . Time trends of overall survival and survival after recurrence in completely resected stage I non-small cell lung cancer. J Thorac Oncol. 2012 Feb;7(2):397–405. doi: 10.1097/JTO.0b013e31823b564a. PMID: 22173701. Exclusion Code: X14.22173701
638 Hung MH, Cheng YJ, Chan KC, . Nonintubated uniportal thoracoscopic surgery for peripheral lung nodules. Ann Thorac Surg. 2014 Dec;98(6):1998–2003. doi: 10.1016/j.athoracsur.2014.07.036. PMID: 25443006. Exclusion Code: X3.25443006
639 Hung MS, Chen IC, Lee CP, . Incidence and risk factors of depression after diagnosis of lung cancer: A nationwide population-based study. Medicine (Baltimore). 2017 May;96(19):e6864. doi: 10.1097/md.0000000000006864. PMID: 28489782. Exclusion Code: X8.28489782
640 Hung SK, Chen YC, Chiou WY, . Irradiation enhanced risks of hospitalised pneumonopathy in lung cancer patients: a population-based surgical cohort study. BMJ Open. 2017 Sep 27;7(9):e015022. doi: 10.1136/bmjopen-2016-015022. PMID: 28963281. Exclusion Code: X3.28963281
641 Hung SK, Lee MS, Chiou WY, . High incidence of ischemic stroke occurrence in irradiated lung cancer patients: a population-based surgical cohort study. PLoS One. 2014;9(4):e94377. doi: 10.1371/journal.pone.0094377. PMID: 24709837. Exclusion Code: X3.24709837
642 Huo J, Hong YR, Bian J, . Low rates of patient-reported physician-patient discussion about lung cancer screening among current smokers: data from Health Information National Trends Survey. Cancer Epidemiol Biomarkers Prev. 2019 May;28(5):963–73. doi: 10.1158/1055-9965.EPI-18-0629. PMID: 31023697. Exclusion Code: X8.31023697
643 Huo J, Xu Y, Sheu T, . Complication rates and downstream medical costs associated with invasive diagnostic procedures for lung abnormalities in the community setting. JAMA Intern Med. 2019 Jan 14doi: 10.1001/jamainternmed.2018.6277. PMID: 30640382. Exclusion Code: X3.30640382
644 Hwang EJ, Kim H, Park CM, . Cone beam computed tomography virtual navigation-guided transthoracic biopsy of small (</= 1 cm) pulmonary nodules: impact of nodule visibility during real-time fluoroscopy. Br J Radiol. 2018 Jul;91(1087):20170805. doi: 10.1259/bjr.20170805. PMID: 29595322. Exclusion Code: X3.29595322
645 Hwang EJ, Park CM, Ryu Y, . Pulmonary adenocarcinomas appearing as part-solid ground-glass nodules: is measuring solid component size a better prognostic indicator? Eur Radiol. 2015 Feb;25(2):558–67. doi: 10.1007/s00330-014-3441-1. PMID: 25274618. Exclusion Code: X8.25274618
646 Hwang J, Chung MJ, Bae Y, . Computer-aided detection of lung nodules: influence of the image reconstruction kernel for computer-aided detection performance. J Comput Assist Tomogr. 2010 Jan;34(1):31–4. doi: 10.1097/RCT.0b013e3181b5c630. PMID: 20118719. Exclusion Code: X5.20118719
647 Hwang Y, Kang CH, Kim HS, . Comparison of thoracoscopic segmentectomy and thoracoscopic lobectomy on the patients with non-small cell lung cancer: a propensity score matching study. Eur J Cardiothorac Surg. 2015 Aug;48(2):273–8. doi: 10.1093/ejcts/ezu422. PMID: 25406426. Exclusion Code: X11.25406426
648 Hyun K, Park IK, Song JW, . Electromagnetic navigation bronchoscopic dye marking for localization of small subsolid nodules: Retrospective observational study. Medicine (Baltimore). 2019 Mar;98(11):e14831. doi: 10.1097/md.0000000000014831. PMID: 30882669. Exclusion Code: X3.30882669
649 Hyun SH, Choi JY, Kim K, . Volume-based parameters of (18)F-fluorodeoxyglucose positron emission tomography/computed tomography improve outcome prediction in early-stage non-small cell lung cancer after surgical resection. Ann Surg. 2013 Feb;257(2):364–70. doi: 10.1097/SLA.0b013e318262a6ec. PMID: 22968069. Exclusion Code: X3.22968069
650 Icard P, Heyndrickx M, Guetti L, . Morbidity, mortality and survival after 110 consecutive bilobectomies over 12 years. Interact Cardiovasc Thorac Surg. 2013 Feb;16(2):179–85. doi: 10.1093/icvts/ivs419. PMID: 23117235. Exclusion Code: X3.23117235
651 Ichiki Y, Nagashima A, Chikaishi Y, . Pneumonectomy for non-small cell lung cancer. Surg Today. 2012 Sep;42(9):830–4. doi: 10.1007/s00595-012-0174-0. PMID: 22484985. Exclusion Code: X3.22484985
652 Ichinose J, Kohno T, Fujimori S, . Invasiveness and malignant potential of pulmonary lesions presenting as pure ground-glass opacities. Ann Thorac Cardiovasc Surg. 2014;20(5):347–52. PMID: 24088912. Exclusion Code: X3.24088912
653 Iguchi T, Hiraki T, Gobara H, . Percutaneous radiofrequency ablation of lung cancer presenting as ground-glass opacity. Cardiovasc Intervent Radiol. 2015 Apr;38(2):409–15. doi: 10.1007/s00270-014-0926-x. PMID: 24938905. Exclusion Code: X6.24938905
654 Iguchi T, Hiraki T, Ishii H, . Transosseous route for CT fluoroscopy-guided radiofrequency ablation of lung tumors. J Vasc Interv Radiol. 2015 Nov;26(11):1694–8. doi: 10.1016/j.jvir.2015.08.012. PMID: 26432461. Exclusion Code: X6.26432461
655 Ihara H, Gobara H, Hiraki T, . Radiofrequency ablation of lung tumors using a multitined expandable electrode: impact of the electrode array diameter on local tumor progression. J Vasc Interv Radiol. 2016 Jan;27(1):87–95. doi: 10.1016/j.jvir.2015.07.025. PMID: 26321016. Exclusion Code: X3.26321016
656 Iizuka Y, Matsuo Y, Umeoka S, . Prediction of clinical outcome after stereotactic body radiotherapy for non-small cell lung cancer using diffusion-weighted MRI and (18)F-FDG PET. Eur J Radiol. 2014 Nov;83(11):2087–92. doi: 10.1016/j.ejrad.2014.07.018. PMID: 25174774. Exclusion Code: X12.25174774
657 Imai K, Minamiya Y, Saito H, . Accuracy of helical computed tomography for the identification of lymph node metastasis in resectable non-small cell lung cancer. Surg Today. 2008;38(12):1083–90. doi: 10.1007/s00595-008-3801-z. PMID: 19039633. Exclusion Code: X3.19039633
658 Infante M, Sestini S, Galeone C, . Lung cancer screening with low-dose spiral computed tomography: evidence from a pooled analysis of two Italian randomized trials. Eur J Cancer Prev. 2017 Jul;26(4):324–9. doi: 10.1097/cej.0000000000000264. PMID: 27222939. Exclusion Code: X10.27222939
659 Inoue M, Okumura M, Sawabata N, . Clinicopathological characteristics and surgical results of lung cancer patients aged up to 50 years: the Japanese Lung Cancer Registry Study 2004. Lung Cancer. 2014 Feb;83(2):246–51. doi: 10.1016/j.lungcan.2013.11.007. PMID: 24296124. Exclusion Code: X3.24296124
660 Inoue T, Shiomi H, Oh RJ. Stereotactic body radiotherapy for Stage I lung cancer with chronic obstructive pulmonary disease: special reference to survival and radiation-induced pneumonitis. J Radiat Res. 2015 Jul;56(4):727–34. doi: 10.1093/jrr/rrv019. PMID: 25887042. Exclusion Code: X10.25887042
661 Iqbal SI, Molgaard C, Williamson C, . Purposeful creation of a pneumothorax and chest tube placement to facilitate CT-guided coil localization of lung nodules before video-assisted thoracoscopic surgical wedge resection. J Vasc Interv Radiol. 2014 Jul;25(7):1133–8. doi: 10.1016/j.jvir.2014.03.010. PMID: 24788210. Exclusion Code: X3.24788210
662 Irie M, Nakanishi R, Yasuda M, . Risk factors for short-term outcomes after thoracoscopic lobectomy for lung cancer. Eur Respir J. 2016 Aug;48(2):495–503. doi: 10.1183/13993003.01939-2015. PMID: 27174883. Exclusion Code: X11.27174883
663 Isaka M, Kojima H, Takahashi S, . Risk factors for local recurrence after lobectomy and lymph node dissection in patients with non-small cell lung cancer: Implications for adjuvant therapy. Lung Cancer. 2018 Jan;115:28–33. doi: 10.1016/j.lungcan.2017.11.014. PMID: 29290258. Exclusion Code: X3.29290258
664 Isaka T, Takahashi K, Maehara T, . Intraoperative core needle biopsy under complete video-assisted thoracic surgery for indeterminate tumor of lung. Surg Endosc. 2015 Dec;29(12):3579–87. doi: 10.1007/s00464-015-4112-2. PMID: 25740637. Exclusion Code: X3.25740637
665 Ishida M, Shimazaki T, Suzuki M, . Case series of lung abscesses following flexible bronchoscopy. Respir Investig. 2015 May;53(3):129–32. doi: 10.1016/j.resinv.2015.01.004. PMID: 25951100. Exclusion Code: X3.25951100
666 Ishijima M, Nakayama H, Itonaga T, . Patients with severe emphysema have a low risk of radiation pneumonitis following stereotactic body radiotherapy. Br J Radiol. 2015 Feb;88(1046):20140596. doi: 10.1259/bjr.20140596. PMID: 25490255. Exclusion Code: X10.25490255
667 Ishikawa Y, Nakayama H, Ito H, . Surgical treatment for synchronous primary lung adenocarcinomas. Ann Thorac Surg. 2014 Dec;98(6):1983–8. doi: 10.1016/j.athoracsur.2014.07.006. PMID: 25443005. Exclusion Code: X11.25443005
668 Iskender I, Kadioglu SZ, Cosgun T, . False-positivity of mediastinal lymph nodes has negative effect on survival in potentially resectable non-small cell lung cancer. Eur J Cardiothorac Surg. 2012 Apr;41(4):874–9. doi: 10.1093/ejcts/ezr054. PMID: 22423060. Exclusion Code: X11.22423060
669 Iskender I, Kadioglu SZ, Kosar A, . Is there any maximum standardized uptake value variation among positron emission tomography scanners for mediastinal staging in non-small cell lung cancer? Interact Cardiovasc Thorac Surg. 2011 Jun;12(6):965–9. doi: 10.1510/icvts.2010.258103. PMID: 21441257. Exclusion Code: X3.21441257
670 Iskender I, Kapicibasi HO, Kadioglu SZ, . Comparison of integrated positron emission tomography/computed tomography and mediastinoscopy in mediastinal staging of non-small cell lung cancer: analysis of 212 patients. Acta Chir Belg. 2012 May-Jun;112(3):219–25. PMID: 22808763. Exclusion Code: X3.22808763
671 Ito H, Nakayama H, Murakami S, . Does the histologic predominance of pathological stage IA lung adenocarcinoma influence the extent of resection? Gen Thorac Cardiovasc Surg. 2017 Sep;65(9):512–8. doi: 10.1007/s11748-017-0790-0. PMID: 28593420. Exclusion Code: X10.28593420
672 Ito H, Nakayama H, Yamada K, . Outcomes of lobectomy in ‘active’ octogenarians with clinical stage I non-small-cell lung cancer. Ann Thorac Cardiovasc Surg. 2015;21(1):24–30. doi: 10.5761/atcs.oa.13-00353. PMID: 24747546. Exclusion Code: X11.24747546
673 Ito H, Nakayama H, Yokose T, . Prophylaxis for acute exacerbation of interstitial pneumonia after lung resection. Asian Cardiovasc Thorac Ann. 2014 Oct;22(8):948–54. doi: 10.1177/0218492314526187. PMID: 24585320. Exclusion Code: X3.24585320
674 Ito M, Miyata Y, Kushitani K, . Prediction for prognosis of resected pT1a-1bN0M0 adenocarcinoma based on tumor size and histological status: relationship of TNM and IASLC/ATS/ERS classifications. Lung Cancer. 2014 Aug;85(2):270–5. doi: 10.1016/j.lungcan.2014.05.014. PMID: 24976332. Exclusion Code: X3.24976332
675 Ito R, Iwano S, Shimamoto H, . A comparative analysis of dual-phase dual-energy CT and FDG-PET/CT for the prediction of histopathological invasiveness of non-small cell lung cancer. Eur J Radiol. 2017 Oct;95:186–91. doi: 10.1016/j.ejrad.2017.08.010. PMID: 28987666. Exclusion Code: X8.28987666
676 Iwano S, Ito S, Tsuchiya K, . What causes false-negative PET findings for solid-type lung cancer? Lung Cancer. 2013 Feb;79(2):132–6. doi: 10.1016/j.lungcan.2012.10.018. PMID: 23177277. Exclusion Code: X3.23177277
677 Iwano S, Kitano M, Matsuo K, . Pulmonary lobar volumetry using novel volumetric computer-aided diagnosis and computed tomography. Interact Cardiovasc Thorac Surg. 2013 Jul;17(1):59–65. doi: 10.1093/icvts/ivt122. PMID: 23526418. Exclusion Code: X3.23526418
678 Iwata H, Shirahashi K, Mizuno Y, . Feasibility of segmental resection in non-small-cell lung cancer with ground-glass opacity. Eur J Cardiothorac Surg. 2014 Sep;46(3):375–9; discussion 9. doi: 10.1093/ejcts/ezu021. PMID: 24562008. Exclusion Code: X3.24562008
679 Iwata H, Shirahashi K, Yamamoto H, . Propensity score-matching analysis of hybrid video-assisted thoracoscopic surgery and thoracoscopic lobectomy for clinical stage I lung cancerdagger. Eur J Cardiothorac Surg. 2016 Apr;49(4):1063–7. doi: 10.1093/ejcts/ezv296. PMID: 26324682. Exclusion Code: X11.26324682
680 Iyen-Omofoman B, Tata LJ, Baldwin DR, . Using socio-demographic and early clinical features in general practice to identify people with lung cancer earlier. Thorax. 2013 May;68(5):451–9. doi: 10.1136/thoraxjnl-2012-202348. PMID: 23321602. Exclusion Code: X3.23321602
681 Izar B, Zhou H, Heist RS, . The prognostic impact of KRAS, its codon and amino acid specific mutations, on survival in resected stage I lung adenocarcinoma. J Thorac Oncol. 2014 Sep;9(9):1363–9. doi: 10.1097/jto.0000000000000266. PMID: 25122432. Exclusion Code: X11.25122432
682 Izumo T, Sasada S, Chavez C, . Radial endobronchial ultrasound images for ground-glass opacity pulmonary lesions. Eur Respir J. 2015 Jun;45(6):1661–8. doi: 10.1183/09031936.00167914. PMID: 25573408. Exclusion Code: X3.25573408
683 Jacobs CD, Jafari ME. Early results of lung cancer screening and radiation dose assessment by low-dose CT at a community hospital. Clin Lung Cancer. 2017 Sep;18(5):e327–e31. doi: 10.1016/j.cllc.2017.01.011. PMID: 28237242. Exclusion Code: X11.28237242
684 Jacomelli M, Demarzo SE, Cardoso PF, . Radial-probe EBUS for the diagnosis of peripheral pulmonary lesions. J Bras Pneumol. 2016 Jul-Aug;42(4):248–53. doi: 10.1590/s1806-37562015000000079. PMID: 27832231. Exclusion Code: X3.27832231
685 Jaconi M, Pagni F, Vacirca F, . C-arm cone-beam CT-guided transthoracic lung core needle biopsy as a standard diagnostic tool: an observational study. Medicine (Baltimore). 2015 Mar;94(12):e698. doi: 10.1097/md.0000000000000698. PMID: 25816042. Exclusion Code: X3.25816042
686 Jain S, Poon I, Soliman H, . Lung stereotactic body radiation therapy (SBRT) delivered over 4 or 11 days: a comparison of acute toxicity and quality of life. Radiother Oncol. 2013;108(2):320–5. doi: 10.1016/j.radonc.2013.06.045. PMID: CN-00913978. Exclusion Code: X3.23993401
687 Jairam PM, de Jong PA, Mali WP, . Impact of cardiovascular calcifications on the detrimental effect of continued smoking on cardiovascular risk in male lung cancer screening participants. PLoS One. 2013;8(6):e66484. doi: 10.1371/journal.pone.0066484. PMID: 23840486. Exclusion Code: X8.23840486
688 Janet-Vendroux A, Loi M, Bobbio A, . Which is the role of pneumonectomy in the era of parenchymal-sparing procedures? Early/long-term survival and functional results of a single-center experience. Lung. 2015 Dec;193(6):965–73. doi: 10.1007/s00408-015-9810-y. PMID: 26411589. Exclusion Code: X3.26411589
689 Jang BS, Kim HJ, Kim BH, . Clinical outcomes of stereotactic ablative radiotherapy in patients with pulmonary metastasis. Jpn J Clin Oncol. 2017 Jan;47(1):61–6. doi: 10.1093/jjco/hyw147. PMID: 28122893. Exclusion Code: X3.28122893
690 Jang H, Kim S, Wu D. Bayesian lead time estimation for the Johns Hopkins Lung Project data. J Epidemiol Glob Health. 2013 Sep;3(3):157–63. doi: 10.1016/j.jegh.2013.05.001. PMID: 23932058. Exclusion Code: X4.23932058
691 Jansen RJ, Alexander BH, Hayes RB, . A mathematical model of case-ascertainment bias: Applied to case-control studies nested within a randomized screening trial. PLoS One. 2018;13(3):e0194608. doi: 10.1371/journal.pone.0194608. PMID: 29554151. Exclusion Code: X7.29554151
692 Janssen S, Kaesmann L, Rudat V, . Stereotactic body radiotherapy (SBRT) with lower doses for selected patients with stage I non-small-cell lung cancer (NSCLC). Lung. 2016 Apr;194(2):291–4. doi: 10.1007/s00408-016-9849-4. PMID: 26842723. Exclusion Code: X10.26842723
693 Jawitz OK, Wang Z, Boffa DJ, . The differential impact of preoperative comorbidity on perioperative outcomes following thoracoscopic and open lobectomies. Eur J Cardiothorac Surg. 2017 Jan;51(1):169–74. doi: 10.1093/ejcts/ezw239. PMID: 27458143. Exclusion Code: X3.27458143
694 Jean RA, DeLuzio MR, Kraev AI, . Analyzing risk factors for morbidity and mortality after lung resection for lung cancer using the NSQIP Database. J Am Coll Surg. 2016 Jun;222(6):992–1000.e1. doi: 10.1016/j.jamcollsurg.2016.02.020. PMID: 27118714. Exclusion Code: X3.27118714
695 Jenkins N, Irusen EM, Koegelenberg CF. Pulmonary scar carcinoma in South Africa. S Afr Med J. 2017 Mar 29;107(4):320–2. doi: 10.7196/SAMJ.2017.v107i4.12158. PMID: 28395683. Exclusion Code: X3.28395683
696 Jensen GL, Tang C, Hess KR, . Patterns of metastatic progression after definitive radiation therapy for early-stage and locally advanced non-small cell lung cancer. Clin Exp Metastasis. 2017 Jun;34(5):315–22. doi: 10.1007/s10585-017-9850-1. PMID: 28744603. Exclusion Code: X3.28744603
697 Jensen KW, Hsia DW, Seijo LM, . Multicenter experience with electromagnetic navigation bronchoscopy for the diagnosis of pulmonary nodules. J Bronchology Interv Pulmonol. 2012 Jul;19(3):195–9. doi: 10.1097/LBR.0b013e3182616ece. PMID: 23207460. Exclusion Code: X4.23207460
698 Jeon HW, Kim YD, Kim KS, . Sublobar resection versus lobectomy in solid-type, clinical stage IA, non-small cell lung cancer. World J Surg Oncol. 2014 Jul 16;12:215. doi: 10.1186/1477-7819-12-215. PMID: 25027055. Exclusion Code: X11.25027055
699 Jeon HW, Moon MH, Kim KS, . Extent of removal for mediastinal nodal stations for patients with clinical stage I non-small cell lung cancer: effect on outcome. Thorac Cardiovasc Surg. 2014 Oct;62(7):599–604. doi: 10.1055/s-0033-1360478. PMID: 24420680. Exclusion Code: X8.24420680
700 Jeong SY, Lee KS, Shin KM, . Efficacy of PET/CT in the characterization of solid or partly solid solitary pulmonary nodules. Lung Cancer. 2008 Aug;61(2):186–94. doi: 10.1016/j.lungcan.2007.12.021. PMID: 18280613. Exclusion Code: X3.18280613
701 Jett JR, Peek LJ, Fredericks L, . Audit of the autoantibody test, EarlyCDT(R)-lung, in 1600 patients: an evaluation of its performance in routine clinical practice. Lung Cancer. 2014 Jan;83(1):51–5. doi: 10.1016/j.lungcan.2013.10.008. PMID: 24268382. Exclusion Code: X5.24268382
702 Jeyabalan A, Medford AR. Endobronchial ultrasound-guided transbronchial needle aspiration: patient satisfaction under light conscious sedation. Respiration. 2014;88(3):244–50. doi: 10.1159/000363063. PMID: 25170748. Exclusion Code: X3.25170748
703 Jeyabalan A, Shelley-Fraser G, Medford AR. Impact of needle gauge on characterization of endobronchial ultrasound-guided transbronchial needle aspiration (EBUS-TBNA) histology samples. Respirology. 2014 Jul;19(5):735–9. doi: 10.1111/resp.12293. PMID: 24697875. Exclusion Code: X3.24697875
704 Jhun BW, Park HY, Jeon K, . Nodal stations and diagnostic performances of endobronchial ultrasound-guided transbronchial needle aspiration in patients with non-small cell lung cancer. J Korean Med Sci. 2012 Jan;27(1):46–51. doi: 10.3346/jkms.2012.27.1.46. PMID: 22219613. Exclusion Code: X3.22219613
705 Jian ZH, Huang JY, Ko PC, . Impact of coexisting pulmonary diseases on survival of patients with lung adenocarcinoma: a STROBE-compliant article. Medicine (Baltimore). 2015 Jan;94(4):e443. doi: 10.1097/md.0000000000000443. PMID: 25634179. Exclusion Code: X3.25634179
706 Jiang W, Pang X, Xi J, . Clinical outcome of subcentimeter non-small cell lung cancer after surgical resection: single institution experience of 105 patients. J Surg Oncol. 2014 Sep;110(3):233–8. doi: 10.1002/jso.23647. PMID: 24888753. Exclusion Code: X3.24888753
707 Jiang ZF, Wang M, Xu JL. Thymidine kinase 1 combined with CEA, CYFRA21-1 and NSE improved its diagnostic value for lung cancer. Life Sci. 2018 Feb 1;194:1–6. doi: 10.1016/j.lfs.2017.12.020. PMID: 29247745. Exclusion Code: X4.29247745
708 Jiao D, Yuan H, Zhang Q, . Flat detector C-arm CT-guided transthoracic needle biopsy of small (</=2.0 cm) pulmonary nodules: diagnostic accuracy and complication in 100 patients. Radiol Med. 2016 Apr;121(4):268–78. doi: 10.1007/s11547-015-0604-3. PMID: 26646263. Exclusion Code: X3.26646263
709 Jiao W, Zhao Y, Wang M, . A retrospective study of diaphragmatic motion, pulmonary function, and quality-of-life following video-assisted thoracoscopic lobectomy in patients with nonsmall cell lung cancer. Indian J Cancer. 2015 Feb;51: Suppl 2:e45–8. doi: 10.4103/0019-509x.151991. PMID: 25712843. Exclusion Code: X3.25712843
710 Jimenez AR, Weiss AS, Campagna AC. Use of pulmonary function test demographic data to identify high-risk patients for lung cancer screening. Monaldi Arch Chest Dis. 2018 Feb 19;88(1):891. doi: 10.4081/monaldi.2018.891. PMID: 29557572. Exclusion Code: X5.29557572
711 Jobst BJ, Weinheimer O, Trauth M, . Effect of smoking cessation on quantitative computed tomography in smokers at risk in a lung cancer screening population. Eur Radiol. 2018 Feb;28(2):807–15. doi: 10.1007/s00330-017-5030-6. PMID: 28884215. Exclusion Code: X8.28884215
712 Jonnalagadda S, Bergamo C, Lin JJ, . Beliefs and attitudes about lung cancer screening among smokers. Lung Cancer. 2012 Sep;77(3):526–31. doi: 10.1016/j.lungcan.2012.05.095. PMID: 22681870. Exclusion Code: X8.22681870
713 Joseph AM, Rothman AJ, Almirall D, . Lung Cancer Screening and Smoking Cessation Clinical Trials. SCALE (Smoking Cessation within the Context of Lung Cancer Screening) Collaboration. Am J Respir Crit Care Med. 2018 Jan 15;197(2):172–82. doi: 10.1164/rccm.201705-0909CI. PMID: 28977754. Exclusion Code: X10.28977754
714 Joseph S, Harrington R, Walter D, . Plasma osteopontin velocity differentiates lung cancers from controls in a CT screening population. Cancer Biomark. 2012;12(4):177–84. doi: 10.3233/cbm-130306. PMID: 23568008. Exclusion Code: X4.23568008
715 Jouglar E, Isnardi V, Goulon D, . Patterns of locoregional failure in locally advanced non-small cell lung cancer treated with definitive conformal radiotherapy: Results from the Gating 2006 trial. Radiother Oncol. 2018 Feb;126(2):291–9. doi: 10.1016/j.radonc.2017.11.002. PMID: 29203290. Exclusion Code: X3.29203290
716 Jung JJ, Cho JH, Hong TH, . Intensive care unit (ICU) readmission after major lung resection: Prevalence, patterns, and mortality. Thorac Cancer. 2017 Jan;8(1):33–9. doi: 10.1111/1759-7714.12406. PMID: 27925393. Exclusion Code: X3.27925393
717 Jung JY, Lee JM, Kim MS, . Comparison of fatigue, depression, and anxiety as factors affecting posttreatment health-related quality of life in lung cancer survivors. Psychooncology. 2018 Feb;27(2):465–70. doi: 10.1002/pon.4513. PMID: 28755492. Exclusion Code: X3.28755492
718 Jung MY, Chong A, Seon HJ, . Indeterminate pleural metastasis on contrast-enhanced chest CT in non-small cell lung cancer: improved differential diagnosis with (18)F-FDG PET/CT. Ann Nucl Med. 2012 May;26(4):327–36. doi: 10.1007/s12149-012-0575-6. PMID: 22350956. Exclusion Code: X3.22350956
719 Jurgens V, Ess S, Cerny T, . A Bayesian generalized age-period-cohort power model for cancer projections. Stat Med. 2014 Nov 20;33(26):4627–36. doi: 10.1002/sim.6248. PMID: 24996118. Exclusion Code: X4.24996118
720 Kabolizadeh P, Kalash R, Huq MS, . Dosimetric definitions of total lung volumes in calculating parameters predictive for radiation-induced pneumonitis. Am J Clin Oncol. 2015 Aug;38(4):401–4. doi: 10.1097/COC.0b013e3182a2588f. PMID: 24064747. Exclusion Code: X3.24064747
721 Kadaria D, Archie DS, SultanAli I, . Dual time point positron emission tomography/computed tomography scan in evaluation of intrathoracic lesions in an area endemic for histoplasmosis and with high prevalence of sarcoidosis. Am J Med Sci. 2013 Nov;346(5):358–62. doi: 10.1097/MAJ.0b013e31827b9b6d. PMID: 23276900. Exclusion Code: X3.23276900
722 Kadeer X, Wang L, Zhang L, . Modified hook-wire placement technique for localizing multiple pulmonary nodules. J Surg Oncol. 2018 Dec;118(7):1188–93. doi: 10.1002/jso.25261. PMID: 30332509. Exclusion Code: X11.30332509
723 Kadota K, Sima CS, Arcila ME, . KRAS mutation is a significant prognostic factor in early-stage lung adenocarcinoma. Am J Surg Pathol. 2016 Dec;40(12):1579–90. doi: 10.1097/pas.0000000000000744. PMID: 27740967. Exclusion Code: X3.27740967
724 Kadoya N, Obata Y, Kato T, . Dose-volume comparison of proton radiotherapy and stereotactic body radiotherapy for non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011 Mar 15;79(4):1225–31. doi: 10.1016/j.ijrobp.2010.05.016. PMID: 20732759. Exclusion Code: X6.20732759
725 Kakar M, Mencattini A, Salmeri M. Extracting fuzzy classification rules from texture segmented HRCT lung images. J Digit Imaging. 2013 Apr;26(2):227–38. doi: 10.1007/s10278-012-9514-2. PMID: 22890442. Exclusion Code: X3.22890442
726 Kakinuma R, Ashizawa K, Kobayashi T, . Comparison of sensitivity of lung nodule detection between radiologists and technologists on low-dose CT lung cancer screening images. Br J Radiol. 2012 Sep;85(1017):e603–8. doi: 10.1259/bjr/75768386. PMID: 22919013. Exclusion Code: X11.22919013
727 Kakinuma R, Noguchi M, Ashizawa K, . Natural history of pulmonary subsolid nodules: a prospective multicenter study. J Thorac Oncol. 2016 Jul;11(7):1012–28. doi: 10.1016/j.jtho.2016.04.006. PMID: 27089851. Exclusion Code: X3.27089851
728 Kalathiya RJ, Davenport D, Saha SP. Long-term survival after pneumonectomy for non-small-cell lung cancer. Asian Cardiovasc Thorac Ann. 2013 Oct;21(5):574–81. doi: 10.1177/0218492312467025. PMID: 24570560. Exclusion Code: X3.24570560
729 Kamiya S, Iwano S, Umakoshi H, . Computer-aided Volumetry of Part-Solid Lung Cancers by Using CT: Solid Component Size Predicts Prognosis. Radiology. 2018 Jun;287(3):1030–40. doi: 10.1148/radiol.2018172319. PMID: 29533722. Exclusion Code: X3.29533722
730 Kanakis MA, Misthos PA, Tsimpinos MD, . Benign emptying of the post-pneumonectomy space: recognizing this rare complication retrospectively. Interact Cardiovasc Thorac Surg. 2015 Nov;21(5):685–7. doi: 10.1093/icvts/ivv207. PMID: 26242316. Exclusion Code: X3.26242316
731 Kanarek NF, Hooker CM, Mathieu L, . Survival after community diagnosis of early-stage non-small cell lung cancer. Am J Med. 2014 May;127(5):443–9. doi: 10.1016/j.amjmed.2013.12.023. PMID: 24486286. Exclusion Code: X3.24486286
732 Kanemoto A, Matsumoto Y, Sugita T. Timing and characteristics of radiation pneumonitis after stereotactic body radiotherapy for peripherally located stage I lung cancer. Int J Clin Oncol. 2015 Aug;20(4):680–5. doi: 10.1007/s10147-014-0766-3. PMID: 25373854. Exclusion Code: X10.25373854
733 Kang H, Hwangbo B, Lee G, . EBUS-centred versus EUS-centred mediastinal staging in lung cancer: a randomised controlled trial. Thorax. 2014;69(3):261–8. doi: 10.1136/thoraxjnl-2013-203881. PMID: CN-00982562. Exclusion Code: X7.24172712
734 Kann BH, Miccio JA, Stahl JM, . Stereotactic body radiotherapy with adjuvant systemic therapy for early-stage non-small cell lung carcinoma: A multi-institutional analysis. Radiother Oncol. 2019 Mar;132:188–96. doi: 10.1016/j.radonc.2018.10.017. PMID: 30391106. Exclusion Code: X8.30391106
735 Kann BH, Verma V, Stahl JM, . Multi-institutional analysis of stereotactic body radiation therapy for operable early-stage non-small cell lung carcinoma. Radiother Oncol. 2019 May;134:44–9. doi: 10.1016/j.radonc.2019.01.027. PMID: 31005223. Exclusion Code: X13.31005223
736 Kanzaki M, Kikkawa T, Shimizu T, . Presurgical planning using a three-dimensional pulmonary model of the actual anatomy of patient with primary lung cancer. Thorac Cardiovasc Surg. 2013 Mar;61(2):144–50. doi: 10.1055/s-0032-1328923. PMID: 23344773. Exclusion Code: X11.23344773
737 Kanzaki M, Maeda H, Wachi N, . Complete video-assisted thoracoscopic multi-subsegmentectomy based on patients’ specific virtual 3-D pulmonary models. Asian J Endosc Surg. 2013 May;6(2):110–5. doi: 10.1111/ases.12015. PMID: 23323687. Exclusion Code: X11.23323687
738 Kapadia NS, Valle LF, George JA, . Patterns of treatment and outcomes for definitive therapy of early stage non-small cell lung cancer. Ann Thorac Surg. 2017 Dec;104(6):1881–8. doi: 10.1016/j.athoracsur.2017.06.065. PMID: 29106887. Exclusion Code: X8.29106887
739 Karki K, Saraiya S, Hugo GD, . Variabilities of magnetic resonance imaging-, computed tomography-, and positron emission tomography-computed tomography-based tumor and lymph node delineations for lung cancer radiation therapy planning. Int J Radiat Oncol Biol Phys. 2017 Sep 1;99(1):80–9. doi: 10.1016/j.ijrobp.2017.05.002. PMID: 28816167. Exclusion Code: X3.28816167
740 Karp I, Sylvestre MP, Abrahamowicz M, . Bridging the etiologic and prognostic outlooks in individualized assessment of absolute risk of an illness: application in lung cancer. Eur J Epidemiol. 2016 Nov;31(11):1091–9. doi: 10.1007/s10654-016-0180-4. PMID: 27401439. Exclusion Code: X4.27401439
741 Kashiwabara K, Semba H, Fujii S, . Preoperative percutaneous transthoracic needle biopsy increased the risk of pleural recurrence in pathological stage I lung cancer patients with sub-pleural pure solid nodules. Cancer Invest. 2016 Sep 13;34(8):373–7. doi: 10.1080/07357907.2016.1212061. PMID: 27532604. Exclusion Code: X11.27532604
742 Kastelijn EA, El Sharouni SY, Hofman FN, . Clinical outcomes in early-stage NSCLC treated with stereotactic body radiotherapy versus surgical resection. Anticancer Res. 2015 Oct;35(10):5607–14. PMID: 26408733. Exclusion Code: X3.26408733
743 Kates M, Swanson S, Wisnivesky JP. Survival following lobectomy and limited resection for the treatment of stage I non-small cell lung cancer<=1 cm in size: a review of SEER data. Chest. 2011 Mar;139(3):491–6. doi: 10.1378/chest.09-2547. PMID: 20576736. Exclusion Code: X10.20576736
744 Katki HA, Kovalchik SA, Petito LC, . Implications of Nine Risk Prediction Models for Selecting Ever-Smokers for Computed Tomography Lung Cancer Screening. Ann Intern Med. 2018 doi: doi: 10.7326/M17-2701. Exclusion Code: X8.
745 Kato T, Ishikawa K, Aragaki M, . Optimal predictive value of preoperative serum carcinoembryonic antigen for surgical outcomes in stage I non-small cell lung cancer: differences according to histology and smoking status. J Surg Oncol. 2013 May;107(6):619–24. doi: 10.1002/jso.23293. PMID: 23192365. Exclusion Code: X11.23192365
746 Kaur MN, Xie F, Shiwcharan A, . Robotic Versus Video-Assisted Thoracoscopic Lung Resection During Early Program Development. Ann Thorac Surg. 2018 Apr;105(4):1050–7. doi: 10.1016/j.athoracsur.2017.11.013. PMID: 29502935. Exclusion Code: X3.29502935
747 Kavanagh J, Liu G, Menezes R, . Importance of Long-term Low-Dose CT Follow-up after Negative Findings at Previous Lung Cancer Screening. Radiology. 2018 Oct;289(1):218–24. doi: 10.1148/radiol.2018180053. PMID: 29989522. Exclusion Code: X11.29989522
748 Kavurmaci O, Akcam TI, Ergonul AG, . Is the Risk of Postoperative Atrial Fibrillation Predictable in Patients Undergoing Surgery Due to Primary Lung Cancer? Heart Lung Circ. 2018 Jul;27(7):835–41. doi: 10.1016/j.hlc.2017.06.729. PMID: 28800934. Exclusion Code: X3.28800934
749 Kawaguchi T, Sawabata N, Miura S, . Prognostic impact of underlying lung disease in pulmonary wedge resection for lung cancer. Int J Clin Oncol. 2019 Apr;24(4):366–74. doi: 10.1007/s10147-018-1367-3. PMID: 30443810. Exclusion Code: X11.30443810
750 Kaya A, Can AB. A weighted rule based method for predicting malignancy of pulmonary nodules by nodule characteristics. J Biomed Inform. 2015 Aug;56:69–79. doi: 10.1016/j.jbi.2015.05.011. PMID: 26008877. Exclusion Code: X4.26008877
751 Kayawake H, Chen-Yoshikawa TF, Oda H, . Complications of endobronchial ultrasound-guided transbronchial needle aspiration. Ann Thorac Surg. 2017 Nov;104(5):e363–e5. doi: 10.1016/j.athoracsur.2017.06.015. PMID: 29054229. Exclusion Code: X3.29054229
752 Kearney P, Hunsucker SW, Li XJ, . An integrated risk predictor for pulmonary nodules. PLoS One. 2017;12(5):e0177635. doi: 10.1371/journal.pone.0177635. PMID: 28545097. Exclusion Code: X3.28545097
753 Kelada OJ, Decker RH, Nath SK, . High Single Doses of Radiation May Induce Elevated Levels of Hypoxia in Early-Stage Non-Small Cell Lung Cancer Tumors. Int J Radiat Oncol Biol Phys. 2018 Sep 1;102(1):174–83. doi: 10.1016/j.ijrobp.2018.05.032. PMID: 30102194. Exclusion Code: X3.30102194
754 Kelley KD, Benninghoff DL, Stein JS, . Medically inoperable peripheral lung cancer treated with stereotactic body radiation therapy. Radiat Oncol. 2015 May 28;10:120. doi: 10.1186/s13014-015-0423-7. PMID: 26018408. Exclusion Code: X3.26018408
755 Kelly RF, Tran T, Holmstrom A, . Accuracy and cost-effectiveness of [18F]-2-fluoro-deoxy-D-glucose-positron emission tomography scan in potentially resectable non-small cell lung cancer. Chest. 2004 Apr;125(4):1413–23. PMID: 15078754. Exclusion Code: X3.15078754
756 Kelsey CR, Higgins KA, Peterson BL, . Local recurrence after surgery for non-small cell lung cancer: a recursive partitioning analysis of multi-institutional data. J Thorac Cardiovasc Surg. 2013 Oct;146(4):768–73.e1. doi: 10.1016/j.jtcvs.2013.05.041. PMID: 23856204. Exclusion Code: X3.23856204
757 Kennedy S, Baerlocher MO. Screening for lung cancer. CMAJ. 2014 May 13;186(8):E296. doi: 10.1503/cmaj.131385. PMID: 24638027. Exclusion Code: X9.24638027
758 Kennedy SA, Milovanovic L, Dao D, . Risk factors for pneumothorax complicating radiofrequency ablation for lung malignancy: a systematic review and meta-analysis. J Vasc Interv Radiol. 2014 Nov;25(11):1671–81.e1. doi: 10.1016/j.jvir.2014.07.025. PMID: 25442131. Exclusion Code: X6.25442131
759 Kent M, Landreneau R, Mandrekar S, . Segmentectomy versus wedge resection for non-small cell lung cancer in high-risk operable patients. Ann Thorac Surg. 2013 Nov;96(5):1747–54; discussion 54-5. doi: 10.1016/j.athoracsur.2013.05.104. PMID: 23998400. Exclusion Code: X11.23998400
760 Kent MS, Mandrekar SJ, Landreneau R, . Impact of sublobar resection on pulmonary function: long-term results from American College of Surgeons Oncology Group Z4032 (Alliance). Ann Thorac Surg. 2016 Jul;102(1):230–8. doi: 10.1016/j.athoracsur.2016.01.069. PMID: 27101728. Exclusion Code: X11.27101728
761 Kent MS, Mandrekar SJ, Landreneau R, . A nomogram to predict recurrence and survival of high-risk patients undergoing sublobar resection for lung cancer: an analysis of a multicenter prospective study (ACOSOG Z4032). Ann Thorac Surg. 2016 Jul;102(1):239–46. doi: 10.1016/j.athoracsur.2016.01.063. PMID: 27101729. Exclusion Code: X10.27101729
762 Kestin L, Grills I, Guckenberger M, . Dose-response relationship with clinical outcome for lung stereotactic body radiotherapy (SBRT) delivered via online image guidance. Radiother Oncol. 2014 Mar;110(3):499–504. doi: 10.1016/j.radonc.2014.02.002. PMID: 24630539. Exclusion Code: X13.24630539
763 Khairy M, Duong DK, Shariff-Marco S, . An Analysis of Lung Cancer Screening Beliefs and Practice Patterns for Community Providers Compared to Academic Providers. Cancer Control. 2018 Jan-Dec;25(1):1073274818806900. doi: 10.1177/1073274818806900. PMID: 30375235. Exclusion Code: X3.30375235
764 Khakwani A, Rich AL, Powell HA, . Lung cancer survival in England: trends in non-small-cell lung cancer survival over the duration of the National Lung Cancer Audit. Br J Cancer. 2013 Oct 15;109(8):2058–65. doi: 10.1038/bjc.2013.572. PMID: 24052044. Exclusion Code: X5.24052044
765 Khan I, Morris S. A non-linear beta-binomial regression model for mapping EORTC QLQ- C30 to the EQ-5D-3L in lung cancer patients: a comparison with existing approaches. Health Qual Life Outcomes. 2014 Nov 12;12:163. doi: 10.1186/s12955-014-0163-7. PMID: 25388439. Exclusion Code: X10.25388439
766 Khan KA, Kennedy MP, Moore E, . Radiological characteristics, histological features and clinical outcomes of lung cancer patients with coexistent idiopathic pulmonary fibrosis. Lung. 2015 Feb;193(1):71–7. doi: 10.1007/s00408-014-9664-8. PMID: 25381634. Exclusion Code: X3.25381634
767 Khandhar SJ, Bowling MR, Flandes J, . Electromagnetic navigation bronchoscopy to access lung lesions in 1,000 subjects: first results of the prospective, multicenter NAVIGATE study. BMC Pulm Med. 2017 Apr 11;17(1):59. doi: 10.1186/s12890-017-0403-9. PMID: 28399830. Exclusion Code: X8.28399830
768 Khawaja RD, Singh S, Lira D, . Role of compressive sensing technique in dose reduction for chest computed tomography: a prospective blinded clinical study. J Comput Assist Tomogr. 2014 Sep-Oct;38(5):760–7. doi: 10.1097/rct.0000000000000098. PMID: 24834892. Exclusion Code: X11.24834892
769 Khawaja RD, Singh S, Madan R, . Ultra low-dose chest CT using filtered back projection: comparison of 80-, 100- and 120 kVp protocols in a prospective randomized study. Eur J Radiol. 2014 Oct;83(10):1934–44. doi: 10.1016/j.ejrad.2014.06.024. PMID: 25063211. Exclusion Code: X11.25063211
770 Khorochkov E, Garvin GJ, Potoczny S, . Injection of Saline Into the Biopsy Tract and Rapid Patient Rollover Decreases Pneumothorax Size Following Computed Tomography-Guided Transthoracic Needle Biopsy. Can Assoc Radiol J. 2018 Nov;69(4):489–92. doi: 10.1016/j.carj.2018.08.002. PMID: 30309700. Exclusion Code: X11.30309700
771 Kiankhooy A, Taylor MD, LaPar DJ, . Predictors of early recurrence for node-negative t1 to t2b non-small cell lung cancer. Ann Thorac Surg. 2014 Oct;98(4):1175–83. doi: 10.1016/j.athoracsur.2014.05.061. PMID: 25134863. Exclusion Code: X12.25134863
772 Kim AW, Detterbeck FC, Boffa DJ, . Characteristics associated with the use of nonanatomic resections among Medicare patients undergoing resections of early-stage lung cancer. Ann Thorac Surg. 2012 Sep;94(3):895–901. doi: 10.1016/j.athoracsur.2012.04.091. PMID: 22835558. Exclusion Code: X11.22835558
773 Kim C, Lee SM, Choe J, . Volume doubling time of lung cancer detected in idiopathic interstitial pneumonia: comparison with that in chronic obstructive pulmonary disease. Eur Radiol. 2018 Apr;28(4):1402–9. doi: 10.1007/s00330-017-5091-6. PMID: 29038933. Exclusion Code: X8.29038933
774 Kim CH, Lee YC, Hung RJ, . Secondhand tobacco smoke exposure and lung adenocarcinoma in situ/minimally invasive adenocarcinoma (AIS/MIA). Cancer Epidemiol Biomarkers Prev. 2015 Dec;24(12):1902–6. doi: 10.1158/1055-9965.epi-15-0436. PMID: 26503035. Exclusion Code: X3.26503035
775 Kim D, Ferraris VA, Davenport D, . Outcomes of lobar and sublobar resections for non-small-cell lung cancer: a single-center experience. South Med J. 2015 Apr;108(4):230–4. doi: 10.14423/smj.0000000000000272. PMID: 25871994. Exclusion Code: X11.25871994
776 Kim D, Kim HK, Choi YS, . Central lung cancer management: impact of bronchial resection margin length. Thorac Cardiovasc Surg. 2015 Oct;63(7):583–8. doi: 10.1055/s-0034-1383813. PMID: 25032722. Exclusion Code: X3.25032722
777 Kim DH, Jung JH, Son SH, . Quantification of intratumoral metabolic macroheterogeneity on 18F-FDG PET/CT and its prognostic significance in pathologic N0 squamous cell lung carcinoma. Clin Nucl Med. 2016 Feb;41(2):e70–5. doi: 10.1097/rlu.0000000000000930. PMID: 26284762. Exclusion Code: X6.26284762
778 Kim DH, Son SH, Kim CY, . Prediction for recurrence using F-18 FDG PET/CT in pathologic N0 lung adenocarcinoma after curative surgery. Ann Surg Oncol. 2014 Feb;21(2):589–96. doi: 10.1245/s10434-013-3270-5. PMID: 24046125. Exclusion Code: X3.24046125
779 Kim ES, Kim YT, Kang CH, . Prevalence of and risk factors for postoperative pulmonary complications after lung cancer surgery in patients with early-stage COPD. Int J Chron Obstruct Pulmon Dis. 2016;11:1317–26. doi: 10.2147/copd.s105206. PMID: 27366059. Exclusion Code: X11.27366059
780 Kim H, Lussier YA, Noh OK, . Prognostic implication of pulmonary function at the beginning of postoperative radiotherapy in non-small cell lung cancer. Radiother Oncol. 2014 Dec;113(3):374–8. doi: 10.1016/j.radonc.2014.11.007. PMID: 25441612. Exclusion Code: X6.25441612
781 Kim H, Park CM, Jeon S, . Validation of prediction models for risk stratification of incidentally detected pulmonary subsolid nodules: a retrospective cohort study in a Korean tertiary medical centre. BMJ Open. 2018 May 24;8(5):e019996. doi: 10.1136/bmjopen-2017-019996. PMID: 29794091. Exclusion Code: X4.29794091
782 Kim H, Park CM, Lee M, . Impact of reconstruction algorithms on CT radiomic features of pulmonary tumors: analysis of intra- and inter-reader variability and inter-reconstruction algorithm variability. PLoS One. 2016;11(10):e0164924. doi: 10.1371/journal.pone.0164924. PMID: 27741289. Exclusion Code: X8.27741289
783 Kim H, Park CM, Woo S, . Pure and part-solid pulmonary ground-glass nodules: measurement variability of volume and mass in nodules with a solid portion less than or equal to 5 mm. Radiology. 2013 Nov;269(2):585–93. doi: 10.1148/radiol.13121849. PMID: 23864104. Exclusion Code: X3.23864104
784 Kim H, Park CM, Yoon SH, . Open Bronchus Sign on CT: A Risk Factor for Hemoptysis after Percutaneous Transthoracic Biopsy. Korean J Radiol. 2018 Sep-Oct;19(5):880–7. doi: 10.3348/kjr.2018.19.5.880. PMID: 30174477. Exclusion Code: X3.30174477
785 Kim HJ, Cha SI, Kim CH, . Risk factors of postoperative acute lung injury following lobectomy for nonsmall cell lung cancer. Medicine (Baltimore). 2019 Mar;98(13):e15078. doi: 10.1097/md.0000000000015078. PMID: 30921242. Exclusion Code: X3.30921242
786 Kim HY, Jung KW, Lim KY, . Lung Cancer Screening with Low-Dose CT in Female Never Smokers: Retrospective Cohort Study with Long-term National Data Follow-up. Cancer Res Treat. 2018 Jul;50(3):748–56. doi: 10.4143/crt.2017.312. PMID: 28724283. Exclusion Code: X10.28724283
787 Kim HY, Naidich DP, Lim KY, . Transient pulmonary eosinophilia incidentally found on low-dose computed tomography: findings in 40 individuals. J Comput Assist Tomogr. 2008 Jan-Feb;32(1):101–7. doi: 10.1097/RCT.0b013e31806535e5. PMID: 18303297. Exclusion Code: X3.18303297
788 Kim IH, Lee IH, Lee JE, . Prognostic impact of multiple clinicopathologic risk factors and c-MET overexpression in patients who have undergone resection of stage IB non-small-cell lung cancer. Clin Lung Cancer. 2016 Sep;17(5):e31–e43. doi: 10.1016/j.cllc.2016.01.005. PMID: 26992846. Exclusion Code: X11.26992846
789 Kim JI, Park CM, Kim H, . Non-specific benign pathological results on transthoracic core-needle biopsy: how to differentiate false-negatives? Eur Radiol. 2017 Sep;27(9):3888–95. doi: 10.1007/s00330-017-4766-3. PMID: 28188426. Exclusion Code: X3.28188426
790 Kim K, Kim SJ, Kim IJ, . Prognostic value of volumetric parameters measured by F-18 FDG PET/CT in surgically resected non-small-cell lung cancer. Nucl Med Commun. 2012 Jun;33(6):613–20. doi: 10.1097/MNM.0b013e328351d4f5. PMID: 22407127. Exclusion Code: X3.22407127
791 Kim KW, Kim HK, Kim J, . Outcomes of curative-intent surgery and adjuvant treatment for pulmonary large cell neuroendocrine carcinoma. World J Surg. 2017 Jul;41(7):1820–7. doi: 10.1007/s00268-017-3908-8. PMID: 28204910. Exclusion Code: X3.28204910
792 Kim MP, Correa AM, Hofstetter W, . Limitations of 18F-2-deoxy-D-glucose positron emission tomography in N1 detection in patients with pathologic stage II-N1 and implications for management. Ann Thorac Surg. 2015 Feb;99(2):414–20. doi: 10.1016/j.athoracsur.2014.09.023. PMID: 25497068. Exclusion Code: X3.25497068
793 Kim SH, Kim HK, Choi YS, . Pleural recurrence and long-term survival after thoracotomy and thoracoscopic lobectomy. Ann Thorac Surg. 2013 Nov;96(5):1769–75. doi: 10.1016/j.athoracsur.2013.05.037. PMID: 23968762. Exclusion Code: X11.23968762
794 Kim SK, Allen-Auerbach M, Goldin J, . Accuracy of PET/CT in characterization of solitary pulmonary lesions. J Nucl Med. 2007 Feb;48(2):214–20. PMID: 17268017. Exclusion Code: X3.17268017
795 Kim SK, Manzerova J, Christos P, . Impact of radiation therapy in surgically resected limited-stage small cell lung carcinoma. Lung. 2017 Jun;195(3):341–6. doi: 10.1007/s00408-017-9992-6. PMID: 28353115. Exclusion Code: X11.28353115
796 Kim SR, Han HJ, Park SJ, . Comparison between surgery and radiofrequency ablation for stage I non-small cell lung cancer. Eur J Radiol. 2012 Feb;81(2):395–9. doi: 10.1016/j.ejrad.2010.12.091. PMID: 21310562. Exclusion Code: X6.21310562
797 Kim SS, Song SY, Kwak J, . Clinical prognostic factors and grading system for rib fracture following stereotactic body radiation therapy (SBRT) in patients with peripheral lung tumors. Lung Cancer. 2013 Feb;79(2):161–6. doi: 10.1016/j.lungcan.2012.10.011. PMID: 23182662. Exclusion Code: X3.23182662
798 Kim TJ, Lee JH, Lee CT, . Diagnostic accuracy of CT-guided core biopsy of ground-glass opacity pulmonary lesions. AJR Am J Roentgenol. 2008 Jan;190(1):234–9. doi: 10.2214/ajr.07.2441. PMID: 18094317. Exclusion Code: X3.18094317
799 Kim Y, Kim YK, Lee BE, . Ultra-low-dose CT of the thorax using iterative reconstruction: evaluation of image quality and radiation dose reduction. AJR Am J Roentgenol. 2015 Jun;204(6):1197–202. doi: 10.2214/ajr.14.13629. PMID: 26001228. Exclusion Code: X3.26001228
800 Kim YJ, Kim SS, Song SY, . Feasibility of stereotactic radiotherapy for lung lesions and conventional radiotherapy for nodal areas in primary lung malignancies. Radiat Oncol. 2018 Jul 11;13(1):127. doi: 10.1186/s13014-018-1071-5. PMID: 29996863. Exclusion Code: X3.29996863
801 Kimura D, Fukuda I, Tsushima T, . Management of acute ischemic stroke after pulmonary resection: incidence and efficacy of endovascular thrombus aspiration. Gen Thorac Cardiovasc Surg. 2019 Mar;67(3):306–11. doi: 10.1007/s11748-018-1024-9. PMID: 30367330. Exclusion Code: X11.30367330
802 Kimura T, Matsuura K, Murakami Y, . CT appearance of radiation injury of the lung and clinical symptoms after stereotactic body radiation therapy (SBRT) for lung cancers: are patients with pulmonary emphysema also candidates for SBRT for lung cancers? Int J Radiat Oncol Biol Phys. 2006 Oct 1;66(2):483–91. doi: 10.1016/j.ijrobp.2006.05.008. PMID: 16904838. Exclusion Code: X3.16904838
803 Kimura T, Togami T, Takashima H, . Radiation pneumonitis in patients with lung and mediastinal tumours: a retrospective study of risk factors focused on pulmonary emphysema. Br J Radiol. 2012 Feb;85(1010):135–41. doi: 10.1259/bjr/32629867. PMID: 21385918. Exclusion Code: X3.21385918
804 Kinoshita F, Toyokawa G, Matsubara T, . Prognosis of Early-stage Part-solid and Pure-solid Lung Adenocarcinomas. Anticancer Res. 2019 May;39(5):2665–70. doi: 10.21873/anticanres.13391. PMID: 31092466. Exclusion Code: X11.31092466
805 Kiranantawat N, Srisala N, Sungsiri J, . Transthoracic imaging-guided biopsy of lung lesions: evaluation of benign non-specific pathologic diagnoses. J Med Assoc Thai. 2015 May;98(5):501–7. PMID: 26058280. Exclusion Code: X11.26058280
806 Kirchner J, Sawicki LM, Nensa F, . Prospective comparison of (18)F-FDG PET/MRI and (18)F-FDG PET/CT for thoracic staging of non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2019 Feb;46(2):437–45. doi: 10.1007/s00259-018-4109-x. PMID: 30074073. Exclusion Code: X8.30074073
807 Kirienko M, Cozzi L, Rossi A, . Ability of FDG PET and CT radiomics features to differentiate between primary and metastatic lung lesions. Eur J Nucl Med Mol Imaging. 2018 Sep;45(10):1649–60. doi: 10.1007/s00259-018-3987-2. PMID: 29623375. Exclusion Code: X3.29623375
808 Kirmani BH, Rintoul RC, Win T, . Stage migration: results of lymph node dissection in the era of modern imaging and invasive staging for lung cancer. Eur J Cardiothorac Surg. 2013 Jan;43(1):104–9; discussion 9-10. doi: 10.1093/ejcts/ezs184. PMID: 22529185. Exclusion Code: X8.22529185
809 Kishi T, Matsuo Y, Ueki N, . Pretreatment Modified Glasgow Prognostic Score predicts clinical outcomes after stereotactic body radiation therapy for early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2015 Jul 1;92(3):619–26. doi: 10.1016/j.ijrobp.2015.02.018. PMID: 26068494. Exclusion Code: X13.26068494
810 Kiss N, Isenring E, Gough K, . The prevalence of weight loss during (chemo)radiotherapy treatment for lung cancer and associated patient- and treatment-related factors. Clin Nutr. 2014 Dec;33(6):1074–80. doi: 10.1016/j.clnu.2013.11.013. PMID: 24325888. Exclusion Code: X3.24325888
811 Kiss N, Krishnasamy M, Everitt S, . Dosimetric factors associated with weight loss during (chemo)radiotherapy treatment for lung cancer. Eur J Clin Nutr. 2014 Dec;68(12):1309–14. doi: 10.1038/ejcn.2014.166. PMID: 25117989. Exclusion Code: X6.25117989
812 Kitamura Y, Suzuki K, Teramukai S, . Feasibility of pulmonary resection for lung cancer in patients with coronary artery disease or atrial fibrillation. Ann Thorac Surg. 2017 Feb;103(2):432–40. doi: 10.1016/j.athoracsur.2016.08.077. PMID: 27793400. Exclusion Code: X10.27793400
813 Klabatsa A, Chicklore S, Barrington SF, . The association of 18F-FDG PET/CT parameters with survival in malignant pleural mesothelioma. Eur J Nucl Med Mol Imaging. 2014 Feb;41(2):276–82. doi: 10.1007/s00259-013-2561-1. PMID: 24057459. Exclusion Code: X3.24057459
814 Kleedehn M, Kim DH, Lee FT, . Preoperative pulmonary nodule localization: a comparison of methylene blue and hookwire techniques. AJR Am J Roentgenol. 2016 Dec;207(6):1334–9. doi: 10.2214/ajr.16.16272. PMID: 27657546. Exclusion Code: X3.27657546
815 Klement RJ, Allgauer M, Appold S, . Support vector machine-based prediction of local tumor control after stereotactic body radiation therapy for early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2014 Mar 1;88(3):732–8. doi: 10.1016/j.ijrobp.2013.11.216. PMID: 24411630. Exclusion Code: X8.24411630
816 Klinkenberg TJ, Dinjens L, Wolf RFE, . CT-guided percutaneous hookwire localization increases the efficacy and safety of VATS for pulmonary nodules. J Surg Oncol. 2017 Jun;115(7):898–904. doi: 10.1002/jso.24589. PMID: 28230245. Exclusion Code: X3.28230245
817 Kluthke RA, Kickuth R, Bansmann PM, . The additional value of the lateral chest radiograph for the detection of small pulmonary nodules-a ROC analysis. Br J Radiol. 2016 Nov;89(1067):20160394. doi: 10.1259/bjr.20160394. PMID: 27605206. Exclusion Code: X5.27605206
818 Kneuertz PJ, Singer E, D’Souza DM, . Postoperative complications decrease the cost-effectiveness of robotic-assisted lobectomy. Surgery. 2019 Feb;165(2):455–60. doi: 10.1016/j.surg.2018.08.024. PMID: 30268372. Exclusion Code: X11.30268372
819 Ko JP, Suh J, Ibidapo O, . Lung adenocarcinoma: correlation of quantitative CT findings with pathologic findings. Radiology. 2016 Sep;280(3):931–9. doi: 10.1148/radiol.2016142975. PMID: 27097236. Exclusion Code: X3.27097236
820 Kobayashi H, Ohkubo M, Narita A, . A method for evaluating the performance of computer-aided detection of pulmonary nodules in lung cancer CT screening: detection limit for nodule size and density. Br J Radiol. 2017 Feb;90(1070):20160313. doi: 10.1259/bjr.20160313. PMID: 27897029. Exclusion Code: X5.27897029
821 Kobayashi M, Matsumoto T, Ryuge S, . CAXII Is a sero-diagnostic marker for lung cancer. PLoS One. 2012;7(3):e33952. doi: 10.1371/journal.pone.0033952. PMID: 22439015. Exclusion Code: X4.22439015
822 Kobayashi Y, Fukui T, Ito S, . How long should small lung lesions of ground-glass opacity be followed? J Thorac Oncol. 2013 Mar;8(3):309–14. doi: 10.1097/JTO.0b013e31827e2435. PMID: 23399958. Exclusion Code: X3.23399958
823 Kocher F, Fiegl M, Mian M, . Cardiovascular comorbidities and events in NSCLC: often underestimated but worth considering. Clin Lung Cancer. 2015 Jul;16(4):305–12. doi: 10.1016/j.cllc.2014.12.007. PMID: 25659438. Exclusion Code: X3.25659438
824 Kocher F, Lunger F, Seeber A, . Incidental diagnosis of asymptomatic non-small-cell lung cancer: a registry-based analysis. Clin Lung Cancer. 2016 Jan;17(1):62–7.e1. doi: 10.1016/j.cllc.2015.08.006. PMID: 26420370. Exclusion Code: X5.26420370
825 Kodama H, Yamakado K, Hasegawa T, . Radiofrequency ablation using a multiple-electrode switching system for lung tumors with 2.0-5.0-cm maximum diameter: phase II clinical study. Radiology. 2015 Dec;277(3):895–902. doi: 10.1148/radiol.2015141153. PMID: 26053308. Exclusion Code: X3.26053308
826 Kodama H, Yamakado K, Hasegawa T, . Radiofrequency ablation for ground-glass opacity-dominant lung adenocarcinoma. J Vasc Interv Radiol. 2014 Mar;25(3):333–9. doi: 10.1016/j.jvir.2013.11.035. PMID: 24581457. Exclusion Code: X3.24581457
827 Kodama K, Higashiyama M, Okami J, . Oncologic outcomes of segmentectomy versus lobectomy for clinical T1a N0 M0 non-small cell lung cancer. Ann Thorac Surg. 2016 Feb;101(2):504–11. doi: 10.1016/j.athoracsur.2015.08.063. PMID: 26542438. Exclusion Code: X11.26542438
828 Koenigkam-Santos M, Optazaite E, Sommer G, . Contrast-enhanced magnetic resonance imaging of pulmonary lesions: description of a technique aiming clinical practice. Eur J Radiol. 2015 Jan;84(1):185–92. doi: 10.1016/j.ejrad.2014.10.007. PMID: 25455411. Exclusion Code: X3.25455411
829 Kohman LJ, Gu L, Altorki N, . Biopsy first: Lessons learned from Cancer and Leukemia Group B (CALGB) 140503. J Thorac Cardiovasc Surg. 2017 Jun;153(6):1592–7. doi: 10.1016/j.jtcvs.2016.12.045. PMID: 28274562. Exclusion Code: X11.28274562
830 Kohutek ZA, Wu AJ, Zhang Z, . FDG-PET maximum standardized uptake value is prognostic for recurrence and survival after stereotactic body radiotherapy for non-small cell lung cancer. Lung Cancer. 2015 Aug;89(2):115–20. doi: 10.1016/j.lungcan.2015.05.019. PMID: 26078260. Exclusion Code: X10.26078260
831 Koike T, Kitahara A, Sato S, . Lobectomy versus segmentectomy in radiologically pure solid small-sized non-small cell lung cancer. Ann Thorac Surg. 2016 Apr;101(4):1354–60. doi: 10.1016/j.athoracsur.2015.10.048. PMID: 26794890. Exclusion Code: X11.26794890
832 Koike T, Koike T, Yamato Y, . Prognostic predictors in non-small cell lung cancer patients undergoing intentional segmentectomy. Ann Thorac Surg. 2012 Jun;93(6):1788–94. doi: 10.1016/j.athoracsur.2012.02.093. PMID: 22560265. Exclusion Code: X11.22560265
833 Koike T, Koike T, Yoshiya K, . Risk factor analysis of locoregional recurrence after sublobar resection in patients with clinical stage IA non-small cell lung cancer. J Thorac Cardiovasc Surg. 2013 Aug;146(2):372–8. doi: 10.1016/j.jtcvs.2013.02.057. PMID: 23870323. Exclusion Code: X11.23870323
834 Koizumi T, Shetty V, Yamaguchi M. Salivary cytokine panel indicative of non-small cell lung cancer. J Int Med Res. 2018 Sep;46(9):3570–82. doi: 10.1177/0300060518775563. PMID: 29916282. Exclusion Code: X5.29916282
835 Kolodziejczyk M, Bujko K, Michalski W, . Incidence of isolated nodal failure in non-small cell lung cancer patients included in a prospective study of the value of PET-CT. Radiother Oncol. 2012 Jul;104(1):58–61. doi: 10.1016/j.radonc.2012.04.012. PMID: 22652096. Exclusion Code: X3.22652096
836 Komatsu H, Izumi N, Tsukioka T, . Prognosis associated with synchronous or metachronous multiple primary malignancies in patients with completely resected non-small cell lung cancer. Surg Today. 2019 Apr;49(4):343–9. doi: 10.1007/s00595-018-1738-4. PMID: 30417262. Exclusion Code: X3.30417262
837 Komisopoulos G, Mavroidis P, Rodriguez S, . Radiobiologic comparison of helical tomotherapy, intensity modulated radiotherapy, and conformal radiotherapy in treating lung cancer accounting for secondary malignancy risks. Med Dosim. 2014 Winter;39(4):337–47. doi: 10.1016/j.meddos.2014.06.001. PMID: 25168596. Exclusion Code: X3.25168596
838 Konings R, van Gool MH, Bard MP, . Prognostic value of pre-operative glucose-corrected maximum standardized uptake value in patients with non-small cell lung cancer after complete surgical resection and 5-year follow-up. Ann Nucl Med. 2016 Jun;30(5):362–8. doi: 10.1007/s12149-016-1070-2. PMID: 26961089. Exclusion Code: X3.26961089
839 Kopek N, Paludan M, Petersen J, . Co-morbidity index predicts for mortality after stereotactic body radiotherapy for medically inoperable early-stage non-small cell lung cancer. Radiother Oncol. 2009 Dec;93(3):402–7. doi: 10.1016/j.radonc.2009.06.002. PMID: 19559492. Exclusion Code: X11.19559492
840 Korbakis D, Dimitromanolakis A, Prassas I, . Serum LAMC2 enhances the prognostic value of a multi-parametric panel in non-small cell lung cancer. Br J Cancer. 2015 Jul 28;113(3):484–91. doi: 10.1038/bjc.2015.171. PMID: 26180921. Exclusion Code: X3.26180921
841 Korzets Ceder Y, Fenig E, Popvtzer A, . Stereotactic body radiotherapy for central lung tumors, yes we can! Radiat Oncol. 2018 Apr 25;13(1):77. doi: 10.1186/s13014-018-1017-y. PMID: 29695273. Exclusion Code: X3.29695273
842 Koshy M, Malik R, Mahmood U, . Stereotactic body radiotherapy and treatment at a high volume facility is associated with improved survival in patients with inoperable stage I non-small cell lung cancer. Radiother Oncol. 2015 Feb;114(2):148–54. doi: 10.1016/j.radonc.2014.12.004. PMID: 25586951. Exclusion Code: X13.25586951
843 Kovalchik SA, De Matteis S, Landi MT, . A regression model for risk difference estimation in population-based case-control studies clarifies gender differences in lung cancer risk of smokers and never smokers. BMC Med Res Methodol. 2013 Nov 19;13:143. doi: 10.1186/1471-2288-13-143. PMID: 24252624. Exclusion Code: X4.24252624
844 Koyi H, Hillerdal G, Kolbeck KG, . Non-small cell lung cancer (NSCLC) in octogenarians in clinical practice. Anticancer Res. 2016 Oct;36(10):5397–402. doi: 10.21873/anticanres.11115. PMID: 27798905. Exclusion Code: X3.27798905
845 Kozak A, Alchimowicz J, Safranow K, . The impact of the sequence of pulmonary vessel ligation during anatomic resection for lung cancer on long-term survival--a prospective randomized trial. Adv Med Sci. 2013;58(1):156–63. doi: 10.2478/v10039-012-0061-3. PMID: 23612700. Exclusion Code: X3.23612700
846 Krafft SP, Rao A, Stingo F, . The utility of quantitative CT radiomics features for improved prediction of radiation pneumonitis. Med Phys. 2018 Nov;45(11):5317–24. doi: 10.1002/mp.13150. PMID: 30133809. Exclusion Code: X6.30133809
847 Kreinbrink P, Blumenfeld P, Tolekidis G, . Lung stereotactic body radiation therapy (SBRT) for early-stage non-small cell lung cancer in the very elderly (>/=80years old): Extremely safe and effective. J Geriatr Oncol. 2017 Sep;8(5):351–5. doi: 10.1016/j.jgo.2017.07.002. PMID: 28739159. Exclusion Code: X10.28739159
848 Kreuter M, Ehlers-Tenenbaum S, Schaaf M, . Treatment and outcome of lung cancer in idiopathic interstitial pneumonias. Sarcoidosis Vasc Diffuse Lung Dis. 2015 Jan 5;31(4):266–74. PMID: 25591137. Exclusion Code: X3.25591137
849 Kron T, Chesson B, Hardcastle N, . Credentialing of radiotherapy centres in Australasia for TROG 09.02 (Chisel), a Phase III clinical trial on stereotactic ablative body radiotherapy of early stage lung cancer. Br J Radiol. 2018 May;91(1085):20170737. doi: 10.1259/bjr.20170737. PMID: 29446317. Exclusion Code: X6.29446317
850 Kubik MJ, Bovbel A, Goli H, . Diagnostic value and accuracy of imprint cytology evaluation during image-guided core needle biopsies: Review of our experience at a large academic center. Diagn Cytopathol. 2015 Oct;43(10):773–9. doi: 10.1002/dc.23300. PMID: 26119885. Exclusion Code: X3.26119885
851 Kudo S, Imai K, Ishiyama K, . New CT criteria for nodal staging in non-small cell lung cancer. Clin Imaging. 2014 Jul-Aug;38(4):448–53. doi: 10.1016/j.clinimag.2014.02.008. PMID: 24651060. Exclusion Code: X3.24651060
852 Kuijvenhoven JC, Crombag L, Breen DP, . Esophageal ultrasound (EUS) assessment of T4 status in NSCLC patients. Lung Cancer. 2017 Dec;114:50–5. doi: 10.1016/j.lungcan.2017.10.017. PMID: 29173765. Exclusion Code: X3.29173765
853 Kumagai S, Marumo S, Arita M, . Development and validation of a preoperative prognostic index independent of TNM stage in resected non-small cell lung cancer. BMC Pulm Med. 2017 Dec 4;17(1):166. doi: 10.1186/s12890-017-0529-9. PMID: 29202834. Exclusion Code: X3.29202834
854 Kumar P, Gareen IF, Lathan C, . Racial differences in tobacco cessation and treatment usage after lung screening: an examination of the National Lung Screening Trial. Oncologist. 2016 Jan;21(1):40–9. doi: 10.1634/theoncologist.2015-0325. PMID: 26712960. Exclusion Code: X7.26712960
855 Kumar S, Feddock J, Li X, . Update of a Prospective Study of Stereotactic Body Radiation Therapy for Post-Chemoradiation Residual Disease in Stage II/III Non-Small Cell Lung Cancer. Int J Radiat Oncol Biol Phys. 2017 Nov 1;99(3):652–9. doi: 10.1016/j.ijrobp.2017.07.036. PMID: 29280459. Exclusion Code: X3.29280459
856 Kumar SG, Garg MK, Khandelwal N, . Role of digital tomosynthesis and dual energy subtraction digital radiography in detecting pulmonary nodules. Eur J Radiol. 2015 Jul;84(7):1383–91. doi: 10.1016/j.ejrad.2015.03.020. PMID: 25892052. Exclusion Code: X5.25892052
857 Kumar V, Cohen JT, van Klaveren D, . Risk-targeted lung cancer screening: a cost-effectiveness analysis. Ann Intern Med. 2018 Jan 2doi: 10.7326/M17-1401. PMID: 29297005. Exclusion Code: X4.29297005
858 Kundel HL. Visual search and lung nodule detection on CT scans. Radiology. 2015 Jan;274(1):14–6. doi: 10.1148/radiol.14142247. PMID: 25531475. Exclusion Code: X10.25531475
859 Kuo CH, Wu CY, Lee KY, . Chronic obstructive pulmonary disease in stage I non-small cell lung cancer that underwent anatomic resection: the role of a recurrence promoter. Copd. 2014 Aug;11(4):407–13. doi: 10.3109/15412555.2013.838946. PMID: 24475998. Exclusion Code: X11.24475998
860 Kuo E, Bharat A, Bontumasi N, . Impact of video-assisted thoracoscopic surgery on benign resections for solitary pulmonary nodules. Ann Thorac Surg. 2012 Jan;93(1):266–72; discussion 72-3. doi: 10.1016/j.athoracsur.2011.08.035. PMID: 22075217. Exclusion Code: X10.22075217
861 Kuo SW, Chen JS, Huang PM, . Prognostic significance of histologic differentiation, carcinoembryonic antigen value, and lymphovascular invasion in stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2014 Oct;148(4):1200–7.e3. doi: 10.1016/j.jtcvs.2014.04.038. PMID: 24993621. Exclusion Code: X3.24993621
862 Kuritzky AM, Aswad BI, Jones RN, . Lobectomy by video-assisted thoracic surgery vs muscle-sparing thoracotomy for stage I lung cancer: a critical evaluation of short- and long-term outcomes. J Am Coll Surg. 2015 Jun;220(6):1044–53. doi: 10.1016/j.jamcollsurg.2014.12.049. PMID: 25868407. Exclusion Code: X11.25868407
863 Kuritzky AM, Ryder BA, Ng T. Long-term survival outcomes of Video-assisted Thoracic Surgery (VATS) lobectomy after transitioning from open lobectomy. Ann Surg Oncol. 2013 Aug;20(8):2734–40. doi: 10.1245/s10434-013-2929-2. PMID: 23463094. Exclusion Code: X11.23463094
864 Kurt A, Tan S, Tatar IG, . The use of bronchial arteries in the characterization of primary lung cancer: an MDCT study. J Comput Assist Tomogr. 2014 Mar-Apr;38(2):169–73. doi: 10.1097/RCT.0b013e3182aa6753. PMID: 24448502. Exclusion Code: X3.24448502
865 Kusk MW, Karstoft J, Mussmann BR. CT triage for lung malignancy: coronal multiplanar reformation versus images in three orthogonal planes. Acta Radiol. 2015 Nov;56(11):1336–41. doi: 10.1177/0284185114556928. PMID: 25406433. Exclusion Code: X3.25406433
866 Kwan SW, Mortell KE, Hippe DS, . An economic analysis of sublobar resection versus thermal ablation for early-stage non-small-cell lung cancer. J Vasc Interv Radiol. 2014 Oct;25(10):1558–64; quiz 65. doi: 10.1016/j.jvir.2014.07.002. PMID: 25130308. Exclusion Code: X8.25130308
867 Kwan SW, Mortell KE, Talenfeld AD, . Thermal ablation matches sublobar resection outcomes in older patients with early-stage non-small cell lung cancer. J Vasc Interv Radiol. 2014 Jan;25(1):1–9.e1. doi: 10.1016/j.jvir.2013.10.018. PMID: 24365502. Exclusion Code: X12.24365502
868 Kwon W, Howard BA, Herndon JE, . FDG uptake on positron emission tomography correlates with survival and time to recurrence in patients with stage I non-small-cell lung cancer. J Thorac Oncol. 2015 Jun;10(6):897–902. doi: 10.1097/jto.0000000000000534. PMID: 25811445. Exclusion Code: X11.25811445
869 Lacasse Y, Martel S, Hebert A, . Accuracy of virtual bronchoscopy to detect endobronchial lesions. Ann Thorac Surg. 2004 May;77(5):1774–80. doi: 10.1016/j.athoracsur.2003.10.068. PMID: 15111185. Exclusion Code: X3.15111185
870 Lachelt S, Alber M, Sohn M, . Intensity-modulated stereotactic radiotherapy for the treatment of medically inoperable patients with NSCLC stage I. Oncol Rep. 2012 Oct;28(4):1309–14. doi: 10.3892/or.2012.1953. PMID: 22895737. Exclusion Code: X10.22895737
871 Lacroix V, Mosala Nezhad Z, Kahn D, . Pain, quality of life, and clinical outcomes after robotic lobectomy. Thorac Cardiovasc Surg. 2017 Aug;65(5):344–50. doi: 10.1055/s-0036-1587590. PMID: 27575276. Exclusion Code: X11.27575276
872 Lai CY, Chang WS, Hsieh YH, . Association of tissue inhibitor of metalloproteinase-1 genotypes with lung cancer risk in Taiwan. Anticancer Res. 2016 Jan;36(1):155–60. PMID: 26722039. Exclusion Code: X3.26722039
873 Lai Y, Du H, Wang X, . Status and perspectives of clinical modes in surgical patients with lung cancer: a retrospective study. Medicine (Baltimore). 2016 Jan;95(2):e2429. doi: 10.1097/md.0000000000002429. PMID: 26765424. Exclusion Code: X11.26765424
874 Lam VK, Miller M, Dowling L, . Community low-dose CT lung cancer screening: a prospective cohort study. Lung. 2015 Feb;193(1):135–9. doi: 10.1007/s00408-014-9671-9. PMID: 25503535. Exclusion Code: X7.25503535
875 Lammers A, Mitin T, Moghanaki D, . Lung cancer specialists’ opinions on treatment for stage I non-small cell lung cancer: a multidisciplinary survey. Adv Radiat Oncol. 2018 Apr-Jun;3(2):125–9. doi: 10.1016/j.adro.2018.01.001. PMID: 29904736. Exclusion Code: X8.29904736
876 Lamprecht B, Porsch P, Wegleitner B, . Electromagnetic navigation bronchoscopy (ENB): Increasing diagnostic yield. Respir Med. 2012 May;106(5):710–5. doi: 10.1016/j.rmed.2012.02.002. PMID: 22391437. Exclusion Code: X3.22391437
877 Landreneau JP, Schuchert MJ, Weyant R, . Anatomic segmentectomy and brachytherapy mesh implantation for clinical stage I non-small cell lung cancer (NSCLC). Surgery. 2014 Feb;155(2):340–6. doi: 10.1016/j.surg.2013.06.055. PMID: 24314884. Exclusion Code: X6.24314884
878 Langer SG, Graner BD, Schueler BA, . Sensitivity of thoracic digital tomosynthesis (DTS) for the identification of lung nodules. J Digit Imaging. 2016 Feb;29(1):141–7. doi: 10.1007/s10278-015-9818-0. PMID: 26349914. Exclusion Code: X3.26349914
879 Langsenlehner U, Hofmann G, Renner W, . Association of vascular endothelial growth factor--a gene polymorphisms and haplotypes with breast cancer metastases. Acta Oncol. 2015 Mar;54(3):368–76. doi: 10.3109/0284186x.2014.948056. PMID: 25152223. Exclusion Code: X3.25152223
880 Lanni TB, Jr., Grills IS, Kestin LL, . Stereotactic radiotherapy reduces treatment cost while improving overall survival and local control over standard fractionated radiation therapy for medically inoperable non-small-cell lung cancer. Am J Clin Oncol. 2011 Oct;34(5):494–8. doi: 10.1097/COC.0b013e3181ec63ae. PMID: 20805737. Exclusion Code: X8.20805737
881 Lao L, Hope AJ, Maganti M, . Incidental prophylactic nodal irradiation and patterns of nodal relapse in inoperable early stage NSCLC patients treated with SBRT: a case-matched analysis. Int J Radiat Oncol Biol Phys. 2014 Sep 1;90(1):209–15. doi: 10.1016/j.ijrobp.2014.05.006. PMID: 24997639. Exclusion Code: X10.24997639
882 Larici AR, Amato M, Ordonez P, . Detection of noncalcified pulmonary nodules on low-dose MDCT: comparison of the sensitivity of two CAD systems by using a double reference standard. Radiol Med. 2012 Sep;117(6):953–67. doi: 10.1007/s11547-012-0795-9. PMID: 22327922. Exclusion Code: X10.22327922
883 Larke FJ, Kruger RL, Cagnon CH, . Estimated radiation dose associated with low-dose chest CT of average-size participants in the National Lung Screening Trial. AJR Am J Roentgenol. 2011 Nov;197(5):1165–9. doi: 10.2214/ajr.11.6533. PMID: 22021510. Exclusion Code: X3.22021510
884 Lasnon C, Hicks RJ, Beauregard JM, . Impact of point spread function reconstruction on thoracic lymph node staging with 18F-FDG PET/CT in non-small cell lung cancer. Clin Nucl Med. 2012 Oct;37(10):971–6. doi: 10.1097/RLU.0b013e318251e3d1. PMID: 22899197. Exclusion Code: X6.22899197
885 Lau YK, Caverly TJ, Cherng ST, . Development and validation of a personalized, web-based decision aid for lung cancer screening using mixed methods: a study protocol. JMIR Res Protoc. 2014 Dec 19;3(4):e78. doi: 10.2196/resprot.4039. PMID: 25532218. Exclusion Code: X5.25532218
886 Leader JK, Warfel TE, Fuhrman CR, . Pulmonary nodule detection with low-dose CT of the lung: agreement among radiologists. AJR Am J Roentgenol. 2005 Oct;185(4):973–8. doi: 10.2214/ajr.04.1225. PMID: 16177418. Exclusion Code: X11.16177418
887 Lee C. Screening for Lung Cancer: Effective Recruitment Methods. AJR Am J Roentgenol. 2018 Mar;210(3):514–7. doi: 10.2214/ajr.17.18755. PMID: 29261350. Exclusion Code: X8.29261350
888 Lee CT, Strauss DM, Stone LE, . Preoperative CHA2DS2-VASc Score Predicts Postoperative Atrial Fibrillation after Lobectomy. Thorac Cardiovasc Surg. 2019 Mar;67(2):125–30. doi: 10.1055/s-0038-1675638. PMID: 30485896. Exclusion Code: X3.30485896
889 Lee DS, Kim YS, Yoo Ie R, . Long-term clinical experience of high-dose ablative lung radiotherapy: high pre-treatment [18F]fluorodeoxyglucose-positron emission tomography maximal standardized uptake value of the primary tumor adversely affects treatment outcome. Lung Cancer. 2013 May;80(2):172–8. doi: 10.1016/j.lungcan.2012.12.023. PMID: 23489556. Exclusion Code: X3.23489556
890 Lee GD, Kim HC, Kim YE, . Value of cytologic analysis of bronchial washings in lung cancer on the basis of bronchoscopic appearance. Clin Respir J. 2013 Apr;7(2):128–34. doi: 10.1111/j.1752-699X.2012.00293.x. PMID: 22568634. Exclusion Code: X8.22568634
891 Lee H, Jeong SH, Jeong BH, . Incidence of brain metastasis at the initial diagnosis of lung squamous cell carcinoma on the basis of stage, excluding brain metastasis. J Thorac Oncol. 2016 Mar;11(3):426–31. doi: 10.1016/j.jtho.2015.11.007. PMID: 26746367. Exclusion Code: X3.26746367
892 Lee H, Jin GY, Han YM, . Comparison of survival rate in primary non-small-cell lung cancer among elderly patients treated with radiofrequency ablation, surgery, or chemotherapy. Cardiovasc Intervent Radiol. 2012 Apr;35(2):343–50. doi: 10.1007/s00270-011-0194-y. PMID: 21626257. Exclusion Code: X11.21626257
893 Lee HJ, Kim YT, Park PJ, . A novel detection method of non-small cell lung cancer using multiplexed bead-based serum biomarker profiling. J Thorac Cardiovasc Surg. 2012 Feb;143(2):421–7. doi: 10.1016/j.jtcvs.2011.10.046. PMID: 22104668. Exclusion Code: X5.22104668
894 Lee HN, Lee SM, Choe J, . Diagnostic performance of CT-guided percutaneous transthoracic core needle biopsy using low tube voltage (100 kVp): comparison with conventional tube voltage (120 kVp). Acta Radiol. 2018 Apr;59(4):425–33. doi: 10.1177/0284185117719589. PMID: 28691525. Exclusion Code: X3.28691525
895 Lee HY, Lee HY, Lee KS, . Reliability of small biopsy or cytology for the diagnosis of pulmonary mucinous adenocarcinoma. J Clin Pathol. 2014 Jul;67(7):587–91. doi: 10.1136/jclinpath-2013-202107. PMID: 24739466. Exclusion Code: X3.24739466
896 Lee J, Kim JI, Ye SJ, . Dosimetric effects of roll rotational setup errors on lung stereotactic ablative radiotherapy using volumetric modulated arc therapy. Br J Radiol. 2015;88(1055):20140862. doi: 10.1259/bjr.20140862. PMID: 26369834. Exclusion Code: X3.26369834
897 Lee JH, Park CM, Kim H, . Persistent part-solid nodules with solid part of 5 mm or smaller: Can the ‘follow-up and surgical resection after interval growth’ policy have a negative effect on patient prognosis? Eur Radiol. 2017 Jan;27(1):195–202. doi: 10.1007/s00330-016-4364-9. PMID: 27126519. Exclusion Code: X3.27126519
898 Lee JW, Kim EY, Kim DJ, . The diagnostic ability of (18)F-FDG PET/CT for mediastinal lymph node staging using (18)F-FDG uptake and volumetric CT histogram analysis in non-small cell lung cancer. Eur Radiol. 2016 Dec;26(12):4515–23. doi: 10.1007/s00330-016-4292-8. PMID: 26943133. Exclusion Code: X3.26943133
899 Lee K, Kim HO, Choi HK, . Real-world treatment patterns for patients 80 years and older with early lung cancer: a nationwide claims study. BMC Pulm Med. 2018 Aug 3;18(1):127. doi: 10.1186/s12890-018-0699-0. PMID: 30075770. Exclusion Code: X3.30075770
900 Lee K, Kim HR, Kim DK, . Post-recurrence survival analysis of stage I non-small-cell lung cancer. Asian Cardiovasc Thorac Ann. 2017 Nov;25(9):623–9. doi: 10.1177/0218492317737641. PMID: 29058973. Exclusion Code: X11.29058973
901 Lee KC, Yong HS, Lee J, . Is the epicardial adipose tissue area on non-ECG gated low-dose chest CT useful for predicting coronary atherosclerosis in an asymptomatic population considered for lung cancer screening? Eur Radiol. 2019 Feb;29(2):932–40. doi: 10.1007/s00330-018-5562-4. PMID: 29955949. Exclusion Code: X8.29955949
902 Lee KH, Lee KW, Park JH, . Nodule Classification on Low-Dose Unenhanced CT and Standard-Dose Enhanced CT: Inter-Protocol Agreement and Analysis of Interchangeability. Korean J Radiol. 2018 May-Jun;19(3):516–25. doi: 10.3348/kjr.2018.19.3.516. PMID: 29713230. Exclusion Code: X8.29713230
903 Lee PC, Kamel M, Nasar A, . Lobectomy for non-small cell lung cancer by video-assisted thoracic surgery: effects of cumulative institutional experience on adequacy of lymphadenectomy. Ann Thorac Surg. 2016 Mar;101(3):1116–22. doi: 10.1016/j.athoracsur.2015.09.073. PMID: 26654728. Exclusion Code: X8.26654728
904 Lee PC, Nasar A, Port JL, . Long-term survival after lobectomy for non-small cell lung cancer by video-assisted thoracic surgery versus thoracotomy. Ann Thorac Surg. 2013 Sep;96(3):951–60; discussion 60-1. doi: 10.1016/j.athoracsur.2013.04.104. PMID: 23866808. Exclusion Code: X11.23866808
905 Lee S, Lee JG, Lee CY, . Pulmonary fissure development is a prognostic factor for patients with resected stage I lung adenocarcinoma. J Surg Oncol. 2016 Dec;114(7):848–52. doi: 10.1002/jso.24438. PMID: 27633283. Exclusion Code: X11.27633283
906 Lee S, Stroian G, Kopek N, . Analytical modelling of regional radiotherapy dose response of lung. Phys Med Biol. 2012 Jun 7;57(11):3309–21. doi: 10.1088/0031-9155/57/11/3309. PMID: 22572393. Exclusion Code: X3.22572393
907 Lee SH, Park MJ, Choi SI, . Reactive oxygen species modulator 1 (Romo1) as a novel diagnostic marker for lung cancer-related malignant effusion. Medicine (Baltimore). 2017 Jan;96(4):e5975. doi: 10.1097/md.0000000000005975. PMID: 28121949. Exclusion Code: X3.28121949
908 Lee SH, Sung C, Lee HS, . Is (18)F-FDG PET/CT useful for the differential diagnosis of solitary pulmonary nodules in patients with idiopathic pulmonary fibrosis? Ann Nucl Med. 2018 Aug;32(7):492–8. doi: 10.1007/s12149-018-1273-9. PMID: 29974372. Exclusion Code: X8.29974372
909 Lee SM, Goo JM, Park CM, . Preoperative staging of non-small cell lung cancer: prospective comparison of PET/MR and PET/CT. Eur Radiol. 2016 Nov;26(11):3850–7. doi: 10.1007/s00330-016-4255-0. PMID: 26883332. Exclusion Code: X3.26883332
910 Lee SM, Park CM, Paeng JC, . Accuracy and predictive features of FDG-PET/CT and CT for diagnosis of lymph node metastasis of T1 non-small-cell lung cancer manifesting as a subsolid nodule. Eur Radiol. 2012 Jul;22(7):1556–63. doi: 10.1007/s00330-012-2395-4. PMID: 22358427. Exclusion Code: X8.22358427
911 Lee SM, Park CM, Song YS, . CT assessment-based direct surgical resection of part-solid nodules with solid component larger than 5 mm without preoperative biopsy: experience at a single tertiary hospital. Eur Radiol. 2017 Dec;27(12):5119–26. doi: 10.1007/s00330-017-4917-6. PMID: 28656460. Exclusion Code: X11.28656460
912 Lee SU, Moon SH, Cho KH, . Ablative dose proton beam therapy for stage I and recurrent non-small cell lung carcinomas : Ablative dose PBT for NSCLC. Strahlenther Onkol. 2016 Sep;192(9):649–57. doi: 10.1007/s00066-016-0985-9. PMID: 27282279. Exclusion Code: X6.27282279
913 Lee SY, Hong MJ, Jeon HS, . Functional intronic ERCC1 polymorphism from regulomeDB can predict survival in lung cancer after surgery. Oncotarget. 2015 Sep 15;6(27):24522–32. doi: 10.18632/oncotarget.4083. PMID: 26056042. Exclusion Code: X17.26056042
914 Lee T, Park JY, Lee HY, . Lung cancer in patients with idiopathic pulmonary fibrosis: clinical characteristics and impact on survival. Respir Med. 2014 Oct;108(10):1549–55. doi: 10.1016/j.rmed.2014.07.020. PMID: 25175479. Exclusion Code: X6.25175479
915 Lee YJ, Choi SM, Lee J, . Utility of the National Lung Screening Trial Criteria for Estimation of Lung Cancer in the Korean Population. Cancer Res Treat. 2018 Jul;50(3):950–5. doi: 10.4143/crt.2017.357. PMID: 29025257. Exclusion Code: X10.29025257
916 Leeman JE, Rimner A, Montecalvo J, . Histologic subtype in core lung biopsies of early-stage lung adenocarcinoma is a prognostic factor for treatment response and failure patterns after stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 2017 Jan 1;97(1):138–45. doi: 10.1016/j.ijrobp.2016.09.037. PMID: 27839909. Exclusion Code: X10.27839909
917 Lemonnier I, Guillemin F, Arveux P, . Quality of life after the initial treatments of non-small cell lung cancer: a persistent predictor for patients’ survival. Health Qual Life Outcomes. 2014 May 15;12:73. doi: 10.1186/1477-7525-12-73. PMID: 24884836. Exclusion Code: X3.24884836
918 Leng S, Liu Y, Weissfeld JL, . 15q12 variants, sputum gene promoter hypermethylation, and lung cancer risk: a GWAS in smokers. J Natl Cancer Inst. 2015 Feb 23;107(5) doi: 10.1093/jnci/djv035. PMID: 25713168. Exclusion Code: X5.25713168
919 Lenglet A, Campeau MP, Mathieu D, . Risk-adapted stereotactic ablative radiotherapy for central and ultra-central lung tumours. Radiother Oncol. 2019 May;134:178–84. doi: 10.1016/j.radonc.2019.01.035. PMID: 31005213. Exclusion Code: X3.31005213
920 Leong P, Deshpande S, Irving LB, . Endoscopic ultrasound fine-needle aspiration by experienced pulmonologists: a cusum analysis. Eur Respir J. 2017 Nov;50(5)doi: 10.1183/13993003.01102-2017. PMID: 29097432. Exclusion Code: X3.29097432
921 Leroy S, Benzaquen J, Mazzetta A, . Circulating tumour cells as a potential screening tool for lung cancer (the AIR study): protocol of a prospective multicentre cohort study in France. BMJ Open. 2017 Dec 26;7(12):e018884. doi: 10.1136/bmjopen-2017-018884. PMID: 29282271. Exclusion Code: X10.29282271
922 Levine ME, Hosgood HD, Chen B, . DNA methylation age of blood predicts future onset of lung cancer in the women’s health initiative. Aging (Albany NY). 2015 Sep;7(9):690–700. doi: 10.18632/aging.100809. PMID: 26411804. Exclusion Code: X7.26411804
923 Lewin G, Morissette K, Dickinson J, . Recommendations on screening for lung cancer. CMAJ. 2016 Apr 05;188(6):425–32. doi: 10.1503/cmaj.151421. PMID: 26952527. Exclusion Code: X10.26952527
924 Li B, Chen K, Tian L, . Detection of pulmonary nodules in CT images based on fuzzy integrated active contour model and hybrid parametric mixture model. Comput Math Methods Med. 2013;2013:515386. doi: 10.1155/2013/515386. PMID: 23690876. Exclusion Code: X3.23690876
925 Li C, Liu B, Meng H, . Efficacy and Radiation Exposure of Ultra-Low-Dose Chest CT at 100 kVp with Tin Filtration in CT-Guided Percutaneous Core Needle Biopsy for Small Pulmonary Lesions Using a Third-Generation Dual-Source CT Scanner. J Vasc Interv Radiol. 2019 Jan;30(1):95–102. doi: 10.1016/j.jvir.2018.06.013. PMID: 30149997. Exclusion Code: X11.30149997
926 Li CC, Matthews AK, Rywant MM, . Racial disparities in eligibility for low-dose computed tomography lung cancer screening among older adults with a history of smoking. Cancer Causes Control. 2019 Mar;30(3):235–40. doi: 10.1007/s10552-018-1092-2. PMID: 30377905. Exclusion Code: X8.30377905
927 Li D, Li F, Wu Y, . Quantification of serum MET in non-small-cell lung cancer and its clinical significance. Clin Biochem. 2015 Feb;48(3):110–4. doi: 10.1016/j.clinbiochem.2014.11.021. PMID: 25489726. Exclusion Code: X3.25489726
928 Li D, Zhu G, Di H, . Associations between genetic variants located in mature microRNAs and risk of lung cancer. Oncotarget. 2016 Jul 5;7(27):41715–24. doi: 10.18632/oncotarget.9566. PMID: 27232940. Exclusion Code: X3.27232940
929 Li F, Arimura H, Suzuki K, . Computer-aided detection of peripheral lung cancers missed at CT: ROC analyses without and with localization. Radiology. 2005 Nov;237(2):684–90. doi: 10.1148/radiol.2372041555. PMID: 16244277. Exclusion Code: X3.16244277
930 Li F, Li Q, Engelmann R, . Improving radiologists’ recommendations with computer-aided diagnosis for management of small nodules detected by CT. Acad Radiol. 2006 Aug;13(8):943–50. doi: 10.1016/j.acra.2006.04.010. PMID: 16843846. Exclusion Code: X3.16843846
931 Li GC, Fu YF, Cao W, . Computed tomography-guided percutaneous cutting needle biopsy for small (</= 20 mm) lung nodules. Medicine (Baltimore). 2017 Nov;96(46):e8703. doi: 10.1097/md.0000000000008703. PMID: 29145307. Exclusion Code: X3.29145307
932 Li H, Wang R, Zhang D, . Lymph node metastasis outside of a tumor-bearing lobe in primary lung cancer and the status of interlobar fissures: The necessity for removing lymph nodes from an adjacent lobe. Medicine (Baltimore). 2019 Mar;98(12):e14800. doi: 10.1097/md.0000000000014800. PMID: 30896623. Exclusion Code: X3.30896623
933 Li K, Husing A, Sookthai D, . Selecting high-risk individuals for lung cancer screening: a prospective evaluation of existing risk models and eligibility criteria in the German EPIC Cohort. Cancer Prev Res (Phila). 2015 Sep;8(9):777–85. doi: 10.1158/1940-6207.capr-14-0424. PMID: 26076698. Exclusion Code: X17.26076698
934 Li M, Yang D, Brock G, . Breath carbonyl compounds as biomarkers of lung cancer. Lung Cancer. 2015 Oct;90(1):92–7. doi: 10.1016/j.lungcan.2015.07.005. PMID: 26233567. Exclusion Code: X4.26233567
935 Li N, Xu M, Cai MY, . Elevated serum bilirubin levels are associated with improved survival in patients with curatively resected non-small-cell lung cancer. Cancer Epidemiol. 2015 Oct;39(5):763–8. doi: 10.1016/j.canep.2015.06.007. PMID: 26159684. Exclusion Code: X3.26159684
936 Li Q, Balagurunathan Y, Liu Y, . Comparison Between Radiological Semantic Features and Lung-RADS in Predicting Malignancy of Screen-Detected Lung Nodules in the National Lung Screening Trial. Clin Lung Cancer. 2018 Mar;19(2):148–56.e3. doi: 10.1016/j.cllc.2017.10.002. PMID: 29137847. Exclusion Code: X11.29137847
937 Li Q, Fan L, Cao ET, . Quantitative CT analysis of pulmonary pure ground-glass nodule predicts histological invasiveness. Eur J Radiol. 2017 Apr;89:67–71. doi: 10.1016/j.ejrad.2017.01.024. PMID: 28267551. Exclusion Code: X3.28267551
938 Li Q, Kim J, Balagurunathan Y, . CT imaging features associated with recurrence in non-small cell lung cancer patients after stereotactic body radiotherapy. Radiat Oncol. 2017 Sep 25;12(1):158. doi: 10.1186/s13014-017-0892-y. PMID: 28946909. Exclusion Code: X10.28946909
939 Li R, Zhang Y, Yuan Y, . Dosimetric comparison of CT-guided iodine-125 seed stereotactic brachytherapy and stereotactic body radiation therapy in the treatment of NSCLC. PLoS One. 2017;12(11):e0187390. doi: 10.1371/journal.pone.0187390. PMID: 29121047. Exclusion Code: X3.29121047
940 Li S, Chai H, Huang J, . Hybrid video-assisted thoracic surgery with segmental-main bronchial sleeve resection for non-small cell lung cancer. Surg Innov. 2014 Apr;21(2):180–6. doi: 10.1177/1553350613492026. PMID: 23793576. Exclusion Code: X3.23793576
941 Li S, Wang Z, Huang J, . Systematic review of prognostic roles of body mass index for patients undergoing lung cancer surgery: does the ‘obesity paradox’ really exist? Eur J Cardiothorac Surg. 2017 May 1;51(5):817–28. doi: 10.1093/ejcts/ezw386. PMID: 28040677. Exclusion Code: X9.28040677
942 Li S, Yang N, Li B, . A pilot study using kernelled support tensor machine for distant failure prediction in lung SBRT. Med Image Anal. 2018 Dec;50:106–16. doi: 10.1016/j.media.2018.09.004. PMID: 30266009. Exclusion Code: X6.30266009
943 Li S, Zhao B, Wang X, . Overestimated value of (18)F-FDG PET/CT to diagnose pulmonary nodules: analysis of 298 patients. Clin Radiol. 2014 Aug;69(8):e352–7. doi: 10.1016/j.crad.2014.04.007. PMID: 24877581. Exclusion Code: X3.24877581
944 Li S, Zheng Q, Ma Y, . Implications of false negative and false positive diagnosis in lymph node staging of NSCLC by means of (1)(8)F-FDG PET/CT. PLoS One. 2013;8(10):e78552. doi: 10.1371/journal.pone.0078552. PMID: 24205256. Exclusion Code: X3.24205256
945 Li S, Zhou K, Du H, . Body surface area is a novel predictor for surgical complications following video-assisted thoracoscopic surgery for lung adenocarcinoma: a retrospective cohort study. BMC Surg. 2017 Jun 12;17(1):69. doi: 10.1186/s12893-017-0264-4. PMID: 28606134. Exclusion Code: X3.28606134
946 Li S, Zhou K, Wang M, . Degree of pulmonary fissure completeness can predict postoperative cardiopulmonary complications and length of hospital stay in patients undergoing video-assisted thoracoscopic lobectomy for early-stage lung cancer. Interact Cardiovasc Thorac Surg. 2018 Jan 1;26(1):25–33. doi: 10.1093/icvts/ivx261. PMID: 29049746. Exclusion Code: X3.29049746
947 Li X, Asmitananda T, Gao L, . Biomarkers in the lung cancer diagnosis: a clinical perspective. Neoplasma. 2012;59(5):500–7. doi: 10.4149/neo_2012_064. PMID: 22668014. Exclusion Code: X5.22668014
948 Li X, Qin S, Sun X, . Prognostic Significance of Albumin-Globulin Score in Patients with Operable Non-Small-Cell Lung Cancer. Ann Surg Oncol. 2018 Nov;25(12):3647–59. doi: 10.1245/s10434-018-6715-z. PMID: 30229416. Exclusion Code: X3.30229416
949 Li X, Zhou C, Hu W. Association between serum angiotensin-converting enzyme 2 level with postoperative morbidity and mortality after major pulmonary resection in non-small cell lung cancer patients. Heart Lung Circ. 2014 Jul;23(7):661–6. doi: 10.1016/j.hlc.2013.12.013. PMID: 24636159. Exclusion Code: X3.24636159
950 Li XC, Wang W, Liu JQ, . Different limited resection of pulmonary lobe methods under the thoracoscopy in the treatment of early nonsmall cell lung cancer occurred in the old age. Indian J Cancer. 2015 Feb;51: Suppl 2:e29–32. doi: 10.4103/0019-509x.151995. PMID: 25712838. Exclusion Code: X3.25712838
951 Li XJ, Wu QF, He DL, . Proteomic profiling of serum from stage I lung squamous cell carcinoma patients. Asian Pac J Cancer Prev. 2013;14(4):2273–6. PMID: 23725126. Exclusion Code: X3.23725126
952 Li XQ, Zhang Y, Huang DB, . Value of C-arm computed tomography in radiofrequency ablation of small lung lesions. Genet Mol Res. 2014 Aug 7;13(3):6027–36. doi: 10.4238/2014.August.7.17. PMID: 25117360. Exclusion Code: X6.25117360
953 Li Y, Dykstra M, Best TD, . Differential inflammatory response dynamics in normal lung following stereotactic body radiation therapy with protons versus photons. Radiother Oncol. 2019 Apr 20;136:169–75. doi: 10.1016/j.radonc.2019.04.004. PMID: 31015121. Exclusion Code: X8.31015121
954 Li Z, Ye B, Bao M, . Radiologic predictors for clinical stage IA lung adenocarcinoma with ground glass components: a multi-center study of long-term outcomes. PLoS One. 2015;10(9):e0136616. doi: 10.1371/journal.pone.0136616. PMID: 26339917. Exclusion Code: X11.26339917
955 Liang M, Tang W, Xu DM, . Low-dose CT screening for lung cancer: computer-aided detection of missed lung cancers. Radiology. 2016 Oct;281(1):279–88. doi: 10.1148/radiol.2016150063. PMID: 27019363. Exclusion Code: X10.27019363
956 Liao C, Chen J, Liang J, . Meta-analysis study of lymph node staging by 18 F-FDG PET/CT scan in non-small cell lung cancer: comparison of TB and non-TB endemic regions (Provisional abstract). Eur J Radiol. 2012;81(11):3518–23. PMID: DARE-12012047008. Exclusion Code: X3.22436434
957 Lievens Y, Obyn C, Mertens AS, . Stereotactic body radiotherapy for lung cancer: how much does it really cost? J Thorac Oncol. 2015 Mar;10(3):454–61. doi: 10.1097/jto.0000000000000421. PMID: 25376514. Exclusion Code: X8.25376514
958 Ligor T, Pater L, Buszewski B. Application of an artificial neural network model for selection of potential lung cancer biomarkers. J Breath Res. 2015 May 6;9(2):027106. doi: 10.1088/1752-7155/9/2/027106. PMID: 25944812. Exclusion Code: X5.25944812
959 Lin CC, Smeltzer MP, Jemal A, . Risk-adjusted margin positivity rate as a surgical quality metric for non-small cell lung cancer. Ann Thorac Surg. 2017 Oct;104(4):1161–70. doi: 10.1016/j.athoracsur.2017.04.033. PMID: 28709665. Exclusion Code: X8.28709665
960 Lin KF, Wu HF, Huang WC, . Propensity score analysis of lung cancer risk in a population with high prevalence of non-smoking related lung cancer. BMC Pulm Med. 2017 Sep 6;17(1):120. doi: 10.1186/s12890-017-0465-8. PMID: 28874145. Exclusion Code: X10.28874145
961 Lin KH, Lee RC, Liu RS, . The prognostic value of tumor shadow disappearance rate on integrated PET/CT evaluation of solitary pulmonary nodules with low glucose metabolism. Nucl Med Commun. 2016 Apr;37(4):356–62. doi: 10.1097/mnm.0000000000000446. PMID: 26796032. Exclusion Code: X8.26796032
962 Lin L, Hu D, Zhong C, . Safety and efficacy of thoracoscopic wedge resection for elderly high-risk patients with stage I peripheral non-small-cell lung cancer. J Cardiothorac Surg. 2013 Dec 21;8:231. doi: 10.1186/1749-8090-8-231. PMID: 24359930. Exclusion Code: X3.24359930
963 Lin Y, Lin WY, Kao CH, . Prognostic value of preoperative metabolic tumor volumes on PET-CT in predicting disease-free survival of patients with stage I non-small cell lung cancer. Anticancer Res. 2012 Nov;32(11):5087–91. PMID: 23155285. Exclusion Code: X11.23155285
964 Linden PA, D’Amico TA, Perry Y, . Quantifying the safety benefits of wedge resection: a society of thoracic surgery database propensity-matched analysis. Ann Thorac Surg. 2014 Nov;98(5):1705–11; discussion 11-2. doi: 10.1016/j.athoracsur.2014.06.017. PMID: 25201723. Exclusion Code: X3.25201723
965 Little MW, Chung D, Boardman P, . Microwave ablation of pulmonary malignancies using a novel high-energy antenna system. Cardiovasc Intervent Radiol. 2013 Apr;36(2):460–5. doi: 10.1007/s00270-012-0465-2. PMID: 22968596. Exclusion Code: X6.22968596
966 Liu B, Tang Y, Yi M, . Genetic variants in the plasminogen activator inhibitor-1 gene are associated with an increased risk of radiation pneumonitis in lung cancer patients. Cancer Med. 2017 Mar;6(3):681–8. doi: 10.1002/cam4.1011. PMID: 28211612. Exclusion Code: X6.28211612
967 Liu BJ, Dong JC, Xu CQ, . Accuracy of 18F-FDG PET/CT for lymph node staging in non-small-cell lung cancers. Chin Med J (Engl). 2009 Aug 5;122(15):1749–54. PMID: 19781319. Exclusion Code: X3.19781319
968 Liu H, Sintay B, Pearman K, . A hybrid planning strategy for stereotactic body radiation therapy of early stage non-small-cell lung cancer. J Appl Clin Med Phys. 2018 Nov;19(6):117–23. doi: 10.1002/acm2.12450. PMID: 30281198. Exclusion Code: X8.30281198
969 Liu H, Ye J, Kim JJ, . Dosimetric comparison of two arc-based stereotactic body radiotherapy techniques for early-stage lung cancer. Med Dosim. 2015 Spring;40(1):76–81. doi: 10.1016/j.meddos.2014.10.004. PMID: 25499078. Exclusion Code: X10.25499078
970 Liu HC, Huang WC, Wu CL, . Surgery for elderly lung cancer. Ann Thorac Cardiovasc Surg. 2013;19(6):416–22. PMID: 23445805. Exclusion Code: X11.23445805
971 Liu J, Mazzone PJ, Cata JP, . Serum free fatty acid biomarkers of lung cancer. Chest. 2014 Sep;146(3):670–9. doi: 10.1378/chest.13-2568. PMID: 24743744. Exclusion Code: X3.24743744
972 Liu L, Zhang LJ, Chen B, . Novel CT-guided coil localization of peripheral pulmonary nodules prior to video-assisted thoracoscopic surgery: a pilot study. Acta Radiol. 2014 Jul;55(6):699–706. doi: 10.1177/0284185113506136. PMID: 24078457. Exclusion Code: X3.24078457
973 Liu M, Huang J, Xu Y, . MR-guided percutaneous biopsy of solitary pulmonary lesions using a 1.0-T open high-field MRI scanner with respiratory gating. Eur Radiol. 2017 Apr;27(4):1459–66. doi: 10.1007/s00330-016-4518-9. PMID: 27516355. Exclusion Code: X3.27516355
974 Liu M, Wampfler JA, Dai J, . Chest wall resection for non-small cell lung cancer: a case-matched study of postoperative pulmonary function and quality of life. Lung Cancer. 2017 Apr;106:37–41. doi: 10.1016/j.lungcan.2017.01.014. PMID: 28285692. Exclusion Code: X3.28285692
975 Liu S, Li C, Yu X, . Diagnostic accuracy of MRI-guided percutaneous transthoracic needle biopsy of solitary pulmonary nodules. Cardiovasc Intervent Radiol. 2015 Apr;38(2):416–21. doi: 10.1007/s00270-014-0915-0. PMID: 24873920. Exclusion Code: X3.24873920
976 Liu S, Ren R, Liu M, . MR imaging-guided percutaneous cryotherapy for lung tumors: initial experience. J Vasc Interv Radiol. 2014 Sep;25(9):1456–62. doi: 10.1016/j.jvir.2014.04.025. PMID: 24985720. Exclusion Code: X6.24985720
977 Liu Y, Tang Y, Xue Z, . Ratio of lymph node to primary tumor SUVmax multiplied by maximal tumor diameter on positron emission tomography/integrated computed tomography may be a predictor of mediastinal lymph node malignancy in lung cancer. Medicine (Baltimore). 2016 Nov;95(46):e5457. doi: 10.1097/md.0000000000005457. PMID: 27861398. Exclusion Code: X3.27861398
978 Liu Y, Wang H, Li Q, . Radiologic features of small pulmonary nodules and lung cancer risk in the national lung screening trial: a nested case-control study. Radiology. 2018 Jan;286(1):298–306. doi: 10.1148/radiol.2017161458. PMID: 28837413. Exclusion Code: X11.28837413
979 Lococo F, Cesario A, Attili F, . Transoesophageal endoscopic ultrasound-guided fine-needle aspiration of pleural effusion for the staging of non-small cell lung cancer. Interact Cardiovasc Thorac Surg. 2013 Aug;17(2):237–41. doi: 10.1093/icvts/ivt166. PMID: 23615434. Exclusion Code: X11.23615434
980 Lococo F, Galeone C, Formisano D, . 18F-fluorodeoxyglucose positron emission tomographic scan in solid-type p-stage-I pulmonary adenocarcinomas: what can produce false-negative results? Eur J Cardiothorac Surg. 2017 Apr 1;51(4):667–73. doi: 10.1093/ejcts/ezw394. PMID: 28043987. Exclusion Code: X3.28043987
981 Loh SE, Wu DD, Venkatesh SK, . CT-guided thoracic biopsy: evaluating diagnostic yield and complications. Ann Acad Med Singapore. 2013 Jun;42(6):285–90. PMID: 23842769. Exclusion Code: X3.23842769
982 Loo FL, Halligan AM, Port JL, . The emerging technique of electromagnetic navigation bronchoscopy-guided fine-needle aspiration of peripheral lung lesions: promising results in 50 lesions. Cancer Cytopathol. 2014 Mar;122(3):191–9. doi: 10.1002/cncy.21373. PMID: 24323803. Exclusion Code: X3.24323803
983 Lopatin S, Tsay JC, Addrizzo-Harris D, . Reduced lung function in smokers in a lung cancer screening cohort with asbestos exposure and pleural plaques. Am J Ind Med. 2016 Mar;59(3):178–85. doi: 10.1002/ajim.22571. PMID: 26815630. Exclusion Code: X8.26815630
984 Lopez Hanninen E, Vogl TJ, Ricke J, . CT-guided percutaneous core biopsies of pulmonary lesions. Diagnostic accuracy, complications and therapeutic impact. Acta Radiol. 2001 Mar;42(2):151–5. PMID: 11259941. Exclusion Code: X3.11259941
985 Lopez-Padilla D, Peghini Gavilanes E, Revilla Ostolaza TY, . Arterial stump thrombosis after lung resection surgery: clinical presentation, treatment and progress. Arch Bronconeumol. 2016 Oct;52(10):512–8. doi: 10.1016/j.arbres.2016.02.009. PMID: 27156986. Exclusion Code: X3.27156986
986 Lorenz J. Not available. Zentralbl Chir. 2016;141(1):11–2. PMID: CN-01263663. Exclusion Code: X1.27336082
987 Lou F, Huang J, Sima CS, . Patterns of recurrence and second primary lung cancer in early-stage lung cancer survivors followed with routine computed tomography surveillance. J Thorac Cardiovasc Surg. 2013 Jan;145(1):75–81; discussion -2. doi: 10.1016/j.jtcvs.2012.09.030. PMID: 23127371. Exclusion Code: X3.23127371
988 Louie A, Chen H, Werkhoven EV, . Caro elekta quality of life following stereotactic ablative radiotherapy for early stage lung cancer: results from the rosel randomized controlled trial and a systematic review. Radiother Oncol. 2016;120:S57–S8. PMID: CN-01252401. Exclusion Code: X2.
989 Louie A, Werkhoven E, Chen H, . Patient reported outcomes following stereotactic ablative radiotherapy or surgery for stage IA non-small-cell lung cancer: results from the ROSEL multicenter randomized trial. Radiother Oncol. 2015;117(1):44–8. doi: 10.1016/j.radonc.2015.08.011. PMID: CN-01105560. Exclusion Code: X8.26492839
990 Louie AV, Senan S, Dahele M, . Stereotactic ablative radiation therapy for subcentimeter lung tumors: clinical, dosimetric, and image guidance considerations. Int J Radiat Oncol Biol Phys. 2014 Nov 15;90(4):843–9. doi: 10.1016/j.ijrobp.2014.06.064. PMID: 25585783. Exclusion Code: X3.25585783
991 Louie BE, Farivar AS, Aye RW, . Early experience with robotic lung resection results in similar operative outcomes and morbidity when compared with matched video-assisted thoracoscopic surgery cases. Ann Thorac Surg. 2012 May;93(5):1598–604; discussion 604-5. doi: 10.1016/j.athoracsur.2012.01.067. PMID: 22440364. Exclusion Code: X3.22440364
992 Louis E, Adriaensens P, Guedens W, . Detection of lung cancer through metabolic changes measured in blood plasma. J Thorac Oncol. 2016 Apr;11(4):516–23. doi: 10.1016/j.jtho.2016.01.011. PMID: 26949046. Exclusion Code: X5.26949046
993 Lovinfosse P, Janvary ZL, Coucke P, . FDG PET/CT texture analysis for predicting the outcome of lung cancer treated by stereotactic body radiation therapy. Eur J Nucl Med Mol Imaging. 2016 Jul;43(8):1453–60. doi: 10.1007/s00259-016-3314-8. PMID: 26830299. Exclusion Code: X13.26830299
994 Lu MS, Chen MF, Lin CC, . Is chronic kidney disease an adverse factor in lung cancer clinical outcome? A propensity score matching study. Thorac Cancer. 2017 Mar;8(2):106–13. doi: 10.1111/1759-7714.12414. PMID: 28207203. Exclusion Code: X11.28207203
995 Lu Q, Cao W, Huang L, . CT-guided percutaneous microwave ablation of pulmonary malignancies: Results in 69 cases. World J Surg Oncol. 2012 May 7;10:80. doi: 10.1186/1477-7819-10-80. PMID: 22564777. Exclusion Code: X6.22564777
996 Lucas JT, Jr., Kuremsky JG, Soike M, . Comparison of accelerated hypofractionation and stereotactic body radiotherapy for Stage 1 and node negative Stage 2 non-small cell lung cancer (NSCLC). Lung Cancer. 2014 Jul;85(1):59–65. doi: 10.1016/j.lungcan.2014.04.003. PMID: 24813936. Exclusion Code: X10.24813936
997 Lucchiari C, Masiero M, Veronesi G, . Benefits of E-Cigarettes Among Heavy Smokers Undergoing a Lung Cancer Screening Program: randomized Controlled Trial Protocol. JMIR res protoc. 2016;5(1):e21. doi: 10.2196/resprot.4805. PMID: CN-01616880. Exclusion Code: X6.26842790
998 Luchtenborg M, Jakobsen E, Krasnik M, . The effect of comorbidity on stage-specific survival in resected non-small cell lung cancer patients. Eur J Cancer. 2012 Dec;48(18):3386–95. doi: 10.1016/j.ejca.2012.06.012. PMID: 22795582. Exclusion Code: X3.22795582
999 Luciano G, Stella F, Dell’Amore A, . Tracheo-bronchoplastic procedures for NSCLC: single-centre experience. Heart Lung Circ. 2015 Oct;24(10):1027–32. doi: 10.1016/j.hlc.2015.04.065. PMID: 25991393. Exclusion Code: X3.25991393
1000 Lugg ST, Agostini PJ, Tikka T, . Long-term impact of developing a postoperative pulmonary complication after lung surgery. Thorax. 2016 Feb;71(2):171–6. doi: 10.1136/thoraxjnl-2015-207697. PMID: 26769017. Exclusion Code: X3.26769017
1001 Lugg ST, Tikka T, Agostini PJ, . Smoking and timing of cessation on postoperative pulmonary complications after curative-intent lung cancer surgery. J Cardiothorac Surg. 2017 Jun 19;12(1):52. doi: 10.1186/s13019-017-0614-4. PMID: 28629433. Exclusion Code: X3.28629433
1002 Luo J, Huang Q, Wang R, . Prognostic and predictive value of the novel classification of lung adenocarcinoma in patients with stage IB. J Cancer Res Clin Oncol. 2016 Sep;142(9):2031–40. doi: 10.1007/s00432-016-2192-6. PMID: 27379889. Exclusion Code: X10.27379889
1003 Luo QQ, Lin H, Tan Q, . Analysis of clinical application of thoracoscopic lobectomy for lung cancer. World J Surg Oncol. 2014 May 21;12:157. doi: 10.1186/1477-7819-12-157. PMID: 24886331. Exclusion Code: X3.24886331
1004 Luzzi L, Marulli G, A DEP, . Prognostic factors and clinical outcome in patients with surgically resected peripheral N0 adenocarcinoma <3 cm. Minerva Chir. 2016 Feb;71(1):1–7. PMID: 26149520. Exclusion Code: X11.26149520
1005 Lyne C, Zaw S, King B, . Low rates of eligibility for lung cancer screening in patients undergoing computed tomography coronary angiography. Intern Med J. 2018 Oct;48(10):1265–8. doi: 10.1111/imj.14061. PMID: 30288901. Exclusion Code: X5.30288901
1006 MA IJ, Shoni M, Siegert C, . Survival After Stereotactic Body Radiation Therapy for Clinically Diagnosed or Biopsy-Proven Early-Stage NSCLC: A Systematic Review and Meta-Analysis. J Thorac Oncol. 2019 Apr;14(4):583–95. doi: 10.1016/j.jtho.2018.12.035. PMID: 30721798. Exclusion Code: X9.30721798
1007 Ma KF, Chu XY, Liu Y. Clinical significance of lymphatic vessel invasion in stage I non-small cell lung cancer patients. Genet Mol Res. 2015 Mar 13;14(1):1819–27. doi: 10.4238/2015.March.13.10. PMID: 25867327. Exclusion Code: X11.25867327
1008 Ma S, Wang W, Xia B, . Multiplexed serum biomarkers for the detection of lung cancer. EBioMedicine. 2016 Sep;11:210–8. doi: 10.1016/j.ebiom.2016.08.018. PMID: 27575387. Exclusion Code: X5.27575387
1009 Ma SJ, Cummings M, Serra LM, . Three- versus five-fraction regimens of stereotactic body radiotherapy for peripheral early-stage non-small-cell lung cancer: a two-institution propensity score-matched analysis. Clin Lung Cancer. 2018 May;19(3):e297–e302. doi: 10.1016/j.cllc.2017.11.007. PMID: 29254649. Exclusion Code: X10.29254649
1010 Macdonald IK, Murray A, Healey GF, . Application of a high throughput method of biomarker discovery to improvement of the EarlyCDT((R))-Lung Test. PLoS One. 2012;7(12):e51002. doi: 10.1371/journal.pone.0051002. PMID: 23272083. Exclusion Code: X5.23272083
1011 Macke RA, Schuchert MJ, Odell DD, . Parenchymal preserving anatomic resections result in less pulmonary function loss in patients with Stage I non-small cell lung cancer. J Cardiothorac Surg. 2015 Apr 1;10:49. doi: 10.1186/s13019-015-0253-6. PMID: 25888465. Exclusion Code: X11.25888465
1012 Maclay JD, Farley JM, McCowan C, . Obtaining tissue diagnosis in lung cancer patients with poor performance status and its influence on treatment and survival. Respir Med. 2017 Mar;124:30–5. doi: 10.1016/j.rmed.2017.01.002. PMID: 28284318. Exclusion Code: X3.28284318
1013 Macpherson R, Benamore R, Panakis N, . A proposed new imaging pathway for patients with suspected lung cancer. Clin Radiol. 2012 Jun;67(6):564–73. doi: 10.1016/j.crad.2011.10.032. PMID: 22300820. Exclusion Code: X5.22300820
1014 Macpherson RE, Higgins GS, Murchison JT, . Non-small-cell lung cancer dimensions: CT-pathological correlation and interobserver variation. Br J Radiol. 2009 May;82(977):421–5. doi: 10.1259/bjr/28687035. PMID: 19153186. Exclusion Code: X3.19153186
1015 MacRedmond R, McVey G, Lee M, . Screening for lung cancer using low dose CT scanning: results of 2 year follow up. Thorax. 2006 Jan;61(1):54–6. doi: 10.1136/thx.2004.037580. PMID: 16396954. Exclusion Code: X11.16396954
1016 Maebayashi T, Ishibashi N, Aizawa T, . Significance of stereotactic body radiotherapy in older patients with early stage non-small cell lung cancer. J Geriatr Oncol. 2018 Mar 21doi: 10.1016/j.jgo.2018.03.005. PMID: 29573969. Exclusion Code: X10.29573969
1017 Maeda H, Kanzaki M, Sakamoto K, . Effect of collagen vascular disease-associated interstitial lung disease on the outcomes of lung cancer surgery. Surg Today. 2017 Sep;47(9):1072–9. doi: 10.1007/s00595-017-1476-z. PMID: 28247107. Exclusion Code: X3.28247107
1018 Mahieu J, Rinieri P, Bubenheim M, . Robot-assisted thoracoscopic surgery versus video-assisted thoracoscopic surgery for lung lobectomy: can a robotic approach improve short-term outcomes and operative safety? Thorac Cardiovasc Surg. 2016 Jun;64(4):354–62. doi: 10.1055/s-0035-1548733. PMID: 25866978. Exclusion Code: X3.25866978
1019 Mahmood S, Bilal H, Faivre-Finn C, . Is stereotactic ablative radiotherapy equivalent to sublobar resection in high-risk surgical patients with stage I non-small-cell lung cancer? Interact Cardiovasc Thorac Surg. 2013 Nov;17(5):845–53. doi: 10.1093/icvts/ivt262. PMID: 23900381. Exclusion Code: X9.23900381
1020 Maisonneuve P, Bagnardi V, Bellomi M, . Lung cancer risk prediction to select smokers for screening CT--a model based on the Italian COSMOS trial. Cancer Prev Res (Phila). 2011 Nov;4(11):1778–89. doi: 10.1158/1940-6207.CAPR-11-0026. PMID: 21813406. Exclusion Code: X7.21813406
1021 Mak RH, Hermann G, Lewis JH, . Outcomes by tumor histology and KRAS mutation status after lung stereotactic body radiation therapy for early-stage non-small-cell lung cancer. Clin Lung Cancer. 2015 Jan;16(1):24–32. doi: 10.1016/j.cllc.2014.09.005. PMID: 25450872. Exclusion Code: X13.25450872
1022 Maki Y, Toyooka S, Soh J, . Early postoperative complications after middle lobe-preserving surgery for secondary lung cancer. Surg Today. 2017 May;47(5):601–5. doi: 10.1007/s00595-016-1413-6. PMID: 27629155. Exclusion Code: X10.27629155
1023 Makinson A, Eymard-Duvernay S, Raffi F, . Feasibility and efficacy of early lung cancer diagnosis with chest computed tomography in HIV-infected smokers. AIDS. 2016 Feb 20;30(4):573–82. doi: 10.1097/qad.0000000000000943. PMID: 26829006. Exclusion Code: X3.26829006
1024 Maldonado F, Boland JM, Raghunath S, . Noninvasive characterization of the histopathologic features of pulmonary nodules of the lung adenocarcinoma spectrum using computer-aided nodule assessment and risk yield (CANARY)--a pilot study. J Thorac Oncol. 2013 Apr;8(4):452–60. doi: 10.1097/JTO.0b013e3182843721. PMID: 23486265. Exclusion Code: X10.23486265
1025 Maldonado F, Duan F, Raghunath SM, . Noninvasive computed tomography-based risk stratification of lung adenocarcinomas in the National Lung Screening Trial. Am J Respir Crit Care Med. 2015 Sep 15;192(6):737–44. doi: 10.1164/rccm.201503-0443OC. PMID: 26052977. Exclusion Code: X3.26052977
1026 Malhotra J, Mhango G, Gomez JE, . Adjuvant chemotherapy for elderly patients with stage I non-small-cell lung cancer >/=4 cm in size: an SEER-Medicare analysis. Ann Oncol. 2015 Apr;26(4):768–73. doi: 10.1093/annonc/mdv008. PMID: 25600562. Exclusion Code: X6.25600562
1027 Mallorie A, Goldring J, Patel A, . Assessment of nodal involvement in non-small-cell lung cancer with 18F-FDG-PET/CT: mediastinal blood pool cut-off has the highest sensitivity and tumour SUVmax/2 has the highest specificity. Nucl Med Commun. 2017 Aug;38(8):715–9. doi: 10.1097/mnm.0000000000000703. PMID: 28658052. Exclusion Code: X5.28658052
1028 Mammarappallil JG, Hiatt KD, Ge Q, . Computed tomography fluoroscopy versus conventional computed tomography guidance for biopsy of intrathoracic lesions: a retrospective review of 1143 consecutive procedures. J Thorac Imaging. 2014 Nov;29(6):340–3. doi: 10.1097/rti.0000000000000109. PMID: 25286292. Exclusion Code: X3.25286292
1029 Mampuya WA, Matsuo Y, Ueki N, . The impact of abdominal compression on outcome in patients treated with stereotactic body radiotherapy for primary lung cancer. J Radiat Res. 2014 Sep;55(5):934–9. doi: 10.1093/jrr/rru028. PMID: 24801474. Exclusion Code: X10.24801474
1030 Mancini BR, Park HS, Harder EM, . Elderly patients undergoing SBRT for inoperable early-stage NSCLC achieve similar outcomes to younger patients. Lung Cancer. 2016 Jul;97:22–7. doi: 10.1016/j.lungcan.2016.04.011. PMID: 27237023. Exclusion Code: X3.27237023
1031 Mangona VS, Aneese AM, Marina O, . Toxicity after central versus peripheral lung stereotactic body radiation therapy: a propensity score matched-pair analysis. Int J Radiat Oncol Biol Phys. 2015 Jan 1;91(1):124–32. doi: 10.1016/j.ijrobp.2014.08.345. PMID: 25442337. Exclusion Code: X3.25442337
1032 Manners D, Hui J, Hunter M, . Estimating eligibility for lung cancer screening in an Australian cohort, including the effect of spirometry. Med J Aust. 2016 Jun 20;204(11):406. PMID: 27318396. Exclusion Code: X8.27318396
1033 Manyam B, Videtic GM, Reddy CA, . Single fraction SBRT for stage i non-small cell lung cancer: treatment outcomes and effect of tumor location on chest wall toxicity. International journal of radiation oncology biology physics. 2017;99(2):E478–. doi: 10.1016/j.ijrobp.2017.06.1747. PMID: CN-01422977. Exclusion Code: X2.
1034 Marchiano AV, Cosentino M, Di Tolla G, . FNA and CNB in the diagnosis of pulmonary lesions: a single-center experience on 665 patients, comparison between two periods. Tumori. 2017 Jul 31;103(4):360–6. doi: 10.5301/tj.5000633. PMID: 28478642. Exclusion Code: X3.28478642
1035 Marcus MW, Chen Y, Raji OY, . LLPi: Liverpool Lung Project Risk Prediction Model for Lung Cancer Incidence. Cancer Prev Res (Phila). 2015 Jun;8(6):570–5. doi: 10.1158/1940-6207.capr-14-0438. PMID: 25873368. Exclusion Code: X7.25873368
1036 Marcus MW, Raji OY, Chen Y, . Factors associated with dropout in a lung cancer highrisk cohort--the Liverpool lung project. Int J Oncol. 2014 Jun;44(6):2146–52. doi: 10.3892/ijo.2014.2371. PMID: 24714788. Exclusion Code: X8.24714788
1037 Marcus MW, Raji OY, Duffy SW, . Incorporating epistasis interaction of genetic susceptibility single nucleotide polymorphisms in a lung cancer risk prediction model. Int J Oncol. 2016 Jul;49(1):361–70. doi: 10.3892/ijo.2016.3499. PMID: 27121382. Exclusion Code: X7.27121382
1038 Marino KA, Sullivan JL, Weksler B. Electromagnetic navigation bronchoscopy for identifying lung nodules for thoracoscopic resection. Ann Thorac Surg. 2016 Aug;102(2):454–7. doi: 10.1016/j.athoracsur.2016.03.010. PMID: 27173068. Exclusion Code: X3.27173068
1039 Markowitz SB, Manowitz A, Miller JA, . Yield of low-dose computerized tomography screening for lung cancer in high-risk workers: The Case of 7189 US Nuclear Weapons Workers. Am J Public Health. 2018 Oct;108(10):1296–302. doi: 10.2105/AJPH.2018.304518. PMID: 30138066. Exclusion Code: X7.30138066
1040 Marshall HM, Courtney DA, Passmore LH, . Brief tailored smoking cessation counseling in a lung cancer screening population is feasible: a pilot randomized controlled trial. Nicotine Tob Res. 2016 Jul;18(7):1665–9. doi: 10.1093/ntr/ntw010. PMID: 26834052. Exclusion Code: X5.26834052
1041 Marty-Ane CH, Canaud L, Solovei L, . Video-assisted thoracoscopic lobectomy: an unavoidable trend? A retrospective single-institution series of 410 cases. Interact Cardiovasc Thorac Surg. 2013 Jul;17(1):36–43. doi: 10.1093/icvts/ivt146. PMID: 23592725. Exclusion Code: X3.23592725
1042 Marwaha G, Stephans KL, Woody NM, . Lung stereotactic body radiation therapy: regional nodal failure is not predicted by tumor size. J Thorac Oncol. 2014 Nov;9(11):1693–7. doi: 10.1097/jto.0000000000000313. PMID: 25185531. Exclusion Code: X13.25185531
1043 Massion PP, Healey GF, Peek LJ, . Autoantibody signature enhances the positive predictive power of computed tomography and nodule-based risk models for detection of lung cancer. J Thorac Oncol. 2017 Mar;12(3):578–84. doi: 10.1016/j.jtho.2016.08.143. PMID: 27615397. Exclusion Code: X5.27615397
1044 Mastrangelo G, Marangi G, Ballarin MN, . Lung cancer risk in past asbestos workers a few decades after exposure cessation and prospects for screening. Arch Environ Occup Health. 2016 Jul 3;71(4):237–44. doi: 10.1080/19338244.2015.1134423. PMID: 26730642. Exclusion Code: X7.26730642
1045 Matsui Y, Hiraki T, Gobara H, . Phrenic nerve injury after radiofrequency ablation of lung tumors: retrospective evaluation of the incidence and risk factors. J Vasc Interv Radiol. 2012 Jun;23(6):780–5. doi: 10.1016/j.jvir.2012.02.014. PMID: 22513393. Exclusion Code: X6.22513393
1046 Matsumura Y, Suzuki H, Ohira T, . Matched-pair analysis of a multi-institutional cohort reveals that epidermal growth factor receptor mutation is not a risk factor for postoperative recurrence of lung adenocarcinoma. Lung Cancer. 2017 Dec;114:23–30. doi: 10.1016/j.lungcan.2017.09.003. PMID: 29173761. Exclusion Code: X11.29173761
1047 Matsumura Y, Yano M, Yoshida J, . Early and late recurrence after intentional limited resection for cT1aN0M0, non-small cell lung cancer: from a multi-institutional, retrospective analysis in Japan. Interact Cardiovasc Thorac Surg. 2016 Sep;23(3):444–9. doi: 10.1093/icvts/ivw125. PMID: 27226401. Exclusion Code: X10.27226401
1048 Matsuo Y, Ueki N, Takayama K, . Evaluation of dynamic tumour tracking radiotherapy with real-time monitoring for lung tumours using a gimbal mounted linac. Radiother Oncol. 2014 Sep;112(3):360–4. doi: 10.1016/j.radonc.2014.08.003. PMID: 25154320. Exclusion Code: X3.25154320
1049 Matsuoka K, Ueda M, Miyamoto Y. Risk factor for respiratory death after lung cancer surgery in octogenarians. Asian Cardiovasc Thorac Ann. 2015 Nov;23(9):1044–9. doi: 10.1177/0218492315605725. PMID: 26385873. Exclusion Code: X11.26385873
1050 Matsuura Y, Mun M, Nakagawa K, . Efficacy and feasibility of a novel and noninvasive computed tomography-guided marking technique for peripheral pulmonary nodules. J Thorac Cardiovasc Surg. 2015 Apr;149(4):1208–9. doi: 10.1016/j.jtcvs.2014.11.040. PMID: 25534486. Exclusion Code: X3.25534486
1051 Mazza F, Ferrari E, Maineri P, . Pleural lavage cytology predicts recurrence and survival, even in early non-small cell lung cancer. Surg Today. 2015 Mar;45(3):322–8. doi: 10.1007/s00595-014-0915-3. PMID: 24817060. Exclusion Code: X11.24817060
1052 Mazza F, Ferrari E, Maineri P, . Pulmonary middle lobectomy for non-small-cell lung cancer: effectiveness and prognostic implications. Eur J Cardiothorac Surg. 2015 Dec;48(6):e117–23. doi: 10.1093/ejcts/ezv314. PMID: 26374866. Exclusion Code: X3.26374866
1053 Mazzella A, Pardolesi A, Maisonneuve P, . Bronchopleural Fistula After Pneumonectomy: Risk Factors and Management, Focusing on Open-Window Thoracostomy. Semin Thorac Cardiovasc Surg. 2018 Spring;30(1):104–13. doi: 10.1053/j.semtcvs.2017.10.003. PMID: 29109057. Exclusion Code: X3.29109057
1054 Mazzone PJ, Obuchowski N, Fu AZ, . Quality of life and healthcare use in a randomized controlled lung cancer screening study. Ann Am Thorac Soc. 2013 Aug;10(4):324–9. doi: 10.1513/AnnalsATS.201301-007OC. PMID: 23952850. Exclusion Code: X5.23952850
1055 Mazzone PJ, Wang XF, Lim S, . Accuracy of volatile urine biomarkers for the detection and characterization of lung cancer. BMC Cancer. 2015 Dec 23;15:1001. doi: 10.1186/s12885-015-1996-0. PMID: 26698840. Exclusion Code: X3.26698840
1056 McAleese J, Baluch S, Drinkwater K. The quality of curative-intent radiotherapy for non-small cell lung cancer in the UK. Clin Oncol (R Coll Radiol). 2015 Sep;27(9):498–504. doi: 10.1016/j.clon.2015.05.006. PMID: 26073694. Exclusion Code: X8.26073694
1057 McCunney RJ, Li J. Radiation risks in lung cancer screening programs: a comparison with nuclear industry workers and atomic bomb survivors. Chest. 2014 Mar 1;145(3):618–24. doi: 10.1378/chest.13-1420. PMID: 24590022. Exclusion Code: X10.24590022
1058 McDevitt JL, Mouli SK, Nemcek AA, . Percutaneous cryoablation for the treatment of primary and metastatic lung tumors: identification of risk factors for recurrence and major complications. J Vasc Interv Radiol. 2016 Sep;27(9):1371–9. doi: 10.1016/j.jvir.2016.04.005. PMID: 27321886. Exclusion Code: X6.27321886
1059 McElnay P, Casali G, Batchelor T, . Adopting a standardized anterior approach significantly increases video-assisted thoracoscopic surgery lobectomy rates. Eur J Cardiothorac Surg. 2014 Jul;46(1):100–5. doi: 10.1093/ejcts/ezt561. PMID: 24335265. Exclusion Code: X3.24335265
1060 McElnay PJ, Molyneux M, Krishnadas R, . Pain and recovery are comparable after either uniportal or multiport video-assisted thoracoscopic lobectomy: an observation study. Eur J Cardiothorac Surg. 2015 May;47(5):912–5. doi: 10.1093/ejcts/ezu324. PMID: 25147352. Exclusion Code: X11.25147352
1061 McGarry RC, Papiez L, Williams M, . Stereotactic body radiation therapy of early-stage non-small-cell lung carcinoma: phase I study. Int J Radiat Oncol Biol Phys. 2005 Nov 15;63(4):1010–5. doi: 10.1016/j.ijrobp.2005.03.073. PMID: 16115740. Exclusion Code: X11.16115740
1062 McGuire AL, Hopman WM, Petsikas D, . Outcomes: wedge resection versus lobectomy for non-small cell lung cancer at the Cancer Centre of Southeastern Ontario 1998-2009. Can J Surg. 2013 Dec;56(6):E165–70. PMID: 24284157. Exclusion Code: X11.24284157
1063 McKee BJ, Regis SM, McKee AB, . Performance of ACR Lung-RADS in a clinical CT lung screening program. J Am Coll Radiol. 2015 Mar;12(3):273–6. doi: 10.1016/j.jacr.2014.08.004. PMID: 25176499. Exclusion Code: X17.25176499
1064 McKenna RJ, Jr., Houck W, Fuller CB. Video-assisted thoracic surgery lobectomy: experience with 1,100 cases. Ann Thorac Surg. 2006 Feb;81(2):421–5; discussion 5-6. doi: 10.1016/j.athoracsur.2005.07.078. PMID: 16427825. Exclusion Code: X3.16427825
1065 McLaughlin J, Han G, Schalper KA, . Quantitative assessment of the heterogeneity of PD-L1 expression in non-small-cell lung cancer. JAMA Oncol. 2016 Jan;2(1):46–54. doi: 10.1001/jamaoncol.2015.3638. PMID: 26562159. Exclusion Code: X8.26562159
1066 McMahon PM, Kong CY, Johnson BE, . Chapter 9: The MGH-HMS lung cancer policy model: tobacco control versus screening. Risk Anal. 2012 Jul;32: Suppl 1:S117–24. doi: 10.1111/j.1539-6924.2011.01652.x. PMID: 22882882. Exclusion Code: X4.22882882
1067 McMahon PM, Meza R, Plevritis SK, . Comparing benefits from many possible computed tomography lung cancer screening programs: extrapolating from the National Lung Screening Trial using comparative modeling. PLoS One. 2014;9(6):e99978. doi: 10.1371/journal.pone.0099978. PMID: 24979231. Exclusion Code: X4.24979231
1068 McWilliams JM, Dalton JB, Landrum MB, . Geographic variation in cancer-related imaging: Veterans Affairs health care system versus Medicare. Ann Intern Med. 2014 Dec 2;161(11):794–802. doi: 10.7326/m14-0650. PMID: 25437407. Exclusion Code: X3.25437407
1069 Medbery RL, Perez SD, Force SD, . Video-assisted thoracic surgery lobectomy cost variability: implications for a bundled payment era. Ann Thorac Surg. 2014 May;97(5):1686–92; discussion 92-3. doi: 10.1016/j.athoracsur.2014.01.021. PMID: 24792254. Exclusion Code: X8.24792254
1070 Mediratta N, Poullis M. Smoking status and 30-day mortality in patients undergoing pulmonary resections. Asian Cardiovasc Thorac Ann. 2016 Sep;24(7):663–9. doi: 10.1177/0218492316657252. PMID: 27365496. Exclusion Code: X7.27365496
1071 Meena N, Bartter T. Ultrasound-guided percutaneous needle aspiration by pulmonologists: a study of factors with impact on procedural yield and complications. J Bronchology Interv Pulmonol. 2015 Jul;22(3):204–8. doi: 10.1097/lbr.0000000000000175. PMID: 26165890. Exclusion Code: X3.26165890
1072 Mehta A, Cordero J, Dobersch S, . Non-invasive lung cancer diagnosis by detection of GATA6 and NKX2-1 isoforms in exhaled breath condensate. EMBO Mol Med. 2016 Dec;8(12):1380–9. doi: 10.15252/emmm.201606382. PMID: 27821429. Exclusion Code: X5.27821429
1073 Mehta HJ, Ravenel JG, Shaftman SR, . The utility of nodule volume in the context of malignancy prediction for small pulmonary nodules. Chest. 2014 Mar 1;145(3):464–72. doi: 10.1378/chest.13-0708. PMID: 23949741. Exclusion Code: X3.23949741
1074 Mehta RS, Lenzner D, Argiris A. Race and health disparities in patient refusal of surgery for early-stage non-small cell lung cancer: a SEER cohort study. Ann Surg Oncol. 2012 Mar;19(3):722–7. doi: 10.1245/s10434-011-2087-3. PMID: 21947698. Exclusion Code: X8.21947698
1075 Meier-Schroers M, Homsi R, Skowasch D, . Lung cancer screening with MRI: results of the first screening round. J Cancer Res Clin Oncol. 2018 Jan;144(1):117–25. doi: 10.1007/s00432-017-2521-4. PMID: 28932985. Exclusion Code: X7.28932985
1076 Meier-Schroers M, Kukuk G, Homsi R, . MRI of the lung using the PROPELLER technique: artifact reduction, better image quality and improved nodule detection. Eur J Radiol. 2016 Apr;85(4):707–13. doi: 10.1016/j.ejrad.2015.12.016. PMID: 26971412. Exclusion Code: X5.26971412
1077 Melfi FM, Fanucchi O, Davini F, . Robotic lobectomy for lung cancer: evolution in technique and technology. Eur J Cardiothorac Surg. 2014 Oct;46(4):626–30; discussion 30-1. doi: 10.1093/ejcts/ezu079. PMID: 24616391. Exclusion Code: X3.24616391
1078 Meng XX, Kuai XP, Dong WH, . Comparison of lung lesion biopsies between low-dose CT-guided and conventional CT-guided techniques. Acta Radiol. 2013 Oct;54(8):909–15. doi: 10.1177/0284185113485937. PMID: 23817682. Exclusion Code: X3.23817682
1079 Merritt RE, Hoang CD, Shrager JB. Lymph node evaluation achieved by open lobectomy compared with thoracoscopic lobectomy for N0 lung cancer. Ann Thorac Surg. 2013 Oct;96(4):1171–7. doi: 10.1016/j.athoracsur.2013.05.044. PMID: 23915591. Exclusion Code: X11.23915591
1080 Mets OM, Vliegenthart R, Gondrie MJ, . Lung cancer screening CT-based prediction of cardiovascular events. JACC Cardiovasc Imaging. 2013 Aug;6(8):899–907. doi: 10.1016/j.jcmg.2013.02.008. PMID: 23769488. Exclusion Code: X8.23769488
1081 Meyers TJ, Chang SC, Chang PY, . Case-control study of cumulative cigarette tar exposure and lung and upper aerodigestive tract cancers. Int J Cancer. 2017 May 1;140(9):2040–50. doi: 10.1002/ijc.30632. PMID: 28164274. Exclusion Code: X4.28164274
1082 Meza R, ten Haaf K, Kong CY, . Comparative analysis of 5 lung cancer natural history and screening models that reproduce outcomes of the NLST and PLCO trials. Cancer. 2014 Jun 1;120(11):1713–24. doi: 10.1002/cncr.28623. PMID: 24577803. Exclusion Code: X7.24577803
1083 Midthun DE. Screening for lung cancer. Clin Chest Med. 2011 Dec;32(4):659–68. doi: 10.1016/j.ccm.2011.08.014. PMID: 22054878. Exclusion Code: X10.22054878
1084 Migliore M, Criscione A, Calvo D, . Preliminary experience with video-assisted thoracic surgery lobectomy for lung malignancies: general considerations moving toward standard practice. Future Oncol. 2015;11:(24 Suppl):43–6. doi: 10.2217/fon.15.305. PMID: 26638923. Exclusion Code: X3.26638923
1085 Miller AT, Kruger P, Conner K, . Initial outcomes of a lung cancer screening program in an integrated community health system. J Am Coll Radiol. 2016 Jun;13(6):733–7. doi: 10.1016/j.jacr.2016.02.013. PMID: 27131618. Exclusion Code: X7.27131618
1086 Miller CJ, Martin B, Stang K, . Predictors of Distant Failure After Stereotactic Body Radiation Therapy for Stages I to IIA Non-Small-Cell Lung Cancer. Clin Lung Cancer. 2019 Jan;20(1):37–42. doi: 10.1016/j.cllc.2018.09.002. PMID: 30279109. Exclusion Code: X13.30279109
1087 Mimae T, Miyata Y, Mimura T, . Radiologic findings to predict low-grade malignant tumour among clinical T1bN0 lung adenocarcinomas: lessons from histological subtypes. Jpn J Clin Oncol. 2015 Aug;45(8):767–73. doi: 10.1093/jjco/hyv078. PMID: 26056324. Exclusion Code: X3.26056324
1088 Mimae T, Suzuki K, Tsuboi M, . Surgical outcomes of lung cancer in patients with combined pulmonary fibrosis and emphysema. Ann Surg Oncol. 2015 Dec;22: Suppl 3:S1371–9. doi: 10.1245/s10434-015-4577-1. PMID: 25956575. Exclusion Code: X3.25956575
1089 Mimae T, Tsutani Y, Miyata Y, . Role of lymphatic invasion in the prognosis of patients with clinical node-negative and pathologic node-positive lung adenocarcinoma. J Thorac Cardiovasc Surg. 2014 Jun;147(6):1820–6. doi: 10.1016/j.jtcvs.2013.11.050. PMID: 24507979. Exclusion Code: X8.24507979
1090 Minami D, Takigawa N, Morichika D, . Endobronchial ultrasound-guided transbronchial biopsy with or without a guide sheath for diagnosis of lung cancer. Respir Investig. 2015 May;53(3):93–7. doi: 10.1016/j.resinv.2014.10.003. PMID: 25951094. Exclusion Code: X3.25951094
1091 Minami D, Takigawa N, Oda N, . Endobronchial ultrasound-guided transbronchial needle aspiration of hilar and mediastinal lymph nodes detected on 18F-fluorodeoxyglucose positron emission tomography/computed tomography. Jpn J Clin Oncol. 2016 Jun;46(6):529–33. doi: 10.1093/jjco/hyw023. PMID: 27004902. Exclusion Code: X3.27004902
1092 Minamimoto R, Senda M, Jinnouchi S, . Detection of lung cancer by FDG-PET cancer screening program: a nationwide Japanese survey. Anticancer Res. 2014 Jan;34(1):183–9. PMID: 24403460. Exclusion Code: X5.24403460
1093 Ming X, Feng Y, Yang C, . Radiation-induced heart disease in lung cancer radiotherapy: a dosimetric update. Medicine (Baltimore). 2016 Oct;95(41):e5051. doi: 10.1097/md.0000000000005051. PMID: 27741117. Exclusion Code: X9.27741117
1094 Mitera G, Swaminath A, Rudoler D, . Cost-effectiveness analysis comparing conventional versus stereotactic body radiotherapy for surgically ineligible stage I non-small-cell lung cancer. J Oncol Pract. 2014 May;10(3):e130–6. doi: 10.1200/jop.2013.001206. PMID: 24643574. Exclusion Code: X10.24643574
1095 Mitsuyoshi T, Nakamura M, Matsuo Y, . Dosimetric comparison of lung stereotactic body radiotherapy treatment plans using averaged computed tomography and end-exhalation computed tomography images: Evaluation of the effect of different dose-calculation algorithms and prescription methods. Med Dosim. 2016 Winter;41(4):305–9. doi: 10.1016/j.meddos.2016.07.003. PMID: 27623737. Exclusion Code: X8.27623737
1096 Miura H, Inoue T, Shiomi H, . Differences in rates of radiation-induced true and false rib fractures after stereotactic body radiation therapy for Stage I primary lung cancer. J Radiat Res. 2015 Mar;56(2):332–7. doi: 10.1093/jrr/rru107. PMID: 25504640. Exclusion Code: X17.25504640
1097 Miura N, Kohno M, Ito K, . Lung cancer surgery in patients aged 80 years or older: an analysis of risk factors, morbidity, and mortality. Gen Thorac Cardiovasc Surg. 2015 Jul;63(7):401–5. doi: 10.1007/s11748-015-0546-7. PMID: 25868520. Exclusion Code: X3.25868520
1098 Miyasaka Y, Suzuki K, Oh S, . Cardiomegaly is a significant predictor of postoperative atelectasis following left upper superior segmentectomy. Thorac Cardiovasc Surg. 2015 Oct;63(7):609–13. doi: 10.1055/s-0034-1377061. PMID: 25136944. Exclusion Code: X3.25136944
1099 Miyazaki T, Yamasaki N, Tsuchiya T, . Inflammation-based scoring is a useful prognostic predictor of pulmonary resection for elderly patients with clinical stage I non-small-cell lung cancer. Eur J Cardiothorac Surg. 2015 Apr;47(4):e140–5. doi: 10.1093/ejcts/ezu514. PMID: 25548132. Exclusion Code: X3.25548132
1100 Miyazaki T, Yamazaki T, Nakamura D, . Surgery or stereotactic body radiotherapy for elderly stage I lung cancer? A propensity score matching analysis. Surg Today. 2017 Dec;47(12):1476–83. doi: 10.1007/s00595-017-1536-4. PMID: 28447170. Exclusion Code: X10.28447170
1101 Modh A, Rimner A, Williams E, . Local control and toxicity in a large cohort of central lung tumors treated with stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 2014 Dec 1;90(5):1168–76. doi: 10.1016/j.ijrobp.2014.08.008. PMID: 25303891. Exclusion Code: X3.25303891
1102 Mohiuddin K, Haneuse S, Sofer T, . Relationship between margin distance and local recurrence among patients undergoing wedge resection for small (</=2 cm) non-small cell lung cancer. J Thorac Cardiovasc Surg. 2014 Apr;147(4):1169–75; discussion 75-7. doi: 10.1016/j.jtcvs.2013.11.056. PMID: 24507406. Exclusion Code: X11.24507406
1103 Mohner M. An approach to adjust standardized mortality ratios for competing cause of death in cohort studies. Int Arch Occup Environ Health. 2016 May;89(4):593–8. doi: 10.1007/s00420-015-1097-z. PMID: 26483290. Exclusion Code: X3.26483290
1104 Mokhles S, Nuyttens JJ, Maat AP, . Survival and treatment of non-small cell lung cancer stage I-II treated surgically or with stereotactic body radiotherapy: patient and tumor-specific factors affect the prognosis. Ann Surg Oncol. 2015 Jan;22(1):316–23. doi: 10.1245/s10434-014-3860-x. PMID: 24962941. Exclusion Code: X3.24962941
1105 Mokhles S, Verstegen N, Maat AP, . Comparison of clinical outcome of stage I non-small cell lung cancer treated surgically or with stereotactic radiotherapy: results from propensity score analysis. Lung Cancer. 2015 Mar;87(3):283–9. doi: 10.1016/j.lungcan.2015.01.005. PMID: 25622781. Exclusion Code: X10.25622781
1106 Moloney F, Ryan D, McCarthy L, . Increasing the accuracy of 18F-FDG PET/CT interpretation of “mildly positive” mediastinal nodes in the staging of non-small cell lung cancer. Eur J Radiol. 2014 May;83(5):843–7. doi: 10.1016/j.ejrad.2014.01.016. PMID: 24581594. Exclusion Code: X3.24581594
1107 Montaudon M, Latrabe V, Pariente A, . Factors influencing accuracy of CT-guided percutaneous biopsies of pulmonary lesions. Eur Radiol. 2004 Jul;14(7):1234–40. doi: 10.1007/s00330-004-2250-3. PMID: 14963689. Exclusion Code: X3.14963689
1108 Moon MH, Beck KS, Moon YK, . Incidence and clinical features of the incidentally found vascular stump thrombus during routine follow up after oncologic lung surgery. PLoS One. 2017;12(9):e0185140. doi: 10.1371/journal.pone.0185140. PMID: 28953945. Exclusion Code: X11.28953945
1109 Moon SW, Cho DG, Cho KD, . Fluoroscopy-assisted thoracoscopic resection for small intrapulmonary lesions after preoperative computed tomography-guided localization using fragmented platinum microcoils. Thorac Cardiovasc Surg. 2012 Sep;60(6):413–8. doi: 10.1055/s-0031-1299582. PMID: 22383151. Exclusion Code: X3.22383151
1110 Moon Y, Lee KY, Moon SW, . Sublobar resection margin width does not affect recurrence of clinical N0 non-small cell lung cancer presenting as GGO-predominant nodule of 3 cm or less. World J Surg. 2017 Feb;41(2):472–9. doi: 10.1007/s00268-016-3743-3. PMID: 27718002. Exclusion Code: X11.27718002
1111 Moon Y, Lee KY, Park JK. Prognosis After Sublobar Resection of Small-sized Non-small Cell Lung Cancer with Visceral Pleural or Lymphovascular Invasion. World J Surg. 2017 Nov;41(11):2769–77. doi: 10.1007/s00268-017-4075-7. PMID: 28597091. Exclusion Code: X11.28597091
1112 Moon Y, Park JK, Lee KY, . Lymphatic invasion is a more significant prognostic factor than visceral pleural invasion in non-small cell lung cancer with tumours of 3 cm or less. Respirology. 2017 Aug;22(6):1179–84. doi: 10.1111/resp.13029. PMID: 28382791. Exclusion Code: X8.28382791
1113 Moon Y, Sung SW, Lee KY, . The importance of the lepidic component as a prognostic factor in stage I pulmonary adenocarcinoma. World J Surg Oncol. 2016 Feb 16;14(1):37. doi: 10.1186/s12957-016-0791-y. PMID: 26879575. Exclusion Code: X11.26879575
1114 Moore W, Chaya Y, Chaudhry A, . Computed tomography assessment of ablation zone enhancement in patients with early-stage lung cancer after stereotactic ablative radiotherapy. J Comput Assist Tomogr. 2015 Sep-Oct;39(5):804–9. doi: 10.1097/rct.0000000000000262. PMID: 25974720. Exclusion Code: X3.25974720
1115 Moore W, Talati R, Bhattacharji P, . Five-year survival after cryoablation of stage I non-small cell lung cancer in medically inoperable patients. J Vasc Interv Radiol. 2015 Mar;26(3):312–9. doi: 10.1016/j.jvir.2014.12.006. PMID: 25735518. Exclusion Code: X6.25735518
1116 Moran A, Daly ME, Yip SSF, . Radiomics-based Assessment of Radiation-induced Lung Injury After Stereotactic Body Radiotherapy. Clin Lung Cancer. 2017 Nov;18(6):e425–e31. doi: 10.1016/j.cllc.2017.05.014. PMID: 28623121. Exclusion Code: X8.28623121
1117 Moran LM, Rodriguez R, Calzado A, . Image quality and dose evaluation in spiral chest CT examinations of patients with lung carcinoma. Br J Radiol. 2004 Oct;77(922):839–46. doi: 10.1259/bjr/71539623. PMID: 15482995. Exclusion Code: X3.15482995
1118 Mordant P, Grand B, Cazes A, . Adenosquamous carcinoma of the lung: surgical management, pathologic characteristics, and prognostic implications. Ann Thorac Surg. 2013 Apr;95(4):1189–95. doi: 10.1016/j.athoracsur.2012.12.037. PMID: 23473060. Exclusion Code: X3.23473060
1119 More JM, Eclov NC, Chung MP, . Feasibility and potential utility of multicomponent exhaled breath analysis for predicting development of radiation pneumonitis after stereotactic ablative radiotherapy. J Thorac Oncol. 2014 Jul;9(7):957–64. doi: 10.1097/jto.0000000000000182. PMID: 24926543. Exclusion Code: X3.24926543
1120 Morgant MC, Pages PB, Orsini B, . Time trends in surgery for lung cancer in France from 2005 to 2012: a nationwide study. Eur Respir J. 2015 Oct;46(4):1131–9. doi: 10.1183/13993003.00354-2015. PMID: 26250496. Exclusion Code: X8.26250496
1121 Morimoto M, Okishio K, Akira M, . Duration of twice-daily thoracic radiotherapy and time from the start of any treatment to the end of chest irradiation as significant predictors of outcomes in limited-disease small-cell lung cancer. Clin Lung Cancer. 2017 Mar;18(2):e117–e27. doi: 10.1016/j.cllc.2016.09.004. PMID: 28340925. Exclusion Code: X3.28340925
1122 Morla O, Liberge R, Arrigoni PP, . Pulmonary nodules and masses in lung transplant recipients: clinical and CT findings. Eur Radiol. 2014 Sep;24(9):2183–91. doi: 10.1007/s00330-014-3264-0. PMID: 24895041. Exclusion Code: X3.24895041
1123 Moroga T, Yamashita S, Tokuishi K, . Thoracoscopic segmentectomy with intraoperative evaluation of sentinel nodes for stage I non-small cell lung cancer. Ann Thorac Cardiovasc Surg. 2012;18(2):89–94. PMID: 22082811. Exclusion Code: X11.22082811
1124 Moseson EM, Wiener RS, Golden SE, . Patient and clinician characteristics associated with adherence. A cohort study of veterans with incidental pulmonary nodules. Ann Am Thorac Soc. 2016 May;13(5):651–9. doi: 10.1513/AnnalsATS.201511-745OC. PMID: 27144794. Exclusion Code: X3.27144794
1125 Mota P, Silva HC, Soares MJ, . Genetic polymorphisms of phase I and phase II metabolic enzymes as modulators of lung cancer susceptibility. J Cancer Res Clin Oncol. 2015 May;141(5):851–60. doi: 10.1007/s00432-014-1868-z. PMID: 25388590. Exclusion Code: X7.25388590
1126 Motoishi M, Sawai S, Hori T, . The preoperative HbA1c level is an independent prognostic factor for the postoperative survival after resection of non-small cell lung cancer in elderly patients. Surg Today. 2018 May;48(5):517–24. doi: 10.1007/s00595-017-1612-9. PMID: 29222669. Exclusion Code: X3.29222669
1127 Moulla Y, Gradistanac T, Wittekind C, . Predictive risk factors for lymph node metastasis in patients with resected non-small cell lung cancer: a case control study. J Cardiothorac Surg. 2019 Jan 16;14(1):11. doi: 10.1186/s13019-019-0831-0. PMID: 30651112. Exclusion Code: X11.30651112
1128 Mu JW, Gao SG, Xue Q, . A matched comparison study of uniportal versus triportal thoracoscopic lobectomy and sublobectomy for early-stage nonsmall cell lung cancer. Chin Med J (Engl). 2015 Oct 20;128(20):2731–5. doi: 10.4103/0366-6999.167298. PMID: 26481738. Exclusion Code: X3.26481738
1129 Muallaoglu S, Karadeniz C, Mertsoylu H, . The clinicopathological and survival differences between never and ever smokers with non-small cell lung cancer. J BUON. 2014 Apr-Jun;19(2):453–8. PMID: 24965406. Exclusion Code: X3.24965406
1130 Muka T, Kraja B, Ruiter R, . Dietary mineral intake and lung cancer risk: the Rotterdam Study. Eur J Nutr. 2017 Jun;56(4):1637–46. doi: 10.1007/s00394-016-1210-4. PMID: 27073037. Exclusion Code: X7.27073037
1131 Muller DC, Johansson M, Brennan P. Lung cancer risk prediction model incorporating lung function: development and validation in the UK Biobank Prospective Cohort Study. J Clin Oncol. 2017 Mar 10;35(8):861–9. doi: 10.1200/jco.2016.69.2467. PMID: 28095156. Exclusion Code: X4.28095156
1132 Munir S, Koppikar S, Hopman WM, . Diagnostic yield for cancer and diagnostic accuracy of computed tomography-guided core needle biopsy of subsolid pulmonary lesions. J Thorac Imaging. 2017 Jan;32(1):50–6. doi: 10.1097/rti.0000000000000245. PMID: 27870823. Exclusion Code: X3.27870823
1133 Murakami J, Ueda K, Sano F, . Pulmonary emphysema and tumor microenvironment in primary lung cancer. J Surg Res. 2016 Feb;200(2):690–7. doi: 10.1016/j.jss.2015.09.004. PMID: 26428090. Exclusion Code: X3.26428090
1134 Murakawa T, Ichinose J, Hino H, . Long-term outcomes of open and video-assisted thoracoscopic lung lobectomy for the treatment of early stage non-small cell lung cancer are similar: a propensity-matched study. World J Surg. 2015 May;39(5):1084–91. doi: 10.1007/s00268-014-2918-z. PMID: 25561187. Exclusion Code: X11.25561187
1135 Muranishi Y, Sonobe M, Hamaji M, . Surgery for metachronous second primary lung cancer versus surgery for primary lung cancer: a propensity score-matched comparison of postoperative complications and survival outcomes. Interact Cardiovasc Thorac Surg. 2018 Apr 1;26(4):631–7. doi: 10.1093/icvts/ivx389. PMID: 29253161. Exclusion Code: X3.29253161
1136 Muranishi Y, Sonobe M, Menju T, . Atrial fibrillation after lung cancer surgery: incidence, severity, and risk factors. Surg Today. 2017 Feb;47(2):252–8. doi: 10.1007/s00595-016-1380-y. PMID: 27382978. Exclusion Code: X3.27382978
1137 Murray L, Karakaya E, Hinsley S, . Lung stereotactic ablative radiotherapy (SABR): dosimetric considerations for chest wall toxicity. Br J Radiol. 2016;89(1058):20150628. doi: 10.1259/bjr.20150628. PMID: 26760508. Exclusion Code: X3.26760508
1138 Murray L, Ramasamy S, Lilley J, . Stereotactic ablative radiotherapy (SABR) in patients with medically inoperable peripheral early stage lung cancer: outcomes for the first UK SABR cohort. Clin Oncol (R Coll Radiol). 2016 Jan;28(1):4–12. doi: 10.1016/j.clon.2015.09.007. PMID: 26474546. Exclusion Code: X10.26474546
1139 Mytelka DS, Li L, Benoit K. Post-diagnosis weight loss as a prognostic factor in non-small cell lung cancer. J Cachexia Sarcopenia Muscle. 2018 Feb;9(1):86–92. doi: 10.1002/jcsm.12253. PMID: 29205930. Exclusion Code: X3.29205930
1140 Nabavizadeh N, Zhang J, Elliott DA, . Electromagnetic navigational bronchoscopy-guided fiducial markers for lung stereotactic body radiation therapy: analysis of safety, feasibility, and interfraction stability. J Bronchology Interv Pulmonol. 2014 Apr;21(2):123–30. doi: 10.1097/lbr.0000000000000065. PMID: 24739685. Exclusion Code: X3.24739685
1141 Nagata M, Ito H, Matsuzaki T, . Body mass index, C-reactive protein and survival in smokers undergoing lobectomy for lung cancerdagger. Eur J Cardiothorac Surg. 2017 Jun 1;51(6):1164–70. doi: 10.1093/ejcts/ezx004. PMID: 28199511. Exclusion Code: X3.28199511
1142 Nagata Y, Takayama K, Matsuo Y, . Clinical outcomes of a phase I/II study of 48 Gy of stereotactic body radiotherapy in 4 fractions for primary lung cancer using a stereotactic body frame. Int J Radiat Oncol Biol Phys. 2005 Dec 1;63(5):1427–31. doi: 10.1016/j.ijrobp.2005.05.034. PMID: 16169670. Exclusion Code: X11.16169670
1143 Nagatani Y, Takahashi M, Ikeda M, . Sub-solid nodule detectability in seven observers of seventy-nine clinical cases: comparison between ultra-low-dose chest digital tomosynthesis with iterative reconstruction and chest radiography by receiver-operating characteristics analysis. Eur J Radiol. 2018 Oct;107:166–74. doi: 10.1016/j.ejrad.2018.08.006. PMID: 30292262. Exclusion Code: X11.30292262
1144 Nagatani Y, Takahashi M, Ikeda M, . Sub-solid nodule detection performance on reduced-dose computed tomography with iterative reduction: comparison between 20 mA (7 mAs) and 120 mA (42 mAs) regarding nodular size and characteristics and association with size-specific dose estimate. Acad Radiol. 2017 Aug;24(8):995–1007. doi: 10.1016/j.acra.2017.01.004. PMID: 28606593. Exclusion Code: X8.28606593
1145 Nagatani Y, Takahashi M, Murata K, . Lung nodule detection performance in five observers on computed tomography (CT) with adaptive iterative dose reduction using three-dimensional processing (AIDR 3D) in a Japanese multicenter study: Comparison between ultra-low-dose CT and low-dose CT by receiver-operating characteristic analysis. Eur J Radiol. 2015 Jul;84(7):1401–12. doi: 10.1016/j.ejrad.2015.03.012. PMID: 25892051. Exclusion Code: X3.25892051
1146 Nagayasu T, Yamasaki N, Tsuchiya T, . The evolution of bronchoplasty and broncho-angioplasty as treatments for lung cancer: evaluation of 30 years of data from a single institution. Eur J Cardiothorac Surg. 2016 Jan;49(1):300–6. doi: 10.1093/ejcts/ezv065. PMID: 25721822. Exclusion Code: X6.25721822
1147 Nair A, Gartland N, Barton B, . Comparing the performance of trained radiographers against experienced radiologists in the UK lung cancer screening (UKLS) trial. Br J Radiol. 2016 Oct;89(1066):20160301. doi: 10.1259/bjr.20160301. PMID: 27461068. Exclusion Code: X7.27461068
1148 Nair VJ, MacRae R, Sirisegaram A, . Pretreatment [18F]-fluoro-2-deoxy-glucose positron emission tomography maximum standardized uptake value as predictor of distant metastasis in early-stage non-small cell lung cancer treated with definitive radiation therapy: rethinking the role of positron emission tomography in personalizing treatment based on risk status. Int J Radiat Oncol Biol Phys. 2014 Feb 1;88(2):312–8. doi: 10.1016/j.ijrobp.2013.10.029. PMID: 24411602. Exclusion Code: X6.24411602
1149 Nakagawa M, Hara M, Sakurai K, . Diagnostic accuracy of 18F-2-deoxy-fluoro-D-glucose positron emission tomography for pN1 lymph nodes in patients with lung cancer. Acta Radiol. 2009 Jul;50(6):638–44. doi: 10.1080/02841850902971255. PMID: 19492198. Exclusion Code: X3.19492198
1150 Nakagawa T, Negoro Y, Matsuoka T, . Comparison of the outcomes of stereotactic body radiotherapy and surgery in elderly patients with cT1-2N0M0 non-small cell lung cancer. Respir Investig. 2014 Jul;52(4):221–6. doi: 10.1016/j.resinv.2014.01.002. PMID: 24998368. Exclusion Code: X10.24998368
1151 Nakagawa T, Tomioka Y, Toyazaki T, . Association between values of preoperative 6-min walk test and surgical outcomes in lung cancer patients with decreased predicted postoperative pulmonary function. Gen Thorac Cardiovasc Surg. 2018 Apr;66(4):220–4. doi: 10.1007/s11748-018-0888-z. PMID: 29344798. Exclusion Code: X11.29344798
1152 Nakajima EC, Frankland MP, Johnson TF, . Assessing the inter-observer variability of Computer-Aided Nodule Assessment and Risk Yield (CANARY) to characterize lung adenocarcinomas. PLoS One. 2018;13(6):e0198118. doi: 10.1371/journal.pone.0198118. PMID: 29856852. Exclusion Code: X3.29856852
1153 Nakajo C, Heinzer S, Montandon S, . Chest CT at a dose below 0.3 mSv: impact of iterative reconstruction on image quality and lung analysis. Acta Radiol. 2016 Mar;57(3):311–7. doi: 10.1177/0284185115578469. PMID: 25838452. Exclusion Code: X3.25838452
1154 Nakamura H, Saji H, Marushima H, . Glucose uptake values in positron emission tomography are useful to predict survival after sublobar resection for lung cancer. Thorac Cardiovasc Surg. 2017 Mar;65(2):150–7. doi: 10.1055/s-0036-1572510. PMID: 26909560. Exclusion Code: X11.26909560
1155 Nakamura H, Saji H, Shinmyo T, . Close association of IASLC/ATS/ERS lung adenocarcinoma subtypes with glucose-uptake in positron emission tomography. Lung Cancer. 2015 Jan;87(1):28–33. doi: 10.1016/j.lungcan.2014.11.010. PMID: 25481488. Exclusion Code: X3.25481488
1156 Nakamura H, Sakai H, Kimura H, . Difference in Postsurgical Prognostic Factors between Lung Adenocarcinoma and Squamous Cell Carcinoma. Ann Thorac Cardiovasc Surg. 2017 Dec 20;23(6):291–7. doi: 10.5761/atcs.oa.17-00020. PMID: 28966230. Exclusion Code: X3.28966230
1157 Nakamura M, Nishimura H, Nakayama M, . Dosimetric factors predicting radiation pneumonitis after CyberKnife stereotactic body radiotherapy for peripheral lung cancer. Br J Radiol. 2016 Dec;89(1068):20160560. doi: 10.1259/bjr.20160560. PMID: 27805837. Exclusion Code: X3.27805837
1158 Nakamura S, Fukui T, Taniguchi T, . Prognostic impact of tumor size eliminating the ground glass opacity component: modified clinical T descriptors of the tumor, node, metastasis classification of lung cancer. J Thorac Oncol. 2013 Dec;8(12):1551–7. doi: 10.1097/jto.0000000000000020. PMID: 24389437. Exclusion Code: X11.24389437
1159 Nakamura T, Otsuki Y, Nakamura H, . Pleural lavage cytology after lung resection in patients with non-small cell lung cancer and the feasibility of 20 mL saline solution. Asian J Surg. 2019 Jan;42(1):283–9. doi: 10.1016/j.asjsur.2018.03.001. PMID: 29628439. Exclusion Code: X3.29628439
1160 Nakanishi R, Nakagawa M, Tokufuchi H, . Video-assisted thoracoscopic lobectomy for clinical stage I non-small cell lung cancer: experience with 111 consecutive patients demonstrating comorbidity. Minerva Chir. 2012 Feb;67(1):67–75. PMID: 22361678. Exclusion Code: X11.22361678
1161 Nakao M, Yoshida J, Goto K, . Long-term outcomes of 50 cases of limited-resection trial for pulmonary ground-glass opacity nodules. J Thorac Oncol. 2012 Oct;7(10):1563–6. doi: 10.1097/JTO.0b013e3182641b5c. PMID: 22878750. Exclusion Code: X11.22878750
1162 Nakatani M, Tanigawa N, Kariya S, . Analysis of factors influencing accuracy and complications in CT-guided lung biopsy. Minim Invasive Ther Allied Technol. 2012 Nov;21(6):415–22. doi: 10.3109/13645706.2012.662155. PMID: 22375617. Exclusion Code: X3.22375617
1163 Nakayama H, Sugahara S, Tokita M, . Proton beam therapy for patients with medically inoperable stage I non-small-cell lung cancer at the university of tsukuba. Int J Radiat Oncol Biol Phys. 2010 Oct 1;78(2):467–71. doi: 10.1016/j.ijrobp.2009.07.1707. PMID: 20056349. Exclusion Code: X6.20056349
1164 Nanda RH, Liu Y, Gillespie TW, . Stereotactic body radiation therapy versus no treatment for early stage non-small cell lung cancer in medically inoperable elderly patients: A National Cancer Data Base analysis. Cancer. 2015 Dec 1;121(23):4222–30. doi: 10.1002/cncr.29640. PMID: 26348268. Exclusion Code: X8.26348268
1165 Narsule CK, Sales Dos Santos R, Gupta A, . The efficacy of electromagnetic navigation to assist with computed tomography-guided percutaneous thermal ablation of lung tumors. Innovations (Phila). 2012 May-Jun;7(3):187–90. doi: 10.1097/IMI.0b013e318265b127. PMID: 22885459. Exclusion Code: X6.22885459
1166 Nasir BS, Edwards M, Tiffault V, . Transesophageal pulmonary nodule biopsy using endoscopic ultrasonography. J Thorac Cardiovasc Surg. 2014 Sep;148(3):850–5; discussion 5. doi: 10.1016/j.jtcvs.2014.06.007. PMID: 25048631. Exclusion Code: X11.25048631
1167 Naur TMH, Konge L, Clementsen PF. Endobronchial Ultrasound-Guided Transbronchial Needle Aspiration for Staging of Patients with Non-Small Cell Lung Cancer without Mediastinal Involvement at Positron Emission Tomography-Computed Tomography. Respiration. 2017;94(3):279–84. doi: 10.1159/000477625. PMID: 28683462. Exclusion Code: X3.28683462
1168 Navani N, Nankivell M, Lawrence DR, . Lung cancer diagnosis and staging with endobronchial ultrasound-guided transbronchial needle aspiration compared with conventional approaches: an open-label, pragmatic, randomised controlled trial. Lancet Respir Med. 2015 Apr;3(4):282–9. doi: 10.1016/s2213-2600(15)00029-6. PMID: 25660225. Exclusion Code: X3.25660225
1169 Navarria P, Ascolese AM, Mancosu P, . Volumetric modulated arc therapy with flattening filter free (FFF) beams for stereotactic body radiation therapy (SBRT) in patients with medically inoperable early stage non small cell lung cancer (NSCLC). Radiother Oncol. 2013 Jun;107(3):414–8. doi: 10.1016/j.radonc.2013.04.016. PMID: 23725859. Exclusion Code: X10.23725859
1170 Nawa T, Fukui K, Nakayama T, . A population-based cohort study to evaluate the effectiveness of lung cancer screening using low-dose CT in Hitachi city, Japan. Jpn J Clin Oncol. 2019 Feb 1;49(2):130–6. doi: 10.1093/jjco/hyy185. PMID: 30541133. Exclusion Code: X10.30541133
1171 Nct. JoLT-Ca Sublobar Resection (SR) Versus Stereotactic Ablative Radiotherapy (SAbR) for Lung Cancer. Https://clinicaltrials.gov/show/nct02468024. 2015 PMID: CN-01552762. Exclusion Code: X16.
1172 Nct. Comparison of Diagnostic and Therapeutic Efficacy of EBUS-TBNA/EUS-FNA and TEMLA in Operable NSCLC. A Randomised Controlled Trial. Https://clinicaltrials.gov/show/nct03188562. 2017 PMID: CN-01588660. Exclusion Code: X16.
1173 Nelson G, Wu M, Hinkel C, . Improved targeting accuracy of lung tumor biopsies with scanning-beam digital x-ray tomosynthesis image guidance. Med Phys. 2016 Dec;43(12):6282. doi: 10.1118/1.4966025. PMID: 27908166. Exclusion Code: X3.27908166
1174 Nemec U, Heidinger BH, Anderson KR, . Software-based risk stratification of pulmonary adenocarcinomas manifesting as pure ground glass nodules on computed tomography. Eur Radiol. 2018 Jan;28(1):235–42. doi: 10.1007/s00330-017-4937-2. PMID: 28710575. Exclusion Code: X3.28710575
1175 Nentwich MF, Bohn BA, Uzunoglu FG, . Lymphatic invasion predicts survival in patients with early node-negative non-small cell lung cancer. J Thorac Cardiovasc Surg. 2013 Oct;146(4):781–7. doi: 10.1016/j.jtcvs.2013.04.037. PMID: 23778087. Exclusion Code: X11.23778087
1176 Neroladaki A, Botsikas D, Boudabbous S, . Computed tomography of the chest with model-based iterative reconstruction using a radiation exposure similar to chest X-ray examination: preliminary observations. Eur Radiol. 2013 Feb;23(2):360–6. doi: 10.1007/s00330-012-2627-7. PMID: 22892722. Exclusion Code: X3.22892722
1177 Netto SM, Silva AC, Nunes RA, . Voxel-based comparative analysis of lung lesions in CT for therapeutic purposes. Med Biol Eng Comput. 2017 Feb;55(2):295–314. doi: 10.1007/s11517-016-1510-0. PMID: 27180182. Exclusion Code: X5.27180182
1178 Neves PC, Guerra M, Martins D, . Surgical treatment of non-small cell lung cancer in octogenarians - safety and prognosis. Rev Port Cir Cardiotorac Vasc. 2012 Apr-Jun;19(2):63–7. PMID: 23814772. Exclusion Code: X3.23814772
1179 Ng CSH, MacDonald JK, Gilbert S, . Optimal Approach to Lobectomy for Non-Small Cell Lung Cancer: Systemic Review and Meta-Analysis. Innovations (Phila). 2019 Apr;14(2):90–116. doi: 10.1177/1556984519837027. PMID: 31039680. Exclusion Code: X3.31039680
1180 Nguyen KNB, Hause DJ, Novak J, . Tumor Control and Toxicity after SBRT for Ultracentral, Central, and Paramediastinal Lung Tumors. Pract Radiat Oncol. 2019 Mar;9(2):e196–e202. doi: 10.1016/j.prro.2018.11.005. PMID: 30496842. Exclusion Code: X3.30496842
1181 Nguyen NP, Godinez J, Shen W, . Is surgery indicated for elderly patients with early stage nonsmall cell lung cancer, in the era of stereotactic body radiotherapy? Medicine (Baltimore). 2016 Oct;95(43):e5212. doi: 10.1097/md.0000000000005212. PMID: 27787380. Exclusion Code: X9.27787380
1182 Ni J, Xu L, Li W, . Simultaneous determination of thirteen kinds of amino acid and eight kinds of acylcarnitine in human serum by LC-MS/MS and its application to measure the serum concentration of lung cancer patients. Biomed Chromatogr. 2016 Nov;30(11):1796–806. doi: 10.1002/bmc.3755. PMID: 27129889. Exclusion Code: X4.27129889
1183 Nie Y, Li Q, Li F, . Integrating PET and CT information to improve diagnostic accuracy for lung nodules: A semiautomatic computer-aided method. J Nucl Med. 2006 Jul;47(7):1075–80. PMID: 16818939. Exclusion Code: X3.16818939
1184 Niezink AG, Dollekamp NJ, Elzinga HJ, . An instrument dedicated for modelling of pulmonary radiotherapy. Radiother Oncol. 2015 Apr;115(1):3–8. doi: 10.1016/j.radonc.2015.03.020. PMID: 25866028. Exclusion Code: X3.25866028
1185 Nikolaidis G, Raji OY, Markopoulou S, . DNA methylation biomarkers offer improved diagnostic efficiency in lung cancer. Cancer Res. 2012 Nov 15;72(22):5692–701. doi: 10.1158/0008-5472.can-12-2309. PMID: 22962272. Exclusion Code: X7.22962272
1186 Nishida A, Abiru H, Hayashi H, . Clinicoradiological outcomes of 33 cases of surgically resected pulmonary pleomorphic carcinoma: correlation with prognostic indicators. Eur Radiol. 2016 Jan;26(1):25–31. doi: 10.1007/s00330-015-3811-3. PMID: 25994197. Exclusion Code: X3.25994197
1187 Nishii T, Yokose T, Miyagi Y, . Prognostic value of EGFR mutations in surgically resected pathological stage I lung adenocarcinoma. Asia Pac J Clin Oncol. 2017 Oct;13(5):e204–e11. doi: 10.1111/ajco.12512. PMID: 27349355. Exclusion Code: X11.27349355
1188 Nishimura S, Takeda A, Sanuki N, . Toxicities of organs at risk in the mediastinal and hilar regions following stereotactic body radiotherapy for centrally located lung tumors. J Thorac Oncol. 2014 Sep;9(9):1370–6. doi: 10.1097/jto.0000000000000260. PMID: 25122433. Exclusion Code: X3.25122433
1189 Nishio W, Yoshimura M, Maniwa Y, . Re-assessment of intentional extended segmentectomy for clinical T1aN0 non-small cell lung cancer. Ann Thorac Surg. 2016 Nov;102(5):1702–10. doi: 10.1016/j.athoracsur.2016.05.071. PMID: 27526651. Exclusion Code: X11.27526651
1190 Nitadori J, Bograd AJ, Morales EA, . Preoperative consolidation-to-tumor ratio and SUVmax stratify the risk of recurrence in patients undergoing limited resection for lung adenocarcinoma </=2 cm. Ann Surg Oncol. 2013 Dec;20(13):4282–8. doi: 10.1245/s10434-013-3212-2. PMID: 23955584. Exclusion Code: X11.23955584
1191 Nomori H, Cong Y, Sugimura H. Limited thoracotomy for segmentectomy: a comparison of postoperative pain with thoracoscopic lobectomy. Surg Today. 2016 Nov;46(11):1243–8. doi: 10.1007/s00595-015-1302-4. PMID: 26782290. Exclusion Code: X11.26782290
1192 Nomori H, Mori T, Ikeda K, . Segmentectomy for selected cT1N0M0 non-small cell lung cancer: a prospective study at a single institute. J Thorac Cardiovasc Surg. 2012 Jul;144(1):87–93. doi: 10.1016/j.jtcvs.2012.03.034. PMID: 22502969. Exclusion Code: X11.22502969
1193 Nomori H, Shiraishi A, Cong Y, . Differences in postoperative changes in pulmonary functions following segmentectomy compared with lobectomy. Eur J Cardiothorac Surg. 2018 Mar 1;53(3):640–7. doi: 10.1093/ejcts/ezx357. PMID: 29048464. Exclusion Code: X11.29048464
1194 Nugent SM, Golden SE, Thomas CR, Jr., . Patient-clinician communication among patients with stage I lung cancer. Support Care Cancer. 2018 May;26(5):1625–33. doi: 10.1007/s00520-017-3992-1. PMID: 29209835. Exclusion Code: X8.29209835
1195 Nwaejike N, Elbur E, Malagon I, . Is there a role for the high-risk multidisciplinary team meeting in thoracic surgery? Interact Cardiovasc Thorac Surg. 2016 Apr;22(4):397–400. doi: 10.1093/icvts/ivv389. PMID: 26810916. Exclusion Code: X3.26810916
1196 Nwogu CE, D’Cunha J, Pang H, . VATS lobectomy has better perioperative outcomes than open lobectomy: CALGB 31001, an ancillary analysis of CALGB 140202 (Alliance). Ann Thorac Surg. 2015 Feb;99(2):399–405. doi: 10.1016/j.athoracsur.2014.09.018. PMID: 25499481. Exclusion Code: X3.25499481
1197 Obuchowski NA. Predicting readers’ diagnostic accuracy with a new CAD algorithm. Acad Radiol. 2011 Nov;18(11):1412–9. doi: 10.1016/j.acra.2011.07.007. PMID: 21917487. Exclusion Code: X5.21917487
1198 O’Connor GT, Hatabu H. Lung cancer screening, radiation, risks, benefits, and uncertainty. JAMA. 2012 Jun 13;307(22):2434–5. doi: 10.1001/jama.2012.6096. PMID: 22692175. Exclusion Code: X10.22692175
1199 Oechsner M, Chizzali B, Devecka M, . Interobserver variability of patient positioning using four different CT datasets for image registration in lung stereotactic body radiotherapy. Strahlenther Onkol. 2017 Oct;193(10):831–9. doi: 10.1007/s00066-017-1184-z. PMID: 28726056. Exclusion Code: X8.28726056
1200 Ogawa F, Satoh Y, Iyoda A, . Clinical impact of lung age on postoperative readmission in non-small cell lung cancer. J Surg Res. 2015 Jan;193(1):442–8. doi: 10.1016/j.jss.2014.08.028. PMID: 25255723. Exclusion Code: X3.25255723
1201 Ogawa Y, Shibamoto Y, Hashizume C, . Repeat stereotactic body radiotherapy (SBRT) for local recurrence of non-small cell lung cancer and lung metastasis after first SBRT. Radiat Oncol. 2018 Jul 28;13(1):136. doi: 10.1186/s13014-018-1080-4. PMID: 30055636. Exclusion Code: X3.30055636
1202 Oh D, Ahn YC, Seo JM, . Potentially curative stereotactic body radiation therapy (SBRT) for single or oligometastasis to the lung. Acta Oncol. 2012 May;51(5):596–602. doi: 10.3109/0284186x.2012.681698. PMID: 22548366. Exclusion Code: X3.22548366
1203 Oh DS, Reddy RM, Gorrepati ML, . Robotic-Assisted, Video-Assisted Thoracoscopic and Open Lobectomy: Propensity-Matched Analysis of Recent Premier Data. Ann Thorac Surg. 2017 Nov;104(5):1733–40. doi: 10.1016/j.athoracsur.2017.06.020. PMID: 29054214. Exclusion Code: X3.29054214
1204 Oh TK, Jeon JH, Lee JM, . Investigation of opioid use and long-term oncologic outcomes for non-small cell lung cancer patients treated with surgery. PLoS One. 2017;12(7):e0181672. doi: 10.1371/journal.pone.0181672. PMID: 28732026. Exclusion Code: X11.28732026
1205 Ohana M, Jeung MY, Bazille G, . Cerebral staging of lung cancer: is one single contrast-enhanced T1-weighted three-dimensional gradient-echo sequence sufficient? Neuroradiology. 2014 Aug;56(8):621–7. doi: 10.1007/s00234-014-1366-7. PMID: 24829164. Exclusion Code: X3.24829164
1206 Ohno Y, Koyama H, Nogami M, . Whole-body MR imaging vs. FDG-PET: comparison of accuracy of M-stage diagnosis for lung cancer patients. J Magn Reson Imaging. 2007 Sep;26(3):498–509. doi: 10.1002/jmri.21031. PMID: 17729341. Exclusion Code: X3.17729341
1207 Ohno Y, Koyama H, Takenaka D, . Dynamic MRI, dynamic multidetector-row computed tomography (MDCT), and coregistered 2-[fluorine-18]-fluoro-2-deoxy-D-glucose-positron emission tomography (FDG-PET)/CT: comparative study of capability for management of pulmonary nodules. J Magn Reson Imaging. 2008 Jun;27(6):1284–95. doi: 10.1002/jmri.21348. PMID: 18504748. Exclusion Code: X3.18504748
1208 Ohno Y, Koyama H, Yoshikawa T, . Standard-, Reduced-, and No-Dose Thin-Section Radiologic Examinations: Comparison of Capability for Nodule Detection and Nodule Type Assessment in Patients Suspected of Having Pulmonary Nodules. Radiology. 2017 Aug;284(2):562–73. doi: 10.1148/radiol.2017161037. PMID: 28263700. Exclusion Code: X5.28263700
1209 Ohno Y, Nishio M, Koyama H, . Journal Club: Comparison of assessment of preoperative pulmonary vasculature in patients with non-small cell lung cancer by non-contrast- and 4D contrast-enhanced 3-T MR angiography and contrast-enhanced 64-MDCT. AJR Am J Roentgenol. 2014 Mar;202(3):493–506. doi: 10.2214/ajr.13.10833. PMID: 24555585. Exclusion Code: X8.24555585
1210 Ohri N, Tome W, Kalnicki S, . Stereotactic body radiation therapy for stage I non-small cell lung cancer: The importance of treatment planning algorithm and evaluation of a tumor control probability model. Pract Radiat Oncol. 2018 Mar - Apr;8(2):e33–e9. doi: 10.1016/j.prro.2017.10.002. PMID: 29233523. Exclusion Code: X8.29233523
1211 Ohtaka K, Hida Y, Kaga K, . Limited resection and two-staged lobectomy for non-small cell lung cancer with ground-glass opacity. J Cardiothorac Surg. 2013 Apr 24;8:111. doi: 10.1186/1749-8090-8-111. PMID: 23618098. Exclusion Code: X11.23618098
1212 Okada A, Hirono T, Watanabe T. Safety and prognosis of limited surgery for octogenarians with non-small-cell lung cancer. Gen Thorac Cardiovasc Surg. 2012 Feb;60(2):97–103. doi: 10.1007/s11748-011-0880-3. PMID: 22327854. Exclusion Code: X11.22327854
1213 Okada M, Tsutani Y, Ikeda T, . Radical hybrid video-assisted thoracic segmentectomy: long-term results of minimally invasive anatomical sublobar resection for treating lung cancer. Interact Cardiovasc Thorac Surg. 2012 Jan;14(1):5–11. doi: 10.1093/icvts/ivr065. PMID: 22108951. Exclusion Code: X11.22108951
1214 Okada S, Shimada J, Kato D, . Prolonged air leak following lobectomy can be predicted in lung cancer patients. Surg Today. 2017 Aug;47(8):973–9. doi: 10.1007/s00595-016-1467-5. PMID: 28091813. Exclusion Code: X11.28091813
1215 Okada S, Shimada J, Kato D, . Clinical significance of prognostic nutritional index after surgical treatment in lung cancer. Ann Thorac Surg. 2017 Jul;104(1):296–302. doi: 10.1016/j.athoracsur.2017.01.085. PMID: 28433217. Exclusion Code: X3.28433217
1216 Okada S, Shimada J, Teramukai S, . Risk Stratification According to the Prognostic Nutritional Index for Predicting Postoperative Complications After Lung Cancer Surgery. Ann Surg Oncol. 2018 May;25(5):1254–61. doi: 10.1245/s10434-018-6368-y. PMID: 29450756. Exclusion Code: X3.29450756
1217 Okamoto J, Kubokura H, Usuda J. Factors determining the choice of surgical procedure in elderly patients with non-small cell lung cancer. Ann Thorac Cardiovasc Surg. 2016 Jun 20;22(3):131–8. doi: 10.5761/atcs.oa.15-00365. PMID: 26822739. Exclusion Code: X11.26822739
1218 Okamoto J, Kubokura H, Usuda J. Prognostic effect of incompletely lobulated fissures in p-Stage I non-small-cell lung cancer. Interact Cardiovasc Thorac Surg. 2018 Feb 1;26(2):264–70. doi: 10.1093/icvts/ivx305. PMID: 29049783. Exclusion Code: X11.29049783
1219 Okamura K, Takayama K, Izumi M, . Diagnostic value of CEA and CYFRA 21-1 tumor markers in primary lung cancer. Lung Cancer. 2013 Apr;80(1):45–9. doi: 10.1016/j.lungcan.2013.01.002. PMID: 23352032. Exclusion Code: X5.23352032
1220 Oken MM, Hocking WG, Kvale PA, . Screening by chest radiograph and lung cancer mortality: the Prostate, Lung, Colorectal, and Ovarian (PLCO) randomized trial. JAMA. 2011 Nov 02;306(17):1865–73. doi: 10.1001/jama.2011.1591. PMID: 22031728. Exclusion Code: X5.22031728
1221 Okereke IC, Bates MF, Jankowich MD, . Effects of implementation of lung cancer screening at one Veterans Affairs medical center. Chest. 2016 Nov;150(5):1023–9. doi: 10.1016/j.chest.2016.08.1431. PMID: 27568228. Exclusion Code: X8.27568228
1222 Oki M, Saka H, Ando M, . Endoscopic ultrasound-guided fine needle aspiration and endobronchial ultrasound-guided transbronchial needle aspiration: Are two better than one in mediastinal staging of non-small cell lung cancer? J Thorac Cardiovasc Surg. 2014 Oct;148(4):1169–77. doi: 10.1016/j.jtcvs.2014.05.023. PMID: 24930616. Exclusion Code: X3.24930616
1223 Olaiya B, Gilliland CA, Force SD, . Preoperative Computed Tomography-Guided Pulmonary Lesion Marking in Preparation for Fluoroscopic Wedge Resection-Rates of Success, Complications, and Pathology Outcomes. Curr Probl Diagn Radiol. 2019 Jan;48(1):27–31. doi: 10.1067/j.cpradiol.2017.10.012. PMID: 29203261. Exclusion Code: X11.29203261
1224 Omori T, Tajiri M, Baba T, . Pulmonary resection for lung cancer in patients with idiopathic interstitial pneumonia. Ann Thorac Surg. 2015 Sep;100(3):954–60. doi: 10.1016/j.athoracsur.2015.03.094. PMID: 26116477. Exclusion Code: X3.26116477
1225 Onaitis MW, Furnary AP, Kosinski AS, . Prediction of long-term survival after lung cancer surgery for elderly patients in The Society of Thoracic Surgeons General Thoracic Surgery Database. Ann Thorac Surg. 2018 Jan;105(1):309–16. doi: 10.1016/j.athoracsur.2017.06.071. PMID: 29174391. Exclusion Code: X3.29174391
1226 Ong P, Grosu H, Eapen GA, . Endobronchial ultrasound-guided transbronchial needle aspiration for systematic nodal staging of lung cancer in patients with N0 disease by computed tomography and integrated positron emission tomography-computed tomography. Ann Am Thorac Soc. 2015 Mar;12(3):415–9. doi: 10.1513/AnnalsATS.201409-429OC. PMID: 25584815. Exclusion Code: X3.25584815
1227 Onishi H, Marino K, Yamashita H, . Case Series of 23 Patients Who Developed Fatal Radiation Pneumonitis After Stereotactic Body Radiotherapy for Lung Cancer. Technol Cancer Res Treat. 2018 Jan 1;17:1533033818801323. doi: 10.1177/1533033818801323. PMID: 30286697. Exclusion Code: X3.30286697
1228 Onishi H, Shioyama Y, Matsumoto Y, . Excellent survival! Multi-institutional study of stereotactic body radiation therapy for medically operable and young (70 years old or younger) patients with stage I non-small cell lung cancer. International journal of radiation oncology. 2016;96(2):E434–. doi: 10.1016/j.ijrobp.2016.06.1720. PMID: CN-01420424. Exclusion Code: X2.
1229 Onishi H, Shirato H, Nagata Y, . Stereotactic body radiotherapy (SBRT) for operable stage I non-small-cell lung cancer: can SBRT be comparable to surgery? Int J Radiat Oncol Biol Phys. 2011 Dec 1;81(5):1352–8. doi: 10.1016/j.ijrobp.2009.07.1751. PMID: 20638194. Exclusion Code: X11.20638194
1230 Ooi H, Chen CY, Hsiao YC, . Influence of thyroid transcription factor-1 on fluorodeoxyglucose uptake and prognosis of non-small cell lung cancer. Anticancer Res. 2014 May;34(5):2467–75. PMID: 24778062. Exclusion Code: X3.24778062
1231 Oor JE, Daniels JM, Debets-Ossenkopp YJ, . Bronchial colonization and complications after lung cancer surgery. Langenbecks Arch Surg. 2016 Sep;401(6):885–92. doi: 10.1007/s00423-016-1487-z. PMID: 27485548. Exclusion Code: X3.27485548
1232 Oosterhuis JW, Verstegen N, Van Der Elst A, . Propensity score-matched analysis of stage I-II non-small cell lung cancer treated by video-assisted thoracoscopic lobectomy or stereotactic ablative radiotherapy. Interact Cardiovasc Thorac Surg. 2013;17doi: 10.1093/icvts/ivt288.1. PMID: CN-01007011. Exclusion Code: X2.
1233 Opoka L, Kunikowska J, Podgajny Z, . Accuracy of FDG PET/CT in the evaluation of solitary pulmonary lesions - own experience. Pneumonol Alergol Pol. 2014;82(3):198–205. doi: 10.5603/PiAP.2014.0027. PMID: 24793147. Exclusion Code: X3.24793147
1234 Ose N, Sawabata N, Minami M, . Lymph node metastasis diagnosis using positron emission tomography with 2-[18F] fluoro-2-deoxy-D-glucose as a tracer and computed tomography in surgical cases of non-small cell lung cancer. Eur J Cardiothorac Surg. 2012 Jul;42(1):89–92. doi: 10.1093/ejcts/ezr287. PMID: 22290887. Exclusion Code: X6.22290887
1235 O’Shea K, Cameron SJ, Lewis KE, . Metabolomic-based biomarker discovery for non-invasive lung cancer screening: a case study. Biochim Biophys Acta. 2016 Nov;1860(11 Pt B):2682–7. doi: 10.1016/j.bbagen.2016.07.007. PMID: 27423423. Exclusion Code: X5.27423423
1236 Oskarsdottir GN, Halldorsson H, Sigurdsson MI, . Lobectomy for non-small cell lung carcinoma: a nationwide study of short- and long-term survival. Acta Oncol. 2017 Jul;56(7):936–42. doi: 10.1080/0284186x.2017.1304652. PMID: 28325129. Exclusion Code: X3.28325129
1237 Oswald N, Halle-Smith J, Kerr A, . Perioperative immune function and pain control may underlie early hospital readmission and 90 day mortality following lung cancer resection: A prospective cohort study of 932 patients. Eur J Surg Oncol. 2019 May;45(5):863–9. doi: 10.1016/j.ejso.2019.02.001. PMID: 30795954. Exclusion Code: X3.30795954
1238 Otake S, Ohtsuka T, Asakura K, . Impact of comorbidity index on morbidity and survival in non-small cell lung cancer. Asian Cardiovasc Thorac Ann. 2016 Jan;24(1):30–3. doi: 10.1177/0218492315617834. PMID: 26567555. Exclusion Code: X3.26567555
1239 Oudkerk M, Heuvelmans MA. Screening for lung cancer by imaging: the Nelson study. Jbr-btr. 2013 May-Jun;96(3):163–6. PMID: 23971173. Exclusion Code: X8.23971173
1240 Ozawa Y, Abe T, Omae M, . Impact of preexisting interstitial lung disease on acute, extensive radiation pneumonitis: retrospective analysis of patients with lung cancer. PLoS One. 2015;10(10):e0140437. doi: 10.1371/journal.pone.0140437. PMID: 26460792. Exclusion Code: X3.26460792
1241 Ozawa Y, Hara M, Sakurai K, . Diagnostic accuracy of (18)F-2-deoxy-fluoro-D-glucose positron emission tomography for pN2 lymph nodes in patients with lung cancer. Acta Radiol. 2010 Mar;51(2):150–5. doi: 10.3109/02841850903485763. PMID: 20092375. Exclusion Code: X3.20092375
1242 Ozeki N, Iwano S, Taniguchi T, . Therapeutic surgery without a definitive diagnosis can be an option in selected patients with suspected lung cancer. Interact Cardiovasc Thorac Surg. 2014 Nov;19(5):830–7. doi: 10.1093/icvts/ivu233. PMID: 25038121. Exclusion Code: X11.25038121
1243 Pages PB, Delpy JP, Orsini B, . Propensity score analysis comparing videothoracoscopic lobectomy with thoracotomy: a French nationwide study. Ann Thorac Surg. 2016 Apr;101(4):1370–8. doi: 10.1016/j.athoracsur.2015.10.105. PMID: 26872732. Exclusion Code: X3.26872732
1244 Pages PB, Mordant P, Cazes A, . Prognosis of lung cancer resection in patients with previous extra-respiratory solid malignancies. Eur J Cardiothorac Surg. 2013 Sep;44(3):534–8. doi: 10.1093/ejcts/ezt031. PMID: 23392106. Exclusion Code: X3.23392106
1245 Pages PB, Mordant P, Grand B, . History of multiple previous malignancies should not be a contraindication to the surgical resection of lung cancer. Ann Thorac Surg. 2013 Mar;95(3):1000–5. doi: 10.1016/j.athoracsur.2012.11.072. PMID: 23375734. Exclusion Code: X3.23375734
1246 Pairon JC, Andujar P, Rinaldo M, . Asbestos exposure, pleural plaques, and the risk of death from lung cancer. Am J Respir Crit Care Med. 2014 Dec 15;190(12):1413–20. doi: 10.1164/rccm.201406-1074OC. PMID: 25383951. Exclusion Code: X7.25383951
1247 Pais FM, Shah RA, Vempilly JJ, . Transesophageal approach to lung, adrenal biopsy and fiducial placement using endoscopic ultrasonography (EUS): An interventional pulmonology experience. Initial experience of the UCSF-FRETOC (fresno tracheobronchial & oesophageal center) study group. Respir Med. 2018 Aug;141:52–5. doi: 10.1016/j.rmed.2018.06.019. PMID: 30053972. Exclusion Code: X11.30053972
1248 Paks M, Leong P, Einsiedel P, . Ultralow dose CT for follow-up of solid pulmonary nodules: A pilot single-center study using Bland-Altman analysis. Medicine (Baltimore). 2018 Aug;97(34):e12019. doi: 10.1097/md.0000000000012019. PMID: 30142849. Exclusion Code: X11.30142849
1249 Palade E, Passlick B, Osei-Agyemang T, . Video-assisted vs open mediastinal lymphadenectomy for Stage I non-small-cell lung cancer: results of a prospective randomized trial. Eur J Cardiothorac Surg. 2013 Aug;44(2):244–9; discussion 9. doi: 10.1093/ejcts/ezs668. PMID: 23295451. Exclusion Code: X11.23295451
1250 Palleschi A, Privitera E, Lazzeri M, . Prophylactic continuous positive airway pressure after pulmonary lobectomy: a randomized controlled trial. J Thorac Dis. 2018 May;10(5):2829–36. doi: 10.21037/jtd.2018.05.46. PMID: 29997946. Exclusion Code: X6.29997946
1251 Palussiere J, Canella M, Cornelis F, . Retrospective review of thoracic neural damage during lung ablation - what the interventional radiologist needs to know about neural thoracic anatomy. Cardiovasc Intervent Radiol. 2013 Dec;36(6):1602–13. doi: 10.1007/s00270-013-0597-z. PMID: 23576208. Exclusion Code: X6.23576208
1252 Palussiere J, Lagarde P, Auperin A, . Percutaneous lung thermal ablation of non-surgical clinical N0 non-small cell lung cancer: results of eight years’ experience in 87 patients from two centers. Cardiovasc Intervent Radiol. 2015 Feb;38(1):160–6. doi: 10.1007/s00270-014-0999-6. PMID: 25394595. Exclusion Code: X6.25394595
1253 Pan L, Qiang Y, Yuan J, . Rapid retrieval of lung nodule CT images based on hashing and pruning methods. Biomed Res Int. 2016;2016:3162649. doi: 10.1155/2016/3162649. PMID: 27995140. Exclusion Code: X3.27995140
1254 Pan TW, Wu B, Xu ZF, . Video-assisted thoracic surgery versus thoracotomy for non-small-cell lung cancer. Asian Pac J Cancer Prev. 2012;13(2):447–50. PMID: 22524804. Exclusion Code: X3.22524804
1255 Panchabhai TS, Arrossi AV, Patil PD, . Unexpected Neoplasms in Lungs Explanted From Lung Transplant Recipients: A Single-Center Experience and Review of Literature. Transplant Proc. 2018 Jan - Feb;50(1):234–40. doi: 10.1016/j.transproceed.2017.12.024. PMID: 29407315. Exclusion Code: X3.29407315
1256 Papiashvilli M, Sasson L, Azzam S, . Video-assisted thoracic surgery lobectomy versus lobectomy by thoracotomy for lung cancer: pilot study. Innovations (Phila). 2013 Jan-Feb;8(1):6–11. doi: 10.1097/IMI.0b013e31828d5f15. PMID: 23571787. Exclusion Code: X3.23571787
1257 Papiashvilli M, Stav D, Cyjon A, . Lobectomy for non-small cell lung cancer: differences in morbidity and mortality between thoracotomy and thoracoscopy. Innovations (Phila). 2012 Jan-Feb;7(1):15–22. doi: 10.1097/IMI.0b013e3182566221. PMID: 22576031. Exclusion Code: X3.22576031
1258 Parashar B, Port J, Arora S, . Analysis of stereotactic radiation vs. wedge resection vs. wedge resection plus Cesium-131 brachytherapy in early stage lung cancer. Brachytherapy. 2015 Sep-Oct;14(5):648–54. doi: 10.1016/j.brachy.2015.04.001. PMID: 25998071. Exclusion Code: X10.25998071
1259 Pardolesi A, Park B, Petrella F, . Robotic anatomic segmentectomy of the lung: technical aspects and initial results. Ann Thorac Surg. 2012 Sep;94(3):929–34. doi: 10.1016/j.athoracsur.2012.04.086. PMID: 22748642. Exclusion Code: X3.22748642
1260 Park B, Lee G, Kim HK, . A retrospective comparative analysis of elderly and younger patients undergoing pulmonary resection for stage I non-small cell lung cancer. World J Surg Oncol. 2016 Jan 19;14(1):13. doi: 10.1186/s12957-015-0762-8. PMID: 26787343. Exclusion Code: X10.26787343
1261 Park BJ. Robotic lobectomy for non-small cell lung cancer: long-term oncologic results. Thorac Surg Clin. 2014 May;24(2):157–62, vi. doi: 10.1016/j.thorsurg.2014.02.011. PMID: 24780419. Exclusion Code: X11.24780419
1262 Park BJ, Melfi F, Mussi A, . Robotic lobectomy for non-small cell lung cancer (NSCLC): long-term oncologic results. J Thorac Cardiovasc Surg. 2012 Feb;143(2):383–9. doi: 10.1016/j.jtcvs.2011.10.055. PMID: 22104677. Exclusion Code: X3.22104677
1263 Park ER, Gareen IF, Jain A, . Examining whether lung screening changes risk perceptions: National Lung Screening Trial participants at 1-year follow-up. Cancer. 2013 Apr 1;119(7):1306–13. doi: 10.1002/cncr.27925. PMID: 23280348. Exclusion Code: X11.23280348
1264 Park HS, Harder EM, Mancini BR, . Central versus peripheral tumor location: influence on survival, local control, and toxicity following stereotactic body radiotherapy for primary non-small-cell lung cancer. J Thorac Oncol. 2015 May;10(5):832–7. doi: 10.1097/jto.0000000000000484. PMID: 25634007. Exclusion Code: X3.25634007
1265 Park S, Nam BH, Yang HR, . Individualized risk prediction model for lung cancer in Korean men. PLoS One. 2013;8(2):e54823. doi: 10.1371/journal.pone.0054823. PMID: 23408946. Exclusion Code: X7.23408946
1266 Park SB, Choi JY, Moon SH, . Prognostic value of volumetric metabolic parameters measured by [18F]fluorodeoxyglucose-positron emission tomography/computed tomography in patients with small cell lung cancer. Cancer Imaging. 2014 Apr 22;14:2. doi: 10.1186/1470-7330-14-2. PMID: 25609313. Exclusion Code: X3.25609313
1267 Park SL, Fesinmeyer MD, Timofeeva M, . Pleiotropic associations of risk variants identified for other cancers with lung cancer risk: the PAGE and TRICL consortia. J Natl Cancer Inst. 2014 Apr;106(4):dju061. doi: 10.1093/jnci/dju061. PMID: 24681604. Exclusion Code: X7.24681604
1268 Park SY, Cho A, Yu WS, . Prognostic value of total lesion glycolysis by 18F-FDG PET/CT in surgically resected stage IA non-small cell lung cancer. J Nucl Med. 2015 Jan;56(1):45–9. doi: 10.2967/jnumed.114.147561. PMID: 25525185. Exclusion Code: X11.25525185
1269 Park SY, Lee HS, Jang HJ, . Wedge bronchoplastic lobectomy for non-small cell lung cancer as an alternative to sleeve lobectomy. J Thorac Cardiovasc Surg. 2012 Apr;143(4):825–31.e3. doi: 10.1016/j.jtcvs.2011.10.057. PMID: 22104687. Exclusion Code: X3.22104687
1270 Pastorino U, Boffi R, Marchiano A, . Stopping smoking reduces mortality in low-dose computed tomography screening participants. J Thorac Oncol. 2016 May;11(5):693–9. doi: 10.1016/j.jtho.2016.02.011. PMID: 26921675. Exclusion Code: X8.26921675
1271 Pastorino U, Morelli D, Marchiano A, . Inflammatory status and lung function predict mortality in lung cancer screening participants. Eur J Cancer Prev. 2018 Jul;27(4):289–95. doi: 10.1097/cej.0000000000000342. PMID: 28333763. Exclusion Code: X4.28333763
1272 Pastorino U, Rossi M, Rosato V, . Annual or biennial CT screening versus observation in heavy smokers: 5-year results of the MILD trial. Eur J Cancer Prev. 2012 May;21(3):308–15. doi: 10.1097/CEJ.0b013e328351e1b6. PMID: 22465911. Exclusion Code: X17.22465911
1273 Pastorino U, Silva M, Sestini S, . Prolonged lung cancer screening reduced 10-year mortality in the MILD trial: new confirmation of lung cancer screening efficacy. Ann Oncol. 2019 Jun 5 doi: 10.1093/annonc/mdz169. PMID: 31168572. Exclusion Code: X17.31168572
1274 Patel MV, Ahmed O, Jilani D, . Computed tomography-guided percutaneous lung biopsy: impact of lesion proximity to diaphragm on biopsy yield and pneumothorax rate. J Thorac Imaging. 2014 Nov;29(6):344–9. doi: 10.1097/rti.0000000000000112. PMID: 25314026. Exclusion Code: X3.25314026
1275 Patel S, Cho A, Lamont A, . Implementing a community hospital lung cancer screening program: a multidisciplinary program and a standardized reporting system. J Am Coll Radiol. 2014 May;11(5):527–30. doi: 10.1016/j.jacr.2013.09.004. PMID: 24529982. Exclusion Code: X10.24529982
1276 Pathak RS, Tibdewal AR, S GL, . Volume changes with stereotactic body radiation therapy in early lung cancer: Time trends and outcomes. J Med Imaging Radiat Oncol. 2016 Oct;60(5):661–7. doi: 10.1111/1754-9485.12476. PMID: 27241661. Exclusion Code: X10.27241661
1277 Patz EF, Jr., Greco E, Gatsonis C, . Lung cancer incidence and mortality in National Lung Screening Trial participants who underwent low-dose CT prevalence screening: a retrospective cohort analysis of a randomised, multicentre, diagnostic screening trial. Lancet Oncol. 2016 May;17(5):590–9. doi: 10.1016/s1470-2045(15)00621-x. PMID: 27009070. Exclusion Code: X7.27009070
1278 Paul S, Isaacs AJ, Treasure T, . Long term survival with thoracoscopic versus open lobectomy: propensity matched comparative analysis using SEER-Medicare database. BMJ. 2014 Oct 2;349:g5575. doi: 10.1136/bmj.g5575. PMID: 25277994. Exclusion Code: X3.25277994
1279 Paul S, Lee PC, Mao J, . Long term survival with stereotactic ablative radiotherapy (SABR) versus thoracoscopic sublobar lung resection in elderly people: national population based study with propensity matched comparative analysis. BMJ. 2016 Jul 8;354:i3570. doi: 10.1136/bmj.i3570. PMID: 27400862. Exclusion Code: X13.27400862
1280 Pawaroo D, Cummings NM, Musonda P, . Non-small cell lung carcinoma: accuracy of PET/CT in determining the size of T1 and T2 primary tumors. AJR Am J Roentgenol. 2011 May;196(5):1176–81. doi: 10.2214/ajr.10.4980. PMID: 21512089. Exclusion Code: X3.21512089
1281 Paximadis P, Beebe-Dimmer JL, George J, . Comparing Treatment Strategies for Stage I Small-cell lung Cancer. Clin Lung Cancer. 2018 Sep;19(5):e559–e65. doi: 10.1016/j.cllc.2018.03.017. PMID: 29656869. Exclusion Code: X3.29656869
1282 Pedersen JH, Petersen RH, Hansen HJ. Lung cancer screening trials: Denmark and beyond. J Thorac Cardiovasc Surg. 2012 Sep;144(3):S7–8. doi: 10.1016/j.jtcvs.2012.03.066. PMID: 22513316. Exclusion Code: X2.22513316
1283 Peikert T, Duan F, Rajagopalan S, . Novel high-resolution computed tomography-based radiomic classifier for screen-identified pulmonary nodules in the National Lung Screening Trial. PLoS One. 2018;13(5):e0196910. doi: 10.1371/journal.pone.0196910. PMID: 29758038. Exclusion Code: X8.29758038
1284 Peled N, Hakim M, Bunn PA, Jr., . Non-invasive breath analysis of pulmonary nodules. J Thorac Oncol. 2012 Oct;7(10):1528–33. doi: 10.1097/JTO.0b013e3182637d5f. PMID: 22929969. Exclusion Code: X3.22929969
1285 Peng H, Wang J, Li J, . A circulating non-coding RNA panel as an early detection predictor of non-small cell lung cancer. Life Sci. 2016 Apr 15;151:235–42. doi: 10.1016/j.lfs.2016.03.002. PMID: 26946307. Exclusion Code: X3.26946307
1286 Peng M, Li Z, Hu H, . Pulmonary ground-glass nodules diagnosis: mean change rate of peak CT number as a discriminative factor of pathology during a follow-up. Br J Radiol. 2016;89(1058):20150556. doi: 10.1259/bjr.20150556. PMID: 26562098. Exclusion Code: X3.26562098
1287 Peng Z, Liu Q, Li M, . Comparison of (11)C-choline PET/CT and enhanced CT in the evaluation of patients with pulmonary abnormalities and locoregional lymph node involvement in lung cancer. Clin Lung Cancer. 2012 Jul;13(4):312–20. doi: 10.1016/j.cllc.2011.09.005. PMID: 22182444. Exclusion Code: X3.22182444
1288 Penn A, Ma M, Chou BB, . Inter-reader variability when applying the 2013 Fleischner guidelines for potential solitary subsolid lung nodules. Acta Radiol. 2015 Oct;56(10):1180–6. doi: 10.1177/0284185114551975. PMID: 25293951. Exclusion Code: X3.25293951
1289 Pepek JM, Marks LB, Berry MF, . Accuracy of positron emission tomography in identifying hilar (N1) lymph node involvement in non-small cell lung cancer: Implications for stereotactic body radiation therapy. Pract Radiat Oncol. 2015 Mar-Apr;5(2):79–84. doi: 10.1016/j.prro.2014.05.002. PMID: 25413417. Exclusion Code: X3.25413417
1290 Perandini S, Soardi GA, Larici AR, . Multicenter external validation of two malignancy risk prediction models in patients undergoing 18F-FDG-PET for solitary pulmonary nodule evaluation. Eur Radiol. 2017 May;27(5):2042–6. doi: 10.1007/s00330-016-4580-3. PMID: 27631108. Exclusion Code: X3.27631108
1291 Perandini S, Soardi GA, Motton M, . Limited value of logistic regression analysis in solid solitary pulmonary nodules characterization: a single-center experience on 288 consecutive cases. J Surg Oncol. 2014 Dec;110(7):883–7. doi: 10.1002/jso.23730. PMID: 25088475. Exclusion Code: X11.25088475
1292 Percac-Lima S, Ashburner JM, Rigotti N, . Lung cancer screening patient navigation for current smokers in community health centers: a randomized controlled trial. J Clin Oncol. 2017;35(15)PMID: CN-01781835. Exclusion Code: X2.
1293 Percac-Lima S, Ashburner JM, Rigotti NA, . Patient navigation for lung cancer screening among current smokers in community health centers a randomized controlled trial. Cancer medicine. 2018;7(3):894–902. doi: 10.1002/cam4.1297. PMID: CN-01764144. Exclusion Code: X6.29464877
1294 Percac-Lima S, Ashburner JM, Shepard JA, . Timeliness of recommended follow-up after an abnormal finding on diagnostic chest CT in smokers at high risk of developing lung cancer. J Am Coll Radiol. 2016 May;13(5):497–504. doi: 10.1016/j.jacr.2016.01.007. PMID: 26924163. Exclusion Code: X11.26924163
1295 Perisinakis K, Seimenis I, Tzedakis A, . Radiation burden and associated cancer risk for a typical population to be screened for lung cancer with low-dose CT: A phantom study. Eur Radiol. 2018 Oct;28(10):4370–8. doi: 10.1007/s00330-018-5373-7. PMID: 29651767. Exclusion Code: X10.29651767
1296 Persson GF, Nygaard DE, Hollensen C, . Interobserver delineation variation in lung tumour stereotactic body radiotherapy. Br J Radiol. 2012 Sep;85(1017):e654–60. doi: 10.1259/bjr/76424694. PMID: 22919015. Exclusion Code: X8.22919015
1297 Peschke A, Wiedemann B, Hoffken G, . Forceps biopsy and suction catheter for sampling in pulmonary nodules and infiltrates. Eur Respir J. 2012 Jun;39(6):1432–6. doi: 10.1183/09031936.00024111. PMID: 22005922. Exclusion Code: X3.22005922
1298 Peters S, Michielin O, Zimmermann S. Dramatic response induced by vemurafenib in a BRAF V600E-mutated lung adenocarcinoma. J Clin Oncol. 2013 Jul 10;31(20):e341–4. doi: 10.1200/jco.2012.47.6143. PMID: 23733758. Exclusion Code: X10.23733758
1299 Petersen RH, Hansen HJ, Dirksen A, . Lung cancer screening and video-assisted thoracic surgery. J Thorac Oncol. 2012 Jun;7(6):1026–31. doi: 10.1097/JTO.0b013e31824fe942. PMID: 22588154. Exclusion Code: X3.22588154
1300 Petit SF, van Elmpt W. Accurate prediction of target dose-escalation and organ-at-risk dose levels for non-small cell lung cancer patients. Radiother Oncol. 2015 Dec;117(3):453–8. doi: 10.1016/j.radonc.2015.07.040. PMID: 26306678. Exclusion Code: X3.26306678
1301 Phillips M, Bauer TL, Cataneo RN, . Blinded validation of breath biomarkers of lung cancer, a potential ancillary to chest CT screening. PLoS One. 2015;10(12):e0142484. doi: 10.1371/journal.pone.0142484. PMID: 26698306. Exclusion Code: X5.26698306
1302 Pierson C, Grinchak T, Sokolovic C, . Response criteria in solid tumors (PERCIST/RECIST) and SUVmax in early-stage non-small cell lung cancer patients treated with stereotactic body radiotherapy. Radiat Oncol. 2018 Feb 27;13(1):34. doi: 10.1186/s13014-018-0980-7. PMID: 29486779. Exclusion Code: X8.29486779
1303 Pilyugin M, Descloux P, Andre PA, . BARD1 serum autoantibodies for the detection of lung cancer. PLoS One. 2017;12(8):e0182356. doi: 10.1371/journal.pone.0182356. PMID: 28786985. Exclusion Code: X5.28786985
1304 Pinato DJ, Shiner RJ, Seckl MJ, . Prognostic performance of inflammation-based prognostic indices in primary operable non-small cell lung cancer. Br J Cancer. 2014 Apr 15;110(8):1930–5. doi: 10.1038/bjc.2014.145. PMID: 24667648. Exclusion Code: X3.24667648
1305 Pine SR, Mechanic LE, Enewold L, . Differential serum cytokine levels and risk of lung cancer between African and European Americans. Cancer Epidemiol Biomarkers Prev. 2016 Mar;25(3):488–97. doi: 10.1158/1055-9965.epi-15-0378. PMID: 26711330. Exclusion Code: X7.26711330
1306 Pinheiro LC, Reeve BB. Investigating the prognostic ability of health-related quality of life on survival: a prospective cohort study of adults with lung cancer. Support Care Cancer. 2018 Nov;26(11):3925–32. doi: 10.1007/s00520-018-4265-3. PMID: 29777380. Exclusion Code: X3.29777380
1307 Pinheiro LC, Zagar TM, Reeve BB. The prognostic value of pre-diagnosis health-related quality of life on survival: a prospective cohort study of older Americans with lung cancer. Qual Life Res. 2017 Jul;26(7):1703–12. doi: 10.1007/s11136-017-1515-7. PMID: 28194618. Exclusion Code: X3.28194618
1308 Pinsky PF, Dunn B, Gierada D, . Incidental renal tumours on low-dose CT lung cancer screening exams. J Med Screen. 2017 Jun;24(2):104–9. doi: 10.1177/0969141316657115. PMID: 28482765. Exclusion Code: X8.28482765
1309 Pinsky PF, Gierada DS, Nath PH, . Lung cancer risk associated with new solid nodules in the National Lung Screening Trial. AJR Am J Roentgenol. 2017 Nov;209(5):1009–14. doi: 10.2214/ajr.17.18252. PMID: 28898131. Exclusion Code: X7.28898131
1310 Pinsky PF, Marcus PM, Kramer BS, . Diagnostic procedures after a positive spiral computed tomography lung carcinoma screen. Cancer. 2005 Jan 1;103(1):157–63. doi: 10.1002/cncr.20746. PMID: 15529306. Exclusion Code: X8.15529306
1311 Pinsky PF, Nath PH, Gierada DS, . Short- and long-term lung cancer risk associated with noncalcified nodules observed on low-dose CT. Cancer Prev Res (Phila). 2014 Dec;7(12):1179–85. doi: 10.1158/1940-6207.capr-13-0438. PMID: 24755313. Exclusion Code: X8.24755313
1312 Pinsky PF, Zhu CS, Kramer BS. Lung cancer risk by years since quitting in 30+ pack year smokers. J Med Screen. 2015 Sep;22(3):151–7. doi: 10.1177/0969141315579119. PMID: 25926339. Exclusion Code: X7.25926339
1313 Planquette B, Le Pimpec-Barthes F, Trinquart L, . Early respiratory acidosis is a new risk factor for pneumonia after lung resection. Interact Cardiovasc Thorac Surg. 2012 Mar;14(3):244–8. doi: 10.1093/icvts/ivr115. PMID: 22184462. Exclusion Code: X3.22184462
1314 Pletnikoff PP, Laukkanen JA, Tuomainen TP, . Cardiorespiratory fitness, C-reactive protein and lung cancer risk: a prospective population-based cohort study. Eur J Cancer. 2015 Jul;51(11):1365–70. doi: 10.1016/j.ejca.2015.04.020. PMID: 26008754. Exclusion Code: X4.26008754
1315 Pletnikoff PP, Tuomainen TP, Laukkanen JA, . Cardiorespiratory fitness and lung cancer risk: a prospective population-based cohort study. J Sci Med Sport. 2016 Feb;19(2):98–102. doi: 10.1016/j.jsams.2015.02.008. PMID: 25800392. Exclusion Code: X4.25800392
1316 Pollom EL, Qian Y, Durkee BY, . Hypofractionated intensity-modulated radiotherapy for patients with non-small-cell lung cancer. Clin Lung Cancer. 2016 Nov;17(6):588–94. doi: 10.1016/j.cllc.2016.05.024. PMID: 27378172. Exclusion Code: X6.27378172
1317 Pompe E, de Jong PA, de Jong WU, . Inter-observer and inter-examination variability of manual vertebral bone attenuation measurements on computed tomography. Eur Radiol. 2016 Sep;26(9):3046–53. doi: 10.1007/s00330-015-4145-x. PMID: 26801161. Exclusion Code: X8.26801161
1318 Pompe E, de Jong PA, Lynch DA, . Computed tomographic findings in subjects who died from respiratory disease in the National Lung Screening Trial. Eur Respir J. 2017 Apr;49(4)doi: 10.1183/13993003.01814-2016. PMID: 28424361. Exclusion Code: X3.28424361
1319 Pompili C, Franks KN, Brunelli A, . Patient reported outcomes following video assisted thoracoscopic (VATS) resection or stereotactic ablative body radiotherapy (SABR) for treatment of non-small cell lung cancer: protocol for an observational pilot study (LiLAC). J Thorac Dis. 2017 Aug;9(8):2703–13. doi: 10.21037/jtd.2017.07.35. PMID: 28932579. Exclusion Code: X10.28932579
1320 Pompili C, Salati M, Refai M, . Preoperative quality of life predicts survival following pulmonary resection in stage I non-small-cell lung cancer. Eur J Cardiothorac Surg. 2013 May;43(5):905–10. doi: 10.1093/ejcts/ezs532. PMID: 23091229. Exclusion Code: X11.23091229
1321 Pompili C, Salati M, Refai M, . Recurrent air leak soon after pulmonary lobectomy: an analysis based on an electronic airflow evaluationdagger. Eur J Cardiothorac Surg. 2016 Apr;49(4):1091–4; discussion 4. doi: 10.1093/ejcts/ezv335. PMID: 26410629. Exclusion Code: X3.26410629
1322 Potaris K, Athanasiou A, Konstantinou M, . Pulmonary hypertension after pneumonectomy for lung cancer. Asian Cardiovasc Thorac Ann. 2014 Nov;22(9):1072–9. doi: 10.1177/0218492314527992. PMID: 24637028. Exclusion Code: X3.24637028
1323 Pou Ucha JL, Nogueiras Alonso JM, Alvarez Paez AM, . Diagnostic yield of baseline and follow-up PET/CT studies in ablative therapy for non-small cell lung cancer. Rev Esp Med Nucl Imagen Mol. 2012 Nov-Dec;31(6):301–7. doi: 10.1016/j.remn.2012.01.001. PMID: 23084012. Exclusion Code: X6.23084012
1324 Poullis M, Shackcloth M, Page R, . Metastatic index of non-small-cell lung cancer and long-term survival. Asian Cardiovasc Thorac Ann. 2015 Feb;23(2):185–90. doi: 10.1177/0218492314545833. PMID: 25107893. Exclusion Code: X5.25107893
1325 Poulou LS, Tsagouli P, Ziakas PD, . Computed tomography-guided needle aspiration and biopsy of pulmonary lesions: a single-center experience in 1000 patients. Acta Radiol. 2013 Jul;54(6):640–5. doi: 10.1177/0284185113481595. PMID: 23528565. Exclusion Code: X3.23528565
1326 Pozo-Rodriguez F, Martin de Nicolas JL, Sanchez-Nistal MA, . Accuracy of helical computed tomography and [18F] fluorodeoxyglucose positron emission tomography for identifying lymph node mediastinal metastases in potentially resectable non-small-cell lung cancer. J Clin Oncol. 2005 Nov 20;23(33):8348–56. doi: 10.1200/jco.2004.00.6361. PMID: 16219937. Exclusion Code: X3.16219937
1327 Pozzi P, Munarini E, Bravi F, . A combined smoking cessation intervention within a lung cancer screening trial: a pilot observational study. Tumori. 2015 May-Jun;101(3):306–11. doi: 10.5301/tj.5000282. PMID: 25838249. Exclusion Code: X7.25838249
1328 Presley CJ, Soulos PR, Tinetti M, . Treatment burden of Medicare beneficiaries with stage I non-small-cell lung cancer. J Oncol Pract. 2017 Feb;13(2):e98–e107. doi: 10.1200/jop.2016.014100. PMID: 27997301. Exclusion Code: X8.27997301
1329 Price A, Yellowlees A, Keerie C, . Radical radiotherapy with or without gemcitabine in patients with early stage medically inoperable non-small cell lung cancer. Lung Cancer. 2012 Sep;77(3):532–6. doi: 10.1016/j.lungcan.2012.05.089. PMID: 22672970. Exclusion Code: X6.22672970
1330 Printz C. Off the mark: current lung cancer screening guidelines miss those most at risk. Cancer. 2015 Aug 01;121(15):2477–8. doi: 10.1002/cncr.28999. PMID: 26198788. Exclusion Code: X10.26198788
1331 Priola AM, Priola SM, Cataldi A, . Diagnostic accuracy and complication rate of CT-guided fine needle aspiration biopsy of lung lesions: a study based on the experience of the cytopathologist. Acta Radiol. 2010 Jun;51(5):527–33. doi: 10.3109/02841851003691979. PMID: 20429755. Exclusion Code: X3.20429755
1332 Priola AM, Priola SM, Giaj-Levra M, . Clinical implications and added costs of incidental findings in an early detection study of lung cancer by using low-dose spiral computed tomography. Clin Lung Cancer. 2013 Mar;14(2):139–48. doi: 10.1016/j.cllc.2012.05.005. PMID: 22868220. Exclusion Code: X7.22868220
1333 Prionas ND, von Eyben R, Yi E, . Increases in serial pretreatment (18)F-FDG PET-CT metrics predict survival in early stage non-small cell lung cancer treated with stereotactic ablative radiation therapy. Adv Radiat Oncol. 2019 Apr-Jun;4(2):429–37. doi: 10.1016/j.adro.2018.11.006. PMID: 31011689. Exclusion Code: X13.31011689
1334 Pritchett MA, Schampaert S, de Groot JAH, . Cone-Beam CT With Augmented Fluoroscopy Combined With Electromagnetic Navigation Bronchoscopy for Biopsy of Pulmonary Nodules. J Bronchology Interv Pulmonol. 2018 Oct;25(4):274–82. doi: 10.1097/lbr.0000000000000536. PMID: 30179922. Exclusion Code: X11.30179922
1335 Prosch H, Stadler A, Schilling M, . CT fluoroscopy-guided vs. multislice CT biopsy mode-guided lung biopsies: accuracy, complications and radiation dose. Eur J Radiol. 2012 May;81(5):1029–33. doi: 10.1016/j.ejrad.2011.01.064. PMID: 21752567. Exclusion Code: X3.21752567
1336 Pruitt SL, Laccetti AL, Xuan L, . Revisiting a longstanding clinical trial exclusion criterion: impact of prior cancer in early-stage lung cancer. Br J Cancer. 2017 Mar 14;116(6):717–25. doi: 10.1038/bjc.2017.27. PMID: 28196065. Exclusion Code: X8.28196065
1337 Puri V, Crabtree T, Kymes S, . A comparison of surgical intervention and stereotactic body radiation therapy for stage I lung cancer in high-risk patients: a decision analysis (Structured abstract). J Thorac Cardiovasc Surg. 2012;143(2):428–36. PMID: NHSEED-22012003670. Exclusion Code: X10.22169443
1338 Puri V, Patel A, Majumder K, . Intraoperative conversion from video-assisted thoracoscopic surgery lobectomy to open thoracotomy: a study of causes and implications. J Thorac Cardiovasc Surg. 2015 Jan;149(1):55–61, 2.e1. doi: 10.1016/j.jtcvs.2014.08.074. PMID: 25439768. Exclusion Code: X8.25439768
1339 Pyenson BS, Sander MS, Jiang Y, . An actuarial analysis shows that offering lung cancer screening as an insurance benefit would save lives at relatively low cost. Health Aff (Millwood). 2012 Apr;31(4):770–9. doi: 10.1377/hlthaff.2011.0814. PMID: 22492894. Exclusion Code: X8.22492894
1340 Pyo JS, Kang G, Sohn JH. ALK immunohistochemistry for ALK gene rearrangement screening in non-small cell lung cancer: a systematic review and meta-analysis. Int J Biol Markers. 2016 Dec 23;31(4):e413–e21. doi: 10.5301/jbm.5000218. PMID: 27338643. Exclusion Code: X5.27338643
1341 Qadri SS, Chaudhry MA, Cale A, . Short- and long-term outcomes of pneumonectomy in a tertiary center. Asian Cardiovasc Thorac Ann. 2016 Mar;24(3):250–6. doi: 10.1177/0218492316629851. PMID: 26843470. Exclusion Code: X11.26843470
1342 Qadri SS, Jarvis M, Ariyaratnam P, . Could Thoracoscore predict postoperative mortality in patients undergoing pneumonectomy? Eur J Cardiothorac Surg. 2014 May;45(5):864–9. doi: 10.1093/ejcts/ezt517. PMID: 24212768. Exclusion Code: X3.24212768
1343 Qi H, Wan C, Zhang L, . Early effective treatment of small pulmonary nodules with video-assisted thoracoscopic surgery combined with CT-guided dual-barbed hookwire localization. Oncotarget. 2017 Jun 13;8(24):38793–801. doi: 10.18632/oncotarget.17044. PMID: 28455967. Exclusion Code: X11.28455967
1344 Qian DC, Han Y, Byun J, . A novel pathway-based approach improves lung cancer risk prediction using germline genetic variations. Cancer Epidemiol Biomarkers Prev. 2016 Aug;25(8):1208–15. doi: 10.1158/1055-9965.epi-15-1318. PMID: 27222311. Exclusion Code: X4.27222311
1345 Qian H, Gao F, Wang H, . The efficacy and safety of crizotinib in the treatment of anaplastic lymphoma kinase-positive non-small cell lung cancer: a meta-analysis of clinical trials. BMC Cancer. 2014 Sep 19;14:683. doi: 10.1186/1471-2407-14-683. PMID: 25239305. Exclusion Code: X10.25239305
1346 Qian LQ, Zhao XJ, Luo QQ, . Experience of segmentectomy from 36 Chinese patients with non-small cell lung cancer at stage I. Chin Med J (Engl). 2013 Jul;126(14):2687–93. PMID: 23876897. Exclusion Code: X11.23876897
1347 Qian Y, Zhu H, Pollom EL, . Sinoatrial node toxicity after stereotactic ablative radiation therapy to lung tumors. Pract Radiat Oncol. 2017 Nov - Dec;7(6):e525–e9. doi: 10.1016/j.prro.2017.04.005. PMID: 28669706. Exclusion Code: X16.28669706
1348 Qiang G, Liang C, Guo Y, . Video-assisted thoracoscopic lobectomy for elderly nonsmall cell lung cancer: Short-term and long-term outcomes. J Cancer Res Ther. 2015 Oct-Dec;11(4):793–7. doi: 10.4103/0973-1482.140930. PMID: 26881520. Exclusion Code: X3.26881520
1349 Qiang G, Liang C, Xiao F, . Impact of chronic obstructive pulmonary disease on postoperative recurrence in patients with resected non-small-cell lung cancer. Int J Chron Obstruct Pulmon Dis. 2016;11:43–9. doi: 10.2147/copd.s97411. PMID: 26766906. Exclusion Code: X11.26766906
1350 Qiu C, Qu X, Shen H, . Evaluation of prognostic nutritional index in patients undergoing radical surgery with nonsmall cell lung cancer. Nutr Cancer. 2015;67(5):741–7. doi: 10.1080/01635581.2015.1032430. PMID: 25941961. Exclusion Code: X3.25941961
1351 Qiu C, Wang G, Xu J, . Sublobectomy versus lobectomy for stage I non-small cell lung cancer in the elderly. Int J Surg. 2017 Jan;37:1–7. doi: 10.1016/j.ijsu.2016.11.090. PMID: 27890654. Exclusion Code: X11.27890654
1352 Quadrelli S, Lyons G, Colt H, . Clinical characteristics and prognosis of incidentally detected lung cancers. Int J Surg Oncol. 2015;2015:287604. doi: 10.1155/2015/287604. PMID: 25685550. Exclusion Code: X3.25685550
1353 Quero-Valenzuela F, Piedra-Fernandez I, Martinez-Ceres M, . Predictors for 30-day readmission after pulmonary resection for lung cancer. J Surg Oncol. 2018 May;117(6):1239–45. doi: 10.1002/jso.24973. PMID: 29355966. Exclusion Code: X11.29355966
1354 Raghavan G, Shaverdian N, Chan S, . Comparing Outcomes of Patients With Early-Stage Non-Small-Cell Lung Cancer Treated With Stereotactic Body Radiotherapy Based on Frailty Status. Clin Lung Cancer. 2018 Sep;19(5):e759–e66. doi: 10.1016/j.cllc.2018.05.008. PMID: 29954680. Exclusion Code: X3.29954680
1355 Raghunath S, Maldonado F, Rajagopalan S, . Noninvasive risk stratification of lung adenocarcinoma using quantitative computed tomography. J Thorac Oncol. 2014 Nov;9(11):1698–703. doi: 10.1097/jto.0000000000000319. PMID: 25170645. Exclusion Code: X3.25170645
1356 Rai A, Doria-Rose VP, Silvestri GA, . Evaluating lung cancer screening uptake, outcomes, and costs in the United States: challenges with existing data and recommendations for improvement. J Natl Cancer Inst. 2019 Apr 1;111(4):342–9. doi: 10.1093/jnci/djy228. PMID: 30698792. Exclusion Code: X10.30698792
1357 Raji O, Agbaje OF, Duffy SW, . The predictive ability of LLP lung cancer risk model with and without seizure 6-Like (SEZ6L) gene. J Thorac Oncol. 2009(4):S408–9. Exclusion Code: X2.
1358 Raji OY, Agbaje OF, Duffy SW, . Incorporation of a genetic factor into an epidemiologic model for prediction of individual risk of lung cancer: the Liverpool Lung Project. Cancer Prev Res (Phila). 2010 May;3(5):664–9. doi: 10.1158/1940-6207.CAPR-09-0141. PMID: 20424129. Exclusion Code: X4.20424129
1359 Raji OY, Duffy SW, Agbaje OF, . Predictive accuracy of the Liverpool Lung Project risk model for stratifying patients for computed tomography screening for lung cancer: a case-control and cohort validation study. Ann Intern Med. 2012 Aug 21;157(4):242–50. doi: 10.7326/0003-4819-157-4-201208210-00004. PMID: 22910935. Exclusion Code: X7.22910935
1360 Ramella S, Spoto S, Fiore M, . A clinical score, including biohumoral parameters, is a useful pretest index to discriminate pulmonary infections from radiation damage in chemoradiation-treated lung cancer patients. Cancer Invest. 2014 May;32(4):110–4. doi: 10.3109/07357907.2014.883525. PMID: 24548301. Exclusion Code: X3.24548301
1361 Ramos R, Girard P, Masuet C, . Mediastinal lymph node dissection in early-stage non-small cell lung cancer: totally thoracoscopic vs thoracotomy. Eur J Cardiothorac Surg. 2012 Jun;41(6):1342–8; discussion 8. doi: 10.1093/ejcts/ezr220. PMID: 22228841. Exclusion Code: X3.22228841
1362 Ramos R, Masuet C, Gossot D. Lobectomy for early-stage lung carcinoma: a cost analysis of full thoracoscopy versus posterolateral thoracotomy. Surg Endosc. 2012 Feb;26(2):431–7. doi: 10.1007/s00464-011-1891-y. PMID: 21898011. Exclusion Code: X11.21898011
1363 Ramos R, Nadal E, Peiro I, . Preoperative nutritional status assessment predicts postoperative outcomes in patients with surgically resected non-small cell lung cancer. Eur J Surg Oncol. 2018 Sep;44(9):1419–24. doi: 10.1016/j.ejso.2018.03.026. PMID: 29685760. Exclusion Code: X11.29685760
1364 Rangel MP, Antonangelo L, Acencio MMP, . Detection of sputum cofilin-1 as indicator of malignancy. Braz J Med Biol Res. 2018;51(8):e7138. doi: 10.1590/1414-431x20187138. PMID: 29846436. Exclusion Code: X10.29846436
1365 Rangel MP, de Sa VK, Martins V, . Tissue hyaluronan expression, as reflected in the sputum of lung cancer patients, is an indicator of malignancy. Braz J Med Biol Res. 2015 Jun;48(6):557–67. doi: 10.1590/1414-431x20144300. PMID: 25992645. Exclusion Code: X4.25992645
1366 Rauschenbach BM, Mackowiak L, Malhotra HK. A dosimetric comparison of three-dimensional conformal radiotherapy, volumetric-modulated arc therapy, and dynamic conformal arc therapy in the treatment of non-small cell lung cancer using stereotactic body radiotherapy. J Appl Clin Med Phys. 2014 Sep 8;15(5):4898. doi: 10.1120/jacmp.v15i5.4898. PMID: 25207575. Exclusion Code: X8.25207575
1367 Rebonato A, Maiettini D, Andolfi M, . CT-Guided Percutaneous Trans-scapular Lung Biopsy in the Diagnosis of Peripheral Pulmonary Lesion Nodules of the Superior Lobes Using Large Needles. Cardiovasc Intervent Radiol. 2018 Feb;41(2):284–90. doi: 10.1007/s00270-017-1768-0. PMID: 28808757. Exclusion Code: X3.28808757
1368 Redberg RF, O’Malley PG. Important questions about lung cancer screening programs when incidental findings exceed lung cancer nodules by 40 to 1. JAMA Intern Med. 2017 Mar 1;177(3):311–2. doi: 10.1001/jamainternmed.2016.9446. PMID: 28135358. Exclusion Code: X10.28135358
1369 Reddy RM, Murlidhar V, Zhao L, . Pulmonary venous blood sampling significantly increases the yield of circulating tumor cells in early-stage lung cancer. J Thorac Cardiovasc Surg. 2016 Mar;151(3):852–8. doi: 10.1016/j.jtcvs.2015.09.126. PMID: 26614417. Exclusion Code: X8.26614417
1370 Reichert M, Steiner D, Kerber S, . A standardized technique of systematic mediastinal lymph node dissection by video-assisted thoracoscopic surgery (VATS) leads to a high rate of nodal upstaging in early-stage non-small cell lung cancer. Surg Endosc. 2016 Mar;30(3):1119–25. doi: 10.1007/s00464-015-4312-9. PMID: 26169635. Exclusion Code: X11.26169635
1371 Remick JS, Schonewolf C, Gabriel P, . First clinical report of proton beam therapy for postoperative radiotherapy for non-small-cell lung cancer. Clin Lung Cancer. 2017 Jul;18(4):364–71. doi: 10.1016/j.cllc.2016.12.009. PMID: 28162946. Exclusion Code: X3.28162946
1372 Rena O, Massera F, Boldorini R, . Non-small cell lung cancer in surgically treated women. Tumori. 2013 Nov-Dec;99(6):661–6. doi: 10.1700/1390.15453. PMID: 24503788. Exclusion Code: X3.24503788
1373 Rennert G, Kremer R, Rennert HS, . Lower lung cancer rates in Jewish smokers in Israel and the USA. Int J Cancer. 2015 Nov 1;137(9):2155–62. doi: 10.1002/ijc.29587. PMID: 25924736. Exclusion Code: X3.25924736
1374 Reshko LB, Kalman NS, Hugo GD, . Cardiac radiation dose distribution, cardiac events and mortality in early-stage lung cancer treated with stereotactic body radiation therapy (SBRT). J Thorac Dis. 2018 Apr;10(4):2346–56. doi: 10.21037/jtd.2018.04.42. PMID: 29850140. Exclusion Code: X3.29850140
1375 Revel MP, Mannes I, Benzakoun J, . Subsolid lung nodule classification: a CT criterion for improving interobserver agreement. Radiology. 2018 Jan;286(1):316–25. doi: 10.1148/radiol.2017170044. PMID: 28796590. Exclusion Code: X3.28796590
1376 Ricardi U, Filippi AR, Guarneri A, . Stereotactic body radiation therapy for early stage non-small cell lung cancer: results of a prospective trial. Lung Cancer. 2010 Apr;68(1):72–7. doi: 10.1016/j.lungcan.2009.05.007. PMID: 19556022. Exclusion Code: X11.19556022
1377 Ricardi U, Frezza G, Filippi AR, . Stereotactic Ablative Radiotherapy for stage I histologically proven non-small cell lung cancer: an Italian multicenter observational study. Lung Cancer. 2014 Jun;84(3):248–53. doi: 10.1016/j.lungcan.2014.02.015. PMID: 24681279. Exclusion Code: X10.24681279
1378 Ricke J, Jurgens JH, Deschamps F, . Irreversible electroporation (IRE) fails to demonstrate efficacy in a prospective multicenter phase II trial on lung malignancies: the ALICE trial. Cardiovasc Intervent Radiol. 2015 Apr;38(2):401–8. doi: 10.1007/s00270-014-1049-0. PMID: 25609208. Exclusion Code: X3.25609208
1379 Rico M, Martinez E, Pellejero S, . Influence of different treatment techniques and clinical factors over the intrafraction variation on lung stereotactic body radiotherapy. Clin Transl Oncol. 2016 Oct;18(10):1011–8. doi: 10.1007/s12094-015-1475-8. PMID: 26758718. Exclusion Code: X8.26758718
1380 Ridge CA, Silk M, Petre EN, . Radiofrequency ablation of T1 lung carcinoma: comparison of outcomes for first primary, metachronous, and synchronous lung tumors. J Vasc Interv Radiol. 2014 Jul;25(7):989–96. doi: 10.1016/j.jvir.2014.02.021. PMID: 24703321. Exclusion Code: X6.24703321
1381 Ridge CA, Yildirim A, Boiselle PM, . Differentiating between subsolid and solid pulmonary nodules at CT: inter- and intraobserver agreement between experienced thoracic radiologists. Radiology. 2016 Mar;278(3):888–96. doi: 10.1148/radiol.2015150714. PMID: 26458208. Exclusion Code: X3.26458208
1382 Rieber J, Tonndorf-Martini E, Schramm O, . Establishing stereotactic body radiotherapy with flattening filter free techniques in the treatment of pulmonary lesions - initial experiences from a single institution. Radiat Oncol. 2016 Jun 8;11:80. doi: 10.1186/s13014-016-0648-0. PMID: 27411832. Exclusion Code: X3.27411832
1383 Rintoul RC, Glover MJ, Jackson C, . Cost effectiveness of endosonography versus surgical staging in potentially resectable lung cancer: a health economics analysis of the ASTER trial from a European perspective. Thorax. 2014 Jul;69(7):679–81. doi: 10.1136/thoraxjnl-2013-204374. PMID: 24064440. Exclusion Code: X3.24064440
1384 Riquet M, Mordant P, Pricopi C, . A review of 250 ten-year survivors after pneumonectomy for non-small-cell lung cancer. Eur J Cardiothorac Surg. 2014 May;45(5):876–81. doi: 10.1093/ejcts/ezt494. PMID: 24132299. Exclusion Code: X3.24132299
1385 Riquet M, Rivera C, Pricopi C, . Is the lymphatic drainage of lung cancer lobe-specific? A surgical appraisal. Eur J Cardiothorac Surg. 2015 Mar;47(3):543–9. doi: 10.1093/ejcts/ezu226. PMID: 24875885. Exclusion Code: X3.24875885
1386 Ritchie AJ, Sanghera C, Jacobs C, . Computer vision tool and technician as first reader of lung cancer screening CT scans. J Thorac Oncol. 2016 May;11(5):709–17. doi: 10.1016/j.jtho.2016.01.021. PMID: 26994641. Exclusion Code: X5.26994641
1387 Roach MC, Rehman S, DeWees TA, . It’s never too late: smoking cessation after stereotactic body radiation therapy for non-small cell lung carcinoma improves overall survival. Pract Radiat Oncol. 2016 Jan-Feb;6(1):12–8. doi: 10.1016/j.prro.2015.09.005. PMID: 26598909. Exclusion Code: X13.26598909
1388 Robbins HA, Berg CD, Cheung LC, . Identification of candidates for longer lung cancer screening intervals following a negative low-dose computed tomography result. J Natl Cancer Inst. 2019 Apr 12doi: 10.1093/jnci/djz041. PMID: 30976808. Exclusion Code: X4.30976808
1389 Robinson JW, Brennan PC, Mello-Thoms C, . Reporting instructions significantly impact false positive rates when reading chest radiographs. Eur Radiol. 2016 Oct;26(10):3654–9. doi: 10.1007/s00330-015-4194-1. PMID: 26780639. Exclusion Code: X3.26780639
1390 Robinson JW, Ryan JT, McEntee MF, . Grey-scale inversion improves detection of lung nodules. Br J Radiol. 2013 Jan;86(1021):20110812. doi: 10.1259/bjr.20110812. PMID: 23239692. Exclusion Code: X3.23239692
1391 Robson JM, Vaidyanathan S, Cheyne L, . Occult nodal disease in patients with non-small-cell lung cancer who are suitable for stereotactic ablative body radiation. Clin Lung Cancer. 2014 Nov;15(6):466–9. doi: 10.1016/j.cllc.2014.07.006. PMID: 25220208. Exclusion Code: X8.25220208
1392 Rocha RD, Azevedo AA, Falsarella PM, . Cerebral air embolism during CT-guided lung biopsy. Thorax. 2015 Nov;70(11):1099–100. doi: 10.1136/thoraxjnl-2015-207205. PMID: 26024689. Exclusion Code: X3.26024689
1393 Rodgers-Fischl PM, Martin JT, Saha SP. Video-assisted thoracoscopic versus open lobectomy: costs and outcomes. South Med J. 2017 Mar;110(3):229–33. doi: 10.14423/smj.0000000000000620. PMID: 28257551. Exclusion Code: X3.28257551
1394 Rodriguez F, Seijo LM, Sanchez PA, . Modified technique for obtaining mediastinal samples with endobronchial ultrasound-guided transbronchial needle aspiration: results from a prospective observational study. Arch Bronconeumol. 2013 Apr;49(4):135–9. doi: 10.1016/j.arbres.2012.10.006. PMID: 23265621. Exclusion Code: X3.23265621
1395 Rodriguez M, Gomez Hernandez MT, Novoa NM, . Poorer survival in stage IB lung cancer patients after pneumonectomy. Arch Bronconeumol. 2015 May;51(5):223–6. doi: 10.1016/j.arbres.2014.09.007. PMID: 25454899. Exclusion Code: X11.25454899
1396 Roesel C, Terjung S, Weinreich G, . Sarcomatoid carcinoma of the lung: a rare histological subtype of non-small cell lung cancer with a poor prognosis even at earlier tumour stages. Interact Cardiovasc Thorac Surg. 2017 Mar 1;24(3):407–13. doi: 10.1093/icvts/ivw392. PMID: 28025310. Exclusion Code: X3.28025310
1397 Rojas-Solano JR, Ugalde-Gamboa L, Machuzak M. Robotic Bronchoscopy for Diagnosis of Suspected Lung Cancer: A Feasibility Study. J Bronchology Interv Pulmonol. 2018 Jul;25(3):168–75. doi: 10.1097/lbr.0000000000000499. PMID: 29762461. Exclusion Code: X11.29762461
1398 Roman M, Labbouz S, Valtzoglou V, . Lobectomy vs. segmentectomy. A propensity score matched comparison of outcomes. Eur J Surg Oncol. 2019 May;45(5):845–50. doi: 10.1016/j.ejso.2018.10.534. PMID: 30409440. Exclusion Code: X3.30409440
1399 Ronit A, Kristensen T, Klitbo DM, . Incidental lung cancers and positive computed tomography images in people living with HIV. AIDS. 2017 Sep 10;31(14):1973–7. doi: 10.1097/qad.0000000000001600. PMID: 28857778. Exclusion Code: X10.28857778
1400 Ros-Mazurczyk M, Jelonek K, Marczyk M, . Serum lipid profile discriminates patients with early lung cancer from healthy controls. Lung Cancer. 2017 Oct;112:69–74. doi: 10.1016/j.lungcan.2017.07.036. PMID: 29191603. Exclusion Code: X11.29191603
1401 Rossi MM, Peulen HM, Belderbos JS, . Intrafraction motion in stereotactic body radiation therapy for non-small cell lung cancer: intensity modulated radiation therapy versus volumetric modulated arc therapy. Int J Radiat Oncol Biol Phys. 2016 Jun 1;95(2):835–43. doi: 10.1016/j.ijrobp.2016.01.060. PMID: 27131084. Exclusion Code: X8.27131084
1402 Rostambeigi N, Scanlon P, Flanagan S, . CT Fluoroscopic-Guided Coil Localization of Lung Nodules prior to Video-Assisted Thoracoscopic Surgical Resection Reduces Complications Compared to Hook Wire Localization. J Vasc Interv Radiol. 2019 Mar;30(3):453–9. doi: 10.1016/j.jvir.2018.10.013. PMID: 30819493. Exclusion Code: X11.30819493
1403 Rotolo N, Floridi C, Imperatori A, . Comparison of cone-beam CT-guided and CT fluoroscopy-guided transthoracic needle biopsy of lung nodules. Eur Radiol. 2016 Feb;26(2):381–9. doi: 10.1007/s00330-015-3861-6. PMID: 26045345. Exclusion Code: X3.26045345
1404 Ryoo JJ, Malin JL, Ordin DL, . Facility characteristics and quality of lung cancer care in an integrated health care system. J Thorac Oncol. 2014 Apr;9(4):447–55. doi: 10.1097/jto.0000000000000108. PMID: 24736065. Exclusion Code: X8.24736065
1405 Sa YJ, Kim JJ, Du Kim Y, . A new protocol for concomitant needle aspiration biopsy and localization of solitary pulmonary nodules. J Cardiothorac Surg. 2015 Jul 29;10:104. doi: 10.1186/s13019-015-0312-z. PMID: 26219285. Exclusion Code: X11.26219285
1406 Safi S, Rauch G, op den Winkel J, . Sublobar resection, radiofrequency ablation or radiotherapy in stage I non-small cell lung cancer. Respiration. 2015;89(6):550–7. doi: 10.1159/000381555. PMID: 25968471. Exclusion Code: X11.25968471
1407 Saghir Z, Ashraf H, Dirksen A, . Contamination during 4 years of annual CT screening in the Danish Lung Cancer Screening Trial (DLCST). Lung Cancer. 2011 Mar;71(3):323–7. doi: 10.1016/j.lungcan.2010.06.006. PMID: 20619924. Exclusion Code: X8.20619924
1408 Saito H, Konno H, Atari M, . Management of intersegmental plane on pulmonary segmentectomy concerning postoperative complications. Ann Thorac Surg. 2017 Jun;103(6):1773–80. doi: 10.1016/j.athoracsur.2017.01.014. PMID: 28366465. Exclusion Code: X11.28366465
1409 Saito H, Nakagawa T, Ito M, . Pulmonary function after lobectomy versus segmentectomy in patients with stage I non-small cell lung cancer. World J Surg. 2014 Aug;38(8):2025–31. doi: 10.1007/s00268-014-2521-3. PMID: 24682312. Exclusion Code: X11.24682312
1410 Saji H, Ueno T, Nakamura H, . A proposal for a comprehensive risk scoring system for predicting postoperative complications in octogenarian patients with medically operable lung cancer: JACS1303. Eur J Cardiothorac Surg. 2018 Apr 1;53(4):835–41. doi: 10.1093/ejcts/ezx415. PMID: 29240884. Exclusion Code: X3.29240884
1411 Sakaguchi M, Maebayashi T, Aizawa T, . Patient outcomes of monotherapy with hypofractionated three-dimensional conformal radiation therapy for stage T2 or T3 non-small cell lung cancer: a retrospective study. Radiat Oncol. 2016 Jan 19;11:3. doi: 10.1186/s13014-016-0582-1. PMID: 26781290. Exclusion Code: X6.26781290
1412 Salati M, Brunelli A, Decaluwe H, . Report from the European Society of Thoracic Surgeons Database 2017: patterns of care and perioperative outcomes of surgery for malignant lung neoplasm. Eur J Cardiothorac Surg. 2017 Dec 1;52(6):1041–8. doi: 10.1093/ejcts/ezx272. PMID: 28950348. Exclusion Code: X3.28950348
1413 Salhi B, Huysse W, Van Maele G, . The effect of radical treatment and rehabilitation on muscle mass and strength: a randomized trial in stages I-III lung cancer patients. Lung Cancer. 2014 Apr;84(1):56–61. doi: 10.1016/j.lungcan.2014.01.011. PMID: 24560331. Exclusion Code: X6.24560331
1414 Samson P, Keogan K, Crabtree T, . Interpreting survival data from clinical trials of surgery versus stereotactic body radiation therapy in operable Stage I non-small cell lung cancer patients. Lung cancer (Amsterdam, Netherlands). 2017;103:6–10. doi: 10.1016/j.lungcan.2016.11.005. PMID: CN-01243643. Exclusion Code: X10.
1415 Samson P, Rehman S, Juloori A, . Local control for clinical stage I non-small cell lung cancer treated with 5-fraction stereotactic body radiation therapy is not associated with treatment schedule. Pract Radiat Oncol. 2018 Nov - Dec;8(6):404–13. doi: 10.1016/j.prro.2018.04.004. PMID: 29907514. Exclusion Code: X8.29907514
1416 Samson P, Robinson CG, Bradley J, . The National Surgical Quality Improvement Program risk calculator does not adequately stratify risk for patients with clinical stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2016 Mar;151(3):697–705.e1. doi: 10.1016/j.jtcvs.2015.08.058. PMID: 26410001. Exclusion Code: X11.26410001
1417 Sancheti MS, Chihara RK, Perez SD, . Hospitalization costs after surgery in high-risk patients with early stage lung cancer. Ann Thorac Surg. 2018 Jan;105(1):263–70. doi: 10.1016/j.athoracsur.2017.08.038. PMID: 29174780. Exclusion Code: X11.29174780
1418 Sancheti MS, Lee R, Ahmed SU, . Percutaneous fiducial localization for thoracoscopic wedge resection of small pulmonary nodules. Ann Thorac Surg. 2014 Jun;97(6):1914–8; discussion 9. doi: 10.1016/j.athoracsur.2014.02.028. PMID: 24725836. Exclusion Code: X3.24725836
1419 Sancheti MS, Melvan JN, Medbery RL, . Outcomes after surgery in high-risk patients with early stage lung cancer. Ann Thorac Surg. 2016 Mar;101(3):1043–50; Discussion 51. doi: 10.1016/j.athoracsur.2015.08.088. PMID: 26572255. Exclusion Code: X11.26572255
1420 Sanchez de Cos Escuin J, Serra Mitjans M, Hernandez Hernandez J, . The Spanish Society of Pulmonology and Thoracic Surgery Lung Cancer Cooperative Group-II registry. A descriptive study. Arch Bronconeumol. 2013 Nov;49(11):462–7. doi: 10.1016/j.arbres.2013.05.002. PMID: 23838409. Exclusion Code: X8.23838409
1421 Sanchez-Salcedo P, Berto J, de-Torres JP, . Lung cancer screening: fourteen year experience of the Pamplona early detection program (P-IELCAP). Arch Bronconeumol. 2015 Apr;51(4):169–76. doi: 10.1016/j.arbres.2014.09.019. PMID: 25641356. Exclusion Code: X7.25641356
1422 Sanderson B, McWilliam A, Faivre-Finn C, . Using the Malthus programme to predict the recruitment of patients to MR-linac research trials in prostate and lung cancer. Radiother Oncol. 2017 Jan;122(1):159–62. doi: 10.1016/j.radonc.2016.11.014. PMID: 27939554. Exclusion Code: X5.27939554
1423 Sandhu AP, Lau SK, Rahn D, . Stereotactic body radiation therapy in octogenarians with stage I lung cancer. Clin Lung Cancer. 2014 Mar;15(2):131–5. doi: 10.1016/j.cllc.2013.08.007. PMID: 24157245. Exclusion Code: X10.24157245
1424 Sandri A, Papagiannopoulos K, Milton R, . High-risk patients and postoperative complications following video-assisted thoracic surgery lobectomy: a case-matched comparison with lower-risk counterpartsdagger. Interact Cardiovasc Thorac Surg. 2015 Dec;21(6):761–5. doi: 10.1093/icvts/ivv254. PMID: 26362624. Exclusion Code: X11.26362624
1425 Sanford L, Molloy J, Kumar S, . Evaluation of plan quality and treatment efficiency for single-isocenter/two-lesion lung stereotactic body radiation therapy. J Appl Clin Med Phys. 2019 Jan;20(1):118–27. doi: 10.1002/acm2.12500. PMID: 30548205. Exclusion Code: X8.30548205
1426 Sangha BS, Hague CJ, Jessup J, . Transthoracic computed tomography-guided lung nodule biopsy: comparison of core needle and fine needle aspiration techniques. Can Assoc Radiol J. 2016 Aug;67(3):284–9. doi: 10.1016/j.carj.2015.10.005. PMID: 27005931. Exclusion Code: X11.27005931
1427 Sas-Korczynska B, Luczynska E, Kamzol W, . Analysis of risk factors for pulmonary complications in patients with limited-stage small cell lung cancer : A single-centre retrospective study. Strahlenther Onkol. 2017 Feb;193(2):141–9. doi: 10.1007/s00066-016-1069-6. PMID: 27785518. Exclusion Code: X3.27785518
1428 Sato A, Hamada S, Urashima Y, . The effect of false-positive results on subsequent participation in chest x-ray screening for lung cancer. J Epidemiol. 2016 Dec 5;26(12):646–53. doi: 10.2188/jea.JE20150106. PMID: 27374136. Exclusion Code: X10.27374136
1429 Sato H, Toyooka S, Soh J, . Advantage of induction chemoradiotherapy for lung cancer in securing cancer-free bronchial margin. Ann Thorac Surg. 2017 Sep;104(3):971–8. doi: 10.1016/j.athoracsur.2017.03.045. PMID: 28610882. Exclusion Code: X3.28610882
1430 Sato S, Koike T, Hashimoto T, . Surgical outcomes of lung cancer patients with combined pulmonary fibrosis and emphysema and those with idiopathic pulmonary fibrosis without emphysema. Ann Thorac Cardiovasc Surg. 2016 Aug 23;22(4):216–23. doi: 10.5761/atcs.oa.15-00315. PMID: 27052999. Exclusion Code: X11.27052999
1431 Sato T, Kondo H, Watanabe A, . A simple risk scoring system for predicting acute exacerbation of interstitial pneumonia after pulmonary resection in lung cancer patients. Gen Thorac Cardiovasc Surg. 2015 Mar;63(3):164–72. doi: 10.1007/s11748-014-0487-6. PMID: 25352311. Exclusion Code: X3.25352311
1432 Sato T, Teramukai S, Kondo H, . Impact and predictors of acute exacerbation of interstitial lung diseases after pulmonary resection for lung cancer. J Thorac Cardiovasc Surg. 2014 May;147(5):1604–11.e3. doi: 10.1016/j.jtcvs.2013.09.050. PMID: 24267779. Exclusion Code: X10.24267779
1433 Sato T, Watanabe A, Kondo H, . Long-term results and predictors of survival after surgical resection of patients with lung cancer and interstitial lung diseases. J Thorac Cardiovasc Surg. 2015 Jan;149(1):64–9, 70.e1–2. doi: 10.1016/j.jtcvs.2014.08.086. PMID: 25439777. Exclusion Code: X10.25439777
1434 Satoh Y, Motosugi U, Nambu A, . Prognostic value of semiautomatic CT volumetry in patients with stage I Non-small cell lung cancer treated with stereotactic body radiation therapy. J Comput Assist Tomogr. 2016 May-Jun;40(3):343–50. doi: 10.1097/rct.0000000000000368. PMID: 26854414. Exclusion Code: X10.26854414
1435 Satoh Y, Motosugi U, Saito A, . Pretreatment (18)F-fluorodeoxyglucose Uptake in the Lung Parenchyma Predicts Poor Survival After Stereotactic Body Radiation Therapy in Patients With Stage I Non-Small Cell Lung Cancer. Technol Cancer Res Treat. 2018 Jan 1;17:1533033818794934. doi: 10.1177/1533033818794934. PMID: 30222060. Exclusion Code: X13.30222060
1436 Satoh Y, Onishi H, Nambu A, . Volume-based parameters measured by using FDG PET/CT in patients with stage I NSCLC treated with stereotactic body radiation therapy: prognostic value. Radiology. 2014 Jan;270(1):275–81. doi: 10.1148/radiol.13130652. PMID: 24029640. Exclusion Code: X10.24029640
1437 Sawabata N, Kanzaki R, Sakamoto T, . Clinical predictor of pre- or minimally invasive pulmonary adenocarcinoma: possibility of sub-classification of clinical T1a. Eur J Cardiothorac Surg. 2014 Feb;45(2):256–61. doi: 10.1093/ejcts/ezt329. PMID: 23868951. Exclusion Code: X11.23868951
1438 Sawicki LM, Grueneisen J, Buchbender C, . Evaluation of the outcome of lung nodules missed on 18F-FDG PET/MRI compared with 18F-FDG PET/CT in patients with known malignancies. J Nucl Med. 2016 Jan;57(1):15–20. doi: 10.2967/jnumed.115.162966. PMID: 26514173. Exclusion Code: X3.26514173
1439 Sayan M, Satir Turk M, Celik A, . Surgical outcomes of early-stage small-cell lung cancer: single-center experience. Asian Cardiovasc Thorac Ann. 2019 Mar;27(3):187–91. doi: 10.1177/0218492319826724. PMID: 30661378. Exclusion Code: X3.30661378
1440 Saydam O, Gokce M, Kilicgun A, . Accuracy of positron emission tomography in mediastinal node assessment in coal workers with lung cancer. Med Oncol. 2012 Jun;29(2):589–94. doi: 10.1007/s12032-011-9879-y. PMID: 21380783. Exclusion Code: X3.21380783
1441 Schaal M, Severac F, Labani A, . Diagnostic performance of ultra-low-dose computed tomography for detecting asbestos-related pleuropulmonary diseases: prospective study in a screening setting. PLoS One. 2016;11(12):e0168979. doi: 10.1371/journal.pone.0168979. PMID: 28033378. Exclusion Code: X11.28033378
1442 Schaefer JF, Vollmar J, Schick F, . Solitary pulmonary nodules: dynamic contrast-enhanced MR imaging--perfusion differences in malignant and benign lesions. Radiology. 2004 Aug;232(2):544–53. doi: 10.1148/radiol.2322030515. PMID: 15215548. Exclusion Code: X3.15215548
1443 Schalekamp S, van Ginneken B, Heggelman B, . New methods for using computer-aided detection information for the detection of lung nodules on chest radiographs. Br J Radiol. 2014 Apr;87(1036):20140015. doi: 10.1259/bjr.20140015. PMID: 24625084. Exclusion Code: X5.24625084
1444 Schanne DH, Nestle U, Allgauer M, . Stereotactic body radiotherapy for centrally located stage I NSCLC: a multicenter analysis. Strahlenther Onkol. 2015 Feb;191(2):125–32. doi: 10.1007/s00066-014-0739-5. PMID: 25159135. Exclusion Code: X3.25159135
1445 Schillaci O, Travascio L, Bolacchi F, . Accuracy of early and delayed FDG PET-CT and of contrast-enhanced CT in the evaluation of lung nodules: a preliminary study on 30 patients. Radiol Med. 2009 Sep;114(6):890–906. doi: 10.1007/s11547-009-0400-z. PMID: 19579015. Exclusion Code: X3.19579015
1446 Schmocker RK, Vanness DJ, Macke RA, . Outpatient air leak management after lobectomy: a CMS cost analysis. J Surg Res. 2016 Jun 15;203(2):390–7. doi: 10.1016/j.jss.2016.03.043. PMID: 27363648. Exclusion Code: X3.27363648
1447 Schneider L, Farrokhyar F, Schieman C, . The burden of death following discharge after lobectomydagger. Eur J Cardiothorac Surg. 2015 Jul;48(1):65–70. doi: 10.1093/ejcts/ezu427. PMID: 25422293. Exclusion Code: X3.25422293
1448 Schneider T, Puderbach M, Kunz J, . Simultaneous computed tomography-guided biopsy and radiofrequency ablation of solitary pulmonary malignancy in high-risk patients. Respiration. 2012;84(6):501–8. doi: 10.1159/000342874. PMID: 23037897. Exclusion Code: X6.23037897
1449 Scholten ET, de Jong PA, de Hoop B, . Towards a close computed tomography monitoring approach for screen detected subsolid pulmonary nodules? Eur Respir J. 2015 Mar;45(3):765–73. doi: 10.1183/09031936.00005914. PMID: 25431271. Exclusion Code: X7.25431271
1450 Scholten ET, Mali WP, Prokop M, . Non-solid lung nodules on low-dose computed tomography: comparison of detection rate between 3 visualization techniques. Cancer Imaging. 2013 Apr 15;13:150–4. doi: 10.1102/1470-7330.2013.0016. PMID: 23598304. Exclusion Code: X8.23598304
1451 Schonewolf CA, Verma V, Post CM, . Outcomes of invasive mediastinal nodal staging versus positron emission tomography staging alone for early-stage non-small cell lung cancer treated with stereotactic body radiation therapy. Lung Cancer. 2018 Mar;117:53–9. doi: 10.1016/j.lungcan.2017.07.005. PMID: 28800837. Exclusion Code: X13.28800837
1452 Schreuder A, van Ginneken B, Scholten ET, . Classification of CT Pulmonary Opacities as Perifissural Nodules: Reader Variability. Radiology. 2018 Sep;288(3):867–75. doi: 10.1148/radiol.2018172771. PMID: 29969076. Exclusion Code: X8.29969076
1453 Schroeder MC, Tien YY, Wright K, . Geographic variation in the use of adjuvant therapy among elderly patients with resected non-small cell lung cancer. Lung Cancer. 2016 May;95:28–34. doi: 10.1016/j.lungcan.2016.02.010. PMID: 27040848. Exclusion Code: X8.27040848
1454 Schuhmann M, Bostanci K, Bugalho A, . Endobronchial ultrasound-guided cryobiopsies in peripheral pulmonary lesions: a feasibility study. Eur Respir J. 2014 Jan;43(1):233–9. doi: 10.1183/09031936.00011313. PMID: 23900983. Exclusion Code: X3.23900983
1455 Schwartz RM, Yip R, Flores RM, . The impact of resection method and patient factors on quality of life among stage IA non-small cell lung cancer surgical patients. J Surg Oncol. 2017 Feb;115(2):173–80. doi: 10.1002/jso.24478. PMID: 27790715. Exclusion Code: X11.27790715
1456 Sconfienza LM, Mauri G, Grossi F, . Pleural and peripheral lung lesions: comparison of US- and CT-guided biopsy. Radiology. 2013 Mar;266(3):930–5. doi: 10.1148/radiol.12112077. PMID: 23204543. Exclusion Code: X3.23204543
1457 Scotti V, Bruni A, Francolini G, . Stereotactic Ablative Radiotherapy as an Alternative to Lobectomy in Patients With Medically Operable Stage I NSCLC: A Retrospective, Multicenter Analysis. Clin Lung Cancer. 2019 Jan;20(1):e53–e61. doi: 10.1016/j.cllc.2018.09.003. PMID: 30348595. Exclusion Code: X13.30348595
1458 Segmen F, Aktas Z, Ozturk A, . How many samples would be optimal for endobronchial cryobiopsy? Surg Endosc. 2017 Mar;31(3):1219–24. doi: 10.1007/s00464-016-5095-3. PMID: 27412127. Exclusion Code: X3.27412127
1459 Sekine Y, Sakairi Y, Yoshino M, . The impact of combined pulmonary fibrosis and chronic obstructive pulmonary disease on long-term survival after lung cancer surgery. Thorac Cardiovasc Surg. 2014 Jun;62(4):332–7. doi: 10.1055/s-0033-1363478. PMID: 24879070. Exclusion Code: X11.24879070
1460 Semaan RW, Lee HJ, Feller-Kopman D, . Same-day computed tomographic chest imaging for pulmonary nodule targeting with electromagnetic navigation bronchoscopy may decrease unnecessary procedures. Ann Am Thorac Soc. 2016 Dec;13(12):2223–8. doi: 10.1513/AnnalsATS.201607-522BC. PMID: 27925781. Exclusion Code: X8.27925781
1461 Senan S, Verstegen NE, Palma D, . Stages I-II non-small cell lung cancer treated using either lobectomy by video-assisted thoracoscopic surgery (VATS) or stereotactic ablative radiotherapy (SABR): outcomes of a propensity score-matched analysis. J Clin Oncol. 2012;30(15)PMID: CN-01008197. Exclusion Code: X2.
1462 Senbaklavaci O. Lobar lung resection in elderly patients with non-small cell lung carcinoma: impact of chronic obstructive pulmonary disease on surgical outcome. Int Surg. 2014 Jul-Aug;99(4):319–24. doi: 10.9738/intsurg-d-14-00015.1. PMID: 25058759. Exclusion Code: X3.25058759
1463 Senthi S, Dahele M, van de Ven PM, . Late radiologic changes after stereotactic ablative radiotherapy for early stage lung cancer: a comparison of fixed-beam versus arc delivery techniques. Radiother Oncol. 2013 Oct;109(1):77–81. doi: 10.1016/j.radonc.2013.08.034. PMID: 24060174. Exclusion Code: X10.24060174
1464 Senthi S, Haasbeek CJ, Slotman BJ, . Outcomes of stereotactic ablative radiotherapy for central lung tumours: a systematic review. Radiother Oncol. 2013 Mar;106(3):276–82. doi: 10.1016/j.radonc.2013.01.004. PMID: 23462705. Exclusion Code: X9.23462705
1465 Senthi S, Lagerwaard FJ, Haasbeek CJ, . Patterns of disease recurrence after stereotactic ablative radiotherapy for early stage non-small-cell lung cancer: a retrospective analysis. Lancet Oncol. 2012 Aug;13(8):802–9. doi: 10.1016/s1470-2045(12)70242-5. PMID: 22727222. Exclusion Code: X3.22727222
1466 Seok Y, Cho S, Kim K, . Partly solid pulmonary nodules: waiting for change or surgery outright? Interact Cardiovasc Thorac Surg. 2014 Oct;19(4):556–60. doi: 10.1093/icvts/ivu205. PMID: 24981106. Exclusion Code: X3.24981106
1467 Seok Y, Cho S, Lee JY, . The effect of postoperative change in bronchial angle on postoperative pulmonary function after upper lobectomy in lung cancer patients. Interact Cardiovasc Thorac Surg. 2014 Feb;18(2):183–8. doi: 10.1093/icvts/ivt463. PMID: 24243734. Exclusion Code: X3.24243734
1468 Serra Fortuny M, Gallego M, Berna L, . FDG-PET parameters predicting mediastinal malignancy in lung cancer. BMC Pulm Med. 2016 Dec 8;16(1):177. doi: 10.1186/s12890-016-0338-6. PMID: 27931198. Exclusion Code: X3.27931198
1469 Sestini S, Boeri M, Marchiano A, . Circulating microRNA signature as liquid-biopsy to monitor lung cancer in low-dose computed tomography screening. Oncotarget. 2015 Oct 20;6(32):32868–77. doi: 10.18632/oncotarget.5210. PMID: 26451608. Exclusion Code: X5.26451608
1470 Shafiek H, Valera JL, Togores B, . Risk of postoperative complications in chronic obstructive lung diseases patients considered fit for lung cancer surgery: beyond oxygen consumption. Eur J Cardiothorac Surg. 2016 Oct;50(4):772–9. doi: 10.1093/ejcts/ezw104. PMID: 27059429. Exclusion Code: X3.27059429
1471 Shah C, Grills IS, Kestin LL, . Intrafraction variation of mean tumor position during image-guided hypofractionated stereotactic body radiotherapy for lung cancer. Int J Radiat Oncol Biol Phys. 2012 Apr 1;82(5):1636–41. doi: 10.1016/j.ijrobp.2011.02.011. PMID: 21489715. Exclusion Code: X8.21489715
1472 Shao F, Liu Z, Pan Y, . Bronchoplasty using continuous suture in complete monitor view: a suitable method of thoracoscopic sleeve lobectomy for non-small cell lung cancer. World J Surg Oncol. 2016 Apr 30;14:134. doi: 10.1186/s12957-016-0895-4. PMID: 27130332. Exclusion Code: X3.27130332
1473 Shapiro M, Kadakia S, Lim J, . Lobe-specific mediastinal nodal dissection is sufficient during lobectomy by video-assisted thoracic surgery or thoracotomy for early-stage lung cancer. Chest. 2013 Nov;144(5):1615–21. doi: 10.1378/chest.12-3069. PMID: 23828253. Exclusion Code: X11.23828253
1474 Sharifi H, van Elmpt W, Oberije C, . Quantification of CT-assessed radiation-induced lung damage in lung cancer patients treated with or without chemotherapy and cetuximab. Acta Oncol. 2016;55(2):156–62. doi: 10.3109/0284186x.2015.1080856. PMID: 26399389. Exclusion Code: X3.26399389
1475 Sharma A, McDermott S, Mathisen DJ, . Preoperative localization of lung nodules with fiducial markers: feasibility and technical considerations. Ann Thorac Surg. 2017 Apr;103(4):1114–20. doi: 10.1016/j.athoracsur.2016.09.112. PMID: 28131426. Exclusion Code: X3.28131426
1476 Sharma R, Wang Y, Chen L, . Utility of a novel triple marker (combination of thyroid transcription factor 1, Napsin A, and P40) in the subclassification of non-small cell lung carcinomas using fine-needle aspiration cases. Hum Pathol. 2016 Aug;54:8–16. doi: 10.1016/j.humpath.2016.02.027. PMID: 27045515. Exclusion Code: X5.27045515
1477 Shaverdian N, Tenn S, Veruttipong D, . The significance of PTV dose coverage on cancer control outcomes in early stage non-small cell lung cancer patients treated with highly ablative stereotactic body radiation therapy. Br J Radiol. 2016;89(1059):20150963. doi: 10.1259/bjr.20150963. PMID: 26764282. Exclusion Code: X10.26764282
1478 Shaverdian N, Veruttipong D, Wang J, . Location matters: stage I non-small-cell carcinomas of the lower lobes treated with stereotactic body radiation therapy are associated with poor outcomes. Clin Lung Cancer. 2017 Mar;18(2):e137–e42. doi: 10.1016/j.cllc.2016.09.001. PMID: 27908620. Exclusion Code: X10.27908620
1479 Shaverdian N, Veruttipong D, Wang J, . Pretreatment immune parameters predict for overall survival and toxicity in early-stage non-small-cell lung cancer patients treated with stereotactic body radiation therapy. Clin Lung Cancer. 2016 Jan;17(1):39–46. doi: 10.1016/j.cllc.2015.07.007. PMID: 26372098. Exclusion Code: X3.26372098
1480 Shaverdian N, Wang PC, Steinberg M, . The patient’s perspective on stereotactic body radiation therapy (SBRT) vs. surgery for treatment of early stage non-small cell lung cancer (NSCLC). Lung Cancer. 2015 Nov;90(2):230–3. doi: 10.1016/j.lungcan.2015.07.009. PMID: 26358313. Exclusion Code: X10.26358313
1481 She Y, Zhang L, Zhu H, . The predictive value of CT-based radiomics in differentiating indolent from invasive lung adenocarcinoma in patients with pulmonary nodules. Eur Radiol. 2018 Dec;28(12):5121–8. doi: 10.1007/s00330-018-5509-9. PMID: 29869172. Exclusion Code: X3.29869172
1482 Sheel AR, McShane J, Poullis MP. Survival of patients with or without symptoms undergoing potentially curative resections for primary lung cancer. Ann Thorac Surg. 2013 Jan;95(1):276–84. doi: 10.1016/j.athoracsur.2012.09.051. PMID: 23200231. Exclusion Code: X3.23200231
1483 Sheikhbahaei S, Mena E, Yanamadala A, . The value of FDG PET/CT in treatment response assessment, follow-up, and surveillance of lung cancer. AJR Am J Roentgenol. 2017 Feb;208(2):420–33. doi: 10.2214/ajr.16.16532. PMID: 27726427. Exclusion Code: X3.27726427
1484 Shelver J, Wendt CH, McClure M, . Effect of an automated tracking registry on the rate of tracking failure in incidental pulmonary nodules. J Am Coll Radiol. 2017 Jun;14(6):773–7. doi: 10.1016/j.jacr.2017.02.001. PMID: 28434846. Exclusion Code: X8.28434846
1485 Shen J, Liao J, Guarnera MA, . Analysis of MicroRNAs in sputum to improve computed tomography for lung cancer diagnosis. J Thorac Oncol. 2014 Jan;9(1):33–40. doi: 10.1097/jto.0000000000000025. PMID: 24305007. Exclusion Code: X5.24305007
1486 Sherman SM, Lane EL. Awareness of risk factors for breast, lung and cervical cancer in a UK student population. J Cancer Educ. 2015 Dec;30(4):660–3. doi: 10.1007/s13187-014-0770-3. PMID: 25510367. Exclusion Code: X5.25510367
1487 Shi GL, Chen Y, Sun Y, . Significance of serum MicroRNAs in the auxiliary diagnosis of non-small cell lung cancer. Clin Lab. 2017 Jan 1;63(1):133–40. doi: 10.7754/Clin.Lab.2016.160710. PMID: 28164492. Exclusion Code: X4.28164492
1488 Shi Q, Wang XS, Vaporciyan AA, . Patient-reported symptom interference as a measure of postsurgery functional recovery in lung cancer. J Pain Symptom Manage. 2016 Dec;52(6):822–31. doi: 10.1016/j.jpainsymman.2016.07.005. PMID: 27521528. Exclusion Code: X3.27521528
1489 Shiels MS, Katki HA, Hildesheim A, . Circulating inflammation markers, risk of lung cancer, and utility for risk stratification. J Natl Cancer Inst. 2015 Oct;107(10)doi: 10.1093/jnci/djv199. PMID: 26220734. Exclusion Code: X3.26220734
1490 Shiels MS, Pfeiffer RM, Hildesheim A, . Circulating inflammation markers and prospective risk for lung cancer. J Natl Cancer Inst. 2013 Dec 18;105(24):1871–80. doi: 10.1093/jnci/djt309. PMID: 24249745. Exclusion Code: X4.24249745
1491 Shien K, Toyooka S, Soh J, . Clinicopathological characteristics and lymph node metastasis pathway of non-small-cell lung cancer located in the left lingular division. Interact Cardiovasc Thorac Surg. 2015 Jun;20(6):791–6. doi: 10.1093/icvts/ivv062. PMID: 25805399. Exclusion Code: X3.25805399
1492 Shim SS, Oh YW, Kong KA, . Pulmonary nodule size evaluation with chest tomosynthesis and CT: a phantom study. Br J Radiol. 2015 Mar;88(1047):20140040. doi: 10.1259/bjr.20140040. PMID: 25605344. Exclusion Code: X4.25605344
1493 Shimada Y, Saji H, Kato Y, . The frequency and prognostic impact of pathological microscopic vascular invasion according to tumor size in non-small cell lung cancer. Chest. 2016 Mar;149(3):775–85. doi: 10.1378/chest.15-0559. PMID: 26379115. Exclusion Code: X3.26379115
1494 Shimamura Y, Sasaki S, Shimohira M, . New technique of percutaneous CT fluoroscopy-guided marking before video-assisted thoracoscopic surgery for small lung lesions: feasibility of using a 25-gauge needle without local anaesthesia. Br J Radiol. 2018 Feb;91(1083):20170692. doi: 10.1259/bjr.20170692. PMID: 29172683. Exclusion Code: X3.29172683
1495 Shimizu K, Mogi A, Yajima T, . Thoracoscopic subsuperior segment segmentectomy. Ann Thorac Surg. 2017 Nov;104(5):e407–e10. doi: 10.1016/j.athoracsur.2017.07.007. PMID: 29054241. Exclusion Code: X3.29054241
1496 Shimizu K, Nagashima T, Yajima T, . Thoracoscopic medial-basal segment segmentectomy. Ann Thorac Surg. 2017 Nov;104(5):e403–e6. doi: 10.1016/j.athoracsur.2017.07.006. PMID: 29054240. Exclusion Code: X6.29054240
1497 Shin JY, Yoon JK, Marwaha G. Progress in the treatment and outcomes for early-stage non-small cell lung cancer. Lung. 2018 Jun;196(3):351–8. doi: 10.1007/s00408-018-0110-1. PMID: 29550987. Exclusion Code: X3.29550987
1498 Shin KE, Lee KS, Yi CA, . Subcentimeter lung nodules stable for 2 years at LDCT: long-term follow-up using volumetry. Respirology. 2014 Aug;19(6):921–8. doi: 10.1111/resp.12337. PMID: 24934105. Exclusion Code: X8.24934105
1499 Shin S, Kim HK, Choi YS, . Prognosis of unexpected and expected pathologic N1 non-small cell lung cancer. Ann Thorac Surg. 2013 Sep;96(3):969–75; discussion 75-6. doi: 10.1016/j.athoracsur.2013.04.070. PMID: 23916803. Exclusion Code: X3.23916803
1500 Shin S, Park HY, Kim H, . Joint effect of airflow limitation and emphysema on postoperative outcomes in early-stage nonsmall cell lung cancer. Eur Respir J. 2016 Dec;48(6):1743–50. doi: 10.1183/13993003.01148-2016. PMID: 27811074. Exclusion Code: X11.27811074
1501 Shin S, Park JS, Kim HK, . Approach to metastasis-suspected nodule accompanying operable non-small cell lung cancer. Thorac Cardiovasc Surg. 2014 Oct;62(7):616–23. doi: 10.1055/s-0033-1363767. PMID: 24752828. Exclusion Code: X3.24752828
1502 Shingyoji M, Nakajima T, Yoshino M, . Endobronchial ultrasonography for positron emission tomography and computed tomography-negative lymph node staging in non-small cell lung cancer. Ann Thorac Surg. 2014 Nov;98(5):1762–7. doi: 10.1016/j.athoracsur.2014.05.078. PMID: 25149044. Exclusion Code: X8.25149044
1503 Shintani Y, Inoue M, Funaki S, . Clinical usefulness of free subcutaneous fat pad for reduction of intraoperative air leakage during thoracoscopic pulmonary resection in lung cancer cases. Surg Endosc. 2015 Oct;29(10):2910–3. doi: 10.1007/s00464-014-4019-3. PMID: 25537378. Exclusion Code: X3.25537378
1504 Shiono S, Abiko M, Sato T. Limited resection for clinical stage IA non-small-cell lung cancers based on a standardized-uptake value index. Eur J Cardiothorac Surg. 2013 Jan;43(1):e7–e12. doi: 10.1093/ejcts/ezs573. PMID: 23129358. Exclusion Code: X11.23129358
1505 Shiono S, Katahira M, Abiko M, . Smoking is a perioperative risk factor and prognostic factor for lung cancer surgery. Gen Thorac Cardiovasc Surg. 2015 Feb;63(2):93–8. doi: 10.1007/s11748-014-0461-3. PMID: 25085320. Exclusion Code: X3.25085320
1506 Shiono S, Yanagawa N, Abiko M, . Detection of non-aggressive stage IA lung cancer using chest computed tomography and positron emission tomography/computed tomography. Interact Cardiovasc Thorac Surg. 2014 Oct;19(4):637–43. doi: 10.1093/icvts/ivu188. PMID: 24994703. Exclusion Code: X11.24994703
1507 Shiono S, Yanagawa N, Abiko M, . Noninvasive differential diagnosis of pulmonary nodules using the Standardized Uptake Value Index. Ann Thorac Cardiovasc Surg. 2015;21(3):236–41. doi: 10.5761/atcs.oa.14-00241. PMID: 25740450. Exclusion Code: X3.25740450
1508 Shioyama Y, Onishi H, Takayama K, . Clinical outcomes of stereotactic body radiotherapy for patients with stage I small-cell lung cancer: analysis of a subset of the japanese radiological society multi-institutional SBRT study group database. Technol Cancer Res Treat. 2018 Jan 1;17:1533033818783904. doi: 10.1177/1533033818783904. PMID: 29983096. Exclusion Code: X3.29983096
1509 Shirata Y, Jingu K, Koto M, . Prognostic factors for local control of stage I non-small cell lung cancer in stereotactic radiotherapy: a retrospective analysis. Radiat Oncol. 2012 Oct 31;7:182. doi: 10.1186/1748-717x-7-182. PMID: 23110967. Exclusion Code: X13.23110967
1510 Shlomi D, Peled N, Schwarz YA, . Non-invasive early detection of malignant pulmonary nodules by FISH-based sputum test. Cancer Genet. 2018 Oct;226-227:1–10. doi: 10.1016/j.cancergen.2018.04.118. PMID: 30005848. Exclusion Code: X3.30005848
1511 Shoji F, Haratake N, Akamine T, . The preoperative controlling nutritional status score predicts survival after curative surgery in patients with pathological stage I non-small cell lung cancer. Anticancer Res. 2017 Feb;37(2):741–7. doi: 10.21873/anticanres.11372. PMID: 28179325. Exclusion Code: X8.28179325
1512 Shoji F, Matsubara T, Kozuma Y, . Preoperative Geriatric Nutritional Risk Index: A predictive and prognostic factor in patients with pathological stage I non-small cell lung cancer. Surg Oncol. 2017 Dec;26(4):483–8. doi: 10.1016/j.suronc.2017.09.006. PMID: 29113668. Exclusion Code: X10.29113668
1513 Shoji F, Miura N, Matsubara T, . Prognostic significance of immune-nutritional parameters for surgically resected elderly lung cancer patients: a multicentre retrospective study. Interact Cardiovasc Thorac Surg. 2018 Mar 1;26(3):389–94. doi: 10.1093/icvts/ivx337. PMID: 29049803. Exclusion Code: X10.29049803
1514 Shoji F, Yamazaki K, Kouso H, . The impact of pleural lavage cytology both before and after lung resection on recurrence of non-small cell lung cancer. Ann Thorac Surg. 2016 Jun;101(6):2141–6. doi: 10.1016/j.athoracsur.2015.12.037. PMID: 27012585. Exclusion Code: X6.27012585
1515 Shrager J. Invited commentary. Ann Thorac Surg. 2016 Jun;101(6):2146–7. doi: 10.1016/j.athoracsur.2016.01.034. PMID: 27211933. Exclusion Code: X10.27211933
1516 Shroyer AL, Quin JA, Grau-Sepulveda MV, . Geographic variations in lung cancer lobectomy outcomes: The General Thoracic Surgery Database. Ann Thorac Surg. 2017 Nov;104(5):1650–5. doi: 10.1016/j.athoracsur.2017.05.066. PMID: 28935347. Exclusion Code: X8.28935347
1517 Shultz DB, Jang SS, Hanlon AL, . The effect of arm position on the dosimetry of thoracic stereotactic ablative radiation therapy using volumetric modulated arc therapy. Pract Radiat Oncol. 2014 May-Jun;4(3):192–7. doi: 10.1016/j.prro.2013.07.010. PMID: 24766687. Exclusion Code: X8.24766687
1518 Shultz DB, Trakul N, Abelson JA, . Imaging features associated with disease progression after stereotactic ablative radiotherapy for stage I non-small-cell lung cancer. Clin Lung Cancer. 2014 Jul;15(4):294–301.e3. doi: 10.1016/j.cllc.2013.12.011. PMID: 24594400. Exclusion Code: X13.24594400
1519 Shultz DB, Trakul N, Maxim PG, . Vagal and recurrent laryngeal neuropathy following stereotactic ablative radiation therapy in the chest. Pract Radiat Oncol. 2014 Jul-Aug;4(4):272–8. doi: 10.1016/j.prro.2013.08.005. PMID: 25012837. Exclusion Code: X3.25012837
1520 Shusharina N, Liao Z, Mohan R, . Differences in lung injury after IMRT or proton therapy assessed by (18)FDG PET imaging. Radiother Oncol. 2018 Jul;128(1):147–53. doi: 10.1016/j.radonc.2017.12.027. PMID: 29352608. Exclusion Code: X3.29352608
1521 Siegelman JW, Supanich MP, Gavrielides MA. Pulmonary nodules with ground-glass opacity can be reliably measured with low-dose techniques regardless of iterative reconstruction: results of a phantom study. AJR Am J Roentgenol. 2015 Jun;204(6):1242–7. doi: 10.2214/ajr.14.13820. PMID: 26001234. Exclusion Code: X3.26001234
1522 Sigel K, Wisnivesky J, Crothers K, . Immunological and infectious risk factors for lung cancer in US veterans with HIV: a longitudinal cohort study. Lancet HIV. 2017 Feb;4(2):e67–e73. doi: 10.1016/s2352-3018(16)30215-6. PMID: 27916584. Exclusion Code: X3.27916584
1523 Sihoe AD, Hiranandani R, Wong H, . Operating on a suspicious lung mass without a preoperative tissue diagnosis: pros and cons. Eur J Cardiothorac Surg. 2013 Aug;44(2):231–7; discussion 7. doi: 10.1093/ejcts/ezs671. PMID: 23299236. Exclusion Code: X11.23299236
1524 Silva M, Galeone C, Sverzellati N, . Screening with low-dose computed tomography does not improve survival of small cell lung cancer. J Thorac Oncol. 2016 Feb;11(2):187–93. doi: 10.1016/j.jtho.2015.10.014. PMID: 26845115. Exclusion Code: X3.26845115
1525 Silva M, Sverzellati N, Manna C, . Long-term surveillance of ground-glass nodules: evidence from the MILD trial. J Thorac Oncol. 2012 Oct;7(10):1541–6. doi: 10.1097/JTO.0b013e3182641bba. PMID: 22968185. Exclusion Code: X11.22968185
1526 Silvestri GA, Vachani A, Whitney D, . A bronchial genomic classifier for the diagnostic evaluation of lung cancer. N Engl J Med. 2015 Jul 16;373(3):243–51. doi: 10.1056/NEJMoa1504601. PMID: 25981554. Exclusion Code: X5.25981554
1527 Sim YT, Goh YG, Dempsey MF, . PET-CT evaluation of solitary pulmonary nodules: correlation with maximum standardized uptake value and pathology. Lung. 2013 Dec;191(6):625–32. doi: 10.1007/s00408-013-9500-6. PMID: 24013495. Exclusion Code: X3.24013495
1528 Simone CB, 2nd, Wildt B, Haas AR, . Stereotactic body radiation therapy for lung cancer. Chest. 2013 Jun;143(6):1784–90. doi: 10.1378/chest.12-2580. PMID: 23732589. Exclusion Code: X10.23732589
1529 Simonsen DF, Sogaard M, Bozi I, . Risk factors for postoperative pneumonia after lung cancer surgery and impact of pneumonia on survival. Respir Med. 2015 Oct;109(10):1340–6. doi: 10.1016/j.rmed.2015.07.008. PMID: 26209227. Exclusion Code: X3.26209227
1530 Sin DD, Tammemagi CM, Lam S, . Pro-surfactant protein B as a biomarker for lung cancer prediction. J Clin Oncol. 2013 Dec 20;31(36):4536–43. doi: 10.1200/jco.2013.50.6105. PMID: 24248694. Exclusion Code: X7.24248694
1531 Singh S, Pinsky P, Fineberg NS, . Evaluation of reader variability in the interpretation of follow-up CT scans at lung cancer screening. Radiology. 2011 Apr;259(1):263–70. doi: 10.1148/radiol.10101254. PMID: 21248232. Exclusion Code: X11.21248232
1532 Singh SP, Gierada DS, Pinsky P, . Reader variability in identifying pulmonary nodules on chest radiographs from the national lung screening trial. J Thorac Imaging. 2012 Jul;27(4):249–54. doi: 10.1097/RTI.0b013e318256951e. PMID: 22627615. Exclusion Code: X5.22627615
1533 Sinicrope PS, Rabe KG, Brockman TA, . Perceptions of lung cancer risk and beliefs in screening accuracy of spiral computed tomography among high-risk lung cancer family members. Acad Radiol. 2010 Aug;17(8):1012–25. doi: 10.1016/j.acra.2010.04.003. PMID: 20599157. Exclusion Code: X11.20599157
1534 Sio TT, Jensen AR, Miller RC, . Influence of patient’s physiologic factors and immobilization choice with stereotactic body radiotherapy for upper lung tumors. J Appl Clin Med Phys. 2014 Sep 8;15(5):4931. doi: 10.1120/jacmp.v15i5.4931. PMID: 25207580. Exclusion Code: X8.25207580
1535 Siva S, Callahan J, Kron T, . A prospective observational study of Gallium-68 ventilation and perfusion PET/CT during and after radiotherapy in patients with non-small cell lung cancer. BMC Cancer. 2014 Oct 2;14:740. doi: 10.1186/1471-2407-14-740. PMID: 25277150. Exclusion Code: X10.25277150
1536 Siva S, Kirby K, Caine H, . Comparison of single-fraction and multi-fraction stereotactic radiotherapy for patients with 18F-fluorodeoxyglucose positron emission tomography-staged pulmonary oligometastases. Clin Oncol (R Coll Radiol). 2015 Jun;27(6):353–61. doi: 10.1016/j.clon.2015.01.004. PMID: 25698068. Exclusion Code: X3.25698068
1537 Sivapalan P, Naur TMH, Colella S, . Impact of EBUS-TBNA on PET-CT imaging of mediastinal nodes. J Bronchology Interv Pulmonol. 2017 Jul;24(3):188–92. doi: 10.1097/lbr.0000000000000373. PMID: 28696964. Exclusion Code: X3.28696964
1538 Sivrikoz CM, Ak I, Simsek FS, . Is mediastinoscopy still the gold standard to evaluate mediastinal lymph nodes in patients with non-small cell lung carcinoma? Thorac Cardiovasc Surg. 2012 Mar;60(2):116–21. doi: 10.1055/s-0030-1271148. PMID: 21692019. Exclusion Code: X3.21692019
1539 Slatore C, Sullivan D, Pappas M, . Patient-centered outcomes among lung cancer screening recipients with computed tomography: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):927–34. PMID: DARE-12014038387. Exclusion Code: X9.
1540 Slatore CG, Golden SE, Ganzini L, . Distress and patient-centered communication among veterans with incidental (not screen-detected) pulmonary nodules. A cohort study. Ann Am Thorac Soc. 2015 Feb;12(2):184–92. doi: 10.1513/AnnalsATS.201406-283OC. PMID: 25521482. Exclusion Code: X3.25521482
1541 Slatore CG, Wiener RS, Golden SE, . Longitudinal assessment of distress among veterans with incidental pulmonary nodules. Ann Am Thorac Soc. 2016 Nov;13(11):1983–91. doi: 10.1513/AnnalsATS.201607-555OC. PMID: 27599153. Exclusion Code: X3.27599153
1542 Slattery MM, Foley C, Kenny D, . Long-term follow-up of non-calcified pulmonary nodules (<10 mm) identified during low-dose CT screening for lung cancer. Eur Radiol. 2012 Sep;22(9):1923–8. doi: 10.1007/s00330-012-2443-0. PMID: 22538626. Exclusion Code: X10.22538626
1543 Slavova-Azmanova NS, Lizama C, Johnson CE, . Impact of the introduction of EBUS on time to management decision, complications, and invasive modalities used to diagnose and stage lung cancer: a pragmatic pre-post study. BMC Cancer. 2016 Jan 28;16:44. doi: 10.1186/s12885-016-2081-z. PMID: 26822160. Exclusion Code: X3.26822160
1544 Smeltzer MP, Faris NR, Ray MA, . Survival Before and After Direct Surgical Quality Feedback in a Population-Based Lung Cancer Cohort. Ann Thorac Surg. 2019 May;107(5):1487–93. doi: 10.1016/j.athoracsur.2018.11.058. PMID: 30594579. Exclusion Code: X3.30594579
1545 Smith CB, Kale M, Mhango G, . Comparative outcomes of elderly stage I lung cancer patients treated with segmentectomy via video-assisted thoracoscopic surgery versus open resection. J Thorac Oncol. 2014 Mar;9(3):383–9. doi: 10.1097/jto.0000000000000083. PMID: 24495998. Exclusion Code: X11.24495998
1546 Smith CB, Swanson SJ, Mhango G, . Survival after segmentectomy and wedge resection in stage I non-small-cell lung cancer. J Thorac Oncol. 2013 Jan;8(1):73–8. doi: 10.1097/JTO.0b013e31827451c4. PMID: 23164939. Exclusion Code: X8.23164939
1547 Smith SL, Bowers D, Jennings P, . Pulmonary radiofrequency ablation in a district general hospital: is it a safe and effective treatment? Clin Radiol. 2016 Sep;71(9):939.e1–8. doi: 10.1016/j.crad.2016.03.021. PMID: 27157314. Exclusion Code: X3.27157314
1548 Snee MP, McParland L, Collinson F, . The SABRTooth feasibility trial protocol: a study to determine the feasibility and acceptability of conducting a phase III randomised controlled trial comparing stereotactic ablative radiotherapy (SABR) with surgery in patients with peripheral stage I non-small cell lung cancer (NSCLC) considered to be at higher risk of complications from surgical resection. Pilot Feasibility Stud. 2016;2:5. doi: 10.1186/s40814-016-0046-2. PMID: 27965826. Exclusion Code: X10.27965826
1549 Snee MP, McParland L, Collinson F, . Erratum to: The SABRTooth feasibility trial protocol: a study to determine the feasibility and acceptability of conducting a phase III randomised controlled trial comparing stereotactic ablative radiotherapy (SABR) with surgery in patients with peripheral stage I non-small cell lung cancer (NSCLC) considered to be at higher risk of complications from surgical resection. Pilot Feasibility Stud. 2016;2:55. doi: 10.1186/s40814-016-0095-6. PMID: 27976752. Exclusion Code: X10.27976752
1550 Soardi GA, Perandini S, Larici AR, . Multicentre external validation of the BIMC model for solid solitary pulmonary nodule malignancy prediction. Eur Radiol. 2017 May;27(5):1929–33. doi: 10.1007/s00330-016-4538-5. PMID: 27553937. Exclusion Code: X3.27553937
1551 Soda M, Isobe K, Inoue A, . A prospective PCR-based screening for the EML4-ALK oncogene in non-small cell lung cancer. Clin Cancer Res. 2012 Oct 15;18(20):5682–9. doi: 10.1158/1078-0432.ccr-11-2947. PMID: 22908099. Exclusion Code: X3.22908099
1552 Soderman C, Johnsson AA, Vikgren J, . Evaluation of accuracy and precision of manual size measurements in chest tomosynthesis using simulated pulmonary nodules. Acad Radiol. 2015 Apr;22(4):496–504. doi: 10.1016/j.acra.2014.11.012. PMID: 25601303. Exclusion Code: X3.25601303
1553 Sofocleous CT, Garg SK, Cohen P, . Ki 67 is an independent predictive biomarker of cancer specific and local recurrence-free survival after lung tumor ablation. Ann Surg Oncol. 2013 Dec;20: Suppl 3:S676–83. doi: 10.1245/s10434-013-3140-1. PMID: 23897007. Exclusion Code: X3.23897007
1554 Solli P, Casiraghi M, Brambilla D, . Surgical treatment of superior sulcus tumors: a 15-year single-center experience. Semin Thorac Cardiovasc Surg. 2017 Spring;29(1):79–88. doi: 10.1053/j.semtcvs.2017.01.010. PMID: 28684003. Exclusion Code: X3.28684003
1555 Solomon J, Mileto A, Nelson RC, . Quantitative features of liver lesions, lung nodules, and renal stones at multi-detector row CT examinations: dependency on radiation dose and reconstruction algorithm. Radiology. 2016 Apr;279(1):185–94. doi: 10.1148/radiol.2015150892. PMID: 26624973. Exclusion Code: X3.26624973
1556 Sommer G, Tremper J, Koenigkam-Santos M, . Lung nodule detection in a high-risk population: comparison of magnetic resonance imaging and low-dose computed tomography. Eur J Radiol. 2014 Mar;83(3):600–5. doi: 10.1016/j.ejrad.2013.11.012. PMID: 24364923. Exclusion Code: X7.24364923
1557 Sommer G, Wiese M, Winter L, . Preoperative staging of non-small-cell lung cancer: comparison of whole-body diffusion-weighted magnetic resonance imaging and 18F-fluorodeoxyglucose-positron emission tomography/computed tomography. Eur Radiol. 2012 Dec;22(12):2859–67. doi: 10.1007/s00330-012-2542-y. PMID: 22772365. Exclusion Code: X8.22772365
1558 Sommer MS, Trier K, Vibe-Petersen J, . Perioperative rehabilitation in operation for lung cancer (PROLUCA) - rationale and design. BMC Cancer. 2014 Jun 4;14:404. doi: 10.1186/1471-2407-14-404. PMID: 24898680. Exclusion Code: X10.24898680
1559 Son JY, Lee HY, Kim JH, . Quantitative CT analysis of pulmonary ground-glass opacity nodules for distinguishing invasive adenocarcinoma from non-invasive or minimally invasive adenocarcinoma: the added value of using iodine mapping. Eur Radiol. 2016 Jan;26(1):43–54. doi: 10.1007/s00330-015-3816-y. PMID: 25981222. Exclusion Code: X3.25981222
1560 Son JY, Lee HY, Lee KS, . Quantitative CT analysis of pulmonary ground-glass opacity nodules for the distinction of invasive adenocarcinoma from pre-invasive or minimally invasive adenocarcinoma. PLoS One. 2014;9(8):e104066. doi: 10.1371/journal.pone.0104066. PMID: 25102064. Exclusion Code: X3.25102064
1561 Song S, Chang JH, Kim HJ, . Survey of the patterns of using stereotactic ablative radiotherapy for early-stage non-small cell lung cancer in Korea. Cancer Res Treat. 2017 Jul;49(3):688–94. doi: 10.4143/crt.2016.219. PMID: 27809459. Exclusion Code: X8.27809459
1562 Song SY, Choi W, Shin SS, . Fractionated stereotactic body radiation therapy for medically inoperable stage I lung cancer adjacent to central large bronchus. Lung Cancer. 2009 Oct;66(1):89–93. doi: 10.1016/j.lungcan.2008.12.016. PMID: 19168260. Exclusion Code: X11.19168260
1563 Sozzi G, Boeri M, Rossi M, . Clinical utility of a plasma-based miRNA signature classifier within computed tomography lung cancer screening: a correlative MILD trial study. J Clin Oncol. 2014 Mar 10;32(8):768–73. doi: 10.1200/jco.2013.50.4357. PMID: 24419137. Exclusion Code: X5.24419137
1564 Speicher PJ, Gu L, Wang X, . Adjuvant chemotherapy after lobectomy for T1-2N0 non-small cell lung cancer: are the guidelines supported? J Natl Compr Canc Netw. 2015 Jun;13(6):755–61. PMID: 26085391. Exclusion Code: X6.26085391
1565 Spencer K, Kennedy M, Lummis K, . Equivalent cancer-specific survival following surgical resection or SABR for stage I lung cancer. Radiother Oncol. 2018;127:S244–S5. PMID: CN-01630579. Exclusion Code: X2.
1566 Spiro S, Shah P, Rintoul R, . Lungsearch: a randomised controlled trial of surveillance for the early detection of lung cancer in a high risk group. Thorax. 2016;71:A76–. doi: 10.1136/thoraxjnl-2016-209333.134. PMID: CN-01360140. Exclusion Code: X2.
1567 Spiro SG, Hackshaw A. Research in progress--LungSEARCH: a randomised controlled trial of surveillance for the early detection of lung cancer in a high-risk group. Thorax. 2016 Jan;71(1):91–3. doi: 10.1136/thoraxjnl-2015-207433. PMID: 26138736. Exclusion Code: X5.26138736
1568 Spitz MR, Amos CI, Land S, . Role of selected genetic variants in lung cancer risk in African Americans. J Thorac Oncol. 2013 Apr;8(4):391–7. doi: 10.1097/JTO.0b013e318283da29. PMID: 23454887. Exclusion Code: X4.23454887
1569 Spitz MR, Etzel CJ, Dong Q, . An expanded risk prediction model for lung cancer. Cancer Prev Res (Phila). 2008 Sep;1(4):250–4. doi: 10.1158/1940-6207.CAPR-08-0060. PMID: 19138968. Exclusion Code: X4.19138968
1570 Spitz MR, Hong WK, Amos CI, . A risk model for prediction of lung cancer. J Natl Cancer Inst. 2007 May 02;99(9):715–26. doi: 10.1093/jnci/djk153. PMID: 17470739. Exclusion Code: X7.17470739
1571 Splatt AM, Steinke K. Major complications of high-energy microwave ablation for percutaneous CT-guided treatment of lung malignancies: Single-centre experience after 4 years. J Med Imaging Radiat Oncol. 2015 Oct;59(5):609–16. doi: 10.1111/1754-9485.12345. PMID: 26238653. Exclusion Code: X6.26238653
1572 Spratt DE, Wu AJ, Adeseye V, . Recurrence patterns and second primary lung cancers after stereotactic body radiation therapy for early-stage non-small-cell lung cancer: implications for surveillance. Clin Lung Cancer. 2016 May;17(3):177–83.e2. doi: 10.1016/j.cllc.2015.09.006. PMID: 26602271. Exclusion Code: X10.26602271
1573 Srisomboon C, Koizumi K, Haraguchi S, . Complete video-assisted thoracoscopic surgery for lung cancer in 400 patients. Asian Cardiovasc Thorac Ann. 2013 Dec;21(6):700–7. doi: 10.1177/0218492313479038. PMID: 24569329. Exclusion Code: X3.24569329
1574 St Julien JB, Pinkerman R, Aldrich MC, . Poor survival for veterans with pathologic stage I non-small-cell lung cancer. Am J Surg. 2012 Nov;204(5):637–42. doi: 10.1016/j.amjsurg.2012.07.008. PMID: 22906246. Exclusion Code: X11.22906246
1575 Stahl JM, Ross R, Harder EM, . The effect of biologically effective dose and radiation treatment schedule on overall survival in stage I non-small cell lung cancer patients treated with stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 2016 Dec 1;96(5):1011–20. doi: 10.1016/j.ijrobp.2016.08.033. PMID: 27869080. Exclusion Code: X10.27869080
1576 Stam B, Tijhuis A, Rossi M, . Cardiac sparing in stereotactic body radiotherapy of early stage NSCLC patients. J Thorac Oncol. 2018;13(10):S1009–. doi: 10.1016/j.jtho.2018.08.1924. PMID: CN-01654361. Exclusion Code: X2.
1577 Stamenovic D, Messerschmidt A, Schneider T. Surgery for lung tumors in the elderly: A retrospective cohort study on the influence of advanced age (over 80 years) on the development of complications by using a multivariate risk model. Int J Surg. 2018 Apr;52:141–8. doi: 10.1016/j.ijsu.2018.02.008. PMID: 29486244. Exclusion Code: X3.29486244
1578 Stefani A, Nesci J, Casali C, . Wedge resection versus lobectomy for T1N0 non-small cell lung cancer. Minerva Chir. 2012 Dec;67(6):489–98. PMID: 23334112. Exclusion Code: X11.23334112
1579 Steger V, Veit S, Walker T, . Does dose matter? Effect of two different neoadjuvant protocols in advanced NSCLC. Thorac Cardiovasc Surg. 2013 Mar;61(2):109–15. doi: 10.1055/s-0032-1311529. PMID: 22821672. Exclusion Code: X3.22821672
1580 Steinfort DP, Farmer MW, Irving LB, . Pulmonologist-performed per-esophageal needle aspiration of parenchymal lung lesions using an EBUS bronchoscope: diagnostic utility and safety. J Bronchology Interv Pulmonol. 2017 Apr;24(2):117–24. doi: 10.1097/lbr.0000000000000350. PMID: 28005836. Exclusion Code: X3.28005836
1581 Steinfort DP, Leong TL, Laska IF, . Diagnostic utility and accuracy of rapid on-site evaluation of bronchoscopic brushings. Eur Respir J. 2015 Jun;45(6):1653–60. doi: 10.1183/09031936.00111314. PMID: 25537567. Exclusion Code: X3.25537567
1582 Steinhauser Motta JP, Kempa AT, Pinto Cardoso A, . Endobronchial ultrasound in real life: primary diagnosis and mediastinal staging of lung cancer in patients submitted to thoracic surgery. BMC Pulm Med. 2016 Jul 19;16(1):101. doi: 10.1186/s12890-016-0264-7. PMID: 27435209. Exclusion Code: X3.27435209
1583 Stephans KL, Djemil T, Diaconu C, . Esophageal dose tolerance to hypofractionated stereotactic body radiation therapy: risk factors for late toxicity. Int J Radiat Oncol Biol Phys. 2014 Sep 1;90(1):197–202. doi: 10.1016/j.ijrobp.2014.05.011. PMID: 25015204. Exclusion Code: X3.25015204
1584 Stephans KL, Djemil T, Reddy CA, . A comparison of two stereotactic body radiation fractionation schedules for medically inoperable stage I non-small cell lung cancer: the Cleveland Clinic experience. J Thorac Oncol. 2009 Aug;4(8):976–82. doi: 10.1097/JTO.0b013e3181adf509. PMID: 19633473. Exclusion Code: X11.19633473
1585 Steunenberg B, Aerts B, De Groot H, . Quality assessment of video mediastinoscopy performed for staging in non-small cell lung cancer. Thorac Cardiovasc Surg. 2016 Sep;64(6):520–5. doi: 10.1055/s-0035-1556082. PMID: 26220697. Exclusion Code: X3.26220697
1586 Stevens H, Bakker PF, Schlosser NJ, . Use of a dual-head coincidence camera and 18F-FDG for detection and nodal staging of non-small cell lung cancer: accuracy as determined by 2 independent observers. J Nucl Med. 2003 Mar;44(3):336–40. PMID: 12620997. Exclusion Code: X3.12620997
1587 Stigt JA, Uil SM, Oostdijk AH, . A diagnostic program for patients suspected of having lung cancer. Clin Lung Cancer. 2012 Nov;13(6):475–81. doi: 10.1016/j.cllc.2012.03.001. PMID: 22498114. Exclusion Code: X3.22498114
1588 Stolz AJ, Harustiak T, Simonek J, . Pneumonectomy for non-small cell lung cancer: predictors of early mortality and morbidity. Acta Chir Belg. 2014 Jan-Feb;114(1):25–30. PMID: 24720134. Exclusion Code: X11.24720134
1589 Stolzmann P, Veit-Haibach P, Chuck N, . Detection rate, location, and size of pulmonary nodules in trimodality PET/CT-MR: comparison of low-dose CT and Dixon-based MR imaging. Invest Radiol. 2013 May;48(5):241–6. doi: 10.1097/RLI.0b013e31826f2de9. PMID: 23070096. Exclusion Code: X3.23070096
1590 Stornaiuolo M, La Regina G, Passacantilli S, . Structure-based lead optimization and biological evaluation of BAX direct activators as novel potential anticancer agents. J Med Chem. 2015 Mar 12;58(5):2135–48. doi: 10.1021/jm501123r. PMID: 25668341. Exclusion Code: X6.25668341
1591 Strano S, Lupo A, Lococo F, . Prognostic significance of vascular and lymphatic emboli in resected pulmonary adenocarcinoma. Ann Thorac Surg. 2013 Apr;95(4):1204–10. doi: 10.1016/j.athoracsur.2012.12.024. PMID: 23415237. Exclusion Code: X3.23415237
1592 Su CT, Bhargava A, Shah CD, . Screening Patterns and Mortality Differences in Patients With Lung Cancer at an Urban Underserved Community. Clin Lung Cancer. 2018 Sep;19(5):e767–e73. doi: 10.1016/j.cllc.2018.05.019. PMID: 29937386. Exclusion Code: X10.29937386
1593 Subotic D, Molins L, Soldatovic I, . Completion pneumonectomy: a valuable option for lung cancer recurrence or new primaries. World J Surg Oncol. 2018 May 28;16(1):98. doi: 10.1186/s12957-018-1398-2. PMID: 29807542. Exclusion Code: X3.29807542
1594 Subotic D, Savic M, Atanasijadis N, . Standard versus extended pneumonectomy for lung cancer: what really matters? World J Surg Oncol. 2014 Aug 3;12:248. doi: 10.1186/1477-7819-12-248. PMID: 25086948. Exclusion Code: X3.25086948
1595 Sugiura H, Takeda A, Hoshi T, . Acute exacerbation of usual interstitial pneumonia after resection of lung cancer. Ann Thorac Surg. 2012 Mar;93(3):937–43. doi: 10.1016/j.athoracsur.2011.12.010. PMID: 22305054. Exclusion Code: X3.22305054
1596 Sui X, Meinel FG, Song W, . Detection and size measurements of pulmonary nodules in ultra-low-dose CT with iterative reconstruction compared to low dose CT. Eur J Radiol. 2016 Mar;85(3):564–70. doi: 10.1016/j.ejrad.2015.12.013. PMID: 26860668. Exclusion Code: X11.26860668
1597 Sui X, Zhao H, Yang F, . Analysis of factors affecting successful microcoil localization for pulmonary nodules. J Surg Res. 2018 Apr;224:193–9. doi: 10.1016/j.jss.2017.12.020. PMID: 29506840. Exclusion Code: X10.29506840
1598 Sullivan DR, Forsberg CW, Ganzini L, . Longitudinal changes in depression symptoms and survival among patients with lung cancer: a national cohort assessment. J Clin Oncol. 2016 Nov 20;34(33):3984–91. doi: 10.1200/jco.2016.66.8459. PMID: 27996350. Exclusion Code: X3.27996350
1599 Sullivan FM, Farmer E, Mair FS, . Detection in blood of autoantibodies to tumour antigens as a case-finding method in lung cancer using the EarlyCDT®-Lung Test (ECLS): study protocol for a randomized controlled trial. BMC Cancer. 2017;17(1):187. doi: 10.1186/s12885-017-3175-y. PMID: CN-01443602. Exclusion Code: X8.28284200
1600 Sumitomo R, Fukui T, Marumo S, . Effects of vessel interruption sequence during thoracoscopic lobectomy for non-small cell lung cancer. Gen Thorac Cardiovasc Surg. 2018 Aug;66(8):464–70. doi: 10.1007/s11748-018-0943-9. PMID: 29802566. Exclusion Code: X11.29802566
1601 Sun B, Wang Y, Kota K, . Telomere length variation: A potential new telomere biomarker for lung cancer risk. Lung Cancer. 2015 Jun;88(3):297–303. doi: 10.1016/j.lungcan.2015.03.011. PMID: 25840848. Exclusion Code: X4.25840848
1602 Sun V, Kim JY, Williams AC, . Quality of life and symptoms following stereotactic body radiotherapy in early-stage lung cancer patients. J Community Support Oncol. 2014 Nov;12(11):407–14. PMID: 25789332. Exclusion Code: X13.25789332
1603 Sun Y, Duan Q, Chen X, . Comparative efficacy and toxicity of induction chemotherapy with concurrent stereotactic body radiotherapy and stereotactic body radiotherapy with subsequent chemotherapy in patients with clinical stage T1-3N0M0 non-small cell lung carcinoma. Clin Transl Oncol. 2017 Dec;19(12):1498–506. doi: 10.1007/s12094-017-1694-2. PMID: 28589432. Exclusion Code: X6.28589432
1604 Sun Y, Yang M, Mao D, . Low-dose volume perfusion computed tomography (VPCT) for diagnosis of solitary pulmonary nodules. Eur J Radiol. 2016 Jun;85(6):1208–18. doi: 10.1016/j.ejrad.2016.03.026. PMID: 27161072. Exclusion Code: X3.27161072
1605 Sung SY, Kwak YK, Lee SW, . Lymphovascular Invasion Increases the Risk of Nodal and Distant Recurrence in Node-Negative Stage I-IIA Non-Small-Cell Lung Cancer. Oncology. 2018;95(3):156–62. doi: 10.1159/000488859. PMID: 29847825. Exclusion Code: X10.29847825
1606 Suo S, Cheng J, Cao M, . Assessment of heterogeneity difference between edge and core by using texture analysis: differentiation of malignant from inflammatory pulmonary nodules and masses. Acad Radiol. 2016 Sep;23(9):1115–22. doi: 10.1016/j.acra.2016.04.009. PMID: 27298058. Exclusion Code: X3.27298058
1607 Suresh S, Salama GR, Ramjit A, . CT-Guided Fine-Needle Aspiration Biopsy of Pulmonary Nodules 8 mm or Less Has a Higher Diagnostic Accuracy than Positron Emission Tomography-CT. J Vasc Interv Radiol. 2018 Apr;29(4):520–3. doi: 10.1016/j.jvir.2017.10.004. PMID: 29287961. Exclusion Code: X3.29287961
1608 Suzuki H, Morimoto J, Mizobuchi T, . Does segmentectomy really preserve the pulmonary function better than lobectomy for patients with early-stage lung cancer? Surg Today. 2017 Apr;47(4):463–9. doi: 10.1007/s00595-016-1387-4. PMID: 27484067. Exclusion Code: X8.27484067
1609 Suzuki O, Mitsuyoshi T, Miyazaki M, . Dose-volume-response analysis in stereotactic radiotherapy for early lung cancer. Radiother Oncol. 2014 Aug;112(2):262–6. doi: 10.1016/j.radonc.2014.07.004. PMID: 25107554. Exclusion Code: X3.25107554
1610 Suzuki Y, Okamoto T, Fujishita T, . Clinical implications of sarcopenia in patients undergoing complete resection for early non-small cell lung cancer. Lung Cancer. 2016 Nov;101:92–7. doi: 10.1016/j.lungcan.2016.08.007. PMID: 27794415. Exclusion Code: X11.27794415
1611 Swaminath A, Wierzbicki M, Parpia S, . Canadian phase III randomized trial of stereotactic body radiotherapy versus conventionally hypofractionated radiotherapy for stage I, medically inoperable non-small-cell lung cancer - rationale and protocol design for the Ontario Clinical Oncology Group (OCOG)-LUSTRE Trial. Clin Lung Cancer. 2017 Mar;18(2):250–4. doi: 10.1016/j.cllc.2016.08.002. PMID: 27876603. Exclusion Code: X10.27876603
1612 Swanick CW, Allen PK, Tao R, . Incidence and predictors of chest wall toxicity after high-dose radiation therapy in 15 fractions. Pract Radiat Oncol. 2017 Jan - Feb;7(1):63–71. doi: 10.1016/j.prro.2016.05.009. PMID: 27637136. Exclusion Code: X3.27637136
1613 Tachibana K, Nakazato Y, Tsuchida S, . Immediate cytology improves accuracy and decreases complication rate in real-time computed tomography-guided needle lung biopsy. Diagn Cytopathol. 2013 Dec;41(12):1063–8. doi: 10.1002/dc.22940. PMID: 23239643. Exclusion Code: X3.23239643
1614 Tachihara M, Tamura D, Kiriu T, . Bronchoscopy Using Virtual Navigation and Endobronchial Ultrasonography with a Guide Sheath (EBUS-GS) with or without Fluoroscopy for Peripheral Pulmonary Lesions. Kobe J Med Sci. 2018 Mar 27;63(4):E99–e104. PMID: 29955020. Exclusion Code: X3.29955020
1615 Tada A, Hiraki T, Iguchi T, . Influence of radiofrequency ablation of lung cancer on pulmonary function. Cardiovasc Intervent Radiol. 2012 Aug;35(4):860–7. doi: 10.1007/s00270-011-0221-z. PMID: 21725672. Exclusion Code: X6.21725672
1616 Tagawa T, Iwata T, Nakajima T, . Evolution of a lung-sparing strategy with sleeve lobectomy and induction therapy for non-small cell lung cancer: 20-year experience at a single institution. World J Surg. 2016 Apr;40(4):906–12. doi: 10.1007/s00268-015-3330-z. PMID: 26711642. Exclusion Code: X3.26711642
1617 Tajima Y, Nakayama H, Itonaga T, . Dosimetric evaluation of compensator intensity modulation-based stereotactic body radiotherapy for Stage I non-small-cell lung cancer. Br J Radiol. 2015 Aug;88(1052):20150122. doi: 10.1259/bjr.20150122. PMID: 25996577. Exclusion Code: X8.25996577
1618 Takahashi EA, Koo CW, White DB, . Prospective Pilot Evaluation of Radiologists and Computer-aided Pulmonary Nodule Detection on Ultra-low-Dose CT With Tin Filtration. J Thorac Imaging. 2018 Nov;33(6):396–401. doi: 10.1097/rti.0000000000000348. PMID: 30048344. Exclusion Code: X3.30048344
1619 Takahashi N, Sawabata N, Kawamura M, . Multicenter prospective study of sublobar resection for c-stage I non-small cell lung cancer patients unable to undergo lobectomy (KLSG-0801): complete republication. Gen Thorac Cardiovasc Surg. 2016 Aug;64(8):470–5. doi: 10.1007/s11748-016-0662-z. PMID: 27234224. Exclusion Code: X11.27234224
1620 Takahashi Y, Horio H, Hato T, . Prognostic significance of preoperative neutrophil-lymphocyte ratios in patients with stage I non-small cell lung cancer after complete resection. Ann Surg Oncol. 2015 Dec;22: Suppl 3:S1324–31. doi: 10.1245/s10434-015-4735-5. PMID: 26198075. Exclusion Code: X3.26198075
1621 Takashima S, Sone S, Li F, . Small solitary pulmonary nodules (< or =1 cm) detected at population-based CT screening for lung cancer: Reliable high-resolution CT features of benign lesions. AJR Am J Roentgenol. 2003 Apr;180(4):955–64. PMID: 12646435. Exclusion Code: X8.12646435
1622 Takeda A, Enomoto T, Sanuki N, . Reassessment of declines in pulmonary function >/=1 year after stereotactic body radiotherapy. Chest. 2013 Jan;143(1):130–7. doi: 10.1378/chest.12-0207. PMID: 22722234. Exclusion Code: X3.22722234
1623 Takeda A, Kunieda E, Fujii H, . Evaluation for local failure by 18F-FDG PET/CT in comparison with CT findings after stereotactic body radiotherapy (SBRT) for localized non-small-cell lung cancer. Lung Cancer. 2013 Mar;79(3):248–53. doi: 10.1016/j.lungcan.2012.11.008. PMID: 23246123. Exclusion Code: X8.23246123
1624 Takeda A, Kunieda E, Ohashi T, . Severe COPD is correlated with mild radiation pneumonitis following stereotactic body radiotherapy. Chest. 2012 Apr;141(4):858–66. doi: 10.1378/chest.11-1193. PMID: 21885726. Exclusion Code: X3.21885726
1625 Takeda A, Sanuki N, Fujii H, . Maximum standardized uptake value on FDG-PET is a strong predictor of overall and disease-free survival for non-small-cell lung cancer patients after stereotactic body radiotherapy. J Thorac Oncol. 2014 Jan;9(1):65–73. doi: 10.1097/jto.0000000000000031. PMID: 24346094. Exclusion Code: X10.24346094
1626 Takeda Y, Miura K, Sato T, . Clinically simplified screening methods to evaluate maximum standard uptake value from F-18-FDG-PET/CT in patients with non-small-cell lung cancer. Medicine (Baltimore). 2018 Jun;97(26):e11226. doi: 10.1097/md.0000000000011226. PMID: 29952981. Exclusion Code: X3.29952981
1627 Takenaka R, Shibamoto Y, Miyakawa A, . The fate of residual tumor masses that persist after stereotactic body radiotherapy for solitary lung nodules: will they recur? Clin Lung Cancer. 2016 Sep;17(5):406–11. doi: 10.1016/j.cllc.2015.12.003. PMID: 26781347. Exclusion Code: X8.26781347
1628 Takenaka T, Inamasu E, Yoshida T, . Influence of the distance between home and the hospital on patients with surgically resected non-small-cell lung cancer. Eur J Cardiothorac Surg. 2016 Mar;49(3):842–6. doi: 10.1093/ejcts/ezv253. PMID: 26201956. Exclusion Code: X11.26201956
1629 Takenaka T, Takenoyama M, Toyozawa R, . Concurrent chemoradiotherapy for patients with postoperative recurrence of surgically resected non-small-cell lung cancer. Clin Lung Cancer. 2015 Jan;16(1):51–6. doi: 10.1016/j.cllc.2014.06.001. PMID: 25038000. Exclusion Code: X3.25038000
1630 Takeuchi K, Togashi Y, Kamihara Y, . Prospective and clinical validation of ALK immunohistochemistry: results from the phase I/II study of alectinib for ALK-positive lung cancer (AF-001JP study). Ann Oncol. 2016 Jan;27(1):185–92. doi: 10.1093/annonc/mdv501. PMID: 26487585. Exclusion Code: X5.26487585
1631 Takx RA, Vliegenthart R, Mohamed Hoesein FA, . Pulmonary function and CT biomarkers as risk factors for cardiovascular events in male lung cancer screening participants: the NELSON study. Eur Radiol. 2015 Jan;25(1):65–71. doi: 10.1007/s00330-014-3384-6. PMID: 25182625. Exclusion Code: X5.25182625
1632 Talapatra K, Majumder D, Chadha P, . Stereotactic body radiotherapy for lung tumors: Dosimetric analysis and clinical outcome. Indian J Cancer. 2018 Apr-Jun;55(2):170–5. doi: 10.4103/ijc.IJC_555_17. PMID: 30604731. Exclusion Code: X3.30604731
1633 Talwar A, Rahman NM, Kadir T, . A retrospective validation study of three models to estimate the probability of malignancy in patients with small pulmonary nodules from a tertiary oncology follow-up centre. Clin Radiol. 2017 Feb;72(2):177.e1–.e8. doi: 10.1016/j.crad.2016.09.014. PMID: 27908443. Exclusion Code: X3.27908443
1634 Talwar A, Willaime JMY, Pickup LC, . Pulmonary nodules: Assessing the imaging biomarkers of malignancy in a “coffee-break”. Eur J Radiol. 2018 Apr;101:82–6. doi: 10.1016/j.ejrad.2018.02.004. PMID: 29571806. Exclusion Code: X3.29571806
1635 Tamburini N, Maniscalco P, Mazzara S, . Multidisciplinary management improves survival at 1 year after surgical treatment for non-small-cell lung cancer: a propensity score-matched study. Eur J Cardiothorac Surg. 2018 Jun 1;53(6):1199–204. doi: 10.1093/ejcts/ezx464. PMID: 29293943. Exclusion Code: X3.29293943
1636 Tammemagi CM, Pinsky PF, Caporaso NE, . Lung cancer risk prediction: Prostate, Lung, Colorectal And Ovarian Cancer Screening Trial models and validation. J Natl Cancer Inst. 2011 Jul 6;103(13):1058–68. doi: 10.1093/jnci/djr173. PMID: 21606442. Exclusion Code: X7.21606442
1637 Tammemagi MC, Berg CD, Riley TL, . Impact of lung cancer screening results on smoking cessation. J Natl Cancer Inst. 2014 Jun;106(6):dju084. doi: 10.1093/jnci/dju084. PMID: 24872540. Exclusion Code: X5.24872540
1638 Tammemagi MC, Lam SC, McWilliams AM, . Incremental value of pulmonary function and sputum DNA image cytometry in lung cancer risk prediction. Cancer Prev Res (Phila). 2011 Apr;4(4):552–61. doi: 10.1158/1940-6207.CAPR-10-0183. PMID: 21411501. Exclusion Code: X7.21411501
1639 Tammemagi MC, ten Haaf K, Toumazis I, . Development and validation of a multivariable lung cancer risk prediction model that includes low-dose computed tomography screening results: a secondary analysis of data from the National Lung Screening Trial. JAMA Netw Open. 2019 Mar 1;2(3):e190204. doi: 10.1001/jamanetworkopen.2019.0204. PMID: 30821827. Exclusion Code: X7.30821827
1640 Tamura A, Suzuki J, Fukami T, . Chronic pulmonary aspergillosis as a sequel to lobectomy for lung cancer. Interact Cardiovasc Thorac Surg. 2015 Nov;21(5):650–6. doi: 10.1093/icvts/ivv239. PMID: 26323287. Exclusion Code: X3.26323287
1641 Tamura M, Matsumoto I, Saito D, . Mean computed tomography value to predict the tumor invasiveness in clinical stage IA lung cancer. Ann Thorac Surg. 2017 Jul;104(1):261–6. doi: 10.1016/j.athoracsur.2017.01.060. PMID: 28410633. Exclusion Code: X8.28410633
1642 Tane S, Nishio W, Okuma H, . Operative outcomes of thoracoscopic lobectomy for non-small-cell lung cancer. Asian Cardiovasc Thorac Ann. 2015 Oct;23(8):950–7. doi: 10.1177/0218492315596657. PMID: 26207005. Exclusion Code: X11.26207005
1643 Tang C, Welsh JW, de Groot P, . Ipilimumab with stereotactic ablative radiation therapy: Phase I results and immunologic correlates from peripheral T cells. Clin Cancer Res. 2017 Mar 15;23(6):1388–96. doi: 10.1158/1078-0432.ccr-16-1432. PMID: 27649551. Exclusion Code: X3.27649551
1644 Taniguchi D, Yamasaki N, Miyazaki T, . The surgical outcomes of lung cancer combined with interstitial pneumonia: a single-institution report. Surg Today. 2017 Nov;47(11):1397–404. doi: 10.1007/s00595-017-1551-5. PMID: 28589262. Exclusion Code: X3.28589262
1645 Tanner NT, Aggarwal J, Gould MK, . Management of pulmonary nodules by community pulmonologists: a multicenter observational study. Chest. 2015 Dec;148(6):1405–14. doi: 10.1378/chest.15-0630. PMID: 26087071. Exclusion Code: X3.26087071
1646 Tanner NT, Egede LE, Shamblin C, . Attitudes and beliefs toward lung cancer screening among US Veterans. Chest. 2013 Dec;144(6):1783–7. doi: 10.1378/chest.13-0056. PMID: 23764896. Exclusion Code: X8.23764896
1647 Tao G, Jingying Y, Tan G, . A novel CT-guided technique using medical adhesive for localization of small pulmonary ground-glass nodules and mixed ground-glass nodules (</=20 mm) before video-assisted thoracoscopic surgery. Diagn Interv Radiol. 2018 Jul;24(4):209–12. doi: 10.5152/dir.2018.17315. PMID: 30091711. Exclusion Code: X3.30091711
1648 Tao H, Hayashi T, Sano F, . Prognostic impact of lymphovascular invasion compared with that of visceral pleural invasion in patients with pN0 non-small-cell lung cancer and a tumor diameter of 2 cm or smaller. J Surg Res. 2013 Nov;185(1):250–4. doi: 10.1016/j.jss.2013.05.104. PMID: 23830361. Exclusion Code: X11.23830361
1649 Tao H, Onoda H, Okabe K, . The impact of coexisting lung diseases on outcomes in patients with pathological Stage I non-small-cell lung cancer. Interact Cardiovasc Thorac Surg. 2018 Jun 1;26(6):1009–15. doi: 10.1093/icvts/ivx441. PMID: 29394349. Exclusion Code: X10.29394349
1650 Tartar A, Kilic N, Akan A. Classification of pulmonary nodules by using hybrid features. Comput Math Methods Med. 2013;2013:148363. doi: 10.1155/2013/148363. PMID: 23970942. Exclusion Code: X3.23970942
1651 Taton O, Bondue B, Gevenois PA, . Diagnostic Yield of Combined Pulmonary Cryobiopsies and Electromagnetic Navigation in Small Pulmonary Nodules. Pulm Med. 2018;2018:6032974. doi: 10.1155/2018/6032974. PMID: 30581621. Exclusion Code: X3.30581621
1652 Taus A, Aguilo R, Curull V, . Impact of 18F-FDG PET/CT in the treatment of patients with non-small cell lung cancer. Arch Bronconeumol. 2014 Mar;50(3):99–104. doi: 10.1016/j.arbres.2013.09.017. PMID: 24360985. Exclusion Code: X3.24360985
1653 Taverner J, Cheang MY, Antippa P, . Negative EBUS-TBNA predicts very low prevalence of mediastinal disease in staging of non-small cell lung cancer. J Bronchology Interv Pulmonol. 2016 Apr;23(2):177–80. doi: 10.1097/lbr.0000000000000234. PMID: 26905440. Exclusion Code: X8.26905440
1654 Tay JH, Irving L, Antippa P, . Radial probe endobronchial ultrasound: factors influencing visualization yield of peripheral pulmonary lesions. Respirology. 2013 Jan;18(1):185–90. doi: 10.1111/j.1440-1843.2012.02276.x. PMID: 23035636. Exclusion Code: X3.23035636
1655 Taylor MD, LaPar DJ, Isbell JM, . Marginal pulmonary function should not preclude lobectomy in selected patients with non-small cell lung cancer. J Thorac Cardiovasc Surg. 2014 Feb;147(2):738–44; Discussion 44-6. doi: 10.1016/j.jtcvs.2013.09.064. PMID: 24252944. Exclusion Code: X3.24252944
1656 Tchouta LN, Park HS, Boffa DJ, . Hospital volume and outcomes of robot-assisted lobectomies. Chest. 2017 Feb;151(2):329–39. doi: 10.1016/j.chest.2016.09.008. PMID: 27687847. Exclusion Code: X3.27687847
1657 Tekatli H, Duijm M, Oomen-de Hoop E, . Normal Tissue Complication Probability Modeling of Pulmonary Toxicity After Stereotactic and Hypofractionated Radiation Therapy for Central Lung Tumors. Int J Radiat Oncol Biol Phys. 2018 Mar 1;100(3):738–47. doi: 10.1016/j.ijrobp.2017.11.022. PMID: 29413285. Exclusion Code: X3.29413285
1658 Tekatli H, van ’t Hof S, Nossent EJ, . Use of stereotactic ablative radiotherapy (SABR) in non-small cell lung cancer measuring more than 5 cm. J Thorac Oncol. 2017 Jun;12(6):974–82. doi: 10.1016/j.jtho.2017.02.021. PMID: 28286243. Exclusion Code: X3.28286243
1659 Tembhekar AR, Wright CL, Daly ME. Cardiac dose and survival after stereotactic body radiotherapy for early-stage non-small-cell lung cancer. Clin Lung Cancer. 2017 May;18(3):293–8. doi: 10.1016/j.cllc.2016.12.007. PMID: 28089158. Exclusion Code: X10.28089158
1660 Temming S, Kocher M, Stoelben E, . Risk-adapted robotic stereotactic body radiation therapy for inoperable early-stage non-small-cell lung cancer. Strahlenther Onkol. 2018 Feb;194(2):91–7. doi: 10.1007/s00066-017-1194-x. PMID: 28812120. Exclusion Code: X3.28812120
1661 ten Haaf K, de Koning HJ. Should never-smokers at increased risk for lung cancer be screened? J Thorac Oncol. 2015 Sep;10(9):1285–91. doi: 10.1097/jto.0000000000000593. PMID: 26287320. Exclusion Code: X4.26287320
1662 ten Haaf K, van Rosmalen J, de Koning HJ. Lung cancer detectability by test, histology, stage, and gender: estimates from the NLST and the PLCO trials. Cancer Epidemiol Biomarkers Prev. 2015 Jan;24(1):154–61. doi: 10.1158/1055-9965.epi-14-0745. PMID: 25312998. Exclusion Code: X8.25312998
1663 Teramoto A, Fujita H, Yamamuro O, . Automated detection of pulmonary nodules in PET/CT images: Ensemble false-positive reduction using a convolutional neural network technique. Med Phys. 2016 Jun;43(6):2821–7. doi: 10.1118/1.4948498. PMID: 27277030. Exclusion Code: X5.27277030
1664 Terzi A, Bertolaccini L, Viti A, . Lung cancer detection with digital chest tomosynthesis: baseline results from the observational study SOS. J Thorac Oncol. 2013 Jun;8(6):685–92. doi: 10.1097/JTO.0b013e318292bdef. PMID: 23612466. Exclusion Code: X5.23612466
1665 Thibault I, Poon I, Yeung L, . Predictive factors for local control in primary and metastatic lung tumours after four to five fraction stereotactic ablative body radiotherapy: a single institution’s comprehensive experience. Clin Oncol (R Coll Radiol). 2014 Nov;26(11):713–9. doi: 10.1016/j.clon.2014.06.018. PMID: 25085765. Exclusion Code: X3.25085765
1666 Thomas DC, Arnold BN, Hoag JR, . Timing and Risk Factors Associated With Venous Thromboembolism After Lung Cancer Resection. Ann Thorac Surg. 2018 May;105(5):1469–75. doi: 10.1016/j.athoracsur.2018.01.072. PMID: 29501644. Exclusion Code: X3.29501644
1667 Thomas PA, Berbis J, Baste JM, . Pneumonectomy for lung cancer: contemporary national early morbidity and mortality outcomes. J Thorac Cardiovasc Surg. 2015 Jan;149(1):73–82. doi: 10.1016/j.jtcvs.2014.09.063. PMID: 25439468. Exclusion Code: X3.25439468
1668 Thomas PA, Falcoz PE, Bernard A, . Bilobectomy for lung cancer: contemporary national early morbidity and mortality outcomes. Eur J Cardiothorac Surg. 2016 Feb;49(2):e38–43; discussion e. doi: 10.1093/ejcts/ezv407. PMID: 27070154. Exclusion Code: X3.27070154
1669 Thornton AA, Owen JE, Kernstine K, . Predictors of finding benefit after lung cancer diagnosis. Psychooncology. 2012 Apr;21(4):365–73. doi: 10.1002/pon.1904. PMID: 21254308. Exclusion Code: X3.21254308
1670 Thorsteinsson H, Alexandersson A, Oskarsdottir GN, . Resection rate and outcome of pulmonary resections for non-small-cell lung cancer: a nationwide study from Iceland. J Thorac Oncol. 2012 Jul;7(7):1164–9. doi: 10.1097/JTO.0b013e318252d022. PMID: 22592213. Exclusion Code: X11.22592213
1671 Timmerman R, McGarry R, Yiannoutsos C, . Excessive toxicity when treating central tumors in a phase II study of stereotactic body radiation therapy for medically inoperable early-stage lung cancer. J Clin Oncol. 2006 Oct 20;24(30):4833–9. doi: 10.1200/jco.2006.07.5937. PMID: 17050868. Exclusion Code: X11.17050868
1672 Timmerman R, Papiez L, McGarry R, . Extracranial stereotactic radioablation: results of a phase I study in medically inoperable stage I non-small cell lung cancer. Chest. 2003 Nov;124(5):1946–55. PMID: 14605072. Exclusion Code: X11.14605072
1673 Timmerman RD, Kavanagh BD. Stereotactic body radiation therapy. Curr Probl Cancer. 2005 May-Jun;29(3):120–57. doi: 10.1016/j.currproblcancer.2005.05.001. PMID: 16059851. Exclusion Code: X10.16059851
1674 Tirzite M, Bukovskis M, Strazda G, . Detection of lung cancer in exhaled breath with an electronic nose using support vector machine analysis. J Breath Res. 2017 Aug 21;11(3):036009. doi: 10.1088/1752-7163/aa7799. PMID: 28585921. Exclusion Code: X5.28585921
1675 Tjulandin S, Imyanitov E, Moiseyenko V, . Prospective cohort study of clinical characteristics and management patterns for patients with non-small-cell lung cancer in the Russian Federation: EPICLIN-Lung. Curr Med Res Opin. 2015 Jun;31(6):1117–27. doi: 10.1185/03007995.2015.1036015. PMID: 25867537. Exclusion Code: X3.25867537
1676 Toba H, Kondo K, Miyoshi T, . Fluoroscopy-assisted thoracoscopic resection after computed tomography-guided bronchoscopic metallic coil marking for small peripheral pulmonary lesions. Eur J Cardiothorac Surg. 2013 Aug;44(2):e126–32. doi: 10.1093/ejcts/ezt220. PMID: 23598353. Exclusion Code: X3.23598353
1677 Tockman M. Survival and mortality from lung cancer in a screened population: The Johns Hopkins study. Chest. 1986;89(Suppl):325s–6s. Exclusion Code: X2.
1678 Tokoro Y, Yasuo M, Kobayashi T, . Computed tomography-guided bronchoscopy in the diagnosis of small peripheral pulmonary lesions: A retrospective study of 240 examinations in a single academic center. Respir Investig. 2016 Sep;54(5):347–54. doi: 10.1016/j.resinv.2016.04.004. PMID: 27566383. Exclusion Code: X3.27566383
1679 Tomita M, Ayabe T, Chosa E, . Impact of smoking on outcome of resected lung adenocarcinoma. Gen Thorac Cardiovasc Surg. 2015 Nov;63(11):608–12. doi: 10.1007/s11748-015-0579-y. PMID: 26243355. Exclusion Code: X3.26243355
1680 Tomita M, Ayabe T, Nakamura K. The advanced lung cancer inflammation index is an independent prognostic factor after surgical resection in patients with non-small-cell lung cancer. Interact Cardiovasc Thorac Surg. 2018 Feb 1;26(2):288–92. doi: 10.1093/icvts/ivx329. PMID: 29049691. Exclusion Code: X3.29049691
1681 Tomizawa K, Shimizu S, Ohara S, . Clinical significance of tumor cavitation in surgically resected early-stage primary lung cancer. Lung Cancer. 2017 Oct;112:57–61. doi: 10.1016/j.lungcan.2017.08.004. PMID: 29191601. Exclusion Code: X3.29191601
1682 Tong AN, Yan P, Yuan GH, . Advantages of CyberKnife for inoperable stage I peripheral non-small-cell lung cancer compared to three-dimensional conformal radiotherapy. Mol Clin Oncol. 2015 Mar;3(2):442–8. doi: 10.3892/mco.2014.475. PMID: 25798283. Exclusion Code: X14.25798283
1683 Tong BC, Kosinski AS, Burfeind WR, Jr., . Sex differences in early outcomes after lung cancer resection: analysis of the Society of Thoracic Surgeons General Thoracic Database. J Thorac Cardiovasc Surg. 2014 Jul;148(1):13–8. doi: 10.1016/j.jtcvs.2014.03.012. PMID: 24726742. Exclusion Code: X3.24726742
1684 Tong LC, Rudomina D, Rekhtman N, . Impact of touch preparations on core needle biopsies. Cancer Cytopathol. 2014 Nov;122(11):851–4. doi: 10.1002/cncy.21447. PMID: 24946755. Exclusion Code: X3.24946755
1685 Toosi K, Velez-Cubian FO, Glover J, . Upstaging and survival after robotic-assisted thoracoscopic lobectomy for non-small cell lung cancer. Surgery. 2016 Nov;160(5):1211–8. doi: 10.1016/j.surg.2016.08.003. PMID: 27665362. Exclusion Code: X3.27665362
1686 Torchio R, Mazzucco A, Guglielmo M, . Minute ventilation to carbon dioxide output (V’E/V’CO2 slope) is the strongest death predictor before larger lung resections. Monaldi Arch Chest Dis. 2017 Sep 22;87(3):817. doi: 10.4081/monaldi.2017.817. PMID: 29424191. Exclusion Code: X3.29424191
1687 Torres EL, Fiorina E, Pennazio F, . Large scale validation of the M5L lung CAD on heterogeneous CT datasets. Med Phys. 2015 Apr;42(4):1477–89. doi: 10.1118/1.4907970. PMID: 25832038. Exclusion Code: X3.25832038
1688 Toyokawa G, Yamada Y, Tagawa T, . Significance of spread through air spaces in early-stage lung adenocarcinomas undergoing limited resection. Thorac Cancer. 2018 Oct;9(10):1255–61. doi: 10.1111/1759-7714.12828. PMID: 30079987. Exclusion Code: X11.30079987
1689 Toyooka S, Okumura N, Nakamura H, . A Multicenter Randomized Controlled Study of Paclitaxel plus Carboplatin versus Oral Uracil-Tegafur as the Adjuvant Chemotherapy in Resected Non-Small Cell Lung Cancer. J Thorac Oncol. 2018;13(5):699–706. doi: 10.1016/j.jtho.2018.02.015. PMID: CN-01913780. Exclusion Code: X3.29505900
1690 Tramontano AC, Cipriano LE, Kong CY, . Microsimulation model predicts survival benefit of radiofrequency ablation and stereotactic body radiotherapy versus radiotherapy for treating inoperable stage I non-small cell lung cancer. AJR Am J Roentgenol. 2013 May;200(5):1020–7. doi: 10.2214/ajr.12.8968. PMID: 23617484. Exclusion Code: X3.23617484
1691 Tramontano AC, Sheehan DF, McMahon PM, . Evaluating the impacts of screening and smoking cessation programmes on lung cancer in a high-burden region of the USA: a simulation modelling study. BMJ Open. 2016 Feb 29;6(2):e010227. doi: 10.1136/bmjopen-2015-010227. PMID: 26928026. Exclusion Code: X7.26928026
1692 Tran AA, Brown SB, Rosenberg J, . Tract embolization with gelatin sponge slurry for prevention of pneumothorax after percutaneous computed tomography-guided lung biopsy. Cardiovasc Intervent Radiol. 2014 Dec;37(6):1546–53. doi: 10.1007/s00270-013-0823-8. PMID: 24366313. Exclusion Code: X3.24366313
1693 Tremblay A, Taghizadeh N, McWilliams AM, . Low prevalence of high-grade lesions detected with autofluorescence bronchoscopy in the setting of lung cancer screening in the Pan-Canadian Lung Cancer Screening Study. Chest. 2016 Nov;150(5):1015–22. doi: 10.1016/j.chest.2016.04.019. PMID: 27142184. Exclusion Code: X5.27142184
1694 Tresoldi S, Flor N, Luciani A, . Contrast enhanced chest-MDCT in oncologic patients. Prospective evaluation of the prevalence of incidental pulmonary embolism and added value of thin reconstructions. Eur Radiol. 2015 Nov;25(11):3200–6. doi: 10.1007/s00330-015-3739-7. PMID: 25899418. Exclusion Code: X3.25899418
1695 Trivino A, Congregado M, Loscertales J, . Experience and development of the video-assisted thoracic surgery lobectomy technique: comparative study with conventional surgery in stage I non-small cell lung cancer. Arch Bronconeumol. 2014 Feb;50(2):57–61. doi: 10.1016/j.arbres.2013.05.007. PMID: 23890810. Exclusion Code: X11.23890810
1696 Trudgen K, Khattar NH, Bensadoun E, . Autoantibody profiling for lung cancer screening longitudinal retrospective analysis of CT screening cohorts. PLoS One. 2014;9(2):e87947. doi: 10.1371/journal.pone.0087947. PMID: 24498409. Exclusion Code: X5.24498409
1697 Tseng TS, Park JY, Zabaleta J, . Role of nicotine dependence on the relationship between variants in the nicotinic receptor genes and risk of lung adenocarcinoma. PLoS One. 2014;9(9):e107268. doi: 10.1371/journal.pone.0107268. PMID: 25233467. Exclusion Code: X10.25233467
1698 Tsubamoto M, Nishida T, Higaki N, . Separation between the chest wall and subpleural lung lesions: A two-step method to preoperatively exclude invasion or focal pleural adhesion by multidetector computed tomography. Eur J Radiol. 2019 Mar;112:180–5. doi: 10.1016/j.ejrad.2019.01.027. PMID: 30777208. Exclusion Code: X3.30777208
1699 Tsukioka T, Izumi N, Mizuguchi S, . Impact of multiple malignancies on surgical outcomes in patients with 1 cm or smaller non-small cell lung cancer. Int J Clin Oncol. 2018 Feb;23(1):66–72. doi: 10.1007/s10147-017-1185-z. PMID: 28864833. Exclusion Code: X3.28864833
1700 Tsunezuka H, Kato D, Okada S, . Surgical outcome of wide wedge resection in poor-risk patients with clinical-N0 non-small cell lung cancer. Gen Thorac Cardiovasc Surg. 2017 Oct;65(10):581–6. doi: 10.1007/s11748-017-0803-z. PMID: 28748318. Exclusion Code: X11.28748318
1701 Tsutani Y, Miyata Y, Kushitani K, . Propensity score-matched analysis of adjuvant chemotherapy for stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2014 Oct;148(4):1179–85. doi: 10.1016/j.jtcvs.2014.05.084. PMID: 25112928. Exclusion Code: X10.25112928
1702 Tsutani Y, Miyata Y, Nakayama H, . Oncologic outcomes of segmentectomy compared with lobectomy for clinical stage IA lung adenocarcinoma: propensity score-matched analysis in a multicenter study. J Thorac Cardiovasc Surg. 2013 Aug;146(2):358–64. doi: 10.1016/j.jtcvs.2013.02.008. PMID: 23477694. Exclusion Code: X11.23477694
1703 Tsutani Y, Miyata Y, Nakayama H, . Appropriate sublobar resection choice for ground glass opacity-dominant clinical stage IA lung adenocarcinoma: wedge resection or segmentectomy. Chest. 2014 Jan;145(1):66–71. doi: 10.1378/chest.13-1094. PMID: 24551879. Exclusion Code: X8.24551879
1704 Tu Q, Yang Z, Gan J, . Transcutaneous Electrical Acupoint Stimulation Improves Immunological Function During the Perioperative Period in Patients With Non-Small Cell Lung Cancer Undergoing Video-Assisted Thoracic Surgical Lobectomy. Technol Cancer Res Treat. 2018 Jan 1;17:1533033818806477. doi: 10.1177/1533033818806477. PMID: 30381011. Exclusion Code: X6.30381011
1705 Tucker SL, Liao Z, Dinh J, . Is there an impact of heart exposure on the incidence of radiation pneumonitis? Analysis of data from a large clinical cohort. Acta Oncol. 2014 May;53(5):590–6. doi: 10.3109/0284186x.2013.831185. PMID: 23992110. Exclusion Code: X3.23992110
1706 Tvilum M, Khalil AA, Moller DS, . Clinical outcome of image-guided adaptive radiotherapy in the treatment of lung cancer patients. Acta Oncol. 2015;54(9):1430–7. doi: 10.3109/0284186x.2015.1062544. PMID: 26206515. Exclusion Code: X3.26206515
1707 Uchida Y, Tsugawa T, Tanaka-Mizuno S, . Exclusion of emphysematous lung from dose-volume estimates of risk improves prediction of radiation pneumonitis. Radiat Oncol. 2017 Oct 2;12(1):160. doi: 10.1186/s13014-017-0891-z. PMID: 28969651. Exclusion Code: X3.28969651
1708 Ueda K, Hayashi M, Tanaka N, . Surgery for undiagnosed ground glass pulmonary nodules: decision making using serial computed tomography. World J Surg. 2015 Jun;39(6):1452–9. doi: 10.1007/s00268-015-2979-7. PMID: 25651958. Exclusion Code: X3.25651958
1709 Ueda K, Murakami J, Sano F, . Similar radiopathological features, but different postoperative recurrence rates, between Stage I lung cancers arising in emphysematous lungs and those arising in nonemphysematous lungs. Eur J Cardiothorac Surg. 2015 May;47(5):905–11. doi: 10.1093/ejcts/ezu311. PMID: 25123673. Exclusion Code: X11.25123673
1710 Ueda K, Sano F, Murakami J, . Does pulmonary resection promote the progression of unresected ground-glass nodules? Anticancer Res. 2014 Dec;34(12):7401–6. PMID: 25503180. Exclusion Code: X3.25503180
1711 Uehara H, Matsuura Y, Nakao M, . Prognostic significance of clinical/pathological stage IA non-small-cell lung cancer showing partially solid or solid tumours on radiological exam. Ann Thorac Cardiovasc Surg. 2015;21(4):338–44. doi: 10.5761/atcs.oa.14-00242. PMID: 25740451. Exclusion Code: X11.25740451
1712 Uehara H, Tsutani Y, Okumura S, . Prognostic role of positron emission tomography and high-resolution computed tomography in clinical stage IA lung adenocarcinoma. Ann Thorac Surg. 2013 Dec;96(6):1958–65. doi: 10.1016/j.athoracsur.2013.06.086. PMID: 24021765. Exclusion Code: X8.24021765
1713 Ueki N, Matsuo Y, Togashi Y, . Impact of pretreatment interstitial lung disease on radiation pneumonitis and survival after stereotactic body radiation therapy for lung cancer. J Thorac Oncol. 2015 Jan;10(1):116–25. doi: 10.1097/jto.0000000000000359. PMID: 25376512. Exclusion Code: X10.25376512
1714 Uribe-Etxebarria Lugariza-Aresti N, Barcelo Galindez R, Pac Ferrer J, . Biopsy of the sentinel node in lung cancer. Med Clin (Barc). 2017 Mar 22;148(6):257–9. doi: 10.1016/j.medcli.2016.10.034. PMID: 27993403. Exclusion Code: X3.27993403
1715 Usuda K, Funasaki A, Sekimura A, . FDG-PET/CT and diffusion-weighted imaging for resected lung cancer: correlation of maximum standardized uptake value and apparent diffusion coefficient value with prognostic factors. Med Oncol. 2018 Apr 9;35(5):66. doi: 10.1007/s12032-018-1128-1. PMID: 29633024. Exclusion Code: X3.29633024
1716 Uzun C, Akkaya Z, Dusunceli Atman E, . Diagnostic accuracy and safety of CT-guided fine needle aspiration biopsy of pulmonary lesions with non-coaxial technique: a single center experience with 442 biopsies. Diagn Interv Radiol. 2017 Mar-Apr;23(2):137–43. doi: 10.5152/dir.2016.16173. PMID: 28029638. Exclusion Code: X3.28029638
1717 Vagn-Hansen C, Pedersen MR, Rafaelsen SR. Diagnostic yield and complications of transthoracic computed tomography-guided biopsies. Dan Med J. 2016 Jun;63(6)PMID: 27264940. Exclusion Code: X3.27264940
1718 Valan CD, Slagsvold JE, Halvorsen TO, . Survival in limited disease small cell lung cancer according to N3 lymph node involvement. Anticancer Res. 2018 Feb;38(2):871–6. doi: 10.21873/anticanres.12296. PMID: 29374714. Exclusion Code: X3.29374714
1719 Valdes G, Robinson C, Lee P, . Tumor control probability and the utility of 4D vs 3D dose calculations for stereotactic body radiotherapy for lung cancer. Med Dosim. 2015 Spring;40(1):64–9. doi: 10.1016/j.meddos.2014.10.002. PMID: 25542785. Exclusion Code: X11.25542785
1720 Valdes G, Solberg TD, Heskel M, . Using machine learning to predict radiation pneumonitis in patients with stage I non-small cell lung cancer treated with stereotactic body radiation therapy. Phys Med Biol. 2016 Aug 21;61(16):6105–20. doi: 10.1088/0031-9155/61/16/6105. PMID: 27461154. Exclusion Code: X10.27461154
1721 van Boerdonk RA, Daniels JM, Snijders PJ, . DNA copy number aberrations in endobronchial lesions: a validated predictor for cancer. Thorax. 2014 May;69(5):451–7. doi: 10.1136/thoraxjnl-2013-203821. PMID: 24227199. Exclusion Code: X7.24227199
1722 van Boerdonk RA, Smesseim I, Heideman DA, . Close surveillance with long-term follow-up of subjects with preinvasive endobronchial lesions. Am J Respir Crit Care Med. 2015 Dec 15;192(12):1483–9. doi: 10.1164/rccm.201504-0822OC. PMID: 26275031. Exclusion Code: X3.26275031
1723 van den Berg LL, Klinkenberg TJ, Groen HJ, . Patterns of recurrence and survival after surgery or stereotactic radiotherapy for early stage NSCLC. J Thorac Oncol. 2015 May;10(5):826–31. doi: 10.1097/jto.0000000000000483. PMID: 25629639. Exclusion Code: X10.25629639
1724 van der Aalst CM, van Klaveren RJ, de Koning HJ. Does participation to screening unintentionally influence lifestyle behaviour and thus lifestyle-related morbidity? Best Pract Res Clin Gastroenterol. 2010 Aug;24(4):465–78. doi: 10.1016/j.bpg.2010.06.001. PMID: 20833350. Exclusion Code: X9.20833350
1725 van der Heijden EH, Hoefsloot W, van Hees HW, . High definition bronchoscopy: a randomized exploratory study of diagnostic value compared to standard white light bronchoscopy and autofluorescence bronchoscopy. Respir Res. 2015 Mar 7;16:33. doi: 10.1186/s12931-015-0193-7. PMID: 25848883. Exclusion Code: X3.25848883
1726 van der Linden N, Bongers ML, Coupe VMH, . Treatment patterns and differences in survival of non-small cell lung cancer patients between academic and non-academic hospitals in the Netherlands. Clin Lung Cancer. 2017 Sep;18(5):e341–e7. doi: 10.1016/j.cllc.2015.11.011. PMID: 28347579. Exclusion Code: X3.28347579
1727 van Iersel CA, de Koning HJ, Draisma G, . Risk-based selection from the general population in a screening trial: selection criteria, recruitment and power for the Dutch-Belgian randomised lung cancer multi-slice CT screening trial (NELSON). Int J Cancer. 2007 Feb 15;120(4):868–74. doi: 10.1002/ijc.22134. PMID: 17131307. Exclusion Code: X8.17131307
1728 van Riel SJ, Ciompi F, Jacobs C, . Malignancy risk estimation of screen-detected nodules at baseline CT: comparison of the PanCan model, Lung-RADS and NCCN guidelines. Eur Radiol. 2017 Oct;27(10):4019–29. doi: 10.1007/s00330-017-4767-2. PMID: 28293773. Exclusion Code: X3.28293773
1729 van Riel SJ, Ciompi F, Winkler Wille MM, . Malignancy risk estimation of pulmonary nodules in screening CTs: comparison between a computer model and human observers. PLoS One. 2017;12(11):e0185032. doi: 10.1371/journal.pone.0185032. PMID: 29121063. Exclusion Code: X5.29121063
1730 VanderWalde NA, Deal AM, Comitz E, . Geriatric assessment as a predictor of tolerance, quality of life, and outcomes in older patients with head and neck cancers and lung cancers receiving radiation therapy. Int J Radiat Oncol Biol Phys. 2017 Jul 15;98(4):850–7. doi: 10.1016/j.ijrobp.2016.11.048. PMID: 28258889. Exclusion Code: X3.28258889
1731 Vansteenkiste JF, Cho BC, Vanakesa T, . Efficacy of the MAGE-A3 cancer immunotherapeutic as adjuvant therapy in patients with resected MAGE-A3-positive non-small-cell lung cancer (MAGRIT): a randomised, double-blind, placebo-controlled, phase 3 trial. Lancet Oncol. 2016 Jun;17(6):822–35. doi: 10.1016/s1470-2045(16)00099-1. PMID: 27132212. Exclusion Code: X6.27132212
1732 Van’t Westeinde SC, Horeweg N, De Leyn P, . Complications following lung surgery in the Dutch-Belgian randomized lung cancer screening trial. Eur J Cardiothorac Surg. 2012 Sep;42(3):420–9. doi: 10.1093/ejcts/ezs081. PMID: 22491665. Exclusion Code: X11.22491665
1733 Varadarajulu S, Schmulewitz N, Wildi SM, . Accuracy of EUS in staging of T4 lung cancer. Gastrointest Endosc. 2004 Mar;59(3):345–8. PMID: 14997129. Exclusion Code: X3.14997129
1734 Vardhanabhuti V, Pang CL, Tenant S, . Prospective intra-individual comparison of standard dose versus reduced-dose thoracic CT using hybrid and pure iterative reconstruction in a follow-up cohort of pulmonary nodules-Effect of detectability of pulmonary nodules with lowering dose based on nodule size, type and body mass index. Eur J Radiol. 2017 Jun;91:130–41. doi: 10.1016/j.ejrad.2017.04.006. PMID: 28629559. Exclusion Code: X5.28629559
1735 Varela G, Gomez-Hernandez MT. Stereotactic ablative radiotherapy for early stage non-small cell lung cancer: a word of caution. Transl Lung Cancer Res. 2016 Feb;5(1):102–5. doi: 10.3978/j.issn.2218-6751.2015.10.10. PMID: 26958502. Exclusion Code: X10.26958502
1736 Varlotto J, Fakiris A, Flickinger J, . Matched-pair and propensity score comparisons of outcomes of patients with clinical stage I non-small cell lung cancer treated with resection or stereotactic radiosurgery. Cancer. 2013 Aug 1;119(15):2683–91. doi: 10.1002/cncr.28100. PMID: 23605504. Exclusion Code: X10.23605504
1737 Vassallo L, Traverso A, Agnello M, . A cloud-based computer-aided detection system improves identification of lung nodules on computed tomography scans of patients with extra-thoracic malignancies. Eur Radiol. 2019 Jan;29(1):144–52. doi: 10.1007/s00330-018-5528-6. PMID: 29948089. Exclusion Code: X3.29948089
1738 Vaz AP, Fernandes G, Souto Moura C, . Integrated PET/CT in non small cell lung cancer staging--clinical and pathological agreement. Rev Port Pneumol. 2012 May-Jun;18(3):109–14. doi: 10.1016/j.rppneu.2012.01.004. PMID: 22405953. Exclusion Code: X11.22405953
1739 Vehmas T. Visually scored calcifications in thoracic arteries predict death: follow-up study after lung cancer CT screening. Acta Radiol. 2012 Jul;53(6):643–7. doi: 10.1258/ar.2012.120247. PMID: 22761343. Exclusion Code: X10.22761343
1740 Velcheti V, Schalper KA, Carvajal DE, . Programmed death ligand-1 expression in non-small cell lung cancer. Lab Invest. 2014 Jan;94(1):107–16. doi: 10.1038/labinvest.2013.130. PMID: 24217091. Exclusion Code: X7.24217091
1741 Veluswamy RR, Ezer N, Mhango G, . Limited resection versus lobectomy for older patients with early-stage lung cancer: impact of histology. J Clin Oncol. 2015 Oct 20;33(30):3447–53. doi: 10.1200/jco.2014.60.6624. PMID: 26240229. Exclusion Code: X7.26240229
1742 Venkitaraman B, Karunanithi S, Kumar A, . Role of 68Ga-DOTATOC PET/CT in initial evaluation of patients with suspected bronchopulmonary carcinoid. Eur J Nucl Med Mol Imaging. 2014 May;41(5):856–64. doi: 10.1007/s00259-013-2659-5. PMID: 24435773. Exclusion Code: X5.24435773
1743 Verma A, Abisheganaden J, Light RW. Identifying malignant pleural effusion by a cancer ratio (serum LDH: pleural fluid ADA ratio). Lung. 2016 Feb;194(1):147–53. doi: 10.1007/s00408-015-9831-6. PMID: 26678281. Exclusion Code: X3.26678281
1744 Verma A, Lim AY, Tai DY, . Timeliness of diagnosing lung cancer: number of procedures and time needed to establish diagnosis: being right the first time. Medicine (Baltimore). 2015 Jul;94(29):e1216. doi: 10.1097/md.0000000000001216. PMID: 26200646. Exclusion Code: X3.26200646
1745 Verma S, Chan J, Chew C, . PET-SUV Max and Upstaging of Lung Cancer. Heart Lung Circ. 2019 Mar;28(3):436–42. doi: 10.1016/j.hlc.2017.12.011. PMID: 29428202. Exclusion Code: X3.29428202
1746 Verma V, Shostrom VK, Zhen W, . Influence of fractionation scheme and tumor location on toxicities after stereotactic body radiation therapy for large (>/=5 cm) non-small cell lung cancer: a multi-institutional analysis. Int J Radiat Oncol Biol Phys. 2017 Mar 15;97(4):778–85. doi: 10.1016/j.ijrobp.2016.11.049. PMID: 28244414. Exclusion Code: X3.28244414
1747 Verma V, Simone CB, 2nd, Allen PK, . Multi-institutional experience of stereotactic ablative radiation therapy for stage I small cell lung cancer. Int J Radiat Oncol Biol Phys. 2017 Feb 1;97(2):362–71. doi: 10.1016/j.ijrobp.2016.10.041. PMID: 28011047. Exclusion Code: X3.28011047
1748 Veronesi G, Maisonneuve P, Rampinelli C, . Computed tomography screening for lung cancer: results of ten years of annual screening and validation of cosmos prediction model. Lung Cancer. 2013 Dec;82(3):426–30. doi: 10.1016/j.lungcan.2013.08.026. PMID: 24099665. Exclusion Code: X4.24099665
1749 Verstegen NE, Lagerwaard FJ, Hashemi SM, . Patterns of disease recurrence after SABR for early stage non-small-cell lung cancer: optimizing follow-up schedules for salvage therapy. J Thorac Oncol. 2015 Aug;10(8):1195–200. doi: 10.1097/jto.0000000000000576. PMID: 26200274. Exclusion Code: X8.26200274
1750 Verstegen NE, Oosterhuis JW, Palma DA, . Stage I-II non-small-cell lung cancer treated using either stereotactic ablative radiotherapy (SABR) or lobectomy by video-assisted thoracoscopic surgery (VATS): outcomes of a propensity score-matched analysis. Ann Oncol. 2013 Jun;24(6):1543–8. doi: 10.1093/annonc/mdt026. PMID: 23425947. Exclusion Code: X3.23425947
1751 Vest MT, Herrin J, Soulos PR, . Use of new treatment modalities for non-small cell lung cancer care in the Medicare population. Chest. 2013 Feb 1;143(2):429–35. doi: 10.1378/chest.12-1149. PMID: 23187634. Exclusion Code: X8.23187634
1752 Vial MR, Khan KA, O’Connell O, . Endobronchial ultrasound-guided transbronchial needle aspiration in the nodal staging of stereotactic ablative body radiotherapy patients. Ann Thorac Surg. 2017 May;103(5):1600–5. doi: 10.1016/j.athoracsur.2016.09.106. PMID: 28027732. Exclusion Code: X3.28027732
1753 Videtic GMM, Donington J, Giuliani M, . Stereotactic body radiation therapy for early-stage non-small cell lung cancer: Executive Summary of an ASTRO Evidence-Based Guideline. Pract Radiat Oncol. 2017 Sep - Oct;7(5):295–301. doi: 10.1016/j.prro.2017.04.014. PMID: 28596092. Exclusion Code: X16.28596092
1754 Videtic GMM, Woody NM, Reddy CA, . Never too old: a single-institution experience of stereotactic body radiation therapy for patients 90 years and older with early stage lung cancer. Pract Radiat Oncol. 2017 Nov - Dec;7(6):e543–e9. doi: 10.1016/j.prro.2017.06.011. PMID: 28867545. Exclusion Code: X3.28867545
1755 Vinogradskiy Y, Diot Q, Kavanagh B, . Spatial and dose-response analysis of fibrotic lung changes after stereotactic body radiation therapy. Med Phys. 2013 Aug;40(8):081712. doi: 10.1118/1.4813916. PMID: 23927309. Exclusion Code: X8.23927309
1756 Vis DC, Kelly MM, Lee AG, . Contralateral recurrence of inflammatory myofibroblastic tumour of the lung 10 years after pneumonectomy. Thorax. 2018 Nov;73(11):1089–90. doi: 10.1136/thoraxjnl-2018-211645. PMID: 29884625. Exclusion Code: X10.29884625
1757 Viti A, Socci L, Congregado M, . The everlasting issue of prolonged air leaks after lobectomy for non-small cell lung cancer: A data-driven prevention planning model in the era of minimally invasive approaches. J Surg Oncol. 2018 Dec;118(8):1285–91. doi: 10.1002/jso.25289. PMID: 30399200. Exclusion Code: X3.30399200
1758 Volk RJ, Linder SK, Leal VB, . Feasibility of a patient decision aid about lung cancer screening with low-dose computed tomography. Prev Med. 2014 May;62:60–3. doi: 10.1016/j.ypmed.2014.02.006. PMID: 24518006. Exclusion Code: X5.24518006
1759 Voltolini L, Bongiolatti S, Luzzi L, . Impact of interstitial lung disease on short-term and long-term survival of patients undergoing surgery for non-small-cell lung cancer: analysis of risk factors. Eur J Cardiothorac Surg. 2013 Jan;43(1):e17–23. doi: 10.1093/ejcts/ezs560. PMID: 23129356. Exclusion Code: X11.23129356
1760 von Reibnitz D, Shaikh F, Wu AJ, . Stereotactic body radiation therapy (SBRT) improves local control and overall survival compared to conventionally fractionated radiation for stage I non-small cell lung cancer (NSCLC). Acta Oncol. 2018 Nov;57(11):1567–73. doi: 10.1080/0284186x.2018.1481292. PMID: 29873277. Exclusion Code: X13.29873277
1761 Wakeam E, Acuna SA, Leighl NB, . Surgery versus chemotherapy and radiotherapy for early and locally advanced small cell lung cancer: a propensity-matched analysis of survival. Lung Cancer. 2017 Jul;109:78–88. doi: 10.1016/j.lungcan.2017.04.021. PMID: 28577955. Exclusion Code: X3.28577955
1762 Walker PR, Cykert S, Edwards L, . An intervention study to reduce black-white treatment disparities in early stage non-small cell lung cancer. J Clin Oncol. 2017;35(15)PMID: CN-01781395. Exclusion Code: X2.
1763 Walter JE, Heuvelmans MA, Bock GH, . Characteristics of new solid nodules detected in incidence screening rounds of low-dose CT lung cancer screening: the NELSON study. Thorax. 2018 Aug;73(8):741–7. doi: 10.1136/thoraxjnl-2017-211376. PMID: 29661918. Exclusion Code: X8.29661918
1764 Walter JE, Heuvelmans MA, ten Haaf K, . Persisting new nodules in incidence rounds of the NELSON CT lung cancer screening study. Thorax. 2019 Mar;74(3):247–53. doi: 10.1136/thoraxjnl-2018-212152. PMID: 30591535. Exclusion Code: X8.30591535
1765 Walts AE, Marchevsky AM. Potential errors in staging primary pulmonary adenocarcinomas by sublobar resection. Ann Diagn Pathol. 2013 Dec;17(6):471–5. doi: 10.1016/j.anndiagpath.2013.05.006. PMID: 23810206. Exclusion Code: X8.23810206
1766 Wang BY, Liu CY, Hsu PK, . Single-incision versus multiple-incision thoracoscopic lobectomy and segmentectomy: a propensity-matched analysis. Ann Surg. 2015 Apr;261(4):793–9. doi: 10.1097/sla.0000000000000712. PMID: 24836148. Exclusion Code: X3.24836148
1767 Wang BY, Tu CC, Liu CY, . Single-incision thoracoscopic lobectomy and segmentectomy with radical lymph node dissection. Ann Thorac Surg. 2013 Sep;96(3):977–82. doi: 10.1016/j.athoracsur.2013.05.002. PMID: 23870694. Exclusion Code: X3.23870694
1768 Wang C, Duan Q, Kelly M, . Accuracy of bronchial brush and wash specimens prepared by the ThinPrep method in the diagnosis of pulmonary small cell carcinoma. Cancer Cytopathol. 2014 Aug;122(8):577–85. doi: 10.1002/cncy.21435. PMID: 24824569. Exclusion Code: X5.24824569
1769 Wang CC, Tseng CC, Hsiao CC, . Circulating endothelial-derived activated microparticle: a useful biomarker for predicting one-year mortality in patients with advanced non-small cell lung cancer. Biomed Res Int. 2014;2014:173401. doi: 10.1155/2014/173401. PMID: 25061601. Exclusion Code: X3.25061601
1770 Wang D, Koh ES, Descallar J, . Application of novel quantitative techniques for fluorodeoxyglucose positron emission tomography/computed tomography in patients with non-small-cell lung cancer. Asia Pac J Clin Oncol. 2016 Dec;12(4):349–58. doi: 10.1111/ajco.12587. PMID: 27550522. Exclusion Code: X3.27550522
1771 Wang H, Shi J, Liu H, . Clinical and diagnostic features of angiosarcoma with pulmonary metastases: A retrospective observational study. Medicine (Baltimore). 2017 Sep;96(36):e8033. doi: 10.1097/md.0000000000008033. PMID: 28885371. Exclusion Code: X3.28885371
1772 Wang L, Anraku M, Sato M, . Impact of the 8th Edition of the UICC-TNM Classification on Clinical Stage 0-IA Lung Adenocarcinoma: Does the New Classification Predict Postoperative Prognosis More Precisely than the Previous One? Ann Thorac Cardiovasc Surg. 2018 Oct 19;24(5):223–9. doi: 10.5761/atcs.oa.18-00051. PMID: 29848840. Exclusion Code: X11.29848840
1773 Wang L, Chen Y, Tang K, . The Value of (18)F-FDG PET/CT Mathematical Prediction Model in Diagnosis of Solitary Pulmonary Nodules. Biomed Res Int. 2018;2018:9453967. doi: 10.1155/2018/9453967. PMID: 29789808. Exclusion Code: X10.29789808
1774 Wang L, Pei Y, Li S, . Left sleeve lobectomy versus left pneumonectomy for the management of patients with non-small cell lung cancer. Thorac Cancer. 2018 Mar;9(3):348–52. doi: 10.1111/1759-7714.12583. PMID: 29341464. Exclusion Code: X3.29341464
1775 Wang L, Yin X, Wang F, . The usefulness of combined diagnostic CT and (99m)Tc-octreotide somatostatin receptor SPECT/CT imaging on pulmonary nodule characterization in patients. Cancer Biother Radiopharm. 2013 Dec;28(10):731–6. doi: 10.1089/cbr.2013.1482. PMID: 24094076. Exclusion Code: X8.24094076
1776 Wang P, Zhang D, Guo XG, . A propensity-matched analysis of surgery and stereotactic body radiotherapy for early stage non-small cell lung cancer in the elderly. Medicine (Baltimore). 2016 Dec;95(52):e5723. doi: 10.1097/md.0000000000005723. PMID: 28033277. Exclusion Code: X14.28033277
1777 Wang S, Ye Q, Lu X. Plasma apolipoprotein E level is associated with the risk of endobronchial biopsy-induced bleeding in patients with lung cancer. Lipids Health Dis. 2018 Jul 21;17(1):166. doi: 10.1186/s12944-018-0821-6. PMID: 30031394. Exclusion Code: X3.30031394
1778 Wang S, Zhang J, Lu X. Non-linear association of plasma level of high-density lipoprotein cholesterol with endobronchial biopsy bleeding in patients with lung cancer. Lipids Health Dis. 2019 Jan 18;18(1):17. doi: 10.1186/s12944-019-0966-y. PMID: 30658636. Exclusion Code: X3.30658636
1779 Wang W, Dou S, Dong W, . Impact of COPD on prognosis of lung cancer: from a perspective on disease heterogeneity. Int J Chron Obstruct Pulmon Dis. 2018;13:3767–76. doi: 10.2147/copd.s168048. PMID: 30538439. Exclusion Code: X3.30538439
1780 Wang W, Feng X, Duan X, . Establishment of two data mining models of lung cancer screening based on three gene promoter methylations combined with telomere damage. Int J Biol Markers. 2017 Mar 2;32(1):e141–e6. doi: 10.5301/jbm.5000232. PMID: 27716889. Exclusion Code: X7.27716889
1781 Wang W, Liu M, Wang J, . Analysis of the discriminative methods for diagnosis of benign and malignant solitary pulmonary nodules based on serum markers. Oncol Res Treat. 2014;37(12):740–6. doi: 10.1159/000369488. PMID: 25531720. Exclusion Code: X5.25531720
1782 Wang X, Li H, Zhu XR, . Multiple-CT optimization of intensity-modulated proton therapy - Is it possible to eliminate adaptive planning? Radiother Oncol. 2018 Jul;128(1):167–73. doi: 10.1016/j.radonc.2017.09.032. PMID: 29054378. Exclusion Code: X6.29054378
1783 Wang X, Liu H, Shen Y, . Low-dose computed tomography (LDCT) versus other cancer screenings in early diagnosis of lung cancer: A meta-analysis. Medicine (Baltimore). 2018 Jul;97(27):e11233. doi: 10.1097/md.0000000000011233. PMID: 29979385. Exclusion Code: X9.29979385
1784 Wang X, Ma K, Cui J, . An individual risk prediction model for lung cancer based on a study in a Chinese population. Tumori. 2015 Jan-Feb;101(1):16–23. doi: 10.5301/tj.5000205. PMID: 25702657. Exclusion Code: X4.25702657
1785 Wang X, Zamdborg L, Ye H, . A matched-pair analysis of stereotactic body radiotherapy (SBRT) for oligometastatic lung tumors from colorectal cancer versus early stage non-small cell lung cancer. BMC Cancer. 2018 Oct 10;18(1):962. doi: 10.1186/s12885-018-4865-9. PMID: 30305131. Exclusion Code: X10.30305131
1786 Wang XY, Zhao YF, Liu Y, . Prognostic value of metabolic variables of [18F]FDG PET/CT in surgically resected stage I lung adenocarcinoma. Medicine (Baltimore). 2017 Sep;96(35):e7941. doi: 10.1097/md.0000000000007941. PMID: 28858121. Exclusion Code: X3.28858121
1787 Wang XY, Zhao YF, Liu Y, . Comparison of different automated lesion delineation methods for metabolic tumor volume of 18F-FDG PET/CT in patients with stage I lung adenocarcinoma. Medicine (Baltimore). 2017 Dec;96(51):e9365. doi: 10.1097/md.0000000000009365. PMID: 29390527. Exclusion Code: X5.29390527
1788 Wang Y, Hu Y, Wang D, . The analysis of volatile organic compounds biomarkers for lung cancer in exhaled breath, tissues and cell lines. Cancer Biomark. 2012;11(4):129–37. doi: 10.3233/cbm-2012-00270. PMID: 23144150. Exclusion Code: X5.23144150
1789 Wang Y, Liu B, Cao P, . Comparison between computed tomography-guided percutaneous microwave ablation and thoracoscopic lobectomy for stage I non-small cell lung cancer. Thorac Cancer. 2018 Nov;9(11):1376–82. doi: 10.1111/1759-7714.12842. PMID: 30152596. Exclusion Code: X10.30152596
1790 Wang Y, McKay JD, Rafnar T, . Rare variants of large effect in BRCA2 and CHEK2 affect risk of lung cancer. Nat Genet. 2014 Jul;46(7):736–41. doi: 10.1038/ng.3002. PMID: 24880342. Exclusion Code: X3.24880342
1791 Wang Y, Wang R, Zheng D, . Predicting the recurrence risk factors and clinical outcomes of peripheral pulmonary adenocarcinoma </=3 cm with wedge resection. J Cancer Res Clin Oncol. 2017 Jun;143(6):1043–51. doi: 10.1007/s00432-016-2337-7. PMID: 28204972. Exclusion Code: X14.28204972
1792 Wang Y, Wang R, Zheng D, . The indication of completion lobectomy for lung adenocarcinoma </=3 cm after wedge resection during surgical operation. J Cancer Res Clin Oncol. 2017 Oct;143(10):2095–104. doi: 10.1007/s00432-017-2452-0. PMID: 28616702. Exclusion Code: X14.28616702
1793 Wang Y, Zheng D, Zheng J, . Predictors of recurrence and survival of pathological T1N0M0 invasive adenocarcinoma following lobectomy. J Cancer Res Clin Oncol. 2018 Jun;144(6):1015–23. doi: 10.1007/s00432-018-2622-8. PMID: 29532227. Exclusion Code: X10.29532227
1794 Wang Z, Zhang J, Cheng Z, . Factors affecting major morbidity after video-assisted thoracic surgery for lung cancer. J Surg Res. 2014 Dec;192(2):628–34. doi: 10.1016/j.jss.2014.07.051. PMID: 25167779. Exclusion Code: X14.25167779
1795 Wargo JJ, Kim AH, Hart A, . It took a village: good’s syndrome. Am J Med. 2015 Jul;128(7):699–701. doi: 10.1016/j.amjmed.2015.03.002. PMID: 25796418. Exclusion Code: X3.25796418
1796 Warren WA, Hagaman JT. Endobronchial ultrasound-guided transbronchial needle aspiration for mediastinal staging in a community medical center. Ann Am Thorac Soc. 2016 Oct;13(10):1802–7. doi: 10.1513/AnnalsATS.201603-216BC. PMID: 27409724. Exclusion Code: X3.27409724
1797 Warth A, Cortis J, Soltermann A, . Tumour cell proliferation (Ki-67) in non-small cell lung cancer: a critical reappraisal of its prognostic role. Br J Cancer. 2014 Sep 9;111(6):1222–9. doi: 10.1038/bjc.2014.402. PMID: 25051406. Exclusion Code: X3.25051406
1798 Warwick R, Mediratta N, Shackcloth M, . Wedge resection verses lobectomy for stage 1 non-small-cell lung cancer. Asian Cardiovasc Thorac Ann. 2013 Oct;21(5):566–73. doi: 10.1177/0218492312466861. PMID: 24570559. Exclusion Code: X8.24570559
1799 Warwick R, Shackcloth M, Mediratta N, . Female sex and long-term survival post curative resection for non-small-cell lung cancer. Eur J Cardiothorac Surg. 2013 Oct;44(4):624–30. doi: 10.1093/ejcts/ezt139. PMID: 23509234. Exclusion Code: X8.23509234
1800 Watanabe I, Kanauchi N, Watanabe H. Preoperative prognostic nutritional index as a predictor of outcomes in elderly patients after surgery for lung cancer. Jpn J Clin Oncol. 2018 Apr 1;48(4):382–7. doi: 10.1093/jjco/hyy014. PMID: 29528442. Exclusion Code: X10.29528442
1801 Way T, Chan HP, Hadjiiski L, . Computer-aided diagnosis of lung nodules on CT scans: ROC study of its effect on radiologists’ performance. Acad Radiol. 2010 Mar;17(3):323–32. doi: 10.1016/j.acra.2009.10.016. PMID: 20152726. Exclusion Code: X3.20152726
1802 Wei B, Broussard B, Bryant A, . Left upper lobectomy after coronary artery bypass grafting. J Thorac Cardiovasc Surg. 2015 Sep;150(3):531–5. doi: 10.1016/j.jtcvs.2015.05.066. PMID: 26149098. Exclusion Code: X3.26149098
1803 Wei B, D’Amico T, Samad Z, . The impact of pulmonary hypertension on morbidity and mortality following major lung resection. Eur J Cardiothorac Surg. 2014 Jun;45(6):1028–33. doi: 10.1093/ejcts/ezt495. PMID: 24132298. Exclusion Code: X11.24132298
1804 Weksler B, Kosinski AS, Burfeind WR, . Racial and ethnic differences in lung cancer surgical stage: an STS database study. Thorac Cardiovasc Surg. 2015 Oct;63(7):538–43. doi: 10.1055/s-0035-1546295. PMID: 25984780. Exclusion Code: X8.25984780
1805 Welch BT, Brinjikji W, Schmit GD, . A national analysis of the complications, cost, and mortality of percutaneous lung ablation. J Vasc Interv Radiol. 2015 Jun;26(6):787–91. doi: 10.1016/j.jvir.2015.02.019. PMID: 25866239. Exclusion Code: X3.25866239
1806 Wen SW, Han L, Lv HL, . A propensity-matched analysis of outcomes of patients with clinical stage I non-small cell lung cancer treated surgically or with stereotactic radiotherapy: a meta-analysis. J Invest Surg. 2019 Jan;32(1):27–34. doi: 10.1080/08941939.2017.1370519. PMID: 28985095. Exclusion Code: X9.28985095
1807 Wesolowski SP, Boros PW, Orlowski TM, . Use the lower limit of normal, not 80% predicted, in judging eligibility for lung resection. Respiration. 2016;92(2):65–71. doi: 10.1159/000447974. PMID: 27428328. Exclusion Code: X3.27428328
1808 White CS, Dharaiya E, Campbell E, . The Vancouver Lung Cancer Risk Prediction Model: assessment by using a subset of the National Lung Screening Trial Cohort. Radiology. 2017 Apr;283(1):264–72. doi: 10.1148/radiol.2016152627. PMID: 27740906. Exclusion Code: X3.27740906
1809 Widder J, Postmus D, Ubbels JF, . Survival and quality of life after stereotactic or 3D-conformal radiotherapy for inoperable early-stage lung cancer. Int J Radiat Oncol Biol Phys. 2011 Nov 15;81(4):e291–7. doi: 10.1016/j.ijrobp.2011.03.052. PMID: 21640503. Exclusion Code: X13.21640503
1810 Widlak P, Pietrowska M, Polanska J, . Serum mass profile signature as a biomarker of early lung cancer. Lung Cancer. 2016 Sep;99:46–52. doi: 10.1016/j.lungcan.2016.06.011. PMID: 27565913. Exclusion Code: X4.27565913
1811 Wiener RS, Gould MK, Slatore CG, . Resource use and guideline concordance in evaluation of pulmonary nodules for cancer: too much and too little care. JAMA Intern Med. 2014 Jun;174(6):871–80. doi: 10.1001/jamainternmed.2014.561. PMID: 24710850. Exclusion Code: X3.24710850
1812 Wiener RS, Gould MK, Woloshin S, . ‘The thing is not knowing’: patients’ perspectives on surveillance of an indeterminate pulmonary nodule. Health Expect. 2015 Jun;18(3):355–65. doi: 10.1111/hex.12036. PMID: 23252477. Exclusion Code: X3.23252477
1813 Wikoff WR, Hanash S, DeFelice B, . Diacetylspermine is a novel prediagnostic serum biomarker for non-small-cell lung cancer and has additive performance with pro-surfactant protein B. J Clin Oncol. 2015 Nov 20;33(33):3880–6. doi: 10.1200/jco.2015.61.7779. PMID: 26282655. Exclusion Code: X10.26282655
1814 Wilbur DC, Meyer MG, Presley C, . Automated 3-dimensional morphologic analysis of sputum specimens for lung cancer detection: Performance characteristics support use in lung cancer screening. Cancer Cytopathol. 2015 Sep;123(9):548–56. doi: 10.1002/cncy.21565. PMID: 26153135. Exclusion Code: X5.26153135
1815 Williams CD, Gajra A, Ganti AK, . Use and impact of adjuvant chemotherapy in patients with resected non-small cell lung cancer. Cancer. 2014 Jul 1;120(13):1939–47. doi: 10.1002/cncr.28679. PMID: 24668613. Exclusion Code: X6.24668613
1816 Williams CD, Salama JK, Moghanaki D, . Impact of race on treatment and survival among U.S. veterans with early-stage lung cancer. J Thorac Oncol. 2016 Oct;11(10):1672–81. doi: 10.1016/j.jtho.2016.05.030. PMID: 27296104. Exclusion Code: X3.27296104
1817 Williams CD, Stechuchak KM, Zullig LL, . Influence of comorbidity on racial differences in receipt of surgery among US veterans with early-stage non-small-cell lung cancer. J Clin Oncol. 2013 Feb 1;31(4):475–81. doi: 10.1200/jco.2012.44.1170. PMID: 23269988. Exclusion Code: X8.23269988
1818 Williams SP, Kinshuck AJ, Williams C, . Incidental head and neck findings on 18F-fluoro-deoxy-glucose positron emission tomography computed tomography. J Laryngol Otol. 2015 Sep;129(9):898–902. doi: 10.1017/s0022215115001826. PMID: 26206309. Exclusion Code: X3.26206309
1819 Wilshire CL, Louie BE, Manning KA, . Radiologic evaluation of small lepidic adenocarcinomas to guide decision making in surgical resection. Ann Thorac Surg. 2015 Sep;100(3):979–88. doi: 10.1016/j.athoracsur.2015.04.030. PMID: 26231858. Exclusion Code: X11.26231858
1820 Wilson DO, Ryan A, Fuhrman C, . Doubling times and CT screen-detected lung cancers in the Pittsburgh Lung Screening Study. Am J Respir Crit Care Med. 2012 Jan 1;185(1):85–9. doi: 10.1164/rccm.201107-1223OC. PMID: 21997335. Exclusion Code: X11.21997335
1821 Wilson DO, Weissfeld J. A simple model for predicting lung cancer occurrence in a lung cancer screening program: The Pittsburgh Predictor. Lung Cancer. 2015 Jul;89(1):31–7. doi: 10.1016/j.lungcan.2015.03.021. PMID: 25863905. Exclusion Code: X7.25863905
1822 Wimaleswaran H, Farmer MW, Irving LB, . Pulmonologist-performed transoesophageal sampling for lung cancer staging using an endobronchial ultrasound video-bronchoscope: an Australian experience. Intern Med J. 2017 Feb;47(2):205–10. doi: 10.1111/imj.13330. PMID: 27860078. Exclusion Code: X3.27860078
1823 Winkler Wille MM, van Riel SJ, Saghir Z, . Predictive accuracy of the PanCan Lung Cancer Risk Prediction Model-external validation based on CT from the Danish Lung Cancer Screening Trial. Eur Radiol. 2015 Oct;25(10):3093–9. doi: 10.1007/s00330-015-3689-0. PMID: 25764091. Exclusion Code: X4.25764091
1824 Wisnivesky JP, Bonomi M, Henschke C, . Radiation therapy for the treatment of unresected stage I-II non-small cell lung cancer. Chest. 2005 Sep;128(3):1461–7. doi: 10.1378/chest.128.3.1461. PMID: 16162744. Exclusion Code: X6.16162744
1825 Witte B, Stenz C, Vahl CF, . Comparative intention-to-treat analysis of the video-assisted thoracoscopic surgery approach to pulmonary segmentectomy for lung carcinomadouble dagger. Interact Cardiovasc Thorac Surg. 2015 Sep;21(3):276–83. doi: 10.1093/icvts/ivv143. PMID: 26063694. Exclusion Code: X3.26063694
1826 Wolf A, Liu B, Leoncini E, . Outcomes for Thoracoscopy Versus Thoracotomy Not Just Technique Dependent: A Study of 9,787 Patients. Ann Thorac Surg. 2018 Mar;105(3):886–91. doi: 10.1016/j.athoracsur.2017.09.059. PMID: 29397101. Exclusion Code: X3.29397101
1827 Wolf AS, Swanson SJ, Yip R, . The impact of margins on outcomes after wedge resection for stage I non-small cell lung cancer. Ann Thorac Surg. 2017 Oct;104(4):1171–8. doi: 10.1016/j.athoracsur.2017.04.024. PMID: 28669499. Exclusion Code: X3.28669499
1828 Wolf FJ, Aswad B, Ng T, . Intraoperative microwave ablation of pulmonary malignancies with tumor permittivity feedback control: ablation and resection study in 10 consecutive patients. Radiology. 2012 Jan;262(1):353–60. doi: 10.1148/radiol.11110015. PMID: 22106348. Exclusion Code: X6.22106348
1829 Wolff HB, Alberts L, Kastelijn EA, . Differences in longitudinal health utility between stereotactic body radiation therapy and surgery in stage I non-small cell lung cancer. J Thorac Oncol. 2018 May;13(5):689–98. doi: 10.1016/j.jtho.2018.01.021. PMID: 29391288. Exclusion Code: X3.29391288
1830 Wong OY, Yau V, Kang J, . Survival Impact of Cardiac Dose Following Lung Stereotactic Body Radiotherapy. Clin Lung Cancer. 2018 Mar;19(2):e241–e6. doi: 10.1016/j.cllc.2017.08.002. PMID: 28941961. Exclusion Code: X3.28941961
1831 Wood DE, Eapen GA, Ettinger DS, . Lung cancer screening. J Natl Compr Canc Netw. 2012 Feb;10(2):240–65. PMID: 22308518. Exclusion Code: X10.22308518
1832 Woody NM, Stephans KL, Andrews M, . A histologic basis for the efficacy of SBRT to the lung. J Thorac Oncol. 2017 Mar;12(3):510–9. doi: 10.1016/j.jtho.2016.11.002. PMID: 28017592. Exclusion Code: X13.28017592
1833 Woody NM, Stephans KL, Andrews M, . A biological basis for local failure after lung stereotactic body radiation therapy. International journal of radiation oncology biology physics. Conference: 58th annual meeting of the american society for radiation oncology, ASTRO 2016. United states. 2016;96(2 Supplement 1):E421–E2. PMID: CN-01463389. Exclusion Code: X2.
1834 Woody NM, Stephans KL, Marwaha G, . Stereotactic body radiation therapy for non-small cell lung cancer tumors greater than 5 cm: safety and efficacy. Int J Radiat Oncol Biol Phys. 2015 Jun 1;92(2):325–31. doi: 10.1016/j.ijrobp.2015.01.045. PMID: 25841625. Exclusion Code: X3.25841625
1835 Woody NM, Videtic GM, Stephans KL, . Predicting chest wall pain from lung stereotactic body radiotherapy for different fractionation schemes. Int J Radiat Oncol Biol Phys. 2012 May 1;83(1):427–34. doi: 10.1016/j.ijrobp.2011.06.1971. PMID: 22197087. Exclusion Code: X3.22197087
1836 Wormanns D, Ludwig K, Beyer F, . Detection of pulmonary nodules at multirow-detector CT: effectiveness of double reading to improve sensitivity at standard-dose and low-dose chest CT. Eur Radiol. 2005 Jan;15(1):14–22. doi: 10.1007/s00330-004-2527-6. PMID: 15526207. Exclusion Code: X3.15526207
1837 Wozniak MB, Scelo G, Muller DC, . Circulating MicroRNAs as non-invasive biomarkers for early detection of non-small-cell lung cancer. PLoS One. 2015;10(5):e0125026. doi: 10.1371/journal.pone.0125026. PMID: 25965386. Exclusion Code: X3.25965386
1838 Wu AJ, Williams E, Modh A, . Dosimetric predictors of esophageal toxicity after stereotactic body radiotherapy for central lung tumors. Radiother Oncol. 2014 Aug;112(2):267–71. doi: 10.1016/j.radonc.2014.07.001. PMID: 25064471. Exclusion Code: X3.25064471
1839 Wu CF, Fernandez R, de la Torre M, . Mid-term survival outcome of single-port video-assisted thoracoscopic anatomical lung resection: a two-centre experience. Eur J Cardiothorac Surg. 2018 Aug 1;54(2):252–9. doi: 10.1093/ejcts/ezy067. PMID: 29514185. Exclusion Code: X3.29514185
1840 Wu CY, Chen JS, Lin YS, . Feasibility and safety of nonintubated thoracoscopic lobectomy for geriatric lung cancer patients. Ann Thorac Surg. 2013 Feb;95(2):405–11. doi: 10.1016/j.athoracsur.2012.10.082. PMID: 23245449. Exclusion Code: X3.23245449
1841 Wu CY, Fu JY, Wu CF, . Survival prediction model using clinico-pathologic characteristics for nonsmall cell lung cancer patients after curative resection. Medicine (Baltimore). 2015 Nov;94(45):e2013. doi: 10.1097/md.0000000000002013. PMID: 26559298. Exclusion Code: X3.26559298
1842 Wu F, Tian SP, Jin X, . CT and histopathologic characteristics of lung adenocarcinoma with pure ground-glass nodules 10 mm or less in diameter. Eur Radiol. 2017 Oct;27(10):4037–43. doi: 10.1007/s00330-017-4829-5. PMID: 28386719. Exclusion Code: X10.28386719
1843 Wu HY, Goan YG, Chang YH, . Qualification and verification of serological biomarker candidates for lung adenocarcinoma by targeted mass spectrometry. J Proteome Res. 2015 Aug 7;14(8):3039–50. doi: 10.1021/pr501195t. PMID: 26120931. Exclusion Code: X3.26120931
1844 Wu YL, Herbst RS, Mann H, . ADAURA: phase III, Double-blind, Randomized Study of Osimertinib Versus Placebo in EGFR Mutation-positive Early-stage NSCLC After Complete Surgical Resection. Clin Lung Cancer. 2018;19(4):e533–e6. doi: 10.1016/j.cllc.2018.04.004. PMID: CN-01708182. Exclusion Code: X3.29789220
1845 Wurstbauer K, Deutschmann H, Dagn K, . DART-bid (Dose-differentiated accelerated radiation therapy, 1.8 Gy twice daily)--a novel approach for non-resected NSCLC: final results of a prospective study, correlating radiation dose to tumor volume. Radiat Oncol. 2013 Mar 5;8:49. doi: 10.1186/1748-717x-8-49. PMID: 23497555. Exclusion Code: X6.23497555
1846 Xia B, Chen GY, Cai XW, . Is involved-field radiotherapy based on CT safe for patients with limited-stage small-cell lung cancer? Radiother Oncol. 2012 Feb;102(2):258–62. doi: 10.1016/j.radonc.2011.10.003. PMID: 22056536. Exclusion Code: X6.22056536
1847 Xia H, Sun Z, Deng L, . Prognostic significance of the preoperative lymphocyte to monocyte ratio in patients with stage I non-small cell lung cancer undergoing complete resection. Cancer Invest. 2016 Sep 13;34(8):378–84. doi: 10.1080/07357907.2016.1213276. PMID: 27558529. Exclusion Code: X3.27558529
1848 Xiao F, Yu Q, Zhang Z, . Novel perspective to evaluate the safety of segmentectomy: clinical significance of lobar and segmental lymph node metastasis in cT1N0M0 lung adenocarcinoma. Eur J Cardiothorac Surg. 2018 Jan 1;53(1):228–34. doi: 10.1093/ejcts/ezx263. PMID: 28950357. Exclusion Code: X11.28950357
1849 Xiao H, Zhang L, Zhou H, . Proteomic analysis of human saliva from lung cancer patients using two-dimensional difference gel electrophoresis and mass spectrometry. Mol Cell Proteomics. 2012 Feb;11(2):M111.012112. doi: 10.1074/mcp.M111.012112. PMID: 22096114. Exclusion Code: X3.22096114
1850 Xie X, Dijkstra AE, Vonk JM, . Chronic respiratory symptoms associated with airway wall thickening measured by thin-slice low-dose CT. AJR Am J Roentgenol. 2014 Oct;203(4):W383–90. doi: 10.2214/ajr.13.11536. PMID: 25247967. Exclusion Code: X8.25247967
1851 Xie X, Willemink MJ, de Jong PA, . Small irregular pulmonary nodules in low-dose CT: observer detection sensitivity and volumetry accuracy. AJR Am J Roentgenol. 2014 Mar;202(3):W202–9. doi: 10.2214/ajr.13.10830. PMID: 24555615. Exclusion Code: X3.24555615
1852 Xing L, Su J, Guarnera MA, . Sputum microRNA biomarkers for identifying lung cancer in indeterminate solitary pulmonary nodules. Clin Cancer Res. 2015 Jan 15;21(2):484–9. doi: 10.1158/1078-0432.ccr-14-1873. PMID: 25593345. Exclusion Code: X5.25593345
1853 Xing R, Chen KB, Xuan Y, . RBX1 expression is an unfavorable prognostic factor in patients with non-small cell lung cancer. Surg Oncol. 2016 Sep;25(3):147–51. doi: 10.1016/j.suronc.2016.05.006. PMID: 27566015. Exclusion Code: X3.27566015
1854 Xu CH, Cao L, Wei Y, . Serum cripto-1 as a clinical marker for lung cancer. Int J Biol Markers. 2015 Nov 11;30(4):e369–73. doi: 10.5301/jbm.5000155. PMID: 26109366. Exclusion Code: X3.26109366
1855 Xu CH, Wang Q, Zhan P, . GSTP1 Ile105Val polymorphism is associated with lung cancer risk among Asian population and smokers: an updated meta-analysis. Mol Biol Rep. 2014 Jul;41(7):4199–212. doi: 10.1007/s11033-014-3290-7. PMID: 24566690. Exclusion Code: X10.24566690
1856 Xu CH, Wang W, Wei Y, . Prognostic value of the new International Association for the Study of Lung Cancer/American Thoracic Society/European Respiratory Society classification in stage IB lung adenocarcinoma. Eur J Surg Oncol. 2015 Oct;41(10):1430–6. doi: 10.1016/j.ejso.2015.06.004. PMID: 26123994. Exclusion Code: X11.26123994
1857 Xu DM, Lee IJ, Zhao S, . CT screening for lung cancer: value of expert review of initial baseline screenings. AJR Am J Roentgenol. 2015 Feb;204(2):281–6. doi: 10.2214/ajr.14.12526. PMID: 25349980. Exclusion Code: X11.25349980
1858 Xu DM, van der Zaag-Loonen HJ, Oudkerk M, . Smooth or attached solid indeterminate nodules detected at baseline CT screening in the NELSON study: cancer risk during 1 year of follow-up. Radiology. 2009 Jan;250(1):264–72. doi: 10.1148/radiol.2493070847. PMID: 18984780. Exclusion Code: X11.18984780
1859 Xu DM, Yip R, Smith JP, . Retrospective review of lung cancers diagnosed in annual rounds of CT screening. AJR Am J Roentgenol. 2014 Nov;203(5):965–72. doi: 10.2214/ajr.13.12115. PMID: 25247825. Exclusion Code: X3.25247825
1860 Xu H, Zhang L. The Feasibility of Thoracoscopic Left Pneumonectomy. Thorac Cardiovasc Surg. 2019 Mar;67(2):137–41. doi: 10.1055/s-0038-1642618. PMID: 29715708. Exclusion Code: X3.29715708
1861 Xu H, Zhang L. The Bronchus First and Vessels Simultaneously Stapled Technique: A Safe and Simple Method for Video-Assisted Right Upper Lobe Lobectomy. Thorac Cardiovasc Surg. 2019 Mar;67(2):131–6. doi: 10.1055/s-0037-1620276. PMID: 29381881. Exclusion Code: X3.29381881
1862 Xu N, Wang M, Zhu Z, . Integrated positron emission tomography and computed tomography in preoperative lymph node staging of non-small cell lung cancer. Chin Med J (Engl). 2014;127(4):607–13. PMID: 24534208. Exclusion Code: X3.24534208
1863 Xu Y, Sun H, Zhang Z, . Assessment of relationship between CT features and serum tumor marker index in early-stage lung adenocarcinoma. Acad Radiol. 2016 Nov;23(11):1342–8. doi: 10.1016/j.acra.2016.06.005. PMID: 27426977. Exclusion Code: X3.27426977
1864 Yaffe D, Koslow M, Haskiya H, . A novel technique for CT-guided transthoracic biopsy of lung lesions: improved biopsy accuracy and safety. Eur Radiol. 2015 Nov;25(11):3354–60. doi: 10.1007/s00330-015-3750-z. PMID: 25903714. Exclusion Code: X3.25903714
1865 Yaffe D, Shitrit D, Gottfried M, . Ipsilateral opposite-side aspiration in resistant pneumothorax after CT image guided lung biopsy: complementary role after simple needle aspiration. Chest. 2013 Sep;144(3):947–51. doi: 10.1378/chest.12-2790. PMID: 23681216. Exclusion Code: X3.23681216
1866 Yamagami T, Yoshimatsu R, Miura H, . Diagnostic performance of percutaneous lung biopsy using automated biopsy needles under CT-fluoroscopic guidance for ground-glass opacity lesions. Br J Radiol. 2013 Feb;86(1022):20120447. doi: 10.1259/bjr.20120447. PMID: 23385998. Exclusion Code: X3.23385998
1867 Yamaguchi M, Furuya A, Edagawa M, . How should we manage small focal pure ground-glass opacity nodules on high-resolution computed tomography? A single institute experience. Surg Oncol. 2015 Sep;24(3):258–63. doi: 10.1016/j.suronc.2015.08.004. PMID: 26298200. Exclusion Code: X3.26298200
1868 Yamamoto T, Jingu K, Shirata Y, . Outcomes after stereotactic body radiotherapy for lung tumors, with emphasis on comparison of primary lung cancer and metastatic lung tumors. BMC Cancer. 2014 Jun 23;14:464. doi: 10.1186/1471-2407-14-464. PMID: 24957478. Exclusion Code: X3.24957478
1869 Yamamoto T, Kadoya N, Morishita Y, . Assessment and agreement of the CT appearance pattern and its severity grading of radiation-induced lung injury after stereotactic body radiotherapy for lung cancer. PLoS One. 2018;13(10):e0204734. doi: 10.1371/journal.pone.0204734. PMID: 30286105. Exclusion Code: X3.30286105
1870 Yamamoto T, Kadoya N, Sato Y, . Prognostic Value of Radiation Pneumonitis After Stereotactic Body Radiotherapy: Effect of Pulmonary Emphysema Quantitated Using CT Images. Clin Lung Cancer. 2018 Jan;19(1):e85–e90. doi: 10.1016/j.cllc.2017.05.022. PMID: 28655592. Exclusion Code: X3.28655592
1871 Yamamoto T, Kadoya N, Shirata Y, . Formula corrected maximal standardized uptake value in FDG-PET for partial volume effect and motion artifact is not a prognostic factor in stage I non-small cell lung cancer treated with stereotactic body radiotherapy. Ann Nucl Med. 2015 Oct;29(8):666–73. doi: 10.1007/s12149-015-0991-5. PMID: 26040413. Exclusion Code: X10.26040413
1872 Yamamoto T, Kadoya N, Shirata Y, . Impact of tumor attachment to the pleura measured by a pretreatment CT image on outcome of stage I NSCLC treated with stereotactic body radiotherapy. Radiat Oncol. 2015 Feb 7;10:35. doi: 10.1186/s13014-015-0343-6. PMID: 25886315. Exclusion Code: X10.25886315
1873 Yamamoto T, Suzuki H, Nagato K, . Is left upper lobectomy for lung cancer a risk factor for cerebral infarction? Surg Today. 2016 Jul;46(7):780–4. doi: 10.1007/s00595-015-1233-0. PMID: 26272485. Exclusion Code: X3.26272485
1874 Yamanashi K, Okumura N, Yamamoto Y, . Adjuvant chemotherapy for elderly patients with non-small-cell lung cancer. Asian Cardiovasc Thorac Ann. 2017 Jun;25(5):371–7. doi: 10.1177/0218492317714669. PMID: 28592139. Exclusion Code: X6.28592139
1875 Yamao Y, Yamakado K, Takaki H, . CT-fluoroscopy in chest interventional radiology: sliding scale of imaging parameters based on radiation exposure dose and factors increasing radiation exposure dose. Clin Radiol. 2013 Feb;68(2):162–6. doi: 10.1016/j.crad.2012.05.020. PMID: 22906574. Exclusion Code: X3.22906574
1876 Yamashita S, Tokuishi K, Anami K, . Thoracoscopic segmentectomy for T1 classification of non-small cell lung cancer: a single center experience. Eur J Cardiothorac Surg. 2012 Jul;42(1):83–8. doi: 10.1093/ejcts/ezr254. PMID: 22228839. Exclusion Code: X11.22228839
1877 Yamashita Y, Mukaida H, Harada H, . Post-thoracotomy pain and long-term survival associated with video-assisted thoracic surgery lobectomy methods for clinical T1N0 lung cancer: a patient-oriented, prospective cohort study. Eur J Cardiothorac Surg. 2013 Jul;44(1):e71–6. doi: 10.1093/ejcts/ezt107. PMID: 23509236. Exclusion Code: X11.23509236
1878 Yan B, Zhang W, Lu F, . Safety of polyethylene glycol recombinant human granulocyte colony-stimulating factor in treating non-small cell lung cancer patients at I b stage. Asian Pac J Trop Med. 2013 Nov;6(11):912–5. doi: 10.1016/s1995-7645(13)60163-7. PMID: 24083590. Exclusion Code: X6.24083590
1879 Yan S, Qian W, Guan Y, . Improving lung cancer prognosis assessment by incorporating synthetic minority oversampling technique and score fusion method. Med Phys. 2016 Jun;43(6):2694–703. doi: 10.1118/1.4948499. PMID: 27277016. Exclusion Code: X4.27277016
1880 Yanagawa M, Honda O, Kikuyama A, . Pulmonary nodules: effect of adaptive statistical iterative reconstruction (ASIR) technique on performance of a computer-aided detection (CAD) system-comparison of performance between different-dose CT scans. Eur J Radiol. 2012 Oct;81(10):2877–86. doi: 10.1016/j.ejrad.2011.09.011. PMID: 21982461. Exclusion Code: X3.21982461
1881 Yanagawa N, Shiono S, Abiko M, . Positive intraoperative pleural lavage cytology is a predictive marker of disease recurrence in stage I lung adenocarcinoma. Interact Cardiovasc Thorac Surg. 2014 May;18(5):621–5. doi: 10.1093/icvts/ivu015. PMID: 24532312. Exclusion Code: X11.24532312
1882 Yang B, Jhun BW, Shin SH, . Comparison of four models predicting the malignancy of pulmonary nodules: A single-center study of Korean adults. PLoS One. 2018;13(7):e0201242. doi: 10.1371/journal.pone.0201242. PMID: 30063725. Exclusion Code: X3.30063725
1883 Yang CC, Fong Y, Lin LC, . The age-adjusted Charlson comorbidity index is a better predictor of survival in operated lung cancer patients than the Charlson and Elixhauser comorbidity indices. Eur J Cardiothorac Surg. 2018 Jan 1;53(1):235–40. doi: 10.1093/ejcts/ezx215. PMID: 29106506. Exclusion Code: X3.29106506
1884 Yang CJ, Wang H, Kumar A, . Impact of timing of lobectomy on survival for clinical stage IA lung squamous cell carcinoma. Chest. 2017 Dec;152(6):1239–50. doi: 10.1016/j.chest.2017.07.032. PMID: 28800867. Exclusion Code: X3.28800867
1885 Yang DW, Zhang Y, Hong QY, . Role of a serum-based biomarker panel in the early diagnosis of lung cancer for a cohort of high-risk patients. Cancer. 2015 Sep 1;121 Suppl 17:3113–21. doi: 10.1002/cncr.29551. PMID: 26331818. Exclusion Code: X4.26331818
1886 Yang H, Sun Y, Yao F, . Surgical therapy for bilateral multiple primary lung cancer. Ann Thorac Surg. 2016 Mar;101(3):1145–52. doi: 10.1016/j.athoracsur.2015.09.028. PMID: 26602007. Exclusion Code: X11.26602007
1887 Yang HX, Woo KM, Sima CS, . Long-term survival based on the surgical approach to lobectomy for clinical stage I nonsmall cell lung cancer: comparison of robotic, video-assisted thoracic surgery, and thoracotomy lobectomy. Ann Surg. 2017 Feb;265(2):431–7. doi: 10.1097/sla.0000000000001708. PMID: 28059973. Exclusion Code: X11.28059973
1888 Yang J, Lin J, Liu T, . Analysis of lncRNA expression profiles in non-small cell lung cancers (NSCLC) and their clinical subtypes. Lung Cancer. 2014 Aug;85(2):110–5. doi: 10.1016/j.lungcan.2014.05.011. PMID: 24906504. Exclusion Code: X5.24906504
1889 Yang J, Xu T, Gomez DR, . Polymorphisms in BMP2/BMP4, with estimates of mean lung dose, predict radiation pneumonitis among patients receiving definitive radiotherapy for non-small cell lung cancer. Oncotarget. 2017 Jun 27;8(26):43080–90. doi: 10.18632/oncotarget.17904. PMID: 28574846. Exclusion Code: X3.28574846
1890 Yang P, Wang Y, Wampfler JA, . Trends in Subpopulations at High Risk for Lung Cancer. J Thorac Oncol. 2016 Feb;11(2):194–202. doi: 10.1016/j.jtho.2015.10.016. PMID: 26811226. Exclusion Code: X3.26811226
1891 Yang R, Jiao W, Zhao Y, . Lymph node evaluation in totally thoracoscopic lobectomy with two-port for clinical early-stage nonsmall-cell lung cancer: Single-center experience of 1086 cases. Indian J Cancer. 2015 Dec;52: Suppl 2:e134–9. doi: 10.4103/0019-509x.172511. PMID: 26728672. Exclusion Code: X10.26728672
1892 Yang SC, Lai WW, Lin CC, . Cost-effectiveness of implementing computed tomography screening for lung cancer in Taiwan. Lung Cancer. 2017 Jun;108:183–91. doi: 10.1016/j.lungcan.2017.04.001. PMID: 28625633. Exclusion Code: X8.28625633
1893 Yang W, Qian F, Teng J, . Community-based lung cancer screening with low-dose CT in China: results of the baseline screening. Lung Cancer. 2018 Mar;117:20–6. doi: 10.1016/j.lungcan.2018.01.003. PMID: 29496251. Exclusion Code: X14.29496251
1894 Yang W, Sun W, Li Q, . Diagnostic accuracy of CT-guided transthoracic needle biopsy for solitary pulmonary nodules. PLoS One. 2015;10(6):e0131373. doi: 10.1371/journal.pone.0131373. PMID: 26110775. Exclusion Code: X3.26110775
1895 Yang X, Ye X, Zheng A, . Percutaneous microwave ablation of stage I medically inoperable non-small cell lung cancer: clinical evaluation of 47 cases. J Surg Oncol. 2014 Nov;110(6):758–63. doi: 10.1002/jso.23701. PMID: 24965604. Exclusion Code: X6.24965604
1896 Yang Y, Zhou Z, Niu XM, . Clinical analysis of postoperative venous thromboembolism risk factors in lung cancer patients. J Surg Oncol. 2012 Nov;106(6):736–41. doi: 10.1002/jso.23190. PMID: 22711667. Exclusion Code: X11.22711667
1897 Yano M, Yoshida J, Koike T, . Survival of 1737 lobectomy-tolerable patients who underwent limited resection for cStage IA non-small-cell lung cancer. Eur J Cardiothorac Surg. 2015 Jan;47(1):135–42. doi: 10.1093/ejcts/ezu138. PMID: 24699203. Exclusion Code: X10.24699203
1898 Yano T, Kawashima O, Takeo S, . A Prospective Observational Study of Pulmonary Resection for Non-small Cell Lung Cancer in Patients Older Than 75 Years. Semin Thorac Cardiovasc Surg. 2017 Winter;29(4):540–7. doi: 10.1053/j.semtcvs.2017.05.004. PMID: 29698655. Exclusion Code: X3.29698655
1899 Yano T, Shimokawa M, Kawashima O, . The influence of comorbidity on the postoperative survival in elderly (>/= 75 years old) with lung cancer. Gen Thorac Cardiovasc Surg. 2018 Jun;66(6):344–50. doi: 10.1007/s11748-018-0919-9. PMID: 29616463. Exclusion Code: X3.29616463
1900 Yao F, Wang J, Yao J, . Three-dimensional image reconstruction with free open-source OsiriX software in video-assisted thoracoscopic lobectomy and segmentectomy. Int J Surg. 2017 Mar;39:16–22. doi: 10.1016/j.ijsu.2017.01.079. PMID: 28115296. Exclusion Code: X11.28115296
1901 Yao F, Wang J, Yao J, . Early Experience with Video-Assisted Thoracoscopic Anatomic Segmentectomy. J Laparoendosc Adv Surg Tech A. 2018 Jul;28(7):819–26. doi: 10.1089/lap.2017.0680. PMID: 29424636. Exclusion Code: X11.29424636
1902 Yao F, Wang J, Yao J, . Reevaluation of the efficacy of preoperative computed tomography-guided hook wire localization: A retrospective analysis. Int J Surg. 2018 Mar;51:24–30. doi: 10.1016/j.ijsu.2018.01.014. PMID: 29367030. Exclusion Code: X3.29367030
1903 Yao W, Lu M, Fan W, . Comparison between microwave ablation and lobectomy for stage I non-small cell lung cancer: a propensity score analysis. Int J Hyperthermia. 2018 Dec;34(8):1329–36. doi: 10.1080/02656736.2018.1434901. PMID: 29378462. Exclusion Code: X11.29378462
1904 Yasaka K, Katsura M, Hanaoka S, . High-resolution CT with new model-based iterative reconstruction with resolution preference algorithm in evaluations of lung nodules: Comparison with conventional model-based iterative reconstruction and adaptive statistical iterative reconstruction. Eur J Radiol. 2016 Mar;85(3):599–606. doi: 10.1016/j.ejrad.2016.01.001. PMID: 26860673. Exclusion Code: X3.26860673
1905 Ye B, Cheng M, Ge XX, . Factors that predict lymph node status in clinical stage T1aN0M0 lung adenocarcinomas. World J Surg Oncol. 2014 Feb 21;12:42. doi: 10.1186/1477-7819-12-42. PMID: 24559138. Exclusion Code: X8.24559138
1906 Ye B, Cheng M, Li W, . Predictive factors for lymph node metastasis in clinical stage IA lung adenocarcinoma. Ann Thorac Surg. 2014 Jul;98(1):217–23. doi: 10.1016/j.athoracsur.2014.03.005. PMID: 24841547. Exclusion Code: X8.24841547
1907 Yeginsu A, Vayvada M, Karademir BC, . Combined Off-Pump Coronary Artery Bypass Grafting and Lung Resection in Patients with Lung Cancer Accompanied by Coronary Artery Disease. Braz J Cardiovasc Surg. 2018 Sep-Oct;33(5):483–9. doi: 10.21470/1678-9741-2018-0126. PMID: 30517257. Exclusion Code: X3.30517257
1908 Yegya-Raman N, Kim S, Deek MP, . Daily Image Guidance With Cone Beam Computed Tomography May Reduce Radiation Pneumonitis in Unresectable Non-Small Cell Lung Cancer. Int J Radiat Oncol Biol Phys. 2018 Aug 1;101(5):1104–12. doi: 10.1016/j.ijrobp.2018.03.025. PMID: 29730063. Exclusion Code: X3.29730063
1909 Yegya-Raman N, Reyhan M, Kim S, . Association of Target Volume Margins With Locoregional Control and Acute Toxicities for Non-small cell lung cancer Treated With Concurrent Chemoradiation Therapy. Pract Radiat Oncol. 2019 Jan;9(1):e74–e82. doi: 10.1016/j.prro.2018.08.007. PMID: 30144583. Exclusion Code: X3.30144583
1910 Yendamuri S, Battoo A, Attwood K, . Concomitant Mediastinoscopy Increases the Risk of Postoperative Pneumonia After Pulmonary Lobectomy. Ann Surg Oncol. 2018 May;25(5):1269–76. doi: 10.1245/s10434-018-6397-6. PMID: 29488189. Exclusion Code: X3.29488189
1911 Yendamuri S, Battoo A, Dy G, . Transcervical extended mediastinal lymphadenectomy: experience from a North American cancer center. Ann Thorac Surg. 2017 Nov;104(5):1644–9. doi: 10.1016/j.athoracsur.2017.05.022. PMID: 28942077. Exclusion Code: X3.28942077
1912 Yendamuri S, Sharma R, Demmy M, . Temporal trends in outcomes following sublobar and lobar resections for small (</= 2 cm) non-small cell lung cancers--a Surveillance Epidemiology End Results database analysis. J Surg Res. 2013 Jul;183(1):27–32. doi: 10.1016/j.jss.2012.11.052. PMID: 23260233. Exclusion Code: X8.23260233
1913 Yeo J, Crawford EL, Zhang X, . A lung cancer risk classifier comprising genome maintenance genes measured in normal bronchial epithelial cells. BMC Cancer. 2017 May 2;17(1):301. doi: 10.1186/s12885-017-3287-4. PMID: 28464886. Exclusion Code: X5.28464886
1914 Yi CA, Lee KS, Lee HY, . Coregistered whole body magnetic resonance imaging-positron emission tomography (MRI-PET) versus PET-computed tomography plus brain MRI in staging resectable lung cancer: comparisons of clinical effectiveness in a randomized trial. Cancer. 2013 May 15;119(10):1784–91. doi: 10.1002/cncr.28000. PMID: 23423920. Exclusion Code: X3.23423920
1915 Yi E, Bae MK, Cho S, . Pathological prognostic factors of recurrence in early stage lung adenocarcinoma. ANZ J Surg. 2018 Apr;88(4):327–31. doi: 10.1111/ans.14033. PMID: 28702948. Exclusion Code: X11.28702948
1916 Yildirim D, Tamam M, Sanli Y, . Virtual bronchoscopy using FDG-PET/CT images for the evaluation of lung cancer. Eur Rev Med Pharmacol Sci. 2012 Dec;16(14):1951–60. PMID: 23242722. Exclusion Code: X8.23242722
1917 Yilmaz A, Uskul TB, Bayramgurler B, . Cell type accuracy of transthoracic fine needle aspiration material in primary lung cancer. Respirology. 2001 Jun;6(2):91–4. PMID: 11422887. Exclusion Code: X3.11422887
1918 Yip PY, Cooper WA, Kohonen-Corish MR, . Phosphorylated Akt expression is a prognostic marker in early-stage non-small cell lung cancer. J Clin Pathol. 2014 Apr;67(4):333–40. doi: 10.1136/jclinpath-2013-201870. PMID: 24265323. Exclusion Code: X11.24265323
1919 Yip R, Henschke CI, Yankelevitz DF, . The impact of the regimen of screening on lung cancer cure: a comparison of I-ELCAP and NLST. Eur J Cancer Prev. 2015 May;24(3):201–8. doi: 10.1097/cej.0000000000000065. PMID: 25089376. Exclusion Code: X7.25089376
1920 Yip R, Yankelevitz DF, Hu M, . Lung cancer deaths in the National Lung Screening Trial attributed to nonsolid nodules. Radiology. 2016 Nov;281(2):589–96. doi: 10.1148/radiol.2016152333. PMID: 27378239. Exclusion Code: X3.27378239
1921 Yong JR, Qi S, van Triest HJ, . Automatic segmentation of juxta-pleural tumors from CT images based on morphological feature analysis. Biomed Mater Eng. 2014;24(6):3137–44. doi: 10.3233/bme-141136. PMID: 25227023. Exclusion Code: X3.25227023
1922 Yoo SS, Jin C, Jung DK, . Putative functional variants of XRCC1 identified by RegulomeDB were not associated with lung cancer risk in a Korean population. Cancer Genet. 2015 Jan-Feb;208(1-2):19–24. doi: 10.1016/j.cancergen.2014.11.004. PMID: 25592768. Exclusion Code: X3.25592768
1923 Yoon HJ, Chung MJ, Hwang HS, . Adaptive statistical iterative reconstruction-applied ultra-low-dose CT with radiography-comparable radiation dose: usefulness for lung nodule detection. Korean J Radiol. 2015 Sep-Oct;16(5):1132–41. doi: 10.3348/kjr.2015.16.5.1132. PMID: 26357505. Exclusion Code: X6.26357505
1924 Yoshida J, Ishii G, Hishida T, . Limited resection trial for pulmonary ground-glass opacity nodules: case selection based on high-resolution computed tomography-interim results. Jpn J Clin Oncol. 2015 Jul;45(7):677–81. doi: 10.1093/jjco/hyv057. PMID: 25900903. Exclusion Code: X11.25900903
1925 Yoshida Y, Kage H, Murakawa T, . Worse prognosis for stage IA lung cancer patients with smoking history and more severe chronic obstructive pulmonary disease. Ann Thorac Cardiovasc Surg. 2015;21(3):194–200. doi: 10.5761/atcs.oa.14-00200. PMID: 25641032. Exclusion Code: X11.25641032
1926 Yoshida Y, Murayama T, Sato Y, . Gender differences in long-term survival after surgery for non-small cell lung cancer. Thorac Cardiovasc Surg. 2016 Sep;64(6):507–14. doi: 10.1055/s-0035-1558995. PMID: 26366891. Exclusion Code: X3.26366891
1927 Yoshimatsu R, Yamagami T, Tanaka O, . Comparison of fully automated and semi-automated biopsy needles for lung biopsy under CT fluoroscopic guidance. Br J Radiol. 2012 Mar;85(1011):208–13. doi: 10.1259/bjr/15132704. PMID: 21828150. Exclusion Code: X3.21828150
1928 Yoshitake T, Nakamura K, Shioyama Y, . Stereotactic body radiation therapy for stage I non-small cell lung cancer patients with chronic respiratory insufficiency requiring domiciliary oxygen therapy. Anticancer Res. 2012 Sep;32(9):4041–4. PMID: 22993357. Exclusion Code: X10.22993357
1929 Young RP, Hopkins RJ. A review of the Hispanic paradox: time to spill the beans? Eur Respir Rev. 2014 Dec;23(134):439–49. doi: 10.1183/09059180.00000814. PMID: 25445942. Exclusion Code: X6.25445942
1930 Young RP, Hopkins RJ, Hay BA, . Lung cancer susceptibility model based on age, family history and genetic variants. PLoS One. 2009;4(4):e5302. doi: 10.1371/journal.pone.0005302. PMID: 19390575. Exclusion Code: X7.19390575
1931 Yousaf-Khan U, van der Aalst C, de Jong PA, . Final screening round of the NELSON lung cancer screening trial: the effect of a 2.5-year screening interval. Thorax. 2017 Jan;72(1):48–56. doi: 10.1136/thoraxjnl-2016-208655. PMID: 27364640. Exclusion Code: X17.27364640
1932 Yu V, Kishan AU, Cao M, . Dose impact in radiographic lung injury following lung SBRT: statistical analysis and geometric interpretation. Med Phys. 2014 Mar;41(3):031701. doi: 10.1118/1.4863483. PMID: 24593705. Exclusion Code: X3.24593705
1933 Yu X, Li Y, Shi C, . Risk factors of lymph node metastasis in patients with non-small cell lung cancer </= 2 cm in size: A monocentric population-based analysis. Thorac Cancer. 2018 Jan;9(1):3–9. doi: 10.1111/1759-7714.12490. PMID: 29034994. Exclusion Code: X10.29034994
1934 Yu YC, Hsu PK, Yeh YC, . Surgical results of synchronous multiple primary lung cancers: similar to the stage-matched solitary primary lung cancers? Ann Thorac Surg. 2013 Dec;96(6):1966–74. doi: 10.1016/j.athoracsur.2013.04.142. PMID: 24021769. Exclusion Code: X3.24021769
1935 Yuan ST, Brown RK, Zhao L, . Timing and intensity of changes in FDG uptake with symptomatic esophagitis during radiotherapy or chemo-radiotherapy. Radiat Oncol. 2014 Jan 27;9(1):37. doi: 10.1186/1748-717x-9-37. PMID: 24467939. Exclusion Code: X3.24467939
1936 Yuan X, Zhang J, Quan C, . Differentiation of malignant and benign pulmonary nodules with first-pass dual-input perfusion CT. Eur Radiol. 2013 Sep;23(9):2469–74. doi: 10.1007/s00330-013-2842-x. PMID: 23793548. Exclusion Code: X3.23793548
1937 Yuan Y, Matsumoto T, Hiyama A, . Role of high-resolution CT in the diagnosis of small pulmonary nodules coexisting with potentially operable lung cancer. Radiat Med. 2002 Sep-Oct;20(5):237–45. PMID: 12450103. Exclusion Code: X3.12450103
1938 Yun JK, Kim MA, Choi CM, . Surgical Outcomes after Pulmonary Resection for Non-Small Cell Lung Cancer with Localized Pleural Seeding First Detected during Surgery. Thorac Cardiovasc Surg. 2018 Mar;66(2):142–9. doi: 10.1055/s-0035-1564928. PMID: 26669768. Exclusion Code: X3.26669768
1939 Yung RC, Zeng MY, Stoddard GJ, . Transcutaneous computed bioconductance measurement in lung cancer: a treatment enabling technology useful for adjunctive risk stratification in the evaluation of suspicious pulmonary lesions. J Thorac Oncol. 2012 Apr;7(4):681–9. doi: 10.1097/JTO.0b013e31824a8dcd. PMID: 22425917. Exclusion Code: X3.22425917
1940 Zanon M, Pacini GS, de Souza VVS, . Early detection of lung cancer using ultra-low-dose computed tomography in coronary CT angiography scans among patients with suspected coronary heart disease. Lung Cancer. 2017 Dec;114:1–5. doi: 10.1016/j.lungcan.2017.10.004. PMID: 29173759. Exclusion Code: X3.29173759
1941 Zehentmayr F, Wurstbauer K, Deutschmann H, . DART-bid: dose-differentiated accelerated radiation therapy, 1.8 Gy twice daily: high local control in early stage (I/II) non-small-cell lung cancer. Strahlenther Onkol. 2015 Mar;191(3):256–63. doi: 10.1007/s00066-014-0754-6. PMID: 25245469. Exclusion Code: X3.25245469
1942 Zeliadt SB, Hoffman RM, Birkby G, . Challenges implementing lung cancer screening in federally qualified health centers. Am J Prev Med. 2018 Apr;54(4):568–75. doi: 10.1016/j.amepre.2018.01.001. PMID: 29429606. Exclusion Code: X8.29429606
1943 Zeng Q, Liu M, Zhou N, . Serum human epididymis protein 4 (HE4) may be a better tumor marker in early lung cancer. Clin Chim Acta. 2016 Apr 1;455:102–6. doi: 10.1016/j.cca.2016.02.002. PMID: 26851650. Exclusion Code: X3.26851650
1944 Zer A, Domachevsky L, Rapson Y, . The Role of 18F-FDG PET/CT on staging and prognosis in patients with small cell lung cancer. Eur Radiol. 2016 Sep;26(9):3155–61. doi: 10.1007/s00330-015-4132-2. PMID: 26685851. Exclusion Code: X3.26685851
1945 Zhang B, Lee SW, Chen S, . Action Levels on Dose and Anatomic Variation for Adaptive Radiation Therapy Using Daily Offline Plan Evaluation: Preliminary Results. Pract Radiat Oncol. 2019 Jan;9(1):49–54. doi: 10.1016/j.prro.2018.08.006. PMID: 30142442. Exclusion Code: X6.30142442
1946 Zhang C, Yu H, Li X, . Diagnostic value of computed tomography scanning in differentiating malignant from benign solitary pulmonary nodules: a meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):8551–8. PMID: DARE-12014034768. Exclusion Code: X9.
1947 Zhang F, Ying L, Jin J, . The C-reactive protein/albumin ratio predicts long-term outcomes of patients with operable non-small cell lung cancer. Oncotarget. 2017 Jan 31;8(5):8835–42. doi: 10.18632/oncotarget.13053. PMID: 27823974. Exclusion Code: X3.27823974
1948 Zhang G, Zou L, Xu H. Anodic alumina coating for extraction of volatile organic compounds in human exhaled breath vapor. Talanta. 2015 Jan;132:528–34. doi: 10.1016/j.talanta.2014.09.035. PMID: 25476340. Exclusion Code: X5.25476340
1949 Zhang H, Gao S, Chen B, . Comparison of the accuracy of <sup>99m</sup>Tc-3P<inf>4</inf>-RGD<inf>2</inf> SPECT and CT in diagnosing solitary pulmonary nodules. Oncol Lett. 2016;12(4):2517–23. doi: 10.3892/ol.2016.5030. PMID: CN-01211975. Exclusion Code: X3.27698821
1950 Zhang J, Li B, Ding X, . Genetic variants in inducible nitric oxide synthase gene are associated with the risk of radiation-induced lung injury in lung cancer patients receiving definitive thoracic radiation. Radiother Oncol. 2014 May;111(2):194–8. doi: 10.1016/j.radonc.2014.03.001. PMID: 24746566. Exclusion Code: X6.24746566
1951 Zhang J, Xu J, Lu H, . Altered phosphatidylcholines expression in sputum for diagnosis of non-small cell lung cancer. Oncotarget. 2016 Sep 27;7(39):63158–65. doi: 10.18632/oncotarget.11283. PMID: 27542233. Exclusion Code: X5.27542233
1952 Zhang J, Xue ZQ, Chu XY, . Surgical treatment and prognosis of octogenarians with non-small cell lung cancer. Asian Pac J Trop Med. 2012 Jun;5(6):465–8. doi: 10.1016/s1995-7645(12)60079-0. PMID: 22575979. Exclusion Code: X3.22575979
1953 Zhang L, Ren Y, Liu Y. Comparison of the effects of lobectomy on immunologic function between video-assisted thoracoscopic surgery and traditional open surgery for non-small-cell lung cancer. Am J Ther. 2016 Nov/Dec;23(6):e1406–e13. doi: 10.1097/mjt.0000000000000254. PMID: 25909924. Exclusion Code: X3.25909924
1954 Zhang M, Yoshizawa A, Kawakami S, . The histological characteristics and clinical outcomes of lung cancer in patients with combined pulmonary fibrosis and emphysema. Cancer Med. 2016 Oct;5(10):2721–30. doi: 10.1002/cam4.858. PMID: 27546810. Exclusion Code: X3.27546810
1955 Zhang R, Kyriss T, Dippon J, . American Society of Anesthesiologists physical status facilitates risk stratification of elderly patients undergoing thoracoscopic lobectomy. Eur J Cardiothorac Surg. 2018 May 1;53(5):973–9. doi: 10.1093/ejcts/ezx436. PMID: 29228138. Exclusion Code: X11.29228138
1956 Zhang S, Liu Y. Computer-based three-dimensional reconstruction of lung cancer using 64-slice CT scanning data and virtual surgery. Nan fang yi ke da xue xue bao [Journal of Southern Medical University]. 2016;36(4):562–6. PMID: CN-01167967. Exclusion Code: X1.
1957 Zhang X, Zhang F, Qiao W, . Low Hematocrit Is a Strong Predictor of Poor Prognosis in Lung Cancer Patients. Biomed Res Int. 2018;2018:6804938. doi: 10.1155/2018/6804938. PMID: 30417013. Exclusion Code: X3.30417013
1958 Zhang Y, Elgizouli M, Schottker B, . Smoking-associated DNA methylation markers predict lung cancer incidence. Clin Epigenetics. 2016;8:127. doi: 10.1186/s13148-016-0292-4. PMID: 27924164. Exclusion Code: X7.27924164
1959 Zhang Y, Ma Y, Li Y, . Are exon 19 deletions and L858R different in early stage lung adenocarcinoma? J Cancer Res Clin Oncol. 2018 Jan;144(1):165–71. doi: 10.1007/s00432-017-2526-z. PMID: 29026990. Exclusion Code: X3.29026990
1960 Zhang Y, Schottker B, Ordonez-Mena J, . F2RL3 methylation, lung cancer incidence and mortality. Int J Cancer. 2015 Oct 1;137(7):1739–48. doi: 10.1002/ijc.29537. PMID: 25821117. Exclusion Code: X7.25821117
1961 Zhang Y, Sun Y, Chen H. A propensity score matching analysis of survival following segmentectomy or wedge resection in early-stage lung invasive adenocarcinoma or squamous cell carcinoma. Oncotarget. 2016 Mar 22;7(12):13880–5. doi: 10.18632/oncotarget.7284. PMID: 26871600. Exclusion Code: X8.26871600
1962 Zhang Y, Zhang L, Li R, . Genetic variations in cancer-related significantly mutated genes and lung cancer susceptibility. Ann Oncol. 2017 Jul 1;28(7):1625–30. doi: 10.1093/annonc/mdx161. PMID: 28383694. Exclusion Code: X7.28383694
1963 Zhang Z, Feng H, Xiao F, . Limited resection in clinical stage I non-small cell lung cancer patients aged 75 years old or more: a meta-analysis. Ann Transl Med. 2018 Sep;6(18):359. doi: 10.21037/atm.2018.08.35. PMID: 30370286. Exclusion Code: X9.30370286
1964 Zhang Z, Gao S, Mao Y, . Surgical outcomes of synchronous multiple primary non-small cell lung cancers. Sci Rep. 2016 Jun 2;6:23252. doi: 10.1038/srep23252. PMID: 27254665. Exclusion Code: X11.27254665
1965 Zhao B, James LP, Moskowitz CS, . Evaluating variability in tumor measurements from same-day repeat CT scans of patients with non-small cell lung cancer. Radiology. 2009 Jul;252(1):263–72. doi: 10.1148/radiol.2522081593. PMID: 19561260. Exclusion Code: X3.19561260
1966 Zhao DP, Yang CL, Zhou X, . Association between CLPTM1L polymorphisms (rs402710 and rs401681) and lung cancer susceptibility: evidence from 27 case-control studies. Mol Genet Genomics. 2014 Oct;289(5):1001–12. doi: 10.1007/s00438-014-0868-7. PMID: 24907075. Exclusion Code: X3.24907075
1967 Zhao H, Marshall HM, Yang IA, . Screen-detected subsolid pulmonary nodules: long-term follow-up and application of the PanCan lung cancer risk prediction model. Br J Radiol. 2016;89(1060):20160016. doi: 10.1259/bjr.20160016. PMID: 26882046. Exclusion Code: X8.26882046
1968 Zhao L, Tong L, Lin J, . Characterization of solitary pulmonary nodules with 18F-FDG PET/CT relative activity distribution analysis. Eur Radiol. 2015 Jul;25(7):1837–44. doi: 10.1007/s00330-015-3592-8. PMID: 25636419. Exclusion Code: X3.25636419
1969 Zhao S, Jiang T, Zhang L, . Clinicopathological and prognostic significance of regulatory T cells in patients with non-small cell lung cancer: A systematic review with meta-analysis. Oncotarget. 2016 Jun 14;7(24):36065–73. doi: 10.18632/oncotarget.9130. PMID: 27153545. Exclusion Code: X3.27153545
1970 Zhao W, Wang H, Xie J, . A Clinicopathological Study of Small Lung Adenocarcinoma 1 cm or Less in Size: Emphasis on Histological Subtypes Associated With Lymph Node Metastasis and Recurrence. Int J Surg Pathol. 2018 Feb;26(1):4–11. doi: 10.1177/1066896917721649. PMID: 28805108. Exclusion Code: X3.28805108
1971 Zhao X, Qian L, Luo Q, . Segmentectomy as a safe and equally effective surgical option under complete video-assisted thoracic surgery for patients of stage I non-small cell lung cancer. J Cardiothorac Surg. 2013 Apr 29;8:116. doi: 10.1186/1749-8090-8-116. PMID: 23628209. Exclusion Code: X11.23628209
1972 Zhao Y, de Bock GH, Vliegenthart R, . Performance of computer-aided detection of pulmonary nodules in low-dose CT: comparison with double reading by nodule volume. Eur Radiol. 2012 Oct;22(10):2076–84. doi: 10.1007/s00330-012-2437-y. PMID: 22814824. Exclusion Code: X11.22814824
1973 Zhao ZR, Xi SY, Li W, . Prognostic impact of pattern-based grading system by the new IASLC/ATS/ERS classification in Asian patients with stage I lung adenocarcinoma. Lung Cancer. 2015 Dec;90(3):604–9. doi: 10.1016/j.lungcan.2015.10.026. PMID: 26547801. Exclusion Code: X11.26547801
1974 Zheng A, Wang X, Yang X, . Major complications after lung microwave ablation: a single-center experience on 204 sessions. Ann Thorac Surg. 2014 Jul;98(1):243–8. doi: 10.1016/j.athoracsur.2014.03.008. PMID: 24793688. Exclusion Code: X6.24793688
1975 Zheng A, Ye X, Yang X, . Local efficacy and survival after microwave ablation of lung tumors: a retrospective study in 183 patients. J Vasc Interv Radiol. 2016 Dec;27(12):1806–14. doi: 10.1016/j.jvir.2016.08.013. PMID: 27789077. Exclusion Code: X6.27789077
1976 Zheng H, Jiang S, Chen C. Stepwise tactile localization and wedge resections for deep pulmonary nodules during video-assisted thoracoscopic surgery. Thorac Cardiovasc Surg. 2016 Mar;64(2):182–6. doi: 10.1055/s-0035-1545262. PMID: 25785763. Exclusion Code: X11.25785763
1977 Zheng X, Xiong H, Li Y, . Application of quantitative autofluorescence bronchoscopy image analysis method in identifying bronchopulmonary cancer. Technol Cancer Res Treat. 2017 Aug;16(4):482–7. doi: 10.1177/1533034616656466. PMID: 27436838. Exclusion Code: X3.27436838
1978 Zheng Y, Shi A, Wang W, . Posttreatment Immune Parameters Predict Cancer Control and Pneumonitis in Stage I Non-Small-Cell Lung Cancer Patients Treated With Stereotactic Ablative Radiotherapy. Clin Lung Cancer. 2018 Jul;19(4):e399–e404. doi: 10.1016/j.cllc.2017.12.012. PMID: 29519614. Exclusion Code: X10.29519614
1979 Zhong C, Fang W, Mao T, . Comparison of thoracoscopic segmentectomy and thoracoscopic lobectomy for small-sized stage IA lung cancer. Ann Thorac Surg. 2012 Aug;94(2):362–7. doi: 10.1016/j.athoracsur.2012.04.047. PMID: 22727321. Exclusion Code: X11.22727321
1980 Zhong C, Yao F, Zhao H. Clinical outcomes of thoracoscopic lobectomy for patients with clinical N0 and pathologic N2 non-small cell lung cancer. Ann Thorac Surg. 2013 Mar;95(3):987–92. doi: 10.1016/j.athoracsur.2012.10.083. PMID: 23261117. Exclusion Code: X3.23261117
1981 Zhong Y, Xu XQ, Pan XL, . Retrospective evaluation of safety, efficacy and risk factors for pneumothorax in simultaneous localizations of multiple pulmonary nodules using hook wire system. Cardiovasc Intervent Radiol. 2017 Sep;40(9):1408–14. doi: 10.1007/s00270-017-1631-3. PMID: 28357573. Exclusion Code: X11.28357573
1982 Zhou H, Tapias LF, Gaissert HA, . Lymph node assessment and impact on survival in video-assisted thoracoscopic lobectomy or segmentectomy. Ann Thorac Surg. 2015 Sep;100(3):910–6. doi: 10.1016/j.athoracsur.2015.04.034. PMID: 26165483. Exclusion Code: X17.26165483
1983 Zhou S, Pei G, Han Y, . Sleeve lobectomy by video-assisted thoracic surgery versus thoracotomy for non-small cell lung cancer. J Cardiothorac Surg. 2015 Sep 10;10:116. doi: 10.1186/s13019-015-0318-6. PMID: 26357875. Exclusion Code: X3.26357875
1984 Zhou T, Lu H, Zhang J, . Pulmonary nodule detection model based on SVM and CT image feature-level fusion with rough sets. Biomed Res Int. 2016;2016:8052436. doi: 10.1155/2016/8052436. PMID: 27722173. Exclusion Code: X3.27722173
1985 Zhu H, Zhang L, Wang Y, . Improved image quality and diagnostic potential using ultra-high-resolution computed tomography of the lung with small scan FOV: A prospective study. PLoS One. 2017;12(2):e0172688. doi: 10.1371/journal.pone.0172688. PMID: 28231320. Exclusion Code: X3.28231320
1986 Zhu J, Zhang HP, Ni J, . Endobronchial ultrasound-guided transbronchial needle aspiration for diagnosing mediastinal lymphadenectasis: a cohort study from a single center. Clin Respir J. 2017 Mar;11(2):159–67. doi: 10.1111/crj.12317. PMID: 25918974. Exclusion Code: X3.25918974
1987 Zhuang YP, Wang HY, Zhang J, . Diagnostic accuracy and safety of CT-guided fine needle aspiration biopsy in cavitary pulmonary lesions. Eur J Radiol. 2013 Jan;82(1):182–6. doi: 10.1016/j.ejrad.2012.09.011. PMID: 23079048. Exclusion Code: X3.23079048
1988 Zimmermann M, Nickl S, Lambers C, . Discrimination of clinical stages in non-small cell lung cancer patients by serum HSP27 and HSP70: a multi-institutional case-control study. Clin Chim Acta. 2012 Jul 11;413(13-14):1115–20. doi: 10.1016/j.cca.2012.03.008. PMID: 22465083. Exclusion Code: X7.22465083
1989 Zinovev D, Duo Y, Raicu DS, . Consensus versus disagreement in imaging research: a case study using the LIDC database. J Digit Imaging. 2012 Jun;25(3):423–36. doi: 10.1007/s10278-011-9445-3. PMID: 22193755. Exclusion Code: X3.22193755