# Appendix B Additional Methods Information

## Appendix B1 Original Search Strategies and Update Searches

### Screening Searches

PubMed, 4-30-18

Search | Query | Items Found
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Lung Neoplasms”[MeSH] OR NSCLC[tiab] OR “lung cancer”[tiab] OR “lung cancers” [tiab] OR “lung-cancer”[tiab] OR “lung malignancy”[tiab] OR “lung malignancies”[tiab] OR “lung nodule”[tiab] OR “lung nodules” [tiab] OR “pulmonary nodule”[tiab] OR “pulmonary nodules”[tiab] OR “lung mass”[tiab] OR “lung masses”[tiab] OR (“Squamous Cell Carcinoma”[MeSH] OR Adenocarcinoma[MeSH]) and (Lung[MeSH] OR Lung Diseases[MeSH]))) | 209038 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mass Screening”[MeSH] OR screen*[tw] OR “Early Diagnosis”[MeSH] OR “Tomography, X-Ray Computed”[Mesh] OR “CT scan”[tiab] OR “CT scans”[tiab] OR “CAT scan”[tiab] OR “CAT scans”[tiab] OR “spiral CT”[tiab] OR “spiral computed tomography”[tiab] OR “low-dose computed tomography”[tiab] OR LDCT[tiab] OR ((early[tiab] or earlier[tiab] or earliest[tiab]) AND (detect*[tiab] or diagnos*[tiab] or discover*[tiab] or find[tiab] or finding[tiab]))) | 1561323 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 33537 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (DANTE[tiab] OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays”[All Fields] OR DLCST[tiab] OR “Danish Lung Cancer Screening Trial”[tiab] OR ITALUNG[tiab] OR “Italian Lung Cancer Screening Trial”[All Fields] OR LUSI[tiab] OR “Lung Cancer Screening Intervention”[All Fields] OR MILD[tiab] OR “Multicentric Italian Lung Detection”[All Fields] OR NELSON[tiab] OR “Dutch-Belgian Lung Cancer Screening trial”[All Fields] OR NLST[tiab] OR “National Lung Screening Trial”[All Fields]) | 306902 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #4) | 2661 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 or #5) | 35398 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 or #5) Filters: Publication date from 2012/01/01 to 2018/12/31 | 12321 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Risk prediction model”[tw] OR “Risk prediction models”[tw] OR “Risk Assessment”[MeSH] OR “risk assessment”[tw] OR “risk model”[tw] OR “risk models”[tw] OR “Decision Support Techniques”[MeSH] OR “Decision Support Systems, Clinical”[Mesh] OR “clinical prediction”[tw] OR “Logistic Models”[MeSH] OR microsimulation*[tw] OR “simulation model”[tw] OR “simulation models”[tw] OR “Assessment tool”[tw] OR “Assessment tools”[tw] OR “prediction score”[tw] OR “Risk Factors”[MeSH] OR “Predictive Value of Tests”[MeSH] OR “Sensitivity and Specificity”[MeSH] OR (Predict*[tw] AND (model*[tw] OR outcome*[tw] OR risk*[tw] OR rule[tw] OR rules[tw])) OR “risk-targeted”[tw] OR “mortality risk”[tw]) | 2073965 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #8) | 26417 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #8) Filters: Publication date from 2014/04/01 to 2018/12/31 | 6640 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) | 16840 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) Filters: Humans | 16584 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) Filters: Humans; English | 15409 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) Filters: Humans; English; Child: birth-18 years | 605 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt]) | 1642710 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#13 NOT #14) | 14804 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#16 NOT #15) | 14186 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “meta synthesis”[ti] OR “cochrane database syst rev”[ta]) | 178836 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #18) | 485 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract])) | 618965 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #20) | 462 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “Program Evaluation”[MeSH] OR “observational study”[tw] OR “observational studies”[tw] OR “Cohort Studies”[MeSH] OR “Comparative Study”[pt] OR “Validation Studies”[pt] OR “Prospective Studies”[MeSH] OR “cohort”[tw] OR “case control”[tw]) | 4054856 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #22) | 5869 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)

Cochrane Library, 5-2-2018

ID | Cochrane Library Search | Hits
#1 | [mh “Lung Neoplasms”] or NSCLC:ti,ab or “lung cancer”:ti,ab or “lung cancers”:ti,ab or “lung-cancer”:ti,ab or “lung malignancy”:ti,ab or “lung malignancies”:ti,ab or “lung nodule”:ti,ab or “lung nodules”:ti,ab or “pulmonary nodule”:ti,ab or “pulmonary nodules”:ti,ab or “lung mass”:ti,ab or “lung masses”:ti,ab or (([mh “Squamous Cell Carcinoma”] or [mh Adenocarcinoma]) and ([mh Lung] or [mh “Lung Diseases”])) | 13223
#2 | [mh “Mass Screening”] or screen*:kw or [mh “Early Diagnosis”] or [mh “Tomography, X-Ray Computed”] or “CT scan”:ti,ab or “CT scans”:ti,ab or “CAT scan”:ti,ab or “CAT scans”:ti,ab or “spiral CT”:ti,ab or “spiral computed tomography”:ti,ab or “low-dose computed tomography”:ti,ab or LDCT:ti,ab or ((early:ti,ab or earlier:ti,ab or earliest:ti,ab) and (detect*:ti,ab or diagnos*:ti,ab or discover*:ti,ab or find:ti,ab or finding:ti,ab)) | 42901
#3 | #1 and #2 | 1293
#4 | DANTE:ti,ab or “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” or DLCST:ti,ab or “Danish Lung Cancer Screening Trial”:ti,ab or ITALUNG:ti,ab or “Italian Lung Cancer Screening Trial” or LUSI:ti,ab or “Lung Cancer Screening Intervention” or MILD:ti,ab or “Multicentric Italian Lung Detection” or NELSON:ti,ab or “Dutch-Belgian Lung Cancer Screening trial” or NLST:ti,ab or “National Lung Screening Trial”:kw | 43092
#5 | #1 and #4 | 541
#6 | #3 or #5 | 1615
#7 | #6 Publication Year from 2012 to 2018 | 916
#8 | “Risk prediction model”:ti,ab,kw or “Risk prediction models”:ti,ab,kw or [mh “Risk Assessment”] or “risk assessment”:ti,ab,kw or “risk model”:ti,ab,kw or “risk models”:ti,ab,kw or [mh “Decision Support Techniques”] or [mh “Decision Support Systems, Clinical”] or “clinical prediction”:ti,ab,kw or [mh “Logistic Models”] or microsimulation*:ti,ab,kw or “simulation model”:ti,ab,kw or “simulation models”:ti,ab,kw or “Assessment tool”:ti,ab,kw or “Assessment tools”:ti,ab,kw or “prediction score”:ti,ab,kw or [mh “Risk Factors”] or [mh “Predictive Value of Tests”] or [mh “Sensitivity and Specificity”] or (Predict*:ti,ab,kw and (model*:ti,ab,kw or outcome*:ti,ab,kw or risk*:ti,ab,kw or rule:ti,ab,kw or rules:ti,ab,kw)) or “risk-targeted”:ti,ab,kw or “mortality risk”:ti,ab,kw | 102435
#9 | #1 and #8 | 1595
#10 | #9 Publication Year from 2014 to 2018 | 637
#11 | #7 or #10 | 1385
#12 | child:ti or child:ab or child:kw or children:ti or children:ab or children:kw or adolescen*:ti or adolescen*:ab or adolescen*:kw or teen:ti or teen:ab or teen:kw or teens:ti or teens:ab or teens:kw or teenage*:ti or teenage*:ab or teenage*:kw or youth:ti or youth:ab or youth:kw or youths:ti or youths:ab or youths:kw or pediatric*:ti or pediatric*:ab or pediatric*:kw or paediatric*:ti or paediatric*:ab or paediatric*:kw or boys:ti or boys:ab or boys:kw or girls:ti or girls:ti or girls:kw | 191065
#13 | #11 not #12 | 1353
#14 | #13 in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 46
#15 | “randomized controlled trial”:pt or “randomized controlled trial”:ti or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 466945
#16 | #13 and #15 | 387
#17 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-Up Studies”] or [mh “Seroepidemiologic Studies”] or “Evaluation Studies”:pt or [mh “Program Evaluation”] or “observational study” or “observational studies” or [mh “case-control studies”] or “comparative study”:pt or “validation studies”:pt or [mh “Prospective Studies”] or “cohort” or “case control” | 305186
#18 | (#13 and #17) not (#14 or #16) in Methods Studies, Technology Assessments, Economic Evaluations and Cochrane Groups | 4

### Intervention searches

PubMed, 5-1-2018

Search | Query | Items Found
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Carcinoma, Non-Small-Cell Lung”[MeSH] OR “non-small-cell lung cancer”[All Fields] OR NSCLC[tiab] OR (“non small cell”[tiab] AND lung*[tiab] AND cancer*[tiab]) OR “Carcinoma, Squamous Cell”[Mesh] OR Adenocarcinoma[MeSH] OR “Carcinoma, Large Cell”[MeSH]) | 493740 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((stag* AND (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb))) | 836529 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (((early or earlier or earliest) AND (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging))) | 880795 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 or #6) | 1496819 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 and #7) | 106951 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Margins of Excision”[Mesh] OR Pneumonectomy OR Lobectomy OR (resection* and lung*[tw])) | 38216 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 and #9) | 3942 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt]) | 1643073 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #11) | 3885 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #11) Filters: Humans | 3647 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #11) Filters: Humans; English | 2921 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #11) Filters: Publication date from 2012/01/01 to 2018/12/31; Humans; English | 1253 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #11) Filters: Publication date from 2012/01/01 to 2018/12/31; Humans; English; Child: birth-18 years | 45 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 NOT #16) | 1208 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “meta synthesis”[ti] OR “cochrane database syst rev”[ta]) | 178955 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #18) | 29 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract])) | 619155 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #20) | 41 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “Program Evaluation”[MeSH] OR “observational study”[tw] OR “observational studies”[tw] OR “Cohort Studies”[MeSH] OR “Comparative Study”[pt] OR “Validation Studies”[pt] OR “Prospective Studies”[MeSH] OR “cohort”[tw] OR “case control”[tw]) | 4056042 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #22) | 842 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)

Cochrane Library, 5-2-2018

ID | Search | Hits
#1 | [mh “Carcinoma, Non-Small-Cell Lung”] or “non-small-cell lung cancer” or NSCLC:ti,ab or (“non small cell”:ti,ab and lung*:ti,ab and cancer*:ti,ab) or [mh “Carcinoma, Squamous Cell”] or [mh Adenocarcinoma] or [mh “Carcinoma, Large Cell”] | 15389
#2 | stag* and (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb) | 62403
#3 | (early or earlier or earliest) and (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging) | 51466
#4 | #2 or #3 | 96758
#5 | #1 and #4 | 6205
#6 | ([mh “Margins of Excision”] or Pneumonectomy or Lobectomy or (resection* and lung*:ti,ab,kw)) | 2545
#7 | #5 and #6 | 540
#8 | letter:pt or newspaper article:pt or editorial:pt or comment:pt | 9229
#9 | #7 not #8 | 539
#10 | child:ti or child:ab or child:kw or children:ti or children:ab or children:kw or adolescen*:ti or adolescen*:ab or adolescen*:kw or teen:ti or teen:ab or teen:kw or teens:ti or teens:ab or teens:kw or teenage*:ti or teenage*:ab or teenage*:kw or youth:ti or youth:ab or youth:kw or youths:ti or youths:ab or youths:kw or pediatric*:ti or pediatric*:ab or pediatric*:kw or paediatric*:ti or paediatric*:ab or paediatric*:kw or boys:ti or boys:ab or boys:kw or girls:ti or girls:ti or girls:kw | 190954
#11 | #9 not #10 | 528
#12 | #11 Publication Year from 2012 to 2018, in Cochrane Reviews, Other Reviews | 30
#13 | “randomized controlled trial”:pt or “randomized controlled trial”:ti or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 466999
#14 | #11 and #13 Publication Year from 2012 to 2018 | 59
#15 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-Up Studies”] or [mh “Seroepidemiologic Studies”] or “Evaluation Studies”:pt or [mh “Program Evaluation”] or “observational study” or “observational studies” or [mh “case-control studies”] or “comparative study”:pt or “validation studies”:pt or [mh “Prospective Studies”] or “cohort” or “case control” | 305126
#16 | #11 and #15 Publication Year from 2012 to 2018, in Methods Studies, Technology Assessments, Economic Evaluations and Cochrane Groups | 2

### SBRT-SABR Patch Searches

PubMed, 8-10-2018

Search | Query | Items Found
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Carcinoma, Non-Small-Cell Lung”[MeSH] OR “non-small-cell lung cancer”[All Fields] OR NSCLC[tiab] OR (“non small cell”[tiab] AND lung*[tiab] AND cancer*[tiab]) OR “Carcinoma, Squamous Cell”[Mesh] OR Adenocarcinoma[MeSH] OR “Carcinoma, Large Cell”[MeSH]) | 500717 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search stag* AND (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb) | 851242 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (early or earlier or earliest) AND (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging) | 896718 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 or #3) | 1523639 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #4) | 108779 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Radiosurgery”[Mesh] OR “stereotactic body radiotherapy” OR SBRT[tw] OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR[tw] | 14808 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #6) | 1086 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt] | 1666509 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 not #8) | 1050 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP])) | 1048 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP])) Sort by: Author Filters: English | 994 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP])) Sort by: Author Filters: Publication date from 2014/01/01 to 2018/12/31; English | 580 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “meta synthesis”[ti] OR “cochrane database syst rev”[ta]))) | 186300 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 and #13) | 22 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) | 629547 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 and #15) | 15 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “Program Evaluation”[MeSH] OR “observational study”[tw] OR “observational studies”[tw] OR “Cohort Studies”[MeSH] OR “Comparative Study”[pt] OR “Validation Studies”[pt] OR “Prospective Studies”[MeSH] OR “cohort”[tw] OR “case control”[tw] | 4116689 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 and #17) | 282 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)

Cochrane Library, 8-13-2018

ID | Search | Hits
#1 | [mh “Carcinoma, Non-Small-Cell Lung”] or “non-small-cell lung cancer” or NSCLC:ti,ab or (“non small cell”:ti,ab and lung*:ti,ab and cancer*:ti,ab) or [mh “Carcinoma, Squamous Cell”] or [mh Adenocarcinoma] or [mh “Carcinoma, Large Cell”] | 16679
#2 | stag* and (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb) | 68855
#3 | (early or earlier or earliest) and (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging) | 52720
#4 | #2 or #3 | 101973
#5 | #1 and #4 | 6519
#6 | [mh “Radiosurgery”] OR “stereotactic body radiotherapy” OR SBRT:ti,ab,kw OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR:ti,ab,kw | 605
#7 | #5 and #6 | 115
#8 | letter:pt or newspaper article:pt or editorial:pt or comment:pt | 9517
#9 | #7 not #8 | 114
#10 | child:ti or child:ab or child:kw or children:ti or children:ab or children:kw or adolescen*:ti or adolescen*:ab or adolescen*:kw or teen:ti or teen:ab or teen:kw or teens:ti or teens:ab or teens:kw or teenage*:ti or teenage*:ab or teenage*:kw or youth:ti or youth:ab or youth:kw or youths:ti or youths:ab or youths:kw or pediatric*:ti or pediatric*:ab or pediatric*:kw or paediatric*:ti or paediatric*:ab or paediatric*:kw or boys:ti or boys:ab or boys:kw or girls:ti or girls:ti or girls:kw | 199855
#11 | #9 and #10 with Cochrane Library publication date between Jan 2014 and Dec 2018 | 3

Gray Literature

[underlined: ClinicalTrials.gov, unlimited by status (Completed/Terminated/Has Results, etc.) 5-8-18]

Screening

“Other terms” search box:

(screen* OR “Early Diagnosis” OR “X-Ray Computed Tomography” OR “CT scan” OR “CT scans” OR “CAT scan” OR “CAT scans” OR “spiral CT” OR “spiral computed tomography” OR “low-dose computed tomography” OR LDCT OR ((early or earlier or earliest) AND (detect* or diagnos* or discover* or find or finding)) OR DANTE OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” OR DLCST OR “Danish Lung Cancer Screening Trial” OR ITALUNG OR “Italian Lung Cancer Screening Trial” OR LUSI OR “Lung Cancer Screening Intervention” OR “Multicentric Italian Lung Detection” OR NELSON and Trial* OR “Dutch-Belgian Lung Cancer Screening trial” OR NLST OR “National Lung Screening Trial”)

Disease search box

(“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung-cancer” OR “lung malignancy” OR “lung malignancies” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR (( “Squamous Cell Carcinoma” OR Adenocarcinoma) AND lung*))

Limit to Age Groups Checkboxes for Adult and Senior

Last update posted 01/01/2012–05/08/2018

For a search of:

(screen* OR “Early Diagnosis” OR “X-Ray Computed Tomography” OR “CT scan” OR “CT scans” OR “CAT scan” OR “CAT scans” OR “spiral CT” OR “spiral computed tomography” OR “low-dose computed tomography” OR LDCT OR ((early or earlier or earliest) AND (detect* or diagnos* or discover* or find or finding)) OR DANTE OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” OR DLCST OR “Danish Lung Cancer Screening Trial” OR ITALUNG OR “Italian Lung Cancer Screening Trial” OR LUSI OR “Lung Cancer Screening Intervention” OR “Multicentric Italian Lung Detection” OR NELSON and Trial* OR “Dutch-Belgian Lung Cancer Screening trial” OR NLST OR “National Lung Screening Trial”) AND (“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung-cancer” OR “lung malignancy” OR “lung malignancies” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR (( “Squamous Cell Carcinoma” OR Adenocarcinoma) AND lung*)) [DISEASE] AND INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND INFLECT ( “01/01/2012” : “05/08/2018” ) [LAST-UPDATE-POSTED]

Intervention search

For a search of:

[underlined: Condition box:]

“Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma”

[underlined: Other terms box:]

(early OR earlier OR earliest) OR (stag* AND (one or 1 or I or two or 2 or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb))

[underlined: Intervention box:]

“Margins of Excision” OR Pneumonectomy OR Lobectomy OR (resection* and lung*)

AND INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND INFLECT ( “01/01/2012” : “05/08/2018” ) [LAST-UPDATE-POSTED]

All together:

early OR (stag* AND (one or 1 or I or two or 2 or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb)) | “Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma” | “Margins of Excision” OR Pneumonectomy OR Lobectomy OR resection* and lung* | Adult, Senior | Last update posted from 01/01/2012 to 05/08/2018

[underlined: WHO ICTRP 5-4-18]

Screening search

[underlined: Title box:]

screen* OR “Early Diagnosis” OR “X-Ray Computed Tomography” OR “CT scan” OR “CT scans” OR “CAT scan” OR “CAT scans” OR “spiral CT” OR “spiral computed tomography” OR “low-dose computed tomography” OR LDCT OR ((early or earlier or earliest) AND (detect* or diagnos* or discover* or find or finding)) OR DANTE OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” OR DLCST OR “Danish Lung Cancer Screening Trial” OR ITALUNG OR “Italian Lung Cancer Screening Trial” OR LUSI OR “Lung Cancer Screening Intervention” OR “Multicentric Italian Lung Detection” OR (NELSON and Trial*) OR “Dutch-Belgian Lung Cancer Screening trial” OR NLST OR “National Lung Screening Trial”

[underlined: Condition box:]

“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung malignancy” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR “Squamous Cell Carcinoma” OR Adenocarcinoma

Recruitment Status: ALL

Limited to trials registered between Jan 1, 2012 – May 4, 2018

[underlined: Condition box:]

“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung malignancy” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR “Squamous Cell Carcinoma” OR Adenocarcinoma

Intervention search

[underlined: Condition box:]

“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung malignancy” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR “Squamous Cell Carcinoma” OR Adenocarcinoma

[underlined: Intervention box:]

“Margins of Excision” OR Pneumonectomy OR Lobectomy OR (resection* and lung*)

Recruitment Status: ALL

Limited to trials registered between Jan 1, 2012 – May 4, 2018

Gray Literature SBRT Searches

ClinicalTrials.gov, 8-13-2018

For a search of:

[underlined: Condition box:]

“Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma”

[underlined: Other terms box:]

(early OR earlier OR earliest) OR (stag* AND (one or 1 or I or two or 2 or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb))

[underlined: Intervention box:]

Radiosurgery OR “stereotactic body radiotherapy” OR SBRT OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR

AND INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND INFLECT ( “01/01/2014” : “08/13/2018” ) [LAST-UPDATE-POSTED]

WHO ICTRP, 8-14-2018

[underlined: Condition box:]

“Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma”

[underlined: Intervention box:]

Radiosurgery OR “stereotactic body radiotherapy” OR SBRT OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR

Recruitment status: ALL

Date of registration between: 01/01/2014 and 08/14/2018

### Update searches

#### SCREENING

PubMed, May 28, 2019

Search | Query | Items found
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Lung Neoplasms”[MeSH] OR NSCLC[tiab] OR “lung cancer”[tiab] OR “lung cancers” [tiab] OR “lung-cancer”[tiab] OR “lung malignancy”[tiab] OR “lung malignancies”[tiab] OR “lung nodule”[tiab] OR “lung nodules” [tiab] OR “pulmonary nodule”[tiab] OR “pulmonary nodules”[tiab] OR “lung mass”[tiab] OR “lung masses”[tiab] OR (“Squamous Cell Carcinoma”[MeSH] OR Adenocarcinoma[MeSH]) and (Lung[MeSH] OR Lung Diseases[MeSH]))) | 219968 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mass Screening”[MeSH] OR screen*[tw] OR “Early Diagnosis”[MeSH] OR “Tomography, X-Ray Computed”[Mesh] OR “CT scan”[tiab] OR “CT scans”[tiab] OR “CAT scan”[tiab] OR “CAT scans”[tiab] OR “spiral CT”[tiab] OR “spiral computed tomography”[tiab] OR “low-dose computed tomography”[tiab] OR LDCT[tiab] OR ((early[tiab] or earlier[tiab] or earliest[tiab]) AND (detect*[tiab] or diagnos*[tiab] or discover*[tiab] or find[tiab] or finding[tiab]))) | 1677161 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 36110 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (DANTE[tiab] OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays”[All Fields] OR DLCST[tiab] OR “Danish Lung Cancer Screening Trial”[tiab] OR ITALUNG[tiab] OR “Italian Lung Cancer Screening Trial”[All Fields] OR LUSI[tiab] OR “Lung Cancer Screening Intervention”[All Fields] OR MILD[tiab] OR “Multicentric Italian Lung Detection”[All Fields] OR NELSON[tiab] OR “Dutch-Belgian Lung Cancer Screening trial”[All Fields] OR NLST[tiab] OR “National Lung Screening Trial”[All Fields]) | 327764 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #4) | 2806 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 or #5) | 38027 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 or #5) Filters: Publication date from 2017/04/30 to 2019/12/31 | 3454 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Risk prediction model”[tw] OR “Risk prediction models”[tw] OR “Risk Assessment”[MeSH] OR “risk assessment”[tw] OR “risk model”[tw] OR “risk models”[tw] OR “Decision Support Techniques”[MeSH] OR “Decision Support Systems, Clinical”[Mesh] OR “clinical prediction”[tw] OR “Logistic Models”[MeSH] OR microsimulation*[tw] OR “simulation model”[tw] OR “simulation models”[tw] OR “Assessment tool”[tw] OR “Assessment tools”[tw] OR “prediction score”[tw] OR “Risk Factors”[MeSH] OR “Predictive Value of Tests”[MeSH] OR “Sensitivity and Specificity”[MeSH] OR (Predict*[tw] AND (model*[tw] OR outcome*[tw] OR risk*[tw] OR rule[tw] OR rules[tw])) OR “risk-targeted”[tw] OR “mortality risk”[tw]) | 2231663 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #8) | 28279 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #8) Filters: Publication date from 2017/04/30 to 2019/12/31 | 2628 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) | 5194 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) NOT (animals[mh] NOT humans[mh]) | 5137 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) NOT (animals[mh] NOT humans[mh]) Filters: English | 4815 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #10) NOT (animals[mh] NOT humans[mh]) Filters: English; Child: birth-18 years | 181 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt])) | 1744651 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#13 not #14) | 4634 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#16 not #15) | 4476 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “meta synthesis”[ti] OR “cochrane database syst rev”[ta]) | 208402 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #18) | 159 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | Search “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) | 656996 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #20) | 118 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “Program Evaluation”[MeSH] OR “observational study”[tw] OR “observational studies”[tw] OR “Cohort Studies”[MeSH] OR “Comparative Study”[pt] OR “Validation Studies”[pt] OR “Prospective Studies”[MeSH] OR “cohort”[tw] OR “case control”[tw]) | 4286922 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 and #22) | 1908 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)

Cochrane Library, May 28, 2019

ID | Cochrane Library Search | Hits
#1 | [mh “Lung Neoplasms”] or NSCLC:ti,ab or “lung cancer”:ti,ab or “lung cancers”:ti,ab or “lung-cancer”:ti,ab or “lung malignancy”:ti,ab or “lung malignancies”:ti,ab or “lung nodule”:ti,ab or “lung nodules”:ti,ab or “pulmonary nodule”:ti,ab or “pulmonary nodules”:ti,ab or “lung mass”:ti,ab or “lung masses”:ti,ab or (([mh “Squamous Cell Carcinoma”] or [mh Adenocarcinoma]) and ([mh Lung] or [mh “Lung Diseases”])) | 18607
#2 | [mh “Mass Screening”] or screen*:kw or [mh “Early Diagnosis”] or [mh “Tomography, X-Ray Computed”] or “CT scan”:ti,ab or “CT scans”:ti,ab or “CAT scan”:ti,ab or “CAT scans”:ti,ab or “spiral CT”:ti,ab or “spiral computed tomography”:ti,ab or “low-dose computed tomography”:ti,ab or LDCT:ti,ab or ((early:ti,ab or earlier:ti,ab or earliest:ti,ab) and (detect*:ti,ab or diagnos*:ti,ab or discover*:ti,ab or find:ti,ab or finding:ti,ab)) | 51662
#3 | #1 and #2 | 1757
#4 | DANTE:ti,ab or “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” or DLCST:ti,ab or “Danish Lung Cancer Screening Trial”:ti,ab or ITALUNG:ti,ab or “Italian Lung Cancer Screening Trial” or LUSI:ti,ab or “Lung Cancer Screening Intervention” or MILD:ti,ab or “Multicentric Italian Lung Detection” or NELSON:ti,ab or “Dutch-Belgian Lung Cancer Screening trial” or NLST:ti,ab or “National Lung Screening Trial”:kw | 55900
#5 | #1 and #4 | 643
#6 | #3 or #5 | 2126
#7 | #6 Publication Year from April 2017 to 2019 | 948
#8 | “Risk prediction model”:ti,ab,kw or “Risk prediction models”:ti,ab,kw or [mh “Risk Assessment”] or “risk assessment”:ti,ab,kw or “risk model”:ti,ab,kw or “risk models”:ti,ab,kw or [mh “Decision Support Techniques”] or [mh “Decision Support Systems, Clinical”] or “clinical prediction”:ti,ab,kw or [mh “Logistic Models”] or microsimulation*:ti,ab,kw or “simulation model”:ti,ab,kw or “simulation models”:ti,ab,kw or “Assessment tool”:ti,ab,kw or “Assessment tools”:ti,ab,kw or “prediction score”:ti,ab,kw or [mh “Risk Factors”] or [mh “Predictive Value of Tests”] or [mh “Sensitivity and Specificity”] or (Predict*:ti,ab,kw and (model*:ti,ab,kw or outcome*:ti,ab,kw or risk*:ti,ab,kw or rule:ti,ab,kw or rules:ti,ab,kw)) or “risk-targeted”:ti,ab,kw or “mortality risk”:ti,ab,kw | 114475
#9 | #1 and #8 | 1868
#10 | #9 Publication Year from April 2017 to 2019 | 748
#11 | #7 or #10 | 1514
#12 | child:ti or child:ab or child:kw or children:ti or children:ab or children:kw or adolescen*:ti or adolescen*:ab or adolescen*:kw or teen:ti or teen:ab or teen:kw or teens:ti or teens:ab or teens:kw or teenage*:ti or teenage*:ab or teenage*:kw or youth:ti or youth:ab or youth:kw or youths:ti or youths:ab or youths:kw or pediatric*:ti or pediatric*:ab or pediatric*:kw or paediatric*:ti or paediatric*:ab or paediatric*:kw or boys:ti or boys:ab or boys:kw or girls:ti or girls:ti or girls:kw | 224306
#13 | #11 not #12 | 1487
#14 | #13 in Cochrane Reviews (Reviews and Protocols) | 8
#15 | “randomized controlled trial”:pt or “randomized controlled trial”:ti or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 512254
#16 | #13 and #15 | 160
#17 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-Up Studies”] or [mh “Seroepidemiologic Studies”] or “Evaluation Studies”:pt or [mh “Program Evaluation”] or “observational study” or “observational studies” or [mh “case-control studies”] or “comparative study”:pt or “validation studies”:pt or [mh “Prospective Studies”] or “cohort” or “case control” | 314610
#18 | (#13 and #17) not (#14 or #16) in other study types | 0

#### INTERVENTIONS

PubMed, May 28, 2019

Search | Query | Items found
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Carcinoma, Non-Small-Cell Lung”[MeSH] OR “non-small-cell lung cancer”[All Fields] OR NSCLC[tiab] OR (“non small cell”[tiab] AND lung*[tiab] AND cancer*[tiab]) OR “Carcinoma, Squamous Cell”[Mesh] OR Adenocarcinoma[MeSH] OR “Carcinoma, Large Cell”[MeSH]) | 523587 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((stag* AND (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb))) | 895746 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((early or earlier or earliest) AND (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging)) | 941894 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#2 or #3) | 1601919 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #4) | 114508 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Margins of Excision”[Mesh] OR Pneumonectomy OR Lobectomy OR (resection* and lung*[tw])) | 40469 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 and #6) | 4291 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt]) | 1744651 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 not #8) | 4226 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) | 4225 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) Filters: English | 3452 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) Filters: Publication date from 2017/05/01 to 2019/12/31; English | 536 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) Filters: Publication date from 2017/05/01 to 2019/12/31; English; Child: birth-18 years | 18 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 not #13) | 518 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((“systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “meta synthesis”[ti] OR “cochrane database syst rev”[ta])) | 208402 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#14 and #15) | 15 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract])) | 656996 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#14 and #17) | 13 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “Program Evaluation”[MeSH] OR “observational study”[tw] OR “observational studies”[tw] OR “Cohort Studies”[MeSH] OR “Comparative Study”[pt] OR “Validation Studies”[pt] OR “Prospective Studies”[MeSH] OR “cohort”[tw] OR “case control”[tw]) | 4286922 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#14 and #19) | 286 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)

Cochrane Library, May 28, 2019

ID | Search | Hits
#1 | [mh “Carcinoma, Non-Small-Cell Lung”] or “non-small-cell lung cancer” or NSCLC:ti,ab or (“non small cell”:ti,ab and lung*:ti,ab and cancer*:ti,ab) or [mh “Carcinoma, Squamous Cell”] or [mh Adenocarcinoma] or [mh “Carcinoma, Large Cell”] | 20425
#2 | stag* and (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb) | 85688
#3 | (early or earlier or earliest) and (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging) | 62072
#4 | #2 or #3 | 125155
#5 | #1 and #4 | 8538
#6 | ([mh “Margins of Excision”] or Pneumonectomy or Lobectomy or (resection* and lung*:ti,ab,kw)) | 3692
#7 | #5 and #6 | 900
#8 | letter:pt or newspaper article:pt or editorial:pt or comment:pt | 14366
#9 | #7 not #8 | 897
#10 | child:ti or child:ab or child:kw or children:ti or children:ab or children:kw or adolescen*:ti or adolescen*:ab or adolescen*:kw or teen:ti or teen:ab or teen:kw or teens:ti or teens:ab or teens:kw or teenage*:ti or teenage*:ab or teenage*:kw or youth:ti or youth:ab or youth:kw or youths:ti or youths:ab or youths:kw or pediatric*:ti or pediatric*:ab or pediatric*:kw or paediatric*:ti or paediatric*:ab or paediatric*:kw or boys:ti or boys:ab or boys:kw or girls:ti or girls:ti or girls:kw | 224306
#11 | #9 not #10 | 880
#12 | #11 Publication Year from 2017 to 2019, in Cochrane Reviews, Cochrane Protocols | 9
#13 | “randomized controlled trial”:pt or “randomized controlled trial”:ti or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 512254
#14 | #11 and #13 Publication Year from 2017 to 2019, in Trials | 30
#15 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-Up Studies”] or [mh “Seroepidemiologic Studies”] or “Evaluation Studies”:pt or [mh “Program Evaluation”] or “observational study” or “observational studies” or [mh “case-control studies”] or “comparative study”:pt or “validation studies”:pt or [mh “Prospective Studies”] or “cohort” or “case control” | 314610
#16 | #11 and #15 publication date from May 2017 to Dec 2019, in Clinical Answers and Special collections | 0

#### SBRT-SABR SEARCHES

PubMed, 5-28-19

Search | Query | Items found
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Carcinoma, Non-Small-Cell Lung”[MeSH] OR “non-small-cell lung cancer”[All Fields] OR NSCLC[tiab] OR (“non small cell”[tiab] AND lung*[tiab] AND cancer*[tiab]) OR “Carcinoma, Squamous Cell”[Mesh] OR Adenocarcinoma[MeSH] OR “Carcinoma, Large Cell”[MeSH])) | 523587 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (stag* AND (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb)) | 895746 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((early or earlier or earliest) AND (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging)) | 941894 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#2 or #3) | 1601919 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #4) | 114508 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Radiosurgery”[Mesh] OR “stereotactic body radiotherapy” OR SBRT[tw] OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR[tw]) | 15921 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((#5 and #6)) | 1217 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt]) | 1744651 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 not #8) | 1176 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) | 1174 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) Filters: English | 1117 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 NOT (animals[mh] NOT humans[mh])) Filters: Publication date from 2017/08/10 to 2019/12/31; English | 253 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (((“systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR (“systematic review”[tiab] AND review[pt]) OR meta synthesis[ti] OR “meta synthesis”[ti] OR “cochrane database syst rev”[ta]))) | 208402 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 and #13) | 7 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract])) | 656996 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 and #15) | 5 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “Program Evaluation”[MeSH] OR “observational study”[tw] OR “observational studies”[tw] OR “Cohort Studies”[MeSH] OR “Comparative Study”[pt] OR “Validation Studies”[pt] OR “Prospective Studies”[MeSH] OR “cohort”[tw] OR “case control”[tw]) | 4286922 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 and #17) | 108 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)

[underlined: Cochrane Library, 5-28-19], SABR search

ID | Search | Hits
#1 | [mh “Carcinoma, Non-Small-Cell Lung”] or “non-small-cell lung cancer” or NSCLC:ti,ab or (“non small cell”:ti,ab and lung*:ti,ab and cancer*:ti,ab) or [mh “Carcinoma, Squamous Cell”] or [mh Adenocarcinoma] or [mh “Carcinoma, Large Cell”] | 20425
#2 | stag* and (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb) | 85688
#3 | (early or earlier or earliest) and (discover* or found or find or finding or uncover* or diagnos* or detect* or stage* or staging) | 62072
#4 | #2 or #3 | 125155
#5 | #1 and #4 | 8538
#6 | [mh “Radiosurgery”] OR “stereotactic body radiotherapy” OR SBRT:ti,ab,kw OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR:ti,ab,kw | 779
#7 | #5 and #6 | 170
#8 | letter:pt or newspaper article:pt or editorial:pt or comment:pt | 14366
#9 | #7 not #8 | 169
#10 | child:ti or child:ab or child:kw or children:ti or children:ab or children:kw or adolescen*:ti or adolescen*:ab or adolescen*:kw or teen:ti or teen:ab or teen:kw or teens:ti or teens:ab or teens:kw or teenage*:ti or teenage*:ab or teenage*:kw or youth:ti or youth:ab or youth:kw or youths:ti or youths:ab or youths:kw or pediatric*:ti or pediatric*:ab or pediatric*:kw or paediatric*:ti or paediatric*:ab or paediatric*:kw or boys:ti or boys:ab or boys:kw or girls:ti or girls:ti or girls:kw | 224306
#11 | #9 not #10 with Cochrane Library publication date from Jan 2014 to Dec 2019 | 163
#12 | #11 in in Cochrane Reviews and Cochrane Protocols | 4
#13 | “randomized controlled trial”:pt or “randomized controlled trial”:ti or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 512254
#14 | #11 and #13 | 17
#15 | [mh “Case-Control Studies”] or [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-Up Studies”] or [mh “Seroepidemiologic Studies”] or “Evaluation Studies”:pt or [mh “Program Evaluation”] or “observational study” or “observational studies” or [mh “case-control studies”] or “comparative study”:pt or “validation studies”:pt or [mh “Prospective Studies”] or “cohort” or “case control” | 314610
#16 | (#11 and #15) NOT (#12 or #14) in Cochrane Reviews, Cochrane Protocols, Trials, Clinical Answers and Special collections | 19

Lung Cancer Gray Literature Updates, May 28, 2019

SCREENING

[underlined: ClinicalTrials.gov, May 28, 2019]

436 results

[underlined: “Other terms” search box]:

(screen* OR “Early Diagnosis” OR “X-Ray Computed Tomography” OR “CT scan” OR “CT scans” OR “CAT scan” OR “CAT scans” OR “spiral CT” OR “spiral computed tomography” OR “low-dose computed tomography” OR LDCT OR ((early or earlier or earliest) AND (detect* or diagnos* or discover* or find or finding)) OR DANTE OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” OR DLCST OR “Danish Lung Cancer Screening Trial” OR ITALUNG OR “Italian Lung Cancer Screening Trial” OR LUSI OR “Lung Cancer Screening Intervention” OR “Multicentric Italian Lung Detection” OR NELSON and Trial* OR “Dutch-Belgian Lung Cancer Screening trial” OR NLST OR “National Lung Screening Trial”)

[underlined: Disease search box:]

(“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung-cancer” OR “lung malignancy” OR “lung malignancies” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR (( “Squamous Cell Carcinoma” OR Adenocarcinoma) AND lung*))

Limit to age groups checkboxes for Adult and Older Adults

Last update posted 05/01/2018 – 05/28/2018

[underlined: WHO ICTRP, May 28, 2019]

51 results

Title box:

screen* OR “Early Diagnosis” OR “X-Ray Computed Tomography” OR “CT scan” OR “CT scans” OR “CAT scan” OR “CAT scans” OR “spiral CT” OR “spiral computed tomography” OR “low-dose computed tomography” OR LDCT OR ((early or earlier or earliest) AND (detect* or diagnos* or discover* or find or finding)) OR DANTE OR “Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays” OR DLCST OR “Danish Lung Cancer Screening Trial” OR ITALUNG OR “Italian Lung Cancer Screening Trial” OR LUSI OR “Lung Cancer Screening Intervention” OR “Multicentric Italian Lung Detection” OR (NELSON and Trial*) OR “Dutch-Belgian Lung Cancer Screening trial” OR NLST OR “National Lung Screening Trial”

Condition box:

“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung malignancy” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR “Squamous Cell Carcinoma” OR Adenocarcinoma

Recruitment Status: ALL

Limited to trials registered between May 1, 2018 – May 28, 2019

INTERVENTIONS

[underlined: ClinicalTrials.gov, May 28, 2019]

40 results

[underlined: Condition box:]

“Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma”

[underlined: Other terms box:]

(early OR earlier OR earliest) OR (stag* AND (one or 1 or I or two or 2 or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb))

[underlined: Intervention box:]

“Margins of Excision” OR Pneumonectomy OR Lobectomy OR (resection* and lung*)

Limit to age groups checkboxes for Adult and Older Adult

Last update posted 05/01/2018 – 05/28/2019

[underlined: WHO ICTRP, May 28, 2019]

26 results

[underlined: Condition box:]

“Lung Neoplasms” OR NSCLC OR “lung cancer” OR “lung cancers” OR “lung malignancy” OR “lung nodule” OR “lung nodules” OR “pulmonary nodule” OR “pulmonary nodules” OR “lung mass” OR “lung masses” OR “Squamous Cell Carcinoma” OR Adenocarcinoma

[underlined: Intervention box:]

“Margins of Excision” OR Pneumonectomy OR Lobectomy OR (resection* and lung*)

Recruitment Status: ALL

Limited to trials registered between May 1, 2018 – May 28, 2019

SBRT-SABR

[underlined: ClinicalTrials.gov, May 28, 2019]

55 results

[underlined: Condition box]

“Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma”

[underlined: Other terms box:]

(early OR earlier OR earliest) OR (stag* AND (one or 1 or I or two or 2 or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb))

[underlined: Intervention box:]

Radiosurgery OR “stereotactic body radiotherapy” OR SBRT OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR

Limit to age groups checkboxes for Adult and Older Adults

Last update posted 05/01/2018 – 05/28/2018

[underlined: WHO ICTRP, May 28, 2019]

87 results

[underlined: Condition box:]

“Non-Small-Cell Lung Carcinoma” OR “non-small-cell lung cancer” OR NSCLC OR “non small cell” AND lung* AND cancer* OR “Squamous Cell Carcinoma” OR Adenocarcinoma OR “Large Cell Carcinoma”

[underlined: Intervention box:]

Radiosurgery OR “stereotactic body radiotherapy” OR SBRT OR “stereotactic body RT” OR “Stereotactic RT” OR “stereotactic ablative radiotherapy” OR SABR

Recruitment status: ALL

Date of registration between: 05/01/2018 – 05/28/2018

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | KQs 1–5, 8: Asymptomatic adults (age ≥18 years); KQs 6, 7: Adults (age ≥18 years) with early (Stage I) non-small cell lung cancer | KQs 1–5, 8: Children, persons with symptoms or prior diagnosis of lung cancer; KQs 6, 7: Children, persons with nonprimary lung cancer or other than Stage I lung cancer
Risk prediction | KQ 2: Externally validated models including demographic variables, clinical variables, or biomarkers intended for identifying persons at increased risk who are more likely to benefit from screening | KQ 2: Models including a single variable or biomarker, models not considering smoking and age (known risk factors for lung cancer)
Screening | KQs 1, 3, 4, 8: LDCT^*^ | KQs 1, 3, 4, 8: No screening, chest X-ray, sputum cytology, and other screening modalities
Workup or surveillance | KQ 5: Computed tomography, biopsy, positron emission tomography, or other tests used after screening | Not applicable
Interventions | KQs 6, 7: Surgical resection or SBRT | KQs 6, 7: Chemotherapy, natural therapies, immunotherapy, or targeted molecular therapy
Comparisons | KQs 1, 8: Chest X-ray, no screening, or usual care; KQ 2: 2013 USPSTF recommendations or criteria used by trials showing benefit (e.g., NLST); KQ 3:; - There is no single gold standard for assessing accuracy; - Comparison (reference standard) could be subsequent diagnosis of lung cancer within 1 year (likely resulting from repeat imaging and subsequent biopsy), biopsy, or subsequent imaging; - Sensitivity and false-negative screens (false reassurance): Typically determined by considering new lung cancer presenting within 1 year of a normal screening study as false-negative screens; - Specificity and false-positive screens: Initial positive LDCT result that is found to be benign with tissue diagnosis or subsequent imaging; KQs 4, 5: Chest X-ray, no screening, usual care, or no comparison group; KQs 6, 7: No comparison group is required; although the review did not assess comparative effectiveness of treatments, comparative effectiveness studies were eligible if they provided data for eligible populations, interventions, and outcomes and met the other eligibility criteria | KQs 1–3, 8: Studies without a comparison group
Outcomes | KQ 1a: Incidence of lung cancer (all stages), distribution of lung cancer types and stages; KQ 1b: All-cause mortality, lung cancer mortality, quality of life, or functional status; KQ 2: Estimated number of deaths from lung cancer or all-cause mortality that can be prevented by screening, estimated screening effectiveness (e.g., number needed to screen), or estimated screening harms; KQ 3: Sensitivity, specificity, and predictive value; KQ 4: Radiation exposure, false-positive results, overdiagnosis,^†^ smoking cessation rates, psychosocial harms, incidental findings leading to additional tests and subsequent harms, and unnecessary treatment (e.g., surgical resection for a benign nodule); KQ 5: Radiation exposure, false-positive results, overdiagnosis,^†^ smoking cessation rates, psychosocial harms, incidental findings leading to additional tests and subsequent harms, unnecessary treatment (e.g., surgical resection for a benign nodule), and harms of workup (e.g., biopsy leading to an adverse event); KQ 6: 5- and 10-year incidence of advanced disease and mortality (survival rates); KQ 7: Harms of treatment, including mortality, infection, bleeding, bronchopleural fistula, and respiratory failure; KQ 8: All-cause and lung cancer mortality | Costs
Study designs | All KQs: Controlled trials; KQ 2: Modeling studies are also eligible, clinical prediction tools must include multiple factors; KQ 3: Studies evaluating accuracy are also eligible; KQs 4, 5, 7: Prospective cohort and case-control studies are also eligible; KQ 6: Prospective cohort studies are also eligible | All other study designs^‡^; KQ 2: Models including a single variable or biomarker, models not considering smoking and age (known risk factors for lung cancer); KQs 1–5, 8: Studies with a sample size less than 1,000; KQs 6, 7: For surgery (established standard treatment), studies with a sample size less than 500; for SBRT, no limit on sample size
Study duration | KQs 1–5, 7, 8: Any length of time; KQ 6: At least 5 years of followup | KQ 6: Less than 5 years of followup
Settings | Published in or after 2001
Countries | Studies conducted in countries categorized as “Very High” on the 2016 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2016 Human Development Index
Language | English | Languages other than English
Study quality | Good or fair quality | Poor quality (according to design-specific USPSTF criteria)

* The review focused on computed tomography but also searched for and allowed for inclusion of new trials (published since the search cutoff dates of the last review) of other screening modalities. Older studies (before 2013) of other screening modalities were not carried forward to this update.

† Defined as detection of disease that would never progress to produce symptoms or death.

‡ Systematic reviews are excluded from the evidence review. However, separate searches were conducted to identify relevant systematic reviews, and the citations of all studies included in those systematic reviews were reviewed to ensure that database searches captured all relevant primary studies.

Abbreviations: KQ=key question; LDCT=low-dose computed tomography; NLST=National Lung Screening Trial; SBRT=stereotactic body radiotherapy; USPSTF=U.S. Preventive Services Task Force.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^51^

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

#### Definition of Ratings Based on Above Criteria

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has a fatal flaw, such as uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^51^