# Appendix A Additional Background and Contextual Questions

Appendix A Table 1 Overview of Lung-RADS Classification System (Version 1.0)

Category Classification | Category Descriptor | Category | Findings | Management
Incomplete | | 0 | Part or all of lungs cannot be evaluated; Prior chest CT examination(s) being located for comparison | Additional lung cancer screening CT images and/or comparison to prior chest CT examinations is needed
Negative | No nodules and definitely benign nodules | 1 | No lung nodules; Nodule(s) with specific calcifications: complete, central, popcorn, concentric rings, and fat- containing nodules | Continue annual screening with LDCT in 12 months
Benign appearance or behavior | Nodules with a very low 90% likelihood of becoming a clinically active cancer due to size or lack of growth | 2 | Solid nodule(s): <6 mm, new <4 mm; Part solid nodule(s): <6 mm total diameter on baseline screening; Nonsolid nodule(s) (GGN): <20 mm OR ≥20 mm and unchanged or slowly growing; Category 3 or 4 nodules unchanged for ≥3 months | Continue annual screening with LDCT in 12 months
Probably benign | Probably benign finding(s): short-term followup suggested; includes nodules with a low likelihood of becoming a clinically active cancer | 3 | Solid nodule(s): ≥6 to <8 mm at baseline OR new 4 mm to <6 mm; Part solid nodule(s) ≥6 mm total diameter with solid component <6 mm OR new <6 mm total diameter nonsolid nodule(s) (GGN) ≥20 mm; Nonsolid nodule(s) (GGN) ≥20 mm on baseline CT or new | 6-month LDCT
Suspicious | Findings for which additional diagnostic testing and/or tissue sampling is recommended | 4A | Solid nodule(s): ≥8 to <15 mm at baseline OR growing <8 mm OR new 6 to <8 mm; Part solid nodule(s): ≥6 mm with solid component ≥6 mm to <8 mm; OR with a new or growing <4 mm solid component; Endobronchial nodule | 3-month LDCT; PET/CT may be used when there is a ≥8 mm solid component
Suspicious | Findings for which additional diagnostic testing and/or tissue sampling is recommended | 4B | Solid nodule(s) ≥15 mm OR new or growing and ≥8 mm; Part solid nodule(s) with a solid component ≥8 mm OR a new or growing ≥4 mm solid component | Chest CT with or without contrast, PET/CT and/or tissue sampling depending on the *probability of malignancy and comorbidities. PET/CT may be used when there is a ≥8 mm solid component.
Suspicious | Findings for which additional diagnostic testing and/or tissue sampling is recommended | 4X | Category 3 or 4 nodules with additional features or imaging findings that increases the suspicion of malignancy | Chest CT with or without contrast, PET/CT and/or tissue sampling depending on the *probability of malignancy and comorbidities. PET/CT may be used when there is a ≥8 mm solid component.

Adapted from Lung‐RADS™ Version 1.0 Assessment Categories Release date: April 28, 2014

Abbreviations: CT=computed tomography; GGN=ground glass nodule; LDCT=low-dose computed tomography; PET=positron emission tomography.

Appendix A Table 2 Overview of Lung-RADS Classification System (Version 1.1)

Category Classification | Category Descriptor | Category | Findings | Management
Incomplete | | 0 | Part or all of lungs cannot be evaluated; prior chest CT examination(s) being located for comparison | Additional lung cancer screening CT images and/or comparison to prior chest CT examinations is needed
Negative | No nodules and definitely benign nodules | 1 | No lung nodules; nodule(s) with specific calcifications: complete, central, popcorn, concentric rings, and fat- containing nodules | Continue annual screening with LDCT in 12 months
Benign appearance or behavior | Nodules with a very low likelihood of becoming a clinically active cancer due to size or lack of growth | 2 | Perifissural nodule(s)^*^ <10 mm (524 mm^3^); Solid nodule(s): <6 mm (<113 mm^3^), new <4 mm (<34 mm^3^); Part solid nodule(s): <6 mm total diameter (<113 mm^3^) on baseline screening; Nonsolid nodule(s) (GGN): <30 mm (<14,137 mm^3^) OR ≥30 mm (≥14,137 mm^3^) and unchanged or slowly growing; Category 3 or 4 nodules unchanged for ≥3 months | Continue annual screening with LDCT in 12 months
Probably benign | Probably benign finding(s): short-term followup suggested; includes nodules with a low likelihood of becoming a clinically active cancer | 3 | Solid nodule(s): ≥6 to <8 mm (≥113 to <268 mm^3^) at baseline OR new 4 mm to <6 mm (34 to <113 mm^3^); Part solid nodule(s): ≥6 mm total diameter (≥113 mm^3^) with solid component <6 mm (<113 mm^3^) OR new <6 mm total diameter (<113 mm^3^); Nonsolid nodule(s): (GGN) ≥30 mm (≥14,137 mm^3^) on baseline CT or new | 6-month LDCT
Suspicious | Findings for which additional diagnostic testing is recommended | 4A | Solid nodule(s): ≥8 to <15 mm at baseline (≥268 to <1,767 mm^3^) OR growing <8 mm (<268 mm^3^) OR new 6 to <8 mm (113 to <268 mm^3^); Part solid nodule(s): ≥6 mm (≥113 mm^3^) with solid component ≥6 mm to <8 mm (≥113 to <268 mm^3^) OR with a new or growing <4 mm (<34 mm^3^) solid component; Endobronchial nodule | 3-month LDCT; PET/CT may be used when there is a ≥8 mm (≥268 mm^3^) solid component
Very suspicious | Findings for which additional diagnostic testing and/or tissue sampling is recommended | 4B | Solid nodule(s) ≥15 mm (≥1,767 mm^3^) OR new and growing and ≥8 mm (≥268 mm^3^); Part solid nodule(s) with a solid component ≥8 mm (≥268 mm^3^) OR a new or growing ≥4 mm (≥34 mm^3^) solid component | Chest CT with or without contrast, PET/CT and/or tissue sampling depending on the *probability of malignancy and comorbidities. PET/CT may be used when there is a ≥8 mm (≥268 mm^3^) solid component. For new large nodules that develop on an annual repeat screening CT, a 1- month LDCT may be recommended to address potentially infectious or inflammatory conditions
Very suspicious | Findings for which additional diagnostic testing and/or tissue sampling is recommended | 4X | Category 3 or 4 nodules with additional features or imaging findings that increase the suspicion of malignancy^†^
Other | Clinically significant or potentially clinically significant findings (nonlung cancer) | S | Modifier: may add on to category 0‐4 coding | As appropriate to the specific finding

Adapted from Lung‐RADS Version 1.1 Assessment Categories Release date: 2019

* Solid nodules with smooth margins, an oval, lentiform or triangular shape, and maximum diameter less than 10 mm or 524 mm^3^ (perifissural nodules) should be classified as category 2.

† These include, for example, spiculation, GGN that doubles in size in 1 year, and enlarged lymph nodes.

Abbreviations: CT=computed tomography; GGN=ground glass nodule; LDCT=low-dose computed tomography; NA=not applicable; PET=positron emission tomography.

Some notes on use of Lung‐RADS Version 1.1:

1) Nodule mean diameter is calculated by measuring both the long and short axes to one decimal point and reporting mean nodule diameter to one decimal point.
2) Size thresholds: Apply to nodules at first detection, and that grow and reach a higher size category.
3) Growth is defined as an increase in size of >1.5 mm (>2 mm^3^).
4) Exam category: Each exam should be coded 0‐4 based on the nodule(s) with the highest degree of suspicion.

Appendix A Table 3 Typical Treatment Approaches of SCLC, by Stage^326^

Stage | Treatment Approach
Limited disease | Clinical stage T1-2, N0: Lobectomy + chemotherapy +/− concurrent radiation therapy; Clinical stage >T1-2, N0: chemotherapy +/− concurrent or sequential radiation therapy tailored to patient performance status
Extensive disease | Chemotherapy +/− radiation therapy tailored to location and symptoms of metastatic site

Abbreviations: SCLC=small-cell lung cancer; T=tumor.

Appendix A Table 4 Stage of Detected Lung Cancers in LDCT Screening Groups for NLST and NELSON Trials

Stage | NLST (%) | NELSON (%)
Ia | 40 | 58
Ib | 10 | 10
IIa | 3.4 | 5
IIb | 3.7 | 1
IIIa | 9.5 | 14
IIIb | 11.7 | 3
IV | 21.7 | 14

* For reference, the stage distribution based on data from the SEER 18 registry in 2010 is as follows: Ia (11.7%), Ib (8.5%), IIa (1.0%), IIb (3.1%), IIIa (8.5%), IIIb (14.8%), IV (45.1%), occult or unknown (7.3%).^327^ Participants in the NLST were younger, better educated, and healthier than individuals of similar age and smoking eligibility in the United States. (SCLC accounted for 7 percent of CT screen-detected cancers in the NELSON trial and 13 percent in NLST).

Abbreviations: LDCT=low-dose computed tomography; NELSON=The Dutch-Belgian Randomized Lung Cancer Screening Trial; NLST=National Lung Screening Trial; SCLC=small cell lung cancer

Appendix A Table 5 Recommendations for Lung Cancer Screening With LDCT

Organization | Year | Target Population | Recommendation and Related Comments | Endorse shared decision making?
American Academy of Family Physicians^44^ | 2013 | Persons with a high risk of lung cancer on the basis of age and smoking history | Insufficient evidence to recommend screening. Screening cannot be recommended on the basis of a single study conducted in major medical centers. | Yes
American Cancer Society^328,^ ^329^ | 2013 | NLST criteria. Excludes life-limiting comorbid conditions, metallic implants or devices in the chest or back, or oxygen requirement | Discussion about screening should be initiated, including benefits, limitations, harms. Recommends only if there is access to a high-volume, high-quality lung cancer screening and treatment center. | Yes
American Lung Association^330^ | 2015 | NLST criteria | Screening with LDCT recommended. Screening should occur in institutions that are able to provide a comprehensive screening program; smoking cessation is the best method of reducing lung cancer risk among those who smoke. | Yes
American Association for Thoracic Surgery^331^ | 2012 | Persons ages 55–79 years with ≥30 pack-year smoking history and persons ages 50–79 years with ≥20 pack-year smoking history and another risk factor for lung cancer^*^ or lung cancer survivor | Annual screening with LDCT. Should be conducted in environments in which there are multidisciplinary teams for managing indeterminate and positive screening scans; desirable to create a program that supports smoking cessation. | Not specified
CHEST Guideline and Expert Panel Report^315^ | 2018 | Asymptomatic persons ages 55–77 years with same smoking history criteria as NLST | Annual screening with LDCT should be offered (weak recommendation, moderate-quality evidence) | Yes
European Union^332^ | 2017 | Lung cancer LDCT programs should use a validated risk stratification approach so that only persons deemed to be at high enough risk are screened^†^ | Screening with LDCT. Management of screen-detected solid nodules should use semi-automatically derived volume measurements and volume-doubling time and should be quality assured. Management of lung nodules by lung cancer multidisciplinary teams. National quality assurance boards should be set up by professional bodies to ensure adherence to all minimum technical standards. | All future screenees should be provided with carefully constructed participant information on the potential benefits and harms to enable them to make an informed decision.
National Comprehensive Cancer Network^43,^ ^333^ | 2012 | NLST criteria and persons age 50 years or older with ≥20 pack-years smoking history and 1 additional risk factor for lung cancer^‡^ | Screening with LDCT. Multidisciplinary screening programs will be helpful; smokers should always be encouraged to quit smoking. It is also reasonable to consider using the PLCOm2012 lung cancer risk calculator to assist in quantifying risk, considering a 1.3% threshold of lung cancer risk (over 6 years). | Patients should have a full understanding of risks and benefits.
Canadian Task Force on Preventive Health Care^334^ | 2016 | NLST criteria | Screening with LDCT every year up to 3 consecutive years (weak, low-quality evidence). Screening should only be performed in health care settings with access to expertise in early diagnosis and treatment of lung cancer. | Yes, discussion about benefits and harms, including false-positive screens, adverse effects of invasive followup testing, and overdiagnosis

* Examples of additional risk factors, as specified by the American Association for Thoracic Surgery, include COPD, environmental or occupational exposure, prior cancer or radiation therapy, and genetic predisposition or family history.

† No specific model is recommended.

‡ Examples of additional risk factors, as specified by the National Comprehensive Cancer Network, include radon exposure, occupational exposure, history of cancer, family history of lung cancer, COPD, and pulmonary fibrosis.

Abbreviations: COPD=chronic obstructive pulmonary disease; CT=computed tomography; LDCT=low-dose computed tomography; NLST=National Lung Screening Trial.

## CQ 1 What Are the Barriers to Implementing Lung Cancer Screening and Surveillance in Clinical Practice in the United States (e.g., Barriers to Shared Decision Making, Systematically Eliciting and Documenting a Detailed Smoking History, Systems for Tracking Nodules and Followup, and Availability of Appropriate LDCT Protocols)?

### Introduction

Since the 2013 USPSTF statement on lung cancer screening, multiple expert groups and specialty societies have published consensus-based guidance documents on screening implementation.^315,^ ^335–339^ Common among these guidance statements is an acknowledgement that implementation of lung cancer screening is a highly complex process requiring multiple, inter-connected steps. There is also a growing body of literature aimed at understanding barriers to implementation of lung cancer screening. A recent perspective article offered a high-level summary of implementation barriers using a multi-level (patient, provider, and system-level) framework (Table 6).^340^ This contextual question section is not on a comprehensive account of the many clinical and technical aspects of screening implementation. Rather, it highlights some of the salient barriers to the appropriate and effective implementation of lung cancer screening that have arisen since the 2013 USPSTF statement. These include barriers to SDM, systematic identification of screen-eligible patients, systems for tracking nodules and followup, and availability of LDCT protocols.

### Barriers to Shared Decision Making

#### Screening Guidelines and SDM

Lung cancer screening guidelines are virtually unanimous in asserting that informed and SDM should occur before a patient proceeds with screening.^315,^ ^334,^ ^335,^ ^341^ The American Cancer Society recommends that “a process of informed and SDM with a clinician related to the potential benefits, limitations, and harms associated with screening for lung cancer with low‐dose computed tomography should occur before any decision is made to initiate lung cancer screening.”^328^ The 2013 USPSTF recommendation stated that “the decision to begin screening should be the result of a thorough discussion of the possible benefits, limitations, and known and uncertain harms.”^1^ In 2014, the CMS coverage decision for lung cancer screening was issued that contained several stipulations including a requirement for “a lung cancer screening counseling and shared decision-making visit.” Required elements of this visit included “the use of one or more decision aids, to include benefits, harms, followup diagnostic testing, over-diagnosis, false positive rate, and total radiation exposure.”^40^

#### SDM in Practice

Unfortunately, emerging evidence raises concerns that SDM in practice may be far from what is intended by guidelines. A recent study found that CMS-required SDM visits were evident in just 10 percent of Medicare beneficiaries who had a screening LDCT in 2016.^342^ Another study analyzed transcribed recordings of discussions between community physicians (primary care physicians and pulmonologists) and patients about initiating lung cancer screening.^343^ In these discussions (n=14), which were identified by searching a large database, SDM quality was universally poor and discussion of screening harms was essentially nonexistent. Average time for screening discussion was 57 seconds and was typically focused on insurance coverage. There was no evidence that decision aids were used.

#### Competing Demands

Systematic reviews have found that SDM is difficult to implement well in practice, regardless of clinical context.^344^ Factors associated with higher quality SDM include time (duration of encounter) and decision support interventions (including decision aids). Since the USPSTF 2013 recommendation, multiple studies have identified competing demands and limited time available to conduct SDM during clinical encounters as a central barrier to implementing SDM.^37,^ ^345–349^

#### Patient Perceptions of Screening

Adding to the challenge of SDM implementation is evidence that patient’s “baseline” perceptions of the benefits and harms of lung cancer screening diverge from what the evidence shows. In one study of (n=50) screen-eligible patients who had not yet seen a decision aid overestimated the likelihood of benefitting from screening by orders of magnitude. Patients also had poor awareness of potential harms of screening.^42^ In another study involving focus groups of screening eligible patients (n=45), participants expressed surprise that the magnitude of their lung cancer risk and benefits of screening were lower than expected.^345^ These studies suggest that patient’s baseline perceptions are systematically inaccurate (i.e., biased) in favor of screening. These biases are not unique to lung cancer screening, and there is robust evidence that patients, members of the public, and clinicians typically overestimate the benefits and underestimate the harms of cancer screening tests.^350–352^

Such biases pose challenges for implementing SDM about screening in practice. Primary care physicians, who routinely discuss cancer screening with patients, recognize that initiating a conversation about the availability of a lung cancer screening test will provoke immediate assumptions on the part of the patient. For meaningful SDM, a provider who initiates such a discussion about lung cancer screening must be prepared to provide balanced information that calibrates patient perceptions and expectations to reflect what is known.

Although providing screen-eligible patients individualized, quantitative risk information is (theoretically) ideal, a first order concern is implementing processes that offer patients a) a reasonable sense of the benefits and harms of screening, including approximate likelihoods for these outcomes; b) an understanding that the screening decision involves tradeoffs between these benefits and harms; and c) a recognition that the “weights” placed on avoiding harms relative to benefits should reflect the values of the patient him/herself.

#### Timing and Context of SDM

Experts have expressed a range of views about whether SDM about lung cancer screening should occur in primary care, subspecialty care, and/or within centralized screening programs.^353,^ ^354^ The potential benefits of SDM in a subspecialized LDCT screening context are the increased chances that providers will be knowledgeable about lung cancer screening, have time to dedicate to the issue of screening, and use established workflows that employ decision support tools. On the other hand, potential downsides of conducting SDM in centralized screening centers is that patients are likely to assume that a referral to a lung cancer screening program is a referral for the screening procedure itself rather than to participate in process by which they will decide whether screening is right for them. Thus, by the time the patient reaches the screening center context, absent a good prior discussion, it is likely they will arrive with inaccurate perceptions of the benefits and harms and will have already decided to be screened.^353–356^

Emerging evidence lends support to the idea that the timing and context of the SDM process (i.e., primary care vs. referral setting) can influence patient decisions. One study in a primary care population of screening-eligible patients (n=50) found viewing a video decision aid improved understanding of the nature and magnitude of the harms and benefits of screening.^42^ When asked to indicate their screening preferences, 50 percent preferred screening while the other 50 percent did not. In another study of screen-eligible primary care patients (n=81) who were reached through an electronic health record portal and viewed a lung cancer screening decision aid, screening preferences were again heterogeneous: 30 percent desired screening, 44 percent were “unsure,” and 26 percent declined screening.^357^ In contrast to these studies in primary care context, a study of patients attending a tertiary referral lung cancer screening program (n=423) who received robust patient education and decision support that included decision aid viewing, 95 percent proceeded to have a screening LDCT.^358^ In sum, there is evidence that, in primary care populations, informed preferences about lung cancer screening are heterogeneous (i.e., that the decision is, in fact, “preference sensitive”). SDM conducted only after a patient reaches a lung cancer screening center may miss the “decision window” during which patients actually make the decision.

### System and Personnel Barriers to Identifying Eligible Populations (Detailed Smoking Histories)

One challenge to population or system level implementation in identifying populations eligible for screening is that detailed, patient-level smoking histories, including average number of cigarettes smoked per day, start dates, and quit dates, are not readily available within the electronic health record.

Moreover, smoking behavior is dynamic, meaning that these data need to be periodically verified for accuracy. Clinical demonstration studies suggest that, even with additional resources dedicated to eliciting and documenting smoking histories, these data fields often still have incomplete or inaccurate information. In the VHA implementation project, substantial resources were dedicated to having nurses elicit and enter these data. Despite this, among 93,033 patients who met basic age and comorbidity criteria, a total of 36,555 patients (39.3%) were missing necessary smoking history data (or the tobacco pack-years were improperly calculated) needed to systematically identify screening-eligible patients.^38^ In 1-year, single-site primary care implementation project, nurses and support staff were able to elicit and document smoking histories in 53 percent of ever smokers between ages 55 and 80 years.^359^

### Availability of Appropriate LDCT Protocols

Another potential implementation issue is whether radiology facilities that are capable of providing LDCT scanning are available. Early studies published soon after the 2013 USPSTF statement raised concerns about limited capacity.^360^ However, the number of lung cancer screening centers is growing rapidly. In 2014, there were 203 screening centers certified by the American College of Radiology (ACR) in the United States. By 2017, that number had increased to 1,748.^361^ According to the ACR website, there are 2,013 ACR-certified centers as of April 2019.^362^

### Systems for Tracking Nodules and Ensuring Followup (Patient Coordination)

The availability of centers that are certified to perform LDCT screening and to report results to a national registry should be distinguished from the availability of infrastructure needed to track and manage individuals with screen-detected lung nodules. There is broad expert consensus that screen-detected lung nodules should be managed based on established algorithms,^315,^ ^335–339^ which call for regular and timely surveillance of screen-detected nodules. Operationalizing surveillance of lung nodules for a large, high-risk population will require robust longitudinal tracking and patient coordination systems for the large numbers of individuals with lung nodules. The VHA Lung Cancer Screening Demonstration Project (LCSDP) found this aspect of implementation to be challenging and complex, as most patients screened had findings that required followup. Specifically, 56 percent of screened patients had one or more nodules that required tracking and 41 percent had incidental findings. Implementation required substantial resources for manual abstraction of patient information from records and the creation of dedicated tracking and patient coordination systems.^38^

While there is no comprehensive accounting of patient coordination and tracking systems in the United States, surveys and interviews have found that both primary care physicians and subspecialists have concerns about whether there is sufficient personnel and tracking infrastructure needed for screening implementation.^37,^ ^345–349,^ ^363^

### Out-of-Pocket Costs for Followup of Screen-Detected Findings

ACA insurance plans are required to cover LDCTs done for screening. However, patients with screen-detected nodules enter diagnostic and surveillance pathways involving evaluations, imaging, and procedures that are not considered screening and are subject to copays and deductibles. Since the 2013 USPSTF statement, multiple studies in both patients and providers have identified the issue that the costs of followup testing after positive screening results will lead to financial harm for patients.^37,^ ^346–349,^ ^364,^ ^365^ Even if less aggressive nodule categorization approaches (e.g., Lung-RADS) are used, the number of patients who will enter surveillance pathways for screen-detected nodules is large. Given that high-deductible insurance plans among low and middle-income Americans, the issue of patient cost as a barrier to lung cancer screening implementation requires further study.^366^

## CQ 2a Are the Participants of Randomized, Controlled Trials of Lung Cancer Screening (e.g., NLST) That Reported a Reduction in All-Cause or Lung Cancer Mortality Representative of Screening-Eligible U.S. Adults (Based on NLST Criteria or USPSTF Recommendations)?

## b How Do the 5-Year Survival Rate and Life Expectancy of Persons Eligible for Lung Cancer Screening in the United States (Based on NLST Criteria or USPSTF Recommendations) Compare With Those of NLST Participants?

## c Are the Settings and Providers in Randomized, Controlled Trials of Lung Cancer Screening (e.g., NLST) That Reported a Reduction in All-Cause or Lung Cancer Mortality Representative of U.S. Health Care Settings and Providers?

The Discussion of this report describes the applicability of NLST and other included studies. Briefly, NLST participants were younger, more highly educated, and less likely to be current smokers than the U.S. screening-eligible population.^367^ Furthermore, the NLST was mainly conducted at large academic centers, potentially limiting its applicability to community-based practice (e.g., because of challenges with implementation, level of expertise). Many of the trial centers are well-recognized for expertise in radiology as well as cancer diagnosis and treatment.^32^ Community centers may be less equipped for screening programs and for treatment of lung cancers identified by screening. For example, the NLST publication noted that mortality associated with surgical resection of lung cancer was much lower in the trial than that reported for the U.S. population (1% vs. 4%).^32,^ ^296^

A study using data from the 2012 Health and Retirement Study (HRS) (a national survey of adults 50 and older) evaluated comorbidities, life expectancy, smoking history, and other characteristics in the screening-eligible population and in NLST participants; it reported a lower 5-year survival rate and life expectancy in the screening-eligible persons compared with NLST participants (87% vs. 93%, p<0.001, and 18.7 years vs. 21.2 years, respectively).^25^ Screening-eligible HRS respondents were older, more likely to be current smokers, and more likely to have been diagnosed with comorbidities than NLST participants. The authors concluded that the general U.S. population eligible for lung cancer screening is probably less likely to benefit from early detection compared with the NLST participants because they face a high risk of death from competing causes, such as heart disease, diabetes, or stroke.

## CQ 3 Does Screening for Lung Cancer With LDCT Have Unintended Benefits From Detecting Incidental Findings (e.g., Coronary Artery Calcium, Chronic Obstructive Pulmonary Disease, or Extrapulmonary Nodules) Leading to Interventions That Improve Health Outcomes?

Common incidental findings identified in this systematic review included coronary artery calcification, aortic aneurysms, emphysema, infections, and masses or nodules (e.g., of the thyroid or pancreas), among others. There is no trial evidence to indicate that screening with LDCT for such findings has greater unintended benefit than unintended harm. The USPSTF portfolio includes evidence reviews and recommendations covering the evidence on potential benefits and harms of screening for many of these conditions/findings in asymptomatic persons. The evidence reviews have resulted in I statements (i.e., insufficient evidence) and D recommendations (i.e., harm of screening greater than benefit). For example, the USPSTF recommendation statement on nontraditional cardiovascular risk factors concluded that the current evidence is insufficient to assess the balance of benefits and harms of screening for coronary artery calcium (CAC) in asymptomatic adults to prevent CVD events.^368^ Further, USPSTF had D recommendations for screening for chronic obstructive pulmonary disease (COPD),^369^ thyroid cancer,^370^ and pancreatic cancer in asymptomatic adults. Regarding screening for aneurysms, USPSTF recommends one-time screening for abdominal aortic aneurysm (AAA) with ultrasonography in men ages 65 to 75 years who have ever smoked^371^; an update is in progress.^372^ There is no trial evidence to indicate greater benefit than harm for using LDCT to screen for aneurysms (thoracic or abdominal).

## CQ 4 What Is the Effectiveness of Smoking Cessation Intervention Among Patients Receiving LDCT Screening?

The provision of smoking cessation interventions with LDCT screening is an opportunity to improve health outcomes. In the NLST, screening with LDCT combined with smoking abstinence of 15 years provided the greatest reduction in lung cancer mortality (comparing, for example, with screening with LDCT and current smoking).^373^ The Centers for Medicare & Medicaid Services also requires that smokers who undergo screening receive counseling on smoking cessation so as not to mistake screening as either a substitute for cessation or a confirmation that it is acceptable to continue smoking if the screening result is normal.^374^ The USPSTF recommends that clinicians ask all adults about tobacco use, advise them to stop using tobacco, and provide behavioral interventions and U.S. Food and Drug Administration (FDA)–approved pharmacotherapy for cessation to adults who use tobacco.^375^

Two systematic reviews focused on this contextual question.^376,^ ^377^ Assessment of these reviews using AMSTAR-2 criteria indicates at least moderate confidence in the results.^378^ Neither systematic review conducted meta-analyses because of heterogeneity of interventions and other factors. The first systematic review^376^ included six studies published through July 1, 2015: three randomized, controlled trials (RCTs) (with a total of 1473 participants) and three uncontrolled studies (total 7,333 participants).^376^ Two of the RCTs compared the use of written self-help materials with internet or computer-based tailored self-help materials for smoking cessation intervention among patients receiving lung cancer screening and found no statistically significant difference in abstinence rates between groups.^379,^ ^380^ The third RCT evaluated the effect of smoking cessation interventions before and after LDCT and found that smoking intervention before LDCT led to numerically higher abstinence rates at 4 months (33.3 vs. 22.2%) and 6 months (22.2% vs. 11.1%) after treatment,^381^ although statistical testing was not provided for the comparison between groups (a subsequently published systematic review conducted its own statistical tests for those comparisons and reported no significant difference between groups, p=1.0^377^). Continuous abstinence rates in uncontrolled studies ranged from 19.8 percent at 1-year followup^382^ to 57.1 percent at 6-months followup^383^ across included studies. No rating of the risk of bias of included studies was reported. The authors reported that their findings suggest that there are benefits to implementing smoking cessation interventions in lung cancer screening programs, which may represent a teachable moment to quit smoking.^376^

The second systematic review^377^ included nine studies published through May 1, 2018. It restricted eligibility to RCTs and observational studies with a comparison group, which excluded the three single-arm studies that were in the other^376^ systematic review. The included five RCTs (with a total of 1,620 participants) and four observational studies (total 5,114 participants) were rated as poor to fair quality with significant potential for bias and limited generalizability.^377^ Though the studies provided insufficient evidence to support a particular approach to smoking cessation interventions in the LDCT screening setting, the authors suggested that more intensive interventions (e.g., multiple counseling sessions) appear to be more effective approaches to smoking cessation. Table 7 summarizes the five RCTs included in the review. Sample sizes ranged from 18 to 1,284, with three of the studies having fewer than 100 participants. The largest study (with 1,284 participants) was part of the NELSON lung cancer screening trial.^380^ Only one of the studies found a statistically significant difference in smoking cessation outcomes between groups, with an intervention of six weekly telephone counseling calls compared to a list of resources.^384^ Two of the studies used two or fewer counseling sessions as the intervention, while the other two distributed tailored smoking cessation resources. Four of the comparison groups for the RCTs distributed nontailored resources; the other altered the timing of smoking cessation counseling sessions. The authors of the systematic review conducted a search of ongoing trials, finding 11 ongoing RCTs assessing smoking cessation interventions in the context of LDCT screening.^377^

In sum, limited evidence exists to establish the effectiveness of smoking cessation interventions in lung cancer screening programs. However, this is an active area of research, with numerous ongoing trials comparing intervention methods. Further research to determine components of smoking cessation interventions that can optimize outcome by testing different modalities in lung cancer screening programs and to identify strategies to effectively integrate smoking cessation interventions in lung cancer screening sites have also been suggested.

Appendix A Table 6 Summary of Multilevel Barriers to Effective Lung Cancer Screening

Patient-level barriers
- Competing needs and demands for health care; - Cost; - Fear (e.g., procedures, diagnosis, treatment); - Lack of awareness; - Lack of interest due to stigma associated with smoking; - Limited access to care due to financial or social factors; - Limited information and misinformation; - Logistical issues (e.g., inconvenience, time); - Mistrust of the health care system and/or health care; - Nihilism
Provider-level barriers
- Competing demands for time; - Evolving attitudes about the effectiveness of screening; - Lack of awareness; - Limited information and misinformation; - Limited training in SDM; - Nihilism related to treatment of lung cancer; - Requirement for behavior change (adaptive challenge)
System-level barriers
- Lack of support from health system leaders; - Limited resources to support screening, including equipment, personnel, and information technology resources; - Competing demands for limited resources (e.g., other screening programs or preventive health interventions); - Uncertain return on investment; - Complexity of implementation (requires multidisciplinary collaboration); ○ Conflicting upper age range recommendations for screening; ○ Identification of screening-eligible patients (gaps in smoking status data)

Source: Carter-Harris L, Gould MK. Multilevel barriers to the successful implementation of lung cancer screening: why does it have to be so hard? Ann Am Thorac Soc. 2017 Aug;14(8):1261–5. doi: 10.1513/AnnalsATS.201703-204PS. PMID: 2854174928541749 .^340^

Appendix A Table 7 Summary of Randomized, Controlled Trials in the Systematic Review From 2019

Author, Year | Trial | Sample Size | Intervention | Comparison | Findings
Clark, 2004^379^ | NA | 171 | Internet-based resources (10 links). | Written self-help materials from the NCI. | No significant difference in 12 month quit rates or change in readiness to quit. Increased number of quit attempts in intervention group (p=0.011).
Aalst, 2012^380^ | NELSON | 1284 | Computer-generated, tailored self-help material based on input of individual smoking behaviors and history. | Standard brochure with smoking cessation information for different stages of readiness to quit. | No significant difference in point prevalence, quit attempts, or prolonged smoking abstinence at 24 months followup.
Ferketich, 2012^381^ | NA | 18 | Smoking cessation counseling with a medical oncologist occurring before LDCT performed followed by 12-week tobacco dependence protocol. | Smoking cessation counseling with a medical oncologist occurring after LDCT performed followed by 12-week tobacco dependence protocol. | No significant difference in abstinence among those who received counseling before LDCT and those who received counseling after LDCT at 4 months and 6 months.
Marshall, 2016^385^ | NA | 55 | Single face-to-face tailored counseling session with take-home audio education materials, printed materials, and telephone helpline referral. | Nontailored printed smoking cessation materials and telephone helpline referral. | No significant difference in quit rates at 12 months for patients receiving counseling intervention compared to the control group.
Taylor, 2017^384^ | NA | 92 | Resources list plus 6 weekly, proactive counseling calls. | Resource list: Booklet, website, contact information for local resources, text messaging link. | Higher 7-day point prevalence cessation at 3-months in patients who received telephone counseling.

Abbreviations: LDCT=low-dose computed tomography; NA=not applicable; NCI=National Cancer Institute; NELSON=Dutch-Belgian Randomized Lung Cancer Screening Trial.