# References

1 Siu AL, USPSTF. Screening for high blood pressure in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2015;163(10):778–86. PMID: 26458123. 10.7326/M15-2223 26458123
2 National High Blood Pressure Education Program. The Seventh Report on the Joint National Committee on prevention, detection, evaluation, and treatment of high blood pressure. Washington, DC: National Institutes of Health; 2004.
3 Beevers G, Lip GY, O’Brien E. ABC of hypertension. Blood pressure measurement. Part I-sphygmomanometry: factors common to all techniques. BMJ. 2001;322(7292):981–5. PMID: 11312235. 10.1136/bmj.322.7292.981 11312235
4 National Institute for Health and Clinical Excellence. Hypertension: The Clinical Management of Primary Hypertension in Adults. Clinical Guideline 127 London, England National Institute for Health and Clinical Excellence,; 2011. PMID: 2285597122855971.
5 Ogedegbe G, Pickering T. Principles and techniques of blood pressure measurement. Cardiology clinics. 2010;28(4):571–86. PMID: 20937442. 10.1016/j.ccl.2010.07.006 20937442
6 Pickering TG, Miller NH, Ogedegbe G, . Call to action on use and reimbursement for home blood pressure monitoring: a joint scientific statement from the American Heart Association, American Society Of Hypertension, and Preventive Cardiovascular Nurses Association. Hypertension. 2008;52(1):10–29. PMID: 18596492. 10.1097/01.jcn.0000317429.98844.04 18497370
7 Carretero OA, Oparil S. Essential hypertension. Part I: definition and etiology. Circulation. 2000;101(3):329–35. PMID: 10645931. 10.1161/01.cir.101.3.329 10645931
8 Patel SA, Winkel M, Ali MK, . Cardiovascular mortality associated with 5 leading risk factors: national and state preventable fractions estimated from survey data. Ann Intern Med. 2015;163(4):245–53. PMID: 26121190. 10.7326/m14-1753 26121190
9 Harris R, Sawaya GF, Moyer VA, . Reconsidering the criteria for evaluating proposed screening programs: reflections from 4 current and former members of the U.S. Preventive services task force. Epidemiol Rev. 2011;33:20–35. PMID: 21666224. 10.1093/epirev/mxr005 21666224
10 LeFevre ML. ACC/AHA Hypertension Guideline: What Is New? What Do We Do? American family physician. 2018;97(6):372–3. PMID: 29671534.29671534
11 Korhonen PE, Kautiainen H, Jarvenpaa S, . Target organ damage and cardiovascular risk factors among subjects with previously undiagnosed hypertension. European journal of preventive cardiology. 2014;21(8):980–8. PMID: 23335655. 10.1177/2047487312474530 23335655
12 Nadar SK, Tayebjee MH, Messerli F, . Target organ damage in hypertension: pathophysiology and implications for drug therapy. Current pharmaceutical design. 2006;12(13):1581–92. PMID: 16729871. 10.2174/138161206776843368 16729871
13 Institute of Medicine. A Population-Based Policy and Systems Change Approach to Prevent and Control Hypertension. Washington, DC: The National Academies Press; 2010.
14 Patnode CD, Evans CV, Senger CA, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2017;318(2):175–93. PMID: 28697259. 10.1001/jama.2017.3303 28697259
15 Graudal NA, Hubeck-Graudal T, Jurgens G. Effects of low sodium diet versus high sodium diet on blood pressure, renin, aldosterone, catecholamines, cholesterol, and triglyceride. The Cochrane database of systematic reviews. 2017;4:CD004022. 10.1002/14651858.CD004022.pub4 28391629
16 Rees K, Dyakova M, Wilson N, . Dietary advice for reducing cardiovascular risk. The Cochrane database of systematic reviews. 2013(12):CD002128. 10.1002/14651858.CD002128.pub5
17 Musini VM, Gueyffier F, Puil L, . Pharmacotherapy for hypertension in adults aged 18 to 59 years. The Cochrane database of systematic reviews. 2017;8:Cd008276. PMID: 28813123. 10.1002/14651858.cd008276.pub2 28813123
18 Musini VM, Tejani AM, Bassett K, . Pharmacotherapy for hypertension in the elderly. The Cochrane database of systematic reviews. 2009(4):Cd000028. PMID: 19821263. 10.1002/14651858.cd000028.pub2 19821263
19 Sprint Research Group, Wright JT, Jr., Williamson JD, . A Randomized Trial of Intensive versus Standard Blood-Pressure Control. N Engl J Med. 2015;373(22):2103–16. PMID: 26551272. 10.1056/nejmoa1511939 26551272
20 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Hypertension. 2017;71(6):e13–e115. PMID: 29133356. 10.1161/hyp.0000000000000065 29133356
21 Ostchega Y, Fryar CD, Nwankwo T, . Hypertension Prevalence Among Adults Aged 18 and Over: United States, 2017-2018. NCHS Data Brief. 2020(364):1–8. PMID: 32487290.32487290
22 Muntner P, Hardy ST, Fine LJ, . Trends in Blood Pressure Control Among US Adults With Hypertension, 1999-2000 to 2017-2018. JAMA. 2020;324(12):1190–200. PMID: 32902588. 10.1001/jama.2020.14545 32902588
23 Lewington S, Clarke R, Qizilbash N, . Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903–13. PMID: 12493255. 10.1016/s0140-6736(02)11911-8 12493255
24 Flint AC, Conell C, Ren X, . Effect of Systolic and Diastolic Blood Pressure on Cardiovascular Outcomes. N Engl J Med. 2019;381(3):243–51. PMID: 31314968. 10.1056/NEJMoa1803180 31314968
25 Weber MA, Townsend RR. Building the case for central blood pressure. Journal of the American College of Cardiology. 2013;62(19):1788–90. PMID: 23850920. 10.1016/j.jacc.2013.06.028 23850920
26 Benjamin EJ, Blaha MJ, Chiuve SE, . Heart Disease and Stroke Statistics-2017 Update: A Report From the American Heart Association. Circulation. 2017;135(10):e146–e603. PMID: 28122885. 10.1161/CIR.0000000000000485 28122885
27 Vasan RS, Beiser A, Seshadri S, . Residual lifetime risk for developing hypertension in middle-aged women and men: The Framingham Heart Study. JAMA. 2002;287(8):1003–10. PMID: 11866648. 10.1001/jama.287.8.1003 11866648
28 Piper MA, Evans CV, Burda BU, . Screening for High Blood Pressure in Adults: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): 2014.
29 Fryar CD, Ostchega Y, Hales CM, . Hypertension Prevalence and Control Among Adults: United States, 2015-2016. NCHS Data Brief. 2017(289):1–8. PMID: 29155682.29155682
30 Kallioinen N, Hill A, Horswill MS, . Sources of inaccuracy in the measurement of adult patients’ resting blood pressure in clinical settings: a systematic review. Journal of hypertension. 2017;35(3):421–41. PMID: 27977471. 10.1097/HJH.0000000000001197 27977471
31 Muntner P, Shimbo D, Carey RM, . Measurement of Blood Pressure in Humans: A Scientific Statement From the American Heart Association. Hypertension. 2019;73(5):e35–e66. PMID: 30827125. 10.1161/HYP.0000000000000087 30827125
32 Conen D, Aeschbacher S, Thijs L, . Age-specific differences between conventional and ambulatory daytime blood pressure values. Hypertension. 2014;64(5):1073–9. PMID: 25185130. 10.1161/HYPERTENSIONAHA.114.03957 25185130
33 Omboni S, Aristizabal D, De la Sierra A, . Hypertension types defined by clinic and ambulatory blood pressure in 14 143 patients referred to hypertension clinics worldwide. Data from the ARTEMIS study. Journal of hypertension. 2016;34(11):2187–98. PMID: 27512964. 10.1097/HJH.0000000000001074 27512964
34 Leung AA, Daskalopoulou SS, Dasgupta K, . Hypertension Canada’s 2017 Guidelines for Diagnosis, Risk Assessment, Prevention, and Treatment of Hypertension in Adults. The Canadian journal of cardiology. 2017;33(5):557–76. PMID: 28449828. 10.1016/j.cjca.2017.03.005 28449828
35 Myers MG, Godwin M, Dawes M, . Measurement of blood pressure in the office: recognizing the problem and proposing the solution. Hypertension. 2010;55(2):195–200. PMID: 20038756. 10.1161/HYPERTENSIONAHA.109.141879 20038756
36 Pickering TG, Hall JE, Appel LJ, . Recommendations for blood pressure measurement in humans and experimental animals: part 1: blood pressure measurement in humans: a statement for professionals from the Subcommittee of Professional and Public Education of the American Heart Association Council on High Blood Pressure Research. Circulation. 2005;111(5):697–716. PMID: 15699287. 10.1161/01.cir.0000154900.76284.f6 15699287
37 Asayama K, Thijs L, Li Y, . Setting thresholds to varying blood pressure monitoring intervals differentially affects risk estimates associated with white-coat and masked hypertension in the population. Hypertension. 2014;64(5):935–42. PMID: 25135185. 10.1161/HYPERTENSIONAHA.114.03614 25135185
38 Pierdomenico SD, Cuccurullo F. Prognostic value of white-coat and masked hypertension diagnosed by ambulatory monitoring in initially untreated subjects: an updated meta analysis. American journal of hypertension. 2011;24(1):52–8. PMID: 20847724. 10.1038/ajh.2010.203 20847724
39 Wang YC, Shimbo D, Muntner P, . Prevalence of Masked Hypertension Among US Adults With Nonelevated Clinic Blood Pressure. American journal of epidemiology. 2017;185(3):194–202. PMID: 28100465. 10.1093/aje/kww237 28100465
40 Al Hamarneh YN, Houle SK, Chatterley P, . The validity of blood pressure kiosk validation studies: a systematic review. [Review]. Blood pressure monitoring. 2013;18(3):167–72. PMID: 23635486. 10.1097/mbp.0b013e328360fb85 23635486
41 Yang WY, Melgarejo JD, Thijs L, . Association of Office and Ambulatory Blood Pressure With Mortality and Cardiovascular Outcomes. JAMA. 2019;322(5):409–20. PMID: 31386134. 10.1001/jama.2019.9811 31386134
42 Shimbo D, Artinian NT, Basile JN, . Self-Measured Blood Pressure Monitoring at Home: A Joint Policy Statement From the American Heart Association and American Medical Association. Circulation. 2020;142(4):e42–e63. PMID: 32567342. 10.1161/cir.0000000000000803 32567342
43 Cohen JB, Padwal RS, Gutkin M, . History and Justification of a National Blood Pressure Measurement Validated Device Listing. Hypertension. 2019;73(2):258–64. PMID: 30580681. 10.1161/HYPERTENSIONAHA.118.11990 30580681
44 Shimbo D. Daichi Shimbo personal communication (Sep 23, 2019). 2019. PMID.
45 Hodgkinson JA, Sheppard JP, Heneghan C, . Accuracy of ambulatory blood pressure monitors: a systematic review of validation studies. Journal of hypertension. 2013;31(2):239–50. PMID: 23303347. 10.1097/hjh.0b013e32835b8d8b 23303347
46 Bello NA, Woolley JJ, Cleary KL, . Accuracy of Blood Pressure Measurement Devices in Pregnancy: A Systematic Review of Validation Studies. Hypertension. 2018;71(2):326–35. PMID: 29229741. 10.1161/HYPERTENSIONAHA.117.10295 29229741
47 Rui P, Okeyode T. National Ambulatory Medical Care Survey: 2016 National Summary Tables. https://www.cdc.gov/nchs/data/ahcd/namcs_summary/2016_namcs_web_tables.pdf. Accessed.
48 Woolsey S, Brown B, Ralls B, . Diagnosing Hypertension in Primary Care Clinics According to Current Guidelines. J Am Board Fam Med. 2017;30(2):170–7. PMID: 28379823. 10.3122/jabfm.2017.02.160111 28379823
49 Carter BU, Kaylor MB. The use of ambulatory blood pressure monitoring to confirm a diagnosis of high blood pressure by primary-care physicians in Oregon. Blood pressure monitoring. 2016;21(2):95–102. PMID: 26683382. 10.1097/MBP.0000000000000166 26683382
50 Ray GM, Nawarskas JJ, Anderson JR. Blood pressure monitoring technique impacts hypertension treatment. Journal of general internal medicine. 2012;27(6):623–9. PMID: 22160847. 10.1007/s11606-011-1937-9 22160847
51 Levy J, Gerber LM, Wu X, . Nonadherence to Recommended Guidelines for Blood Pressure Measurement. Journal of Clinical Hypertension. 2016;18(11):1157–61. 10.1111/jch.12846 27246635
52 Burgess SE, MacLaughlin EJ, Smith PA, . Blood pressure rising: differences between current clinical and recommended measurement techniques. Journal of the American Society of Hypertension. 2011;5(6):484–8. PMID: 22015319. 10.1016/j.jash.2011.08.007 22015319
53 Minor DS, Butler KR, Jr., Artman KL, . Evaluation of blood pressure measurement and agreement in an academic health sciences center. Journal of clinical hypertension (Greenwich, Conn). 2012;14(4):222–7. PMID: 22458743. 10.1111/j.1751-7176.2012.00599.x 22458743
54 Kronish IM, Kent S, Moise N, . Barriers to conducting ambulatory and home blood pressure monitoring during hypertension screening in the United States. Journal of the American Society of Hypertension. 2017;11(9):573–80. PMID: 28734798. 10.1016/j.jash.2017.06.012 28734798
55 Tunis S, Kendall P, Londner M, . National Coverage Decision: Decision Memo for Ambulatory Blood Pressure Monitoring (CAG-00067N). Baltimore, MD: Centers for Medicare and Medicaid Services; 2001.
56 Shimbo D, Kent ST, Diaz KM, . The use of ambulatory blood pressure monitoring among Medicare beneficiaries in 2007-2010. Journal of the American Society of Hypertension. 2014;8(12):891–7. PMID: 25492832. 10.1016/j.jash.2014.09.015 25492832
57 Kent ST, Shimbo D, Huang L, . Rates, amounts, and determinants of ambulatory blood pressure monitoring claim reimbursements among Medicare beneficiaries. Journal of the American Society of Hypertension. 2014;8(12):898–908. PMID: 25492833. 10.1016/j.jash.2014.09.020 25492833
58 Syrek Jensen T, Chin J, Ashby L, . National Coverage Determination: Decision Memo for Ambulatory Blood Pressure Monitoring (ABPM) (CAG-00067R2). Baltimore, MD: Centers for Medicare and Medicaid Services; 2019.
59 Report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. A cooperative study. JAMA. 1977;237(3):255–61. PMID: 276159.576159
60 Gueyffier F, Froment A, Gouton M. New meta-analysis of treatment trials of hypertension: improving the estimate of therapeutic benefit. Journal of human hypertension. 1996;10(1):1–8. PMID: 8642184.8642184
61 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed. Baltimore, MD: Williams & Wilkins; 1996.
62 U.S. Preventive Services Task Force. Screening for high blood pressure: recommendations and rationale. American Journal of Preventive Medicine. 2003;25(2):159–64. PMID: 12880885. 10.1016/s0749-3797(03)00122-3 12880885
63 U.S. Preventive Services Task Force. Screening for high blood pressure: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2007;147(11):783–6. PMID: 18056662. 10.7326/0003-4819-147-11-200712040-00009 18056662
64 Piper MA, Evans CV, Burda BU, . Diagnostic and predictive accuracy of blood pressure screening methods with consideration of rescreening intervals: a systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2015;162(3):192–204. PMID: 25531400. 10.7326/M14-1539 25531400
65 Roerecke M, Kaczorowski J, Myers MG. Comparing Automated Office Blood Pressure Readings With Other Methods of Blood Pressure Measurement for Identifying Patients With Possible Hypertension: A Systematic Review and Meta-analysis. JAMA internal medicine. 2019;179(3):351–62. PMID: 30715088. 10.1001/jamainternmed.2018.6551 30715088
66 Hodgkinson J, Mant J, Martin U, . Relative effectiveness of clinic and home blood pressure monitoring compared with ambulatory blood pressure monitoring in diagnosis of hypertension: systematic review. BMJ. 2011;342:d3621. PMID: 21705406. 10.1136/bmj.d3621 21705406
67 Melgarejo JD, Maestre GE, Thijs L, . Prevalence, Treatment, and Control Rates of Conventional and Ambulatory Hypertension Across 10 Populations in 3 Continents. Hypertension. 2017;70(1):50–8. PMID: 28483916. 10.1161/HYPERTENSIONAHA.117.09188 28483916
68 National Institute for Health and Care Excellence. Hypertension in adults: diagnosis and managment, draft for consultation. Mar 2019.
69 Omboni S, Kario K, Bakris G, . Effect of antihypertensive treatment on 24-h blood pressure variability: pooled individual data analysis of ambulatory blood pressure monitoring studies based on olmesartan mono or combination treatment. Journal of hypertension. 2018;36(4):720–33. 10.1097/HJH.0000000000001608 29045341
70 Webb AJ, Fischer U, Mehta Z, . Effects of antihypertensive-drug class on interindividual variation in blood pressure and risk of stroke: a systematic review and meta-analysis. Lancet. 2010;375(9718):906–15. PMID: 20226989. 10.1016/S0140-6736(10)60235-8 20226989
71 United Nations Development Programme. Human Development Report 2016: Human Development Everyone. New York, NY: United Nations Development Programme; 2016.
72 Hansen TW, Kikuya M, Thijs L, . Prognostic superiority of daytime ambulatory over conventional blood pressure in four populations: a meta-analysis of 7,030 individuals. Journal of hypertension. 2007;25(8):1554–64. PMID: 17620947. 10.1097/hjh.0b013e3281c49da5 17620947
73 Shin J, Park SH, Kim JH, . Discordance between ambulatory versus clinic blood pressure according to global cardiovascular risk group. The Korean journal of internal medicine. 2015;30(5):610–9. PMID: 26354055. 10.3904/kjim.2015.30.5.610 26354055
74 de la Sierra A, Vinyoles E, Banegas JR, . Prevalence and clinical characteristics of white-coat hypertension based on different definition criteria in untreated and treated patients. Journal of hypertension. 2017;35(12):2388–94. PMID: 28723880. 10.1097/HJH.0000000000001493 28723880
75 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
76 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: December 3, 2018.
77 Whiting P, Rutjes AW, Reitsma JB, . The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. PMID: 14606960. 10.1186/1471-2288-3-25 14606960
78 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
79 Williams B, Mancia G, Spiering W, . 2018 ESC/ESH Guidelines for the management of arterial hypertension. Eur Heart J. 2018;39(33):3021–104. PMID: 30165516. 10.1093/eurheartj/ehy339 30165516
80 Larkin KT, Schauss SL, Elnicki DM. Isolated clinic hypertension and normotension: false positives and false negatives in the assessment of hypertension. Blood pressure monitoring. 1998;3:247–54.
81 Hanninen MR, Niiranen TJ, Puukka PJ, . Comparison of home and ambulatory blood pressure measurement in the diagnosis of masked hypertension. Journal of hypertension. 2010;28(4):709–14. PMID: 20061982. 10.1097/HJH.0b013e3283369faa 20061982
82 Gill P, Haque MS, Martin U, . Measurement of blood pressure for the diagnosis and management of hypertension in different ethnic groups: one size fits all. BMC Cardiovasc Disord. 2017;17(1):55. PMID: 28178928. 10.1186/s12872-017-0491-8 28178928
83 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]. The Cochrane Collaboration, 2011.
84 Centers for Disease Control and Prevention, National Center for Health Statistics. Health, United States, 2017 - Data Finder. https://www.cdc.gov/nchs/hus/contents2017.htm#054. Accessed: 06/15/2019, 2019.
85 Centers for Disease Control and Prevention, National Center for Health Statistics. National Health Interview Survey: Tables of Summary Health Statistics. https://www.cdc.gov/nchs/nhis/SHS/tables.htm. Accessed: 06/15/2019, 2019.
86 Centers for Disease Control and Prevention, National Center for Health Statistics. Summary Health Statistics: National Health Interview Survey, 2017. Table A-1. https://ftp.cdc.gov/pub/Health_Statistics/NCHS/NHIS/SHS/2017_SHS_Table_A-1.pdf. Accessed: 06/15/2019.
87 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314–49.
88 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
89 Kaczorowski J, Chambers LW, Dolovich L, . Improving cardiovascular health at population level: 39 community cluster randomised trial of Cardiovascular Health Awareness Program (CHAP). BMJ. 2011;342:d442. PMID: 21300712. 10.1136/bmj.d442 21300712
90 Abdalla M, Goldsmith J, Muntner P, . Is Isolated Nocturnal Hypertension A Reproducible Phenotype? American journal of hypertension. 2016;29(1):33–8. PMID: 25904648. 10.1093/ajh/hpv058 25904648
91 Fagard RH, van den Broeke C, de Cort P. Prognostic significance of blood pressure measured in the office, at home and during ambulatory monitoring in older patients in general practice. Journal of human hypertension. 2005;19(10):801–7. PMID: 15959536. 10.1038/sj.jhh.1001903 15959536
92 Gosse P, Dauphinot V, Roche F, . Prevalence of clinical and ambulatory hypertension in a population of 65-year-olds: the PROOF study. Journal of clinical hypertension (Greenwich, Conn). 2010;12(3):160–5. PMID: 20433528. 10.1111/j.1751-7176.2009.00235.x 20433528
93 Gourlay SG, McNeil JJ, Marriner T, . Discordance of mercury sphygmomanometer and ambulatory blood pressure measurements for the detection of untreated hypertension in a population study. Journal of human hypertension. 1993;7(5):467–72. PMID: 8263887.8263887
94 Hansen TW, Jeppesen J, Rasmussen S, . Ambulatory blood pressure monitoring and risk of cardiovascular disease: a population based study. American journal of hypertension. 2006;19(3):243–50. PMID: 16500508. 10.1016/j.amjhyper.2005.09.018 16500508
95 Ishikawa J, Hoshide S, Eguchi K, . Masked hypertension defined by ambulatory blood pressure monitoring is associated with an increased serum glucose level and urinary albumin-creatinine ratio. Journal of clinical hypertension (Greenwich, Conn). 2010;12(8):578–87. PMID: 20695934. 10.1111/j.1751-7176.2010.00286.x 20695934
96 Kanno A, Metoki H, Kikuya M, . Usefulness of assessing masked and white-coat hypertension by ambulatory blood pressure monitoring for determining prevalent risk of chronic kidney disease: the Ohasama study. Hypertension research. 2010;33(11):1192–8. PMID: 20703228. 10.1038/hr.2010.139 20703228
97 Lyamina NP, Smith ML, Lyamina SV, . Pressor response to 30-s breathhold: a predictor of masked hypertension. Blood Press. 2012;21(6):372–6. PMID: 22725829. 10.3109/08037051.2012.694213 22725829
98 Mancia G, Facchetti R, Bombelli M, . Long-term risk of mortality associated with selective and combined elevation in office, home, and ambulatory blood pressure. Hypertension. 2006;47(5):846–53. PMID: 16567588. 10.1161/01.HYP.0000215363.69793.bb 16567588
99 O’Flynn AM, Curtin RJ, Perry IJ, . Hypertension Prevalence, Awareness, Treatment, and Control: Should 24-Hour Ambulatory Blood Pressure Monitoring be the Tool of Choice? J Clin Hypertens. 2016;18(7):697–702. PMID: 26611695. 10.1111/jch.12737 26611695
100 Poudel B, Booth JN, 3rd, Sakhuja S, . Prevalence of ambulatory blood pressure phenotypes using the 2017 American College of Cardiology/American Heart Association blood pressure guideline thresholds: data from the Coronary Artery Risk Development in Young Adults study. Journal of hypertension. 2019;37(7):1401–10. PMID: 31145711. 10.1097/HJH.0000000000002055 31145711
101 Scuteri A, Morrell CH, Orru M, . Gender specific profiles of white coat and masked hypertension impacts on arterial structure and function in the SardiNIA study. International journal of cardiology. 2016;217:92–8. PMID: 27179214. 10.1016/j.ijcard.2016.04.172 27179214
102 Selenta C, Hogan BE, Linden W. How often do office blood pressure measurements fail to identify true hypertension? An exploration of white-coat normotension. Arch Fam Med. 2000;9(6):533–40. PMID: 10862216. 10.1001/archfami.9.6.533 10862216
103 Shimbo D, Newman JD, Schwartz JE. Masked hypertension and prehypertension: diagnostic overlap and interrelationships with left ventricular mass: the Masked Hypertension Study. American journal of hypertension. 2012;25(6):664–71. PMID: 22378035. 10.1038/ajh.2012.15 22378035
104 Thomas SJ, Booth JN, 3rd, Bromfield SG, . Clinic and ambulatory blood pressure in a population-based sample of African Americans: the Jackson Heart Study. Journal of the American Society of Hypertension. 2017;11(4):204–12.e5. PMID: 28285829. 10.1016/j.jash.2017.02.001 28285829
105 Wei FF, Zhang ZY, Thijs L, . Conventional and Ambulatory Blood Pressure as Predictors of Retinal Arteriolar Narrowing. Hypertension. 2016;68(2):511–20. PMID: 27324224. 10.1161/HYPERTENSIONAHA.116.07523 27324224
106 Wojciechowska W, Stolarz-Skrzypek K, Olszanecka A, . Subclinical arterial and cardiac damage in white-coat and masked hypertension. Blood Press. 2016;25(4):249–56. PMID: 26953075. 10.3109/08037051.2016.1150563 26953075
107 Wood S, Martin U, Gill P, . Blood pressure in different ethnic groups (BP-Eth): a mixed methods study. BMJ Open. 2012;2(6):2012. PMID: 23129572. 10.1136/bmjopen-2012-001598 23129572
108 Martin U, Haque MS, Wood S, . Ethnicity and differences between clinic and ambulatory blood pressure measurements. American journal of hypertension. 2015;28(6):729–38. PMID: 25398890. 10.1093/ajh/hpu211 25398890
109 Sehestedt T, Jeppesen J, Hansen TW, . Can ambulatory blood pressure measurements substitute assessment of subclinical cardiovascular damage? Journal of hypertension. 2012;30(3):513–21. PMID: 22241138. 10.1097/HJH.0b013e32834f6f60 22241138
110 Hoshide S, Ishikawa J, Eguchi K, . Masked nocturnal hypertension and target organ damage in hypertensives with well-controlled self-measured home blood pressure. Hypertension research. 2007;30(2):143–9. PMID: 17460384. 10.1291/hypres.30.143 17460384
111 Hozawa A, Ohkubo T, Kikuya M, . Blood pressure control assessed by home, ambulatory and conventional blood pressure measurements in the Japanese general population: the Ohasama study. Hypertension research. 2002;25(1):57–63. PMID: 11924727. 10.1291/hypres.25.57 11924727
112 Imai Y, Tsuji I, Nagai K, . Ambulatory blood pressure monitoring in evaluating the prevalence of hypertension in adults in Ohasama, a rural Japanese community. Hypertension research. 1996;19(3):207–12. PMID: 8891750. 10.1291/hypres.19.207 8891750
113 Cuspidi C, Facchetti R, Bombelli M, . Risk of new-onset metabolic syndrome associated with white-coat and masked hypertension: data from a general population. Journal of hypertension. 2018;36(9):1833–9. PMID: 29965885. 10.1097/hjh.0000000000001767 29965885
114 Mancia G, Sega R, Bravi C, . Ambulatory blood pressure normality: results from the PAMELA study. Journal of hypertension. 1995;13(12 Pt 1):1377–90. PMID: 8866899.8866899
115 Muntner P, Lewis CE, Diaz KM, . Racial differences in abnormal ambulatory blood pressure monitoring measures: Results from the Coronary Artery Risk Development in Young Adults (CARDIA) study. American journal of hypertension. 2015;28(5):640–8. PMID: 25376639. 10.1093/ajh/hpu193 25376639
116 Scuteri A, Najjar SS, Orru M, . Age- and gender-specific awareness, treatment, and control of cardiovascular risk factors and subclinical vascular lesions in a founder population: the SardiNIA Study. Nutr Metab Cardiovasc Dis. 2009;19(8):532–41. PMID: 19321325. 10.1016/j.numecd.2008.11.004 19321325
117 Terracciano A, Scuteri A, Strait J, . Are personality traits associated with white-coat and masked hypertension? Journal of hypertension. 2014;32(10):1987–92; discussion 92. PMID: 25186529. 10.1097/HJH.0000000000000289 25186529
118 Oe Y, Shimbo D, Ishikawa J, . Alterations in diastolic function in masked hypertension: findings from the masked hypertension study. American journal of hypertension. 2013;26(6):808–15. PMID: 23446956. 10.1093/ajh/hpt021 23446956
119 Diaz KM, Veerabhadrappa P, Brown MD, . Prevalence, Determinants, and Clinical Significance of Masked Hypertension in a Population-Based Sample of African Americans: The Jackson Heart Study. American journal of hypertension. 2015;28(7):900–8. PMID: 25499058. 10.1093/ajh/hpu241 25499058
120 McMullan CJ, Hickson DA, Taylor HA, . Prospective analysis of the association of ambulatory blood pressure characteristics with incident chronic kidney disease. Journal of hypertension. 2015;33(9):1939–46; discussion 46. PMID: 26066645. 10.1097/HJH.0000000000000638 26066645
121 Mancia G, Fagard R, Narkiewicz K, . 2013 ESH/ESC Guidelines for the management of arterial hypertension: the Task Force for the management of arterial hypertension of the European Society of Hypertension (ESH) and of the European Society of Cardiology (ESC). Journal of hypertension. 2013;31(7):1281–357. PMID: 23817082. 10.1097/01.hjh.0000431740.32696.cc 23817082
122 Bayo J, Cos FX, Roca C, . Home blood pressure self-monitoring: diagnostic performance in white-coat hypertension. Blood pressure monitoring. 2006;11(2):47–52. PMID: 16534404. 10.1097/01.mbp.0000200479.19046.94 16534404
123 de la Sierra A, Vinyoles E, Banegas JR, . Short-Term and Long-Term Reproducibility of Hypertension Phenotypes Obtained by Office and Ambulatory Blood Pressure Measurements. J Clin Hypertens. 2016;18(9):927–33. PMID: 26890293. 10.1111/jch.12792 26890293
124 Ernst ME, Sezate GS, Lin W, . Indication-specific 6-h systolic blood pressure thresholds can approximate 24-h determination of blood pressure control. Journal of human hypertension. 2011;25(4):250–5. PMID: 20574446. 10.1038/jhh.2010.66 20574446
125 Ernst ME, Weber CA, Dawson JD, . How well does a shortened time interval characterize results of a full ambulatory blood pressure monitoring session? Journal of clinical hypertension (Greenwich, Conn). 2008;10(6):431–5. PMID: 18550932. 10.1111/j.1751-7176.2008.07784.x 18550932
126 Fogari R, Corradi L, Zoppi A, . Repeated office blood pressure controls reduce the prevalence of white-coat hypertension and detect a group of white-coat normotensive patients. Blood pressure monitoring. 1996;1(1):51–4. PMID: 10226202.10226202
127 Gerc V, Favrat B, Brunner HR, . Is nurse-measured blood pressure a valid substitute for ambulatory blood pressure monitoring? Blood pressure monitoring. 2000;5(4):203–9. PMID: 11035861. 10.1097/00126097-200008000-00002 11035861
128 Hoegholm A, Kristensen KS, Madsen NH, . White coat hypertension diagnosed by 24-h ambulatory monitoring. Examination of 159 newly diagnosed hypertensive patients. American journal of hypertension. 1992;5(2):64–70. PMID: 1550667. 10.1093/ajh/5.2.64 1550667
129 Hoegholm A, Kristensen KS, Madsen NH, . The frequency of white coat hypertension among patients with newly diagnosed hypertension. Cardiovasc Rev Rep. 1994;15:55–61. PMID: None.
130 Husain A, Lin FC, Tuttle LA, . The Reproducibility of Racial Differences in Ambulatory Blood Pressure Phenotypes and Measurements. American journal of hypertension. 2017;30(10):961–7. PMID: 28531258. 10.1093/ajh/hpx079 28531258
131 Kim S, Park JJ, Lee SA, . Diagnostic accuracy of manual office blood pressure measurement in ambulatory hypertensive patients in Korea. The Korean journal of internal medicine. 2018;33(1):113–20. PMID: 28602060. 10.3904/kjim.2016.161 28602060
132 Kotsis V, Stabouli S, Toumanidis S, . Target organ damage in “white coat hypertension” and “masked hypertension”. American journal of hypertension. 2008;21(4):393–9. PMID: 18292757. 10.1038/ajh.2008.15 18292757
133 Manios ED, Koroboki EA, Tsivgoulis GK, . Factors influencing white-coat effect. American journal of hypertension. 2008;21(2):153–8. PMID: 18174883. 10.1038/ajh.2007.43 18174883
134 Nasothimiou EG, Tzamouranis D, Rarra V, . Diagnostic accuracy of home vs. ambulatory blood pressure monitoring in untreated and treated hypertension. Hypertension research. 2012;35(7):750–5. PMID: 22357523. 10.1038/hr.2012.19 22357523
135 Nunan D, Thompson M, Heneghan CJ, . Accuracy of self-monitored blood pressure for diagnosing hypertension in primary care. Journal of hypertension. 2015;33(4):755–62; discussion 62. PMID: 25915880. 10.1097/HJH.0000000000000489 25915880
136 Park JS, Rhee MY, Namgung J, . Comparison of Optimal Diagnostic Thresholds of Hypertension With Home Blood Pressure Monitoring and 24-Hour Ambulatory Blood Pressure Monitoring. American journal of hypertension. 2017;30(12):1170–6. PMID: 28992112. 10.1093/ajh/hpx115 28992112
137 Presta V, Figliuzzi I, D’Agostino M, . Nocturnal blood pressure patterns and cardiovascular outcomes in patients with masked hypertension. J Clin Hypertens. 2018;20(9). PMID: 30058135. 10.1111/jch.13361 30058135
138 Rhee MY, Kim JY, Kim JH, . Optimal schedule of home blood-pressure measurements for the diagnosis of hypertension. Hypertension research. 2018;41(9):738–47. PMID: 29977083. 10.1038/s41440-018-0069-6 29977083
139 Salazar MR, Espeche WG, Stavile RN, . Could self-measured office blood pressure be a hypertension screening tool for limited-resources settings? Journal of human hypertension. 2018;32(6):415–22. PMID: 29713048. 10.1038/s41371-018-0057-y 29713048
140 Stergiou GS, Salgami EV, Tzamouranis DG, . Masked hypertension assessed by ambulatory blood pressure versus home blood pressure monitoring: is it the same phenomenon? American journal of hypertension. 2005;18(6):772–8. PMID: 15925734. 10.1016/j.amjhyper.2005.01.003 15925734
141 Stergiou GS, Skeva II, Baibas NM, . Diagnosis of hypertension using home or ambulatory blood pressure monitoring: comparison with the conventional strategy based on repeated clinic blood pressure measurements. Journal of hypertension. 2000;18(12):1745–51. PMID: 11132597. 10.1097/00004872-200018120-00007 11132597
142 Tocci G, Presta V, Figliuzzi I, . Prevalence and clinical outcomes of white-coat and masked hypertension: Analysis of a large ambulatory blood pressure database. J Clin Hypertens. 2018;20(2):297–305. PMID: 29370477. 10.1111/jch.13181 29370477
143 Ungar A, Pepe G, Monami M, . Isolated ambulatory hypertension is common in outpatients referred to a hypertension centre. Journal of human hypertension. 2004;18(12):897–903. PMID: 15241442. 10.1038/sj.jhh.1001756 15241442
144 Viera AJ, Lin FC, Tuttle LA, . Reproducibility of masked hypertension among adults 30 years or older. Blood pressure monitoring. 2014;19(4):208–15. PMID: 24842491. 10.1097/MBP.0000000000000054 24842491
145 Zabludowski JR, Rosenfeld JB. Evaluation of clinic blood pressure measurements: assessment by daytime ambulatory blood pressure monitoring. Isr J Med Sci. 1992;28(6):345–8. PMID: 1607269.1607269
146 Zakopoulos NA, Kotsis VT, Pitiriga V, . White-coat effect in normotension and hypertension. Blood pressure monitoring. 2002;7(5):271–6. PMID: 12409886. 10.1097/00126097-200210000-00004 12409886
147 de la Sierra A. Alejandro de la Sierra personal communication (Mar 11, 2019). 2019.
148 Ameling EH, de Korte DF, Man it, V. Impact of diagnosis and treatment of hypertension on quality of life: a double-blind, randomized, placebo-controlled, cross-over study of betaxolol. J Cardiovasc Pharmacol. 1991;18(5):752–60. PMID: 1723773. 10.1097/00005344-199111000-00014 1723773
149 Haynes RB, Sackett DL, Taylor DW, . Increased absenteeism from work after detection and labeling of hypertensive patients. N Engl J Med. 1978;299(14):741–4. PMID: 692548. 10.1056/NEJM197810052991403 692548
150 Mann AH. The psychological effect of a screening programme and clinical trial for hypertension upon the participants. Psychol Med. 1977;7(3):431–8. PMID: 905459.905459
151 Rudd P, Price MG, Graham LE, . Consequences of worksite hypertension screening. Changes in absenteeism. Hypertension. 1987;10(4):425–36. PMID: 3653971. 10.1161/01.hyp.10.4.425 3653971
152 Taylor DW, Haynes RB, Sackett DL, . Longterm follow-up of absenteeism among working men following the detection and treatment of their hypertension. Clin Invest Med. 1981;4(3–4):173–7. PMID: 7337988.7337988
153 [No author listed]. Randomised controlled trial of treatment for mild hypertension: design and pilot trial. Report of Medical Research Council Working Party on Mild to Moderate Hypertension. Br Med J. 1977;1(6074):1437–40. PMID: 324577. 10.1136/bmj.1.6074.1437 324577
154 Manning G, Vijan SG, Millar-Craig MW. [80] Does perception of sleep quality affect diurnal variation of blood pressure and heart rate during 24Hr blood pressure monitoring? Clin Sci. 1992;83:(Suppl 27):22P–3P. PMID: None.
155 Spruill TM, Feltheimer SD, Harlapur M, . Are there consequences of labeling patients with prehypertension? An experimental study of effects on blood pressure and quality of life. J Psychosom Res. 2013;74(5):433–8. PMID: 23597332. 10.1016/j.jpsychores.2013.01.009 23597332
156 Verdecchia P, Angeli F, Borgioni C, . Ambulatory blood pressure and cardiovascular outcome in relation to perceived sleep deprivation. Hypertension. 2007;49(4):777–83. PMID: 17261645. 10.1161/01.HYP.0000258215.26755.20 17261645
157 Viera AJ, Lingley K, Esserman D. Effects of labeling patients as prehypertensive. J Am Board Fam Med. 2010;23(5):571–83. PMID: 20823351. 10.3122/jabfm.2010.05.100047 20823351
158 Viera AJ, Lingley K, Hinderliter AL. Tolerability of the Oscar 2 ambulatory blood pressure monitor among research participants: a cross-sectional repeated measures study. BMC Med Res Methodol. 2011;11:59. PMID: 21524301. 10.1186/1471-2288-11-59 21524301
159 Manning G, Rushton L, Donnelly R, . Variability of diurnal changes in ambulatory blood pressure and nocturnal dipping status in untreated hypertensive and normotensive subjects. American journal of hypertension. 2000;13(9):1035–8. PMID: 10981556. 10.1016/s0895-7061(00)00261-2 10981556
160 Nasothimiou EG, Karpettas N, Dafni MG, . Patients’ preference for ambulatory versus home blood pressure monitoring. Journal of human hypertension. 2013;28(4):224–9. PMID: 24152822. 10.1038/jhh.2013.104 24152822
161 Kuwajima I, Nishinaga M, Kanamaru A. The accuracy and clinical performance of a new compact ambulatory blood pressure monitoring device, the ES-H531. American journal of hypertension. 1998;11(11:Pt 1):t–33. PMID: 9832176. 10.1016/s0895-7061(98)00155-1 9832176
162 Tompson AC, Ward AM, McManus RJ, . Acceptability and psychological impact of out-of-office monitoring to diagnose hypertension: an evaluation of survey data from primary care patients. British Journal of General Practice. 2019;69(683):e389–e97. PMID: 30910876. 10.3399/bjgp19X702221 30910876
163 Sherwood A, Hill LK, Blumenthal JA, . The Effects of Ambulatory Blood Pressure Monitoring on Sleep Quality in Men and Women With Hypertension: Dipper vs. Nondipper and Race Differences. American journal of hypertension. 2019;32(1):54–60. PMID: 30204833. 10.1093/ajh/hpy138 30204833
164 Czernichow S, Zanchetti A, Turnbull F, . The effects of blood pressure reduction and of different blood pressure-lowering regimens on major cardiovascular events according to baseline blood pressure: meta-analysis of randomized trials. Journal of hypertension. 2011;29(1):4–16. PMID: 20881867. 10.1097/HJH.0b013e32834000be 20881867
165 Blood Pressure Lowering Treatment Trialists Collaboration. Blood pressure-lowering treatment based on cardiovascular risk: a meta-analysis of individual patient data. Lancet. 2014;384(9943):591–8. PMID: 25131978. 10.1016/S0140-6736(14)61212-5 25131978
166 Xie X, Atkins E, Lv J, . Effects of intensive blood pressure lowering on cardiovascular and renal outcomes: updated systematic review and meta-analysis. Lancet. 2016;387(10017):435–43. PMID: 26559744. 10.1016/S0140-6736(15)00805-3 26559744
167 Ettehad D, Emdin CA, Kiran A, . Blood pressure lowering for prevention of cardiovascular disease and death: a systematic review and meta-analysis. Lancet. 2016;387(10022):957–67. PMID: 26724178. 10.1016/S0140-6736(15)01225-8 26724178
168 Bundy JD, Li C, Stuchlik P, . Systolic Blood Pressure Reduction and Risk of Cardiovascular Disease and Mortality: A Systematic Review and Network Meta-analysis. JAMA Cardiol. 2017;2(7):775–81. PMID: 28564682. 10.1001/jamacardio.2017.1421 28564682
169 Brunstrom M, Carlberg B. Association of Blood Pressure Lowering With Mortality and Cardiovascular Disease Across Blood Pressure Levels: A Systematic Review and Meta-analysis. JAMA internal medicine. 2018;178(1):28–36. PMID: 29131895. 10.1001/jamainternmed.2017.6015 29131895
170 Moran AE, Pletcher MJ, Bibbins-Domingo K. Whom to Treat for High Blood Pressure-Time for a Precision Approach. JAMA internal medicine. 2018;178(1):37–8. PMID: 29297011. 10.1001/jamainternmed.2017.7853 29297011
171 Wilt TJ, Kansagara D, Qaseem A. Hypertension Limbo: Balancing Benefits, Harms, and Patient Preferences Before We Lower the Bar on Blood Pressure. Ann Intern Med. 2018;168(5):369–70. PMID: 29357397. 10.7326/M17-3293 29357397
172 National Institute for Health and Care Excellence. Hypertension in adults: diagnosis and managment. D. Evidence review for targets. 2019.
173 Weiss J, Kerfoot A, Freeman M, . Benefits and Harms of Treating Blood Pressure in Older Adults: A Systematic Review and Meta-analysis Department of Veterans Affairs, Health Services Research and Development Service; 2015.
174 Garrison SR, Kolber MR, Korownyk CS, . Blood pressure targets for hypertension in older adults. The Cochrane database of systematic reviews. 2017;8:CD011575. PMID: 28787537. 10.1002/14651858.CD011575.pub2 28787537
175 Sundstrom J, Arima H, Jackson R, . Effects of blood pressure reduction in mild hypertension: a systematic review and meta-analysis. Ann Intern Med. 2015;162(3):184–91. PMID: 25531552. 10.7326/M14-0773 25531552
176 Bress AP, Colantonio LD, Cooper RS, . Potential Cardiovascular Disease Events Prevented with Adoption of the 2017 American College of Cardiology/American Heart Association Blood Pressure Guideline. Circulation. 2019;139(1):24–36. PMID: 30586736. 10.1161/CIRCULATIONAHA.118.035640 30586736
177 National Institute for Health and Care Excellence. Hypertension in adults: diagnosis and managment. A. Evidence review for diagnosis. 2019.
178 Reino-Gonzalez S, Pita-Fernandez S, Seoane-Pillado T, . How in-office and ambulatory BP monitoring compare: A systematic review and meta-analysis. Journal of Family Practice. 2017;66(1):E5–E12. PMID: 28188315.28188315
179 Trudel X, Milot A, Brisson C. Persistence and progression of masked hypertension: a 5-year prospective study. International Journal of Hypertension. 2013;2013:836387. PMID: 24455208. 10.1155/2013/836387 24455208
180 Stergiou GS, Ntineri A, Kollias A. Management of Masked Hypertension: Why Are We Still Sitting on the Fence? Hypertension. 2016;68(6):1344–5. PMID: 27777358. 10.1161/HYPERTENSIONAHA.116.08393 27777358
181 Cuspidi C, Tadic M, Mancia G, . White-Coat Hypertension: the Neglected Subgroup in Hypertension. Sunhwangi. 2018;48(7):552–64. PMID: 29938429. 10.4070/kcj.2018.0167 29938429
182 Briasoulis A, Androulakis E, Palla M, . White-coat hypertension and cardiovascular events: a meta-analysis. Journal of hypertension. 2016;34(4):593–9. PMID: 26734955. 10.1097/HJH.0000000000000832 26734955
183 Huang Y, Huang W, Mai W, . White-coat hypertension is a risk factor for cardiovascular diseases and total mortality. Journal of hypertension. 2017;35(4):677–88. PMID: 28253216. 10.1097/HJH.0000000000001226 28253216
184 Cohen JB, Lotito MJ, Trivedi UK, . Cardiovascular Events and Mortality in White Coat Hypertension: A Systematic Review and Meta-analysis. Ann Intern Med. 2019;170(12):853–62. PMID: 31181575. 10.7326/m19-0223 31181575
185 Shimbo D, Muntner P. Should Out-of-Office Monitoring Be Performed for Detecting White Coat Hypertension? Ann Intern Med. 2019;170(12):890–2. PMID: 31181573. 10.7326/m19-1134 31181573
186 Sheppard JP, Martin U, Gill P, . Prospective external validation of the Predicting Out-of-OFfice Blood Pressure (PROOF-BP) strategy for triaging ambulatory monitoring in the diagnosis and management of hypertension: observational cohort study. BMJ. 2018;361:k2478. PMID: 29950396. 10.1136/bmj.k2478 29950396
187 Booth JN, 3rd, Muntner P, Diaz KM, . Evaluation of Criteria to Detect Masked Hypertension. J Clin Hypertens. 2016;18(11):1086–94. 10.1111/jch.12830
188 Anstey DE, Booth JN, 3rd, Abdalla M, . Predicted Atherosclerotic Cardiovascular Disease Risk and Masked Hypertension Among Blacks in the Jackson Heart Study. Circ Cardiovasc Qual Outcomes. 2017;10(7). PMID: 28698190. 10.1161/CIRCOUTCOMES.116.003421 28698190
189 Herrett E, Gadd S, Jackson R, . Eligibility and subsequent burden of cardiovascular disease of four strategies for blood pressure-lowering treatment: a retrospective cohort study. Lancet. 2019;394(10199):663–71. PMID: 31353050. 10.1016/S0140-6736(19)31359-5 31353050
190 Fagard RH, Staessen JA, Thijs L, . Response to antihypertensive therapy in older patients with sustained and nonsustained systolic hypertension. Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. Circulation. 2000;102:1139–44. PMID: 10973843. 10.1161/01.cir.102.10.1139 10973843
191 Beckett NS, Peters R, Fletcher AE, . Treatment of hypertension in patients 80 years of age or older. N Engl J Med. 2008;358(18):1887–98. PMID: 18378519. 10.1056/NEJMoa0801369 18378519
192 Bulpitt CJ, Beckett N, Peters R, . Does white coat hypertension require treatment over age 80?: Results of the hypertension in the very elderly trial ambulatory blood pressure side project. Hypertension. 2013;61(1):89–94. PMID: 23172934. 10.1161/hypertensionaha.112.191791 23172934
193 Giorgini P, Weder AB, Jackson EA, . A review of blood pressure measurement protocols among hypertension trials: implications for “evidence-based” clinical practice. Journal of the American Society of Hypertension. 2014;8(9):670–6. PMID: 25224868. 10.1016/j.jash.2014.07.024 25224868
194 Chen Y, Lei L, Wang JG. Methods of Blood Pressure Assessment Used in Milestone Hypertension Trials. Pulse. 2018;6(1–2):112–23. PMID: 30283753. 10.1159/000489855 30283753
195 Nerenberg KA, Zarnke KB, Leung AA, . Hypertension Canada’s 2018 Guidelines for Diagnosis, Risk Assessment, Prevention, and Treatment of Hypertension in Adults and Children. The Canadian journal of cardiology. 2018;34(5):506–25. PMID: 29731013. 10.1016/j.cjca.2018.02.022 29731013
196 Chiolero A, Anker D. Screening interval: a public health blind spot. Lancet Public Health. 2019;4(4):e171–e2. PMID: 30954137. 10.1016/S2468-2667(19)30041-6 30954137
197 Garrison GM, Oberhelman S. Screening for hypertension annually compared with current practice. Ann Fam Med. 2013;11(2):116–21. PMID: 23508597. 10.1370/afm.1467 23508597
198 Niiranen TJ, Henglin M, Claggett B, . Trajectories of Blood Pressure Elevation Preceding Hypertension Onset: An Analysis of the Framingham Heart Study Original Cohort. JAMA Cardiol. 2018;3(5):427–31. PMID: 29562081. 10.1001/jamacardio.2018.0250 29562081
199 Ye C, Fu T, Hao S, . Prediction of Incident Hypertension Within the Next Year: Prospective Study Using Statewide Electronic Health Records and Machine Learning. J Med Internet Res. 2018;20(1):e22. PMID: 29382633. 10.2196/jmir.9268 29382633
200 Selassie A, Wagner CS, Laken ML, . Progression is accelerated from prehypertension to hypertension in blacks. Hypertension. 2011;58(4):579–87. PMID: 21911708. 10.1161/hypertensionaha.111.177410 21911708
201 Thomas SJ, Booth JN, 3rd, Dai C, . Cumulative Incidence of Hypertension by 55 Years of Age in Blacks and Whites: The CARDIA Study. J Am Heart Assoc. 2018;7(14). PMID: 29997132. 10.1161/JAHA.117.007988 29997132
202 Pannarale G, Moroni C, Acconcia MC, . The natural history of prehypertension. A 20-year follow-up. Eur Rev Med Pharmacol Sci. 2017;21(6):1329–34. PMID: 28387894.28387894
203 Lindbohm JV, Sipila PN, Mars NJ, . 5-year versus risk-category-specific screening intervals for cardiovascular disease prevention: a cohort study. Lancet Public Health. 2019;4(4):e189–e99. PMID: 30954144. 10.1016/S2468-2667(19)30023-4 30954144
204 Myers MG, Cloutier L, Gelfer M, . Blood Pressure Measurement in the Post-SPRINT Era: A Canadian Perspective. Hypertension. 2016;68(1):e1–3. PMID: 27185747. 10.1161/hypertensionaha.116.07598 27185747
205 Jegatheswaran J, Ruzicka M, Hiremath S, . Are Automated Blood Pressure Monitors Comparable to Ambulatory Blood Pressure Monitors? A Systematic Review and Meta-analysis. The Canadian journal of cardiology. 2017;33(5):644–52. PMID: 28449834. 10.1016/j.cjca.2017.01.020 28449834
206 Pappaccogli M, Di Monaco S, Perlo E, . Comparison of Automated Office Blood Pressure With Office and Out-Off-Office Measurement Techniques. Hypertension. 2019;73(2):481–90. PMID: 30624994. 10.1161/hypertensionaha.118.12079 30624994
207 Rinfret F, Cloutier L, Wistaff R, . Comparison of Different Automated Office Blood Pressure Measurement Devices: Evidence of Nonequivalence and Clinical Implications. Canadian Journal of Cardiology. 2017;33(12):1639–44. PMID: 29173603. 10.1016/j.cjca.2017.09.011 29173603
208 Myers MG, Valdivieso M, Kiss A, . Comparison of two automated sphygmomanometers for use in the office setting. Blood pressure monitoring. 2009;14(1):45–7. PMID: 19190490. 10.1097/MBP.0b013e32831e314f 19190490
209 Lindholt JS, Sogaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017;390(10109):2256–65. PMID: 28859943. 10.1016/S0140-6736(17)32250-X 28859943
210 Shimbo D, Abdalla M, Falzon L, . Studies comparing ambulatory blood pressure and home blood pressure on cardiovascular disease and mortality outcomes: a systematic review. Journal of the American Society of Hypertension. 2016;10(3):224–34 e17. PMID: 26822864. 10.1016/j.jash.2015.12.013 26822864
211 Salles GF, Reboldi G, Fagard RH, . Prognostic Effect of the Nocturnal Blood Pressure Fall in Hypertensive Patients: The Ambulatory Blood Pressure Collaboration in Patients With Hypertension (ABC-H) Meta-Analysis. Hypertension. 2016;67(4):693–700. 10.1161/HYPERTENSIONAHA.115.06981 26902495
212 Schmidt BM, Durao S, Toews I, . Screening strategies for hypertension: a systematic review protocol. BMJ Open. 2019;9(1):e025043. PMID: 30647046. 10.1136/bmjopen-2018-025043 30647046
213 Green B. Blood Pressure Checks for Diagnosing Hypertension (BP-CHECK). NCT03130257. https://clinicaltrials.gov/ct2/show/NCT03130257?term=BP-CHECK&rank=1. Accessed.
214 Rhee M. Diagnosis of Hypertension by Home Blood Pressure Monitoring: NCT03855605. https://clinicaltrials.gov/ct2/show/NCT03855605. Accessed.
215 Kronish I. Implementing Hypertension Screening Guidelines in Primary Care: NCT03480217. https://clinicaltrials.gov/show/nct03480217. Accessed.
216 Siso Almairall A. Validity of 1BPM for Diagnosis of Hypertension: NCT03147573. https://clinicaltrials.gov/ct2/show/NCT03147573. Accessed.
217 Egan BM, Li J, Hutchison FN, . Hypertension in the United States, 1999 to 2012: progress toward Healthy People 2020 goals. Circulation. 2014;130(19):1692–9. PMID: 25332288. 10.1161/CIRCULATIONAHA.114.010676 25332288
218 Department of Veterans Affairs, Department of Defense. VA/DoD clinical practice guideline for the diagnosis and management of hypertension in the primary care setting. https://www.healthquality.va.gov/guidelines/CD/htn/VADoDHypertensionCPG508Corrected792020.pdf. Accessed.
219 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. Leawood, KS: 2017.
220 James PA, Oparil S, Carter BL, . 2014 Evidence-based guideline for the management of high blood pressure in adults: Report from the panel members appointed to the Eighth Joint National Committee (JNC 8). JAMA. 2014;311(5):507–20. PMID: 24352797. 10.1001/jama.2013.284427 24352797