# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH and Brandy Peaker, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Heart, Lung, and Blood Institute and Centers for Disease Control and Prevention for providing federal partner review of the draft report; Beverly Green, MD, MPH, Mike LeFevre, MD, MSPH, Paul Muntner, PhD, Daichi Shimbo, MD, and Reem Mustafa, MBBS, PhD, MPH, who provided expert review of the draft report; Jennifer S Lin, MD, MCR, for mentoring and project oversight; and Todd Hannon, MLS, and Katherine Essick, BS, for technical and editorial assistance at the Center for Health Research.