# Chapter 4 Discussion

## Summary of Evidence

The summary of evidence and context for this update can be found in Tables 19 and 20. There were no population-based trials strictly evaluating screening for hypertension versus no screening. We did include one trial of a community-based, multicomponent, CVD health-promotion program on CVD health outcomes where hypertension screening was the primary intervention. This trial showed a 9 percent relative reduction in the number of CVD-related hospital admissions (KQ1). Given that hypertension screening is considered standard of care in developed countries and there is an established evidence base linking asymptomatic hypertension treatment to improved CVD outcomes,^164–169^ we would not expect to find contemporary population-based trials of hypertension screening. Thus, the focus of this review was on the accuracy of screening (KQ2) and confirmatory blood pressure (KQ3) measurements, protocol variations that may influence accuracy (KQ2a/KQ3a), and the harms of screening and confirmation of hypertension (KQ4).

Table 19 Summary of Evidence

Key question | Studies (k); Study designs; Observations (n) | Summary of findings | Consistency and precision | Other limitations | Strength of evidence | Applicability
KQ 1; Screening | k=1 Cluster RCT; (0 new); n=140,642 | No trials examined the effectiveness of HTN screening alone vs no screening; 1 community-based cluster RCT of a multicomponent CVD health promotion trial reported a 9% reduction in the number of CVD-related hospital admissions (rate ratio, 0.91 [95% CI, 0.86 to 0.97]) but no difference in all-cause mortality. | Consistency NA, reasonably precise | Confounding from multicomponent intervention; Short 10-week intervention and 1year followup duration.; Administrative records used for outcomes. | MODERATE for small benefit | Population: Older adults ≥65 years; Intervention: Community-based intervention (community pharmacy)
KQ 2; Diagnostic accuracy of initial OBPM | k=20 cross sectional studies; (20 new); n=12,614 | Meta-analysis of 15 studies using SBP/DBP thresholds and measuring blood pressure at 1 visit (N=11,309) showed a pooled sensitivity of 0.54 (95% CI, 0.37 to 0.70) and a pooled specificity of 0.90 (95% CI, 0.84 to 0.95) with considerable heterogeneity. | Inconsistent, imprecise | Heterogeneous group of studies in terms of population, measurement protocols, BP thresholds. | LOW evidence for low sensitivity and adequate specificity | Population: General adult population; Intervention: Index test measurement protocols deviated somewhat from commonly performed protocols in U.S. practice in that studies mostly used a mercury sphygmomanometer, had participants rest for 5 minutes prior to measurement, and used the average of multiple measurements.; No studies report accuracy for ≥130/80 mm Hg threshold
KQ 2a; Diagnostic accuracy of different OBPM protocol characteristics | K=4 cross sectional studies; (4 new); N=1,612 | 3 studies addressed how number of measurements and visits influences accuracy and showed mixed results. | Inconsistent, imprecise | Few studies overall; single studies evaluating different comparisons of comparative accuracy of number of visits and measurements making conclusions difficult. | INSUFFICIENT to evaluate any single protocol characteristic | Population: General adult population; Intervention: variations in number of office measurements and visits
KQ 3; Diagnostic Accuracy of Confirmatory Screen | k=18 cross sectional studies; (12 new); n=57,128; Repeat OBPM: 13 studies; (n=55,759); HBPM: 4 studies; (n=1,001); Self-administered OBPM: 2 studies; (n=698); Truncated vs 24-h ABPM: 1 study; (n=263) | Repeat OBPM: Meta-analysis of 8 OBPM confirmation studies (N=53,183) reporting SBP/DBP thresholds showed a pooled sensitivity of 0.80 (95% CI, 0.68 to 0.88) and a pooled specificity of 0.55 (95% CI, 0.42 to 0.66) with considerable heterogeneity.; HBPM: Meta-analysis of 4 HBPM confirmation studies (N=1,001) showed a pooled sensitivity of 0.84 (95% CI, 0.76 to 0.90), and pooled specificity of 0.60 (95% CI, 0.48 to 0.71) with considerable heterogeneity.; Self-OBPM: 2 studies reported wide ranging sensitivities (0.20 to 0.92) and specificities (0.25 to 0.97).; Truncated vs 24-h ABPM: 1 study reporting separate analyses by indication. Sensitivity and specificity were 0.94 and 0.76, respectively, for ABPM indication of borderline HTN (N=126) and 0.89 and 0.70 for the ABPM indication of suspected white coat HTN (N=137). | Repeat OBPM: inconsistent and imprecise; HBPM: inconsistent and imprecise; Self-OPBM: inconsistent and imprecise; Truncated ABPM: NA for consistency, precision | Repeat office: heterogeneity in population recruitment, blood pressure measurement protocols, thresholds; Self OBPM and truncated ABPM; too few studies; AOBP: no studies | Repeat OBPM: LOW for adequate sensitivity and low specificity; HBPM: LOW for adequate sensitivity and low specificity; Self-OPBM: INSUFFICIENT; Truncated ABPM: INSUFFICIENT | Population: Adults referred for ABPM due to elevated office blood pressures or suspicious for white coat hypertension.; Intervention:; Repeat OBPM: Most index test protocols had 5 minutes rest and used mercury sphygmomanometer; HBPM: Diagnostic threshold, devices, and protocol characteristics similar to those in current practice; Self OBPM and truncated ABPM; Neither intervention commonly used in clinical practice for confirmation.
KQ 3a; Diagnostic accuracy of different confirmatory protocol characteristics | k=5 cross-sectional studies; (4 new); n=1,550 | Evidence on accuracy of protocol variations was sparse.; Repeat OBPM: Two studies examined different office protocols with mixed results; HBPM: Two studies reported similar accuracies with home protocols based on 7 compared to 5 days of measurement; Self-OPBM: One study reported similar accuracy for 3 compared to 5 measurements in a single sitting | Office: inconsistent, imprecise; Home: consistent, imprecise; Self: NA single study | The only protocol variations examined were number of measurements and days of measurements. No studies looked at rest time, patient positioning, timing of measurements during the day or any other variations. | INSUFFICIENT to evaluate any single protocol characteristic for any modality | Population: Referred for ABPM due to elevated office blood pressures or suspicious for white coat hypertension.; Intervention: office and home BP variations in protocol could be applicable to current practice.
KQ 4; Harms | k=13 studies [2 RCTs, 6 cohort, 5 cross sectional]; (4 newly included); n=5,150 | Limited evidence suggests that screening is not associated with any substantial short term QOL changes. Scant evidence on absenteeism is mixed.; ABPM is associated with minor adverse events including temporary sleep disturbance, arm discomfort, and bruising. | QOL: consistent, imprecise; Absenteeism: Inconsistent, imprecise; Tolerability/ sleep disturbance: consistent, imprecise | Heterogenous group of dated studies, generally small in size and of limited quality. QOL studies and absenteeism studies did not control for confounders. Sleep disturbance and tolerability studies limited by cross sectional design without comparators and lack of validated measures. | LOW for minor harms | Population: Employment based and clinic-based studies in very high HDI countries.

Abbreviations: ABPM = ambulatory blood pressure measurement; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; HBPM = home blood pressure measurement; HDI = Human Development Index; HTN = hypertension; k = number of studies; mm Hg = millimeter of mercury; NA = not applicable; OBPM = office-based blood pressure measurement; QoL = quality of life; RCT = randomized clinical trial; SBP = systolic blood pressure

Table 20 Summary of Existing and New Evidence

Key Question | Rationale for existing 2015 recommendation | Limitations of foundational evidence | New evidence | Limitations of new evidence | Consistency of new evidence with prior recommendation
Benefits of screening and treatment | Screening and treatment substantially reduce CVD events based on:; - Direct evidence: 1 large cluster RCT (CHAP); - Indirect evidence: IPD MA and MA of treatment benefit | CHAP study: conducted in participants ≥65 years, community pharmacy setting, multicomponent intervention; Identification of HTN in treatment trials based on OBPM alone; thus, treatment evidence includes white coat HTN in addition to sustained HTN. Treatment benefit of white coat and masked HTN unknown | No new KQ1 evidence; MAs and IPD MAs of treatment continue to accrue with focus on risk stratification and attention to BP goals | NA | Consistent. Despite low sensitivity of OBPM for initial screening, treatment benefit based on OBPM-based trials is substantial; Clinical uncertainty remains as to how to integrate accuracy results with foundational treatment evidence because effectiveness of WCH and MH treatment remain a research gap
Diagnostic accuracy of screening and confirmation | NA | Much of 2015 review focused on establishing ABPM as reference standard based on prognostic value in predicting future CVD events; Did not address diagnostic accuracy of screening/confirmatory BP modalities against ABPM reference standard | Initial OBPM screening accuracy:; Low sensitivity, adequate specificity; Confirmation accuracy:; Adequate sensitivity, low specificity for OBPM, HBPM modalities | Accuracy evidence with clinical heterogeneity; Index test protocols are “research quality” and deviate from current practice; No studies of 130/80 mm Hg threshold, limited data for AOBP
Harms of screening | Few major harms of screening | Heterogeneous group of small, older studies of varied design and limited quality | Few major harms of screening | Same limitations | Consistent

Abbreviations: AOBP = automated office-based blood pressure; BP = blood pressure; CVD = cardiovascular disease; CHAP = Cardiovascular Health Awareness Program; IPD MA = individual-patient data meta-analysis; KQ = key question; MA = meta-analysis; MH = masked hypertension; NA = not applicable; OBPM = office-based blood pressure measurement; RCT = randomized control trial; WCH = white coat hypertension

Our meta-analysis of 15 screening studies (N=11,309) using SBP/DBP thresholds and measuring blood pressure at a single visit showed a pooled sensitivity of 0.54 (95% CI, 0.37 to 0.70) and a pooled specificity of 0.90 (95% CI, 0.84 to 0.95) with considerable heterogeneity not explained by participant or test characteristics (I^2^ sensitivity=97.8%; I^2^ specificity=97.1%). Evidence for this key question is derived primarily from heterogeneous population-based samples and heterogeneous measurement protocols deviating somewhat from commonly performed protocols in current U.S. practice. These studies mostly used a mercury sphygmomanometer, had participants rest for 5 minutes prior to measurement, and used the average of multiple measurements, which is not standard in current clinical practice where single measurements are performed immediately upon rooming patients. Studies comparing protocol variations showed mixed results, making it difficult to arrive at conclusions about the ideal protocol to maximize screening accuracy.

In contrast to KQ2 results, which showed that initial screening with OBPM is not sensitive but is specific in an unselected population, KQ3 showed that confirmatory modalities, when applied to a preselected population with an initially elevated OBPM, are generally sensitive but not specific. The only two confirmation modalities with sufficient data for quantitative pooling, OBPM and HBPM, showed roughly similar test accuracy with overlapping confidence intervals. Meta-analysis of eight OBPM confirmation studies (N=53,183) reporting SBP/DBP thresholds showed a pooled sensitivity of 0.80 (95% CI, 0.68 to 0.88) and a pooled specificity of 0.55 (95% CI, 0.42 to 0.66) with considerable heterogeneity (I^2^ sensitivity=99.2%; I^2^ specificity=98.6%). Meta-analysis of four HBPM confirmation studies (N=1,001) showed a pooled sensitivity of 0.84 (95% CI, 0.76 to 0.90), and pooled specificity of 0.60 (95% CI, 0.48 to 0.71), also with considerable heterogeneity (I^2^ sensitivity=85.1%; I^2^ specificity=77.8%). Only one study each examined the accuracy of self-OBPM or truncated ABPM using SBP/DBP thresholds; the self-OBPM study (N=698) showed high sensitivity and low specificity (0.92 and 0.25), while the truncated ABPM study (N=126) showed a high sensitivity and moderate specificity (0.94 and 0.76, respectively), in a population for whom the ABPM indication was borderline hypertension.

There is scant evidence on how protocol variations influence accuracy for confirmatory OBPM or HBPM. Again, the research protocols in these studies are different than those followed in common clinical practice where a single repeated measurement is often used for confirmation and multiple values are rarely averaged; when home blood pressure measurement is used for confirmation in practice, patient instructions for measurement and result interpretation are variable.

Evidence on harms of screening and confirmation is limited but generally suggests that direct harms of screening and confirmation are minimal. The more important potential indirect harm of screening is misdiagnosis (missed cases or overdiagnosis and overtreatment). Some have argued that the 2017 ACC/AHA guideline^2^ advocating more aggressive treatment targets did not consider the totality of evidence, such as a systematic assessment of harms of more intensive treatment goals.^10,^ ^170^ The downstream adverse events of treatment may be greater in magnitude with more intensive treatment.^166,^ ^171–176^

## Comparison to Results of Other Systematic Reviews

To our knowledge, this is the only systematic review comparing the accuracy of office-based screening with the ABPM gold standard. A large, international, individual patient data meta-analysis of population-based cohorts, the International Database of Ambulatory Blood Pressure in relation to Cardiovascular Outcome (IDACO) (N=4997), reported data that allowed us to calculate accuracy for office blood pressure measurements. Sensitivity is reasonably consistent with our results (0.66 [95% CI, 0.64 to 0.68]), while specificity is slightly lower than our pooled estimates for KQ2 (0.82 [95% CI, 0.81 to 0.83]).^67^ Given the high prevalence and clinical importance of hypertension, it is surprising that there are not more reviews examining the accuracy of screening office blood pressure measured on one or more occasions, as is performed in current practice. Other systematic reviews have estimated test accuracy for confirmatory office or home measurements, but these studies include mixed populations (treated and untreated individuals, and populations with and without a previous elevated blood pressure).^33,^ ^66,^ ^177,^ ^178^ Reported pooled point estimates for sensitivity and specificity for OBPM in these reviews ranged from 0.75 to 0.82 and 0.41 to 0.76, respectively, and for HBPM ranged from 0.86 to 0.90 and 0.62 to 0.84. These reviews have overlapping confidence intervals with our pooled sensitivity for KQ3, however, reported specificities are quite variable and likely reflect heterogeneity in populations and measurement protocols.

Although mm Hg difference in blood pressure between modalities was not a prespecified outcome in our review, we performed an exploratory analysis of this outcome in our included studies. The relationship between OPBM and ABPM values was inconsistent in our included studies of OBPM screening accuracy (KQ2). Within-study differences for SBP ranged from −9.3 mm Hg (ABPM>OBPM)^115^ to 12.6 mm Hg (OBPM>ABPM);^98^ within-study differences for DBP ranged from −3.6 (ABPM>OBPM)^104^ to 11.0 (OBPM>ABPM).^99^ Between-study heterogeneity and large standard deviations in screening blood pressures within individual studies preclude identification of characteristics associated with higher or lower OBPM relative to ABPM from this body of literature. An analysis of IDACO by Conen and colleagues,^32^ which has the advantage of including individual patient data, suggests that on average, OBPM may be lower than ABPM in younger age strata (-6.0 mm Hg in ages 18-30 years) compared with the reverse phenomenon in the oldest age strata (13.1 mm Hg in ages ≥70 years). However, screening blood pressures similarly exhibit wide variation in these data, particularly at older ages, so the influence of age on OBPM-ABPM differences should be interpreted cautiously. We were unable to further analyze how age may influence this association because of lack of outcome reporting by age. In contrast to the inconsistent association we found between OBPM and ABPM in screening studies (KQ2), OBPM appears to be consistently higher than ABPM in the included studies that examined populations with a previous elevated screen (KQ3). Within included KQ3 studies, SBP from OBPM was 3.0 to 17.2 mm Hg higher than ABPM and DBP from OBPM was 1.8 to 12.8 mm Hg higher than ABPM. This more consistent association between OBPM and ABPM in studies of confirmation measurement may be an expected finding, given that individuals with masked hypertension would not be included in this population.

## Understanding the Clinical Relevance of Test Accuracy of Screening and Confirmatory Testing

Applying our pooled accuracies to a hypothetical cohort, it is apparent that screening for hypertension with OBPM misses a substantial number of masked hypertension cases and to a lesser extent, leads to treatment of white coat hypertension cases (Figure 5, Figure 6 and Table 20). The clinical significance of delays in the identification and treatment of masked hypertension and in the treatment of white coat hypertension are not fully understood (as discussed in the next section). Nonetheless, the evidence supporting hypertension screening and treatment have historically been based solely on OBPM.

Figure 5 Hypothetical Screening With Confirmation Testing Done in Office, Treatment Based on Repeat OBPM Confirmation

Abbreviations: ABPM = ambulatory blood pressure measurement; OBPM = office blood pressure measurement; HTN = hypertension; N = number; tx = treatment

Figure 5 shows a hypothetical pathway and implications of screening with confirmation testing done in office, and treatment based on repeat OBPM confirmation.

Assumptions: Prevalence of 30.6% based on 24-h ABPM in untreated population 40-60 years old based on IDACO IPD-MA.^32^ Screening OBPM sensitivity 0.54, specificity 0.90 based on KQ2 pooled estimates; for confirmatory testing with OBPM, sensitivity 0.80, specificity 0.55 based on KQ3 pooled estimates.

Figure 6 Hypothetical Screening and Repeat Office Testing With ABPM Confirmation, Treatment Based on ABPM Confirmation

Abbreviations: ABPM = ambulatory blood pressure measurement; OBPM = office blood pressure measurement; HTN = hypertension; N = number; tx = treatment

Figure 6 shows a hypothetical pathway and implications of screening and repeat office testing with ABPM confirmation, and treatment based on ABPM confirmations.

Assumptions: Prevalence of 30.6% based on 24-h ABPM in untreated population 40-60 years old based on IDACO IPD-MA.^32^ Screening OBPM sensitivity 0.54, specificity 0.90 based on KQ2 pooled estimates; for confirmatory testing with OBPM, sensitivity 0.80, specificity 0.55 based on KQ3 pooled estimates.

In a hypothetical population of 1,000 individuals age 40-60 years, using our pooled screening accuracy of a single-occasion blood pressure measurement (0.54 sensitivity, 0.90 specificity) and a prevalence of sustained hypertension of 30.6 percent based on ABPM,^32^ the PPV would be 70 percent and the NPV would be 82 percent. This translates to 165 true positives, 625 true negatives, 141 masked hypertension cases (false negatives), and 69 treated white coat hypertension cases (false positives) (Table 21). In clinical practice, patients rarely go on to treatment based on a single office blood pressure measurement. A more likely clinical scenario would be that those who screened positive on initial office blood pressure would return for at least one additional office measurement, and treatment would be based on the repeat office measurement. In this more realistic scenario, 132 sustained hypertension cases would be detected; 174 with ABPM-defined HTN would be missed (masked hypertension) and would not receive treatment, and 31 without ABPM-defined HTN (white coat hypertension) would receive treatment (Figure 5). In a third clinical scenario in which only those who screened positive on an initial office BP received repeat OBPM, then only those with positive repeat OBPM went on to ABPM for confirmation and treatment decisions, 132 true cases would be detected and 174 would still be missed (masked hypertension), but none would receive potentially unnecessary treatment (Figure 6). Therefore, treatment based on confirmatory ABPM (compared to treatment based on confirmatory OBPM) does not change the masked hypertensive cases as these false negatives occurred during the low-sensitivity initial screen, however, the ABPM confirmation does avoid treating a small number of white coat hypertensives with lifelong antihypertensive treatment.

Table 21 Estimated Positive and Negative Predictive Values in a Hypothetical Population (n=1,000), Based on KQ2 Meta-Analysis, by Age Group

Pooled estimate | Age group, years | Prevalence of hypertension, percent | Sensitivity | Specificity | TP, n | TN, n | FN, n | FP, n | PPV | NPV
Lower bound of sensitivity CI and upper bound of specificity CI | 18-40 | 22.6 | 0.37 | 0.95 | 84 | 735 | 142 | 39 | 0.68 | 0.84
Lower bound of sensitivity CI and upper bound of specificity CI | 40-60 | 30.6 | 0.37 | 0.95 | 113 | 659 | 193 | 35 | 0.77 | 0.77
Lower bound of sensitivity CI and upper bound of specificity CI | ≥60 | 41.6 | 0.37 | 0.95 | 154 | 555 | 262 | 29 | 0.84 | 0.68
Pooled point estimates | 18-40 | 22.6 | 0.54 | 0.90 | 122 | 697 | 104 | 77 | 0.61 | 0.87
Pooled point estimates | 40-60 | 30.6 | 0.54 | 0.90 | 165 | 625 | 141 | 69 | 0.70 | 0.82
Pooled point estimates | ≥60 | 41.6 | 0.54 | 0.90 | 225 | 526 | 191 | 58 | 0.79 | 0.73
Upper bound of sensitivity CI and lower bound of specificity CI | 18-40 | 22.6 | 0.70 | 0.84 | 158 | 650 | 68 | 124 | 0.56 | 0.91
Upper bound of sensitivity CI and lower bound of specificity CI | 40-60 | 30.6 | 0.70 | 0.84 | 214 | 583 | 92 | 111 | 0.66 | 0.86
Upper bound of sensitivity CI and lower bound of specificity CI | ≥60 | 41.6 | 0.70 | 0.84 | 291 | 491 | 125 | 93 | 0.76 | 0.80
Lower bound of sensitivity CI and lower bound of specificity CI | 18-40 | 22.6 | 0.37 | 0.84 | 84 | 650 | 142 | 124 | 0.40 | 0.82
Lower bound of sensitivity CI and lower bound of specificity CI | 40-60 | 30.6 | 0.37 | 0.84 | 113 | 583 | 193 | 111 | 0.50 | 0.75
Lower bound of sensitivity CI and lower bound of specificity CI | ≥60 | 41.6 | 0.37 | 0.84 | 154 | 491 | 262 | 93 | 0.62 | 0.65
Upper bound of sensitivity CI and upper bound of specificity CI | 18-40 | 22.6 | 0.70 | 0.95 | 158 | 735 | 68 | 39 | 0.80 | 0.92
Upper bound of sensitivity CI and upper bound of specificity CI | 40-60 | 30.6 | 0.70 | 0.95 | 214 | 659 | 92 | 35 | 0.86 | 0.88
Upper bound of sensitivity CI and upper bound of specificity CI | ≥60 | 41.6 | 0.70 | 0.95 | 291 | 555 | 125 | 29 | 0.91 | 0.82

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

While exceedingly few of our included studies reported direct comparative accuracy data, we can apply the accuracy point estimates for each modality to our hypothetical population (Table 22) Not surprisingly, the most accurate strategy for identifying sustained and masked hypertension based on an ABPM-based hypertension definition is to screen the entire population with ABPM. Clearly, this is a resource intensive strategy with feasibility challenges given the OBPM standard of care and limited ABPM accessibility.^54^ The next most accurate strategy is to apply ABPM confirmation for all of those with elevated screening OBPM. The remaining confirmation strategies correctly classify a similar percentage of the population but any strategy that does not use ABPM for confirmation and treatment decisions introduces treatment of a number of white coat hypertension cases. This hypothetical cohort example should be interpreted with caution. First, very few of these studies were designed as direct comparative studies and measured the same participants with different modalities.^134,^ ^135^ Moreover, these are based on pooled estimates with considerable statistical, clinical and methodologic heterogeneity, and the strength of evidence was rated as low. Regardless, in every screening and confirmation strategy except that using ABPM alone, there are a considerable number of missed cases.

Table 22 Comparative Screening and Confirmation Strategies Using a Hypothetical Population of 1,000 With a Hypertension Prevalence of 30.6%

Screening | Confirmation (Tx based on final modality) | Identified HTN cases | WCH treated | Missed masked HTN | Normotensives identified | Number of office visits | Number of ABPMs | Number of HBPMs | Percent of population correctly classified | Percent of hypertensives correctly classified
ABPM | ABPM | 306 | 0 | 0 | 694 | 0 | 1000 | 0 | 100.0 | 100.0
Office | ABPM | 165 | 0 | 141 | 694 | 1000 | 234 | 0 | 85.9 | 53.9
Office^*^ | Repeat office, then ABPM | 132 | 0 | 174 | 694 | 1234 | 163 | 0 | 82.6 | 43.1
Office^*^ | Repeat Office | 132 | 31 | 174 | 663 | 1234 | 0 | 0 | 79.5 | 43.1
Office^*^ | HBPM | 139 | 28 | 167 | 666 | 1000 | 0 | 234 | 80.5 | 45.4

* One or multiple elevated office measure could have been used to indicate confirmation

Assumptions: Prevalence of 30.6% based on 24-h ABPM in untreated population 40-60 years old based on IDACO IPD-MA.^32^ Screening OBPM sensitivity 0.54, specificity 0.90 based on KQ2 pooled estimates; for confirmatory testing with OBPM (sensitivity 0.80, specificity 0.55) or HBPM (sensitivity 0.84, specificity 0.60) based on KQ3 pooled estimates.

Abbreviations: ABPM = ambulatory blood pressure measurement; HBPM = home blood pressure measurement; HTN = hypertension; Tx = treatment; WCH = white coat hypertension

In the traditional screening paradigm, high sensitivity is valued at the first step to detect as many potential cases as possible, and high specificity is valued for confirmatory testing to rule out the false positives detected during highly sensitive initial screening. Screening for hypertension currently shows the opposite pattern, with a lower sensitivity/higher specificity at initial screening—leading to missed cases—and a higher specificity/lower sensitivity at the confirmatory step—leading to possible overtreatment in normotensive adults. This may be because those patients who screen positive could have blood pressures that are closer to borderline thresholds and their cases could be more difficult to diagnose. While missing cases (low sensitivity) will leave patients at risk for CVD events without treatment, rescreening is common in clinical practice, so in those populations with adequate access to healthcare, there may be ample opportunity to identify these individuals at another healthcare visit. The clinical significance of the delay in identification and treatment of masked hypertension is incompletely understood but would presumably depend on its duration. An analysis of data from the Spanish ABPM registry (a preselected population with previous elevated screen that was included for KQ3) found that among untreated individuals, masked hypertension status was maintained by 47 percent with a median followup of 3 months (interquartile range 0-13), and 33 percent of those with masked hypertension transitioned to sustained hypertension during this period.^123^ A longer-term study in a different population suggests that delays may persist. In a workplace-based study of adults not selected based on blood pressure, which may be the more germane population, masked hypertension status persisted in 38 and 18.5 percent, respectively, after 3 and 5 years and 26 and 37 percent of masked hypertensives progressed to sustained hypertension after 3 and 5 years, respectively.^179^ Some researchers have posited that age is the mechanism by which masked hypertension is unmasked. Shimbo and colleagues^103^ have hypothesized that as both OBPM and ABPM increase with age, ABPM first exceeds the diagnostic threshold while OBPM remains normotensive—and that OBPM will eventually cross the diagnostic threshold, resulting in sustained hypertension. With respect to white coat hypertension, adhering to a do-no-harm philosophy, potential overtreatment and ensuing lifelong treatment with possible side effects may be important to avoid.^177^

## White Coat and Masked Hypertension

As discussed above, white coat and masked hypertension are both common with clinical significance and management that remain highly debated.^180,^ ^181^ In the IDACO individual patient data meta-analysis of population-based studies, the prevalence of white coat hypertension in untreated adults defined by a 24-h ABPM reference standard was 7.9 percent and the prevalence of masked hypertension was 14.3 percent.^32^ These reported prevalences are consistent with those in our included studies, in which white coat hypertension ranged from 0 to 22 percent (weighted mean 9.6 percent) and masked hypertension ranged from 2 to 31 percent (weighted mean 11.0 percent). Existing meta-analyses suggest that for untreated individuals generally recruited from population-based cohorts, cardiovascular risk progressively increases in ABPM phenotypes, in the order of normotension, white coat hypertension, masked hypertension, and sustained hypertension (Table 23).^37,^ ^38,^ ^182–185^ Most of the prognostic literature addresses white coat hypertension compared to a normotensive reference group and synthesized literature shows mixed results. A 2019 study-level meta-analysis by Cohen and colleagues^184^ reported a hazard ratio of 1.36 (95% CI, 1.03 to 2.00) for untreated white coat hypertension compared to normotension, where adjustments for cardiovascular risk factors from the primary studies were used. In contrast, an individual patient-data meta-analysis by Asayama and colleagues^37^ found that the risk for white coat hypertension was not statistically significantly increased compared to normotension (1.21 [95% CI, 0.91 to 1.61) in untreated individuals when using a 24-h ABPM reference standard (adjusting for age, sex, BMI, smoking, drinking, total cholesterol, diabetes, CVD history and cohort). Adjustment for blood pressure values is not common in the primary studies that contribute to the Cohen analysis and the Asayama analysis does not control for blood pressure values, thus, some have argued that residual confounding remains since out-of-office blood pressure has been higher in white coat hypertensives compared to normotensives, which may partially explain increased CVD risk.^185^ Shimbo and Muntner extend the Cohen analysis to compare the risk of CVD events for sustained hypertension compared to normotension (HR 2.31 [95% CI, 1.91 to 3.15]) and conclude that the risk associated with untreated white coat hypertension is only moderately increased.^185^ In a smaller number of systematic reviews evaluating prognosis of masked hypertension, evidence consistently shows that masked hypertension confers an increased risk of cardiovascular events compared with normotension.^37,^ ^38^ We identified only one source reporting the prognosis of masked hypertension compared with a sustained hypertension reference group; it showed that masked hypertension has a more favorable prognosis (for fewer) CVD events (adjusted HR 0.70 [95% CI, 0.54 to 0.91]).^37^ This same analysis reports an adjusted hazard ratio of 0.51 (95% CI, 0.40 to 0.64) for the risk of CVD events in those with white coat hypertension compared to a sustained hypertension reference group.

Table 23 Risk for Cardiovascular Events Associated With ABPM Phenotypes in Synthesized Literature

Author Study type | N analyzed and N events | Baseline treatment status | ABPM interval | Measure of risk and adjustments | WCHTN vs NT | WCHTN vs SHTN | MHTN vs NT | MHTN vs SHTN | SHTN vs NT
Briasoulis, 2016^182^; SR/MA of 14 studies | N analyzed: 29,100^*^; N events: NR | Treated and untreated (proportion NR) | Daytime, 24-h, and HBPM^†^ | OR (95% CI); adjustments not reported | 1.73 (1.27 to 2.36) | 0.40 (0.32 to 0.51) | NR | NR | NR
Huang, 2017^183^; SR/MA of 8 studies including 23 cohorts^‡^ | N analyzed: 20,445; N CVD events: NR | Untreated^§^ | Daytime, 24-h and HBPM^‖^ | RR (95% CI); study-level adjustments for various CVD risk factors | 1.38 (1.15 to 1.65) | NR | NR | NR | NR
Pierdomenico, 2011^38^; SR/MA of 8 studies | N=7,961; N CVD events: 696 | Untreated | Daytime, 24-h^¶^ | HR (95% CI); study-level adjustments for various CVD risk factors | 0.96 (0.65 to 1.42) | NR | 2.09 (1.55 to 2.81) | NR | 2.59 (2.0 to 3.35)
Asayama, 2014^37^; IPD-MA of 12 cohorts | N analyzed: 8,237; N CVD events: 729 | Untreated | 24-h | HR (95% CI); age, sex, BMI, smoking, drinking, TC, DM, CVD history, and cohort | 1.21 (0.91 to 1.61) | 0.51 (0.40 to 0.64) | 2.03 (1.55 to 2.67) | 0.70 (0.54 to 0.91) | NR
Asayama, 2014^37^; IPD-MA of 12 cohorts | N analyzed: 8,237; N CVD events: 729 | Untreated | Daytime | HR (95% CI); age, sex, BMI, smoking, drinking, TC, DM, CVD history, and cohort | 1.38 (1.03 to 1.87) | 0.57 (0.44 to 0.73) | 1.85 (1.42 to 2.40) | 0.61 (0.48 to 0.78) | NR
Cohen, 2019^184^; SR/MA of 27 studies | N analyzed: 85,239; N CVD events: NR | Untreated^#^ | Daytime, 24-h^**^ | HR (95% CI); study-level adjustments for various CVD risk factors^††^ | 1.36 (1.03 to 2.00) | NR | NR | NR | 2.31 (1.91 to 3.15) ^‡‡^,^185^

* Total N analyzed across all outcomes; NR by outcome

† One study used intra-arterial 24-h ABPM and 3 studies used HBPM

‡ For untreated population

§ Results for untreated population reported in table; in the treated population, the relative risk for a CVD event was nonsignificantly increased in those with WCHTN compared to NT [1.16 (95% CI, 0.91 to 1.49)]

‖ 1 study used HBPM

¶ Daytime ABPM used in seven out of eight studies

# In analyses restricted to treated participants, the adjusted HR for white coat hypertension compared to normotension was 1.12 (95% CI, 0.91 to 1.39)

** Five studies used HBPM

†† As reported in Supplement Table 4

‡‡ Shimbo and colleagues report hazard ratios for white coat vs sustained hypertension for the studies of untreated white coat hypertension reported in the review by Cohen and colleagues

Abbreviations: ABPM=ambulatory blood pressure monitoring; ACM=all-cause mortality; CVD=cardiovascular disease; HBPM=home blood pressure monitoring; IPD MA=individual patient-data meta-analysis; MHTN=masked hypertension; N=number; NR=not reported; NT=normotension; SHTN=sustained hypertension; SR/MA=systematic review and meta-analysis; WHTN=white coat hypertension

Masked hypertension is not detectable within the current paradigm of office-based screening. Given the barriers to routine use of ABPM, multivariate risk prediction models or single risk factors could be an efficient strategy to identify a targeted population for whom out-of-office measurement might be most useful. One such risk prediction model is PROOF-BP, an externally validated triage approach that uses basic clinical characteristics (age, sex, BMI, previous diagnosis of hypertension, and history of CVD) and a set of 3 OBPM measures taken at one visit to identify those with definitively normal blood pressure, those with definitively high blood pressure, and those requiring further testing with ABPM.^186^ PROOF-BP is intended to be used in patients with suspected hypertension. In the validation subset limited to those with no previous history of hypertension, the use of the triage protocol correctly classified 91 percent of people against a daytime ABPM reference standard (244/268 people). The sensitivity of the protocol was 0.95 (95% CI, 0.92 to 0.98), and the specificity was 0.85 (95% CI, 0.78 to 0.92). In this population, 62 percent of participants were referred for ABPM, suggesting that the triage protocol can result in meaningful reductions in the need for ABPM referrals while maintaining good accuracy. Use of a triage tool may represent an intermediate approach between the ABPM everyone strategy and the office to ABPM strategy (Table 22). However, to avoid missed cases that are introduced from the initial screen, a triage approach for an unselected population would be helpful. A free, web-based version of BP-PROOF is available online at https://sentry.phc.ox.ac.uk/proof-bp/.

Because of the diagnostic overlap between prehypertension and masked hypertension, several investigators have examined whether an OBPM level alone can be established that would effectively identify a population for whom ABPM should be used to detect masked hypertension. Additionally, AHA guidelines suggest screening for masked hypertension in adults with untreated office blood pressures that are consistently between 120 mm Hg and 129 mm Hg for SBP or between 75 mm Hg and 79 mm Hg for DBP.^20^ In a population not selected for previous OBPM elevation, Shimbo and colleagues^103^ found that masked hypertension was rare (3.9%) when OBPM was <120/80 mm Hg. However, other analyses have found that this threshold may result in an excess number of ABPM tests being conducted.^187^ Using NHANES data, Booth and colleagues found that a cutpoint of ≥120/80 mm Hg has high sensitivity (0.825) and lower specificity (0.615) and would refer 59.3 million U.S. adults to ABPM. A higher threshold of ≥130/85 mm Hg has lower sensitivity (0.423) and higher specificity (0.866) and would result in fewer adults—20.3 million—being referred for ABPM. As a means to balance sensitivity and specificity, these researchers developed and validated an OBPM index (clinic SBP+1.3*clinic DBP) that could be used to refer adults to ABPM.

Estimated 10-year CVD risk could also be used to identify subpopulations that may benefit from ABPM to identify masked hypertension. An analysis of the Jackson Heart Study found that increased 10-year risk is associated with a higher prevalence of masked hypertension and that as many as two-thirds of those with ≥10 percent 10-year CVD risk have masked hypertension. However, the discrimination of CVD risk was not better than using clinic BP alone.^188^ A recent analysis examining the comparative effectiveness of different blood pressure treatment approaches demonstrated that strategies based on CVD risk alone or a combination of both blood pressure threshold and CVD risk prevented more events than treatment strategies based on blood pressure threshold alone.^189^

The most recent ACC/AHA guidelines use both BP level and CVD risk to guide treatment, and recommend initiation of pharmacological treatment based on ABPM or HBPM, thus calling for treatment of masked hypertension but not white coat hypertension.^20^ Historically and in current clinical practice, treatment decisions have been made based on office measurements, reflecting the treatment literature showing CVD benefit based on trials using OBPM inclusion criteria and OBPM treatment targets. Assuming that the accuracy of blood pressure eligibility screens for trial inclusion is similar to our confirmation populations in KQ3, these treatment trials include white coat hypertensives who are presumably receiving some of the reported treatment benefit, unless there is unknown heterogeneity of treatment benefit by ABPM phenotype. An ABPM substudy of the Systolic Hypertension in Europe (Syst-Eur) trial found that treatment did not reduce cardiovascular events in those with white coat hypertension, which comprised about one-quarter of the subsample.^190^ However, this study was limited to adults age 60 or older with isolated systolic hypertension, defined by SBP 160-219 mm Hg, and was conducted in a subsample of the larger trial so this analysis was not adequately powered. On the other hand, the Hypertension in the Very Elderly (HYVET) trial of patients 80 years and older with SBP ≥160 mm Hg reported reduction in CVD mortality and all-cause mortality as well as stroke and heart failure in the active treatment group; an estimated 40 to 60 percent of the participants may have had white coat hypertension according to the ABPM substudy.^191,^ ^192^ HYVET authors posited that it would be surprising if the substantial treatment benefits did not apply to those with white coat hypertension since they comprised such a large proportion of participants. Contemporary trial data using clinically relevant treatment thresholds are needed to clarify the potential benefit of treatment in white coat hypertension. Additionally, research is urgently needed to identify whether there is a benefit of treating masked hypertension. Any potential treatment benefit of masked hypertension is not being realized in clinical practice because screening office blood pressure measurement is missing a large subpopulation of patients with masked hypertension. A large Italian study is underway to compare intermediate cardiovascular outcomes in antihypertensive treatment guided by OBPM versus 24-hr ABPM; however, this study is being conducted in masked uncontrolled hypertensives (e,g., those already on treatment and with OBPM <140/90 mm Hg, but elevated ABPM) (NCT02804074). A trial of treatment versus placebo in treatment-naïve and newly screen-detected masked hypertensives would most directly answer this question; however, this is unlikely given ethical issues around withholding treatment from a group with research for adverse prognosis (Table 23). A counterpoint to a call for trials in individuals with white coat and masked hypertension would be a redoubled effort for blood pressure to be measured in clinical practice in the same way that it is measured in the treatment trials showing benefit.^193,^ ^194^ Limited evidence on routine methods for measurement in current practice suggests that these fall short of “research quality” protocols used in treatment trials, including use of a validated and calibrated device, multiple measurements taken in one sitting, measurement in both arms, and appropriate cuff size.

## Rescreening

Professional organizations endorse rescreening intervals based on expert opinion and these intervals range from every 1-5 years or according to clinician discretion.^1,^ ^2,^ ^68,^ ^195^ There are surprisingly few studies, and no randomized trials, designed to compare screening intervals for blood pressure measurement.^28,^ ^196^ One small retrospective case-control study (N=372) compared annual screening to current practice suggesting that annual screening can improve specificity (0.820 vs. 0.704) without substantially changing sensitivity (1.00 versus 0.926).^197^

The most recent systematic review (k=39; mean age 23.6 to 64.6 years; N’s ranging from 275 to 115,736) addressing rescreening interval was the previous 2014 report for the USPSTF, which evaluated incident hypertension rates from a variety of cohort studies that concluded that hypertension incidence following a normal blood pressure screen was highly variable, ranging from 2.5 to 4.4 percent at 1 year, 1.2 to 12.3 percent at 2 years, and 6.6 to 24.9 percent at 3 years.^28^ Subpopulations identified to be at higher risk for incident HTN in that review included older adults, persons with elevated BMI, African Americans, and persons with blood pressure in the high-normal range. Thus, the USPSTF recommended a shorter rescreening interval of 1 year in those with these risk factors, and an rescreening interval of 3 to 5 years in those without.^1^ Since the publication of the previous review, analyses from large, U.S. population-based cardiovascular cohorts as well as risk models confirm that these patient characteristics identified in the last review are associated with higher incident hypertension rates, suggesting a more tailored approach to screening interval may be warranted.^198–202^

Analyses of the broader outcome of CVD risk progression reinforce that individualized rescreening intervals by risk may be appropriate. A retrospective analysis from the British Whitehall II cohort study of 6,964 individuals followed for mean of 22 years with repeated biomedical screenings every 5 years to calculate 10-year ASCVD risk concluded that 5-year intervals may be too frequent for low risk individuals to progress to the high risk category and not frequent enough for intermediate and high risk individuals. Based on this analysis, authors suggested 7-year interval, 4-year interval, and 1- year interval for low, intermediate, and high risk individuals, respectively.^203^

## AOBP

Many have suggested that there is a potential role for AOBP in replacing traditional office screening and out of office confirmation modalities.^204^ However, we found no studies of unattended AOBP and only one study of attended AOBP reporting test accuracy (sensitivity and specificity) against an ABPM reference standard. The single included KQ1 screening study (CHAP) used attended AOBP but applicability issues regarding the setting of measurements, which occurred in a community pharmacy, reduce relevance to U.S.-based primary care setting.^89^ The one attended AOBP study for KQ2 showed a sensitivity of 0.65 (95% CI, 0.54 to 0.75), which is higher than our overall pooled estimate of OBPM but confidence intervals overlap; the specificity of 0.74 (95% CI, 0.66 to 0.82) was lower than our pooled estimate and confidence intervals did not overlap.^82^ This one study is insufficient for drawing conclusions about the accuracy of attended AOBP, particularly in the context of a body of evidence with notable methodologic and population heterogeneity.

While there are a dearth of studies reporting test accuracy of AOBP, many studies evaluate mean BP differences between AOBP and other modalities. A 2019 systematic review and meta-analysis by Roerecke et al^65^ (31 articles, N=9279) evaluated the mean differences between AOBP and other methods of BP measurement in treated and untreated individuals with systolic AOBP of 130 mm Hg or more. They estimated a pooled mean difference of 14.5 mm Hg (95% CI, 11.8 to 17.2 mm Hg; n = 9; I^2^ = 94.3%) between systolic OBPM readings and AOBP but similar awake ambulatory BP and AOBP readings, with a pooled mean difference of 0.3 mm Hg (95% CI, −1.1 to 1.7 mm Hg; n = 19; I^2^ = 90%). While the results from this and other systematic reviews may suggest that, on average, there are no statistical differences in pooled AOBP and ABPM values, study-level AOBP and ABPM differences show substantial heterogeneity.^205,^ ^206^ More importantly, without analysis of test accuracy outcomes (e.g., sensitivity, specificity), it is not possible to conclude whether AOBP would result in similar clinical screening and diagnostic results as ABPM or HBPM. Complicating this issue is conflicting literature questioning the equivalence of different AOBP models.^207,^ ^208^ Future studies recruiting untreated individuals reporting accuracy outcomes for AOBP in the setting of screening and confirmation are needed. At least one AOBP test accuracy study is underway (Appendix G).

## Limitations of Our Approach

For KQ1, we included a trial from the previous review^28^ that tested a CVD health promotion intervention in a community-based setting; however, this intervention was largely a hypertension screening intervention and was the only available trial carried forward from the last review. Another multicomponent screening trial, VIVA, was not included because the independent benefit of the hypertension screening component could not be evaluated separately from the trial’s abdominal aortic aneurysm and peripheral artery disease screening interventions and other CVD preventive interventions.^209^ For all key questions, we sought to approximate screening populations so excluded screening studies in which 20 percent or more of participants were treated. While this limited the included studies, as mentioned above, the accuracy of blood pressure measurements may be influenced by blood pressure variability and hypertension medications may reduce such variations. As such, this limitation precludes extrapolating the accuracy results from this review to treated populations. For KQ3, if a population was described as being “referred for ABPM,” we accepted this to be relevant for KQ3. Although there are a number of indications for ABPM, we considered the lack of treatment a proxy for an ABPM indication of diagnostic confirmation. There are other indications for ABPM, so our included populations may not strictly represent those referred for confirmation of diagnosis. Additionally, we did not examine how subpopulation characteristics may have influenced accuracy, but given the heterogeneity in study design for the set of accuracy studies (KQ2 and KQ3), it is unlikely that such a subanalysis would have yielded credible results.

Our pooled analyses yielded considerable statistical heterogeneity which was not explained by any single population or test characteristic, thereby limiting the precision of the point estimates. Furthermore, included studies used heterogeneous reference standards (24-h, daytime, and combination ABPM). Indeed, many studies reported that they conducted a 24-h ABPM test, but they used a daytime reference standard to define true hypertension. Our hypothesis is that this was done to achieve comparable measurement intervals among participants. In our main analysis, we pooled all ABPM reference standards for inclusivity. We conducted exploratory analyses limiting to studies using a 24-h reference standard and found higher sensitivity and lower specificity for single visit OBPM screening accuracy (KQ2), and the opposite for the OBPM confirmation modality (KQ3)—although confidence intervals overlapped between the main analyses and exploratory analyses. Because there was additional population heterogeneity in these studies that might confound results of pooling by reference standard modality, we consider these analyses to be exploratory. Moreover, because of the rarity of studies reporting accuracy using both a 24-h and daytime reference standard, we have little direct evidence for comparative accuracy based on different reference standards. Very recent analyses from IDACO have shown that 24-h and nighttime ABPM have prognostic value over and above daytime ABPM and perhaps serve as a superior reference standard.^41^ However, most included studies use daytime ABPM as the reference standard (e.g., 13/20 studies in KQ2).

We did not include accuracy studies that only reported mm Hg differences between measurement modalities or studies that only included kappas as a measure of agreement. While our review defined hypertension as a dichotomous outcome in order to calculate sensitivity and specificity, we acknowledge that blood pressure is a continuous variable associated with CVD risk. Nonetheless, clinical decision-making to start treatment is almost entirely based on blood pressures exceeding a defined threshold.

The previous review addressed the prognostic value of office, ambulatory and home blood pressure measurements in predicting future CVD events.^28^ Based on that review, we solely accepted ABPM as the gold standard for hypertension diagnosis and did not re-review the evidence on the prognostic value of various blood pressure measurement modalities. That review noted that the body of evidence for HBPM to independently predict CVD outcomes is smaller than the evidence for ABPM, and that direct evidence for the prognostic value of HBPM compared to ABPM is sparse. However, this smaller body of evidence suggests but does not confirm that HBPM may serve as a similar predictor of outcomes. HBPM was not an eligible reference standard in the current review but could be considered an alternate reference standard.^210^

We did not systematically address the prognosis of white coat hypertension or masked hypertension in our review, but we have discussed these clinically important issues in the Discussion section to provide context. We did not address circadian blood pressure patterns and screening for nighttime dipping. There is prognostic data to suggest that this is important.^211^ Finally, we did not address treatment benefit and harms. We acknowledge that there is a robust literature supporting cardiovascular benefits of treatment,^164–169^ and there are also important harms of treatment, but they are beyond the scope of this review and screening framework.

## Limitations of the Studies, Ongoing Research, and Future Research Needs

Hypertension screening is a long-standing routine clinical practice based on treatment effectiveness literature, so the lack of direct evidence (KQ1) from clinical settings would be anticipated. Indeed, we are aware of no in-progress trials evaluating the effectiveness of blood pressure screening alone versus no screening.^212^ Given the clinical importance of hypertension as a CVD risk factor, however, it is surprising that existing blood pressure screening and confirmation accuracy literature is not more robust. Instead, this evidence base comprises a heterogeneous group of studies with various populations and blood pressure measurement protocols, resulting in inconsistent and imprecise accuracy estimates. Moreover, the included protocol characteristics likely represent “research quality” measures not found in current practice. Moreover, because many of the studies utilized older devices not currently available, there remains some uncertainty about extrapolation of studies’ accuracy data to contemporary clincal practice. The US Blood Pressure Validated Device Listing is a recent resource that catalogues contemporary blood pressure measurement devices that have been validated for clinical accuracy as determined through an independent review process (https://www.validatebp.org/). Despite current interest in unattended AOBP, there is a lack of accuracy studies of AOBP for screening or confirmation in an untreated, screening-relevant population. There are limited data to compare the accuracy among the various confirmation modalities or to identify optimal protocol characteristics for blood pressure measurement. A few ongoing studies are particularly relevant in addressing the accuracy and feasibility of various screening and confirmation algorithms in clinical practice^213–216^ (Appendix G).

Future research needs include:

- AOBP and kiosk-based accuracy studies for screening and confirmation in an untreated population
- Accuracy studies with direct comparisons of different protocol characteristics (e.g., rest times, number of repeated measurements over number of separate days, attendance of measurement by medical personnel)
- Accuracy studies using the most recent ACC/AHA office threshold of 130/80 mm Hg compared with the ABPM gold standard and accuracy studies with direct comparisons of ≥130/80 mm Hg vs ≥140/90 mm Hg using the same ABPM reference standard threshold.
- Comparative accuracy of different screening and confirmation modalities in nationally representative samples including diverse populations (by age, race/ethnicity, CVD risk status)
- More studies evaluating the accuracy of truncated ABPM versus 24-h ABPM to determine if a limited number of hours of ABPM is acceptable, thereby reducing a barrier to confirmation with 24-h ABPM
- More long-term prognostic studies comparing the value of OBPM, ABPM and HBPM in predicting future CVD events
- Externally validated risk models from large U.S. cohorts to identify higher risk adults for whom more frequent screening may be appropriate
- Studies examining validated risk models to identify patients for masked hypertension screening
- Clinical effectiveness trials examining the benefits and harms of treatment of white coat and masked hypertension.
- Systems approaches to improve ABPM use for hypertension confirmation

## Conclusions

Our meta-analysis demonstrated that blood pressure screening administered at a single visit has a low sensitivity and adequate specificity for detection of hypertension, leading to a substantial number of potentially missed cases. In contrast, we found that confirmatory office or home blood pressure measurements, when applied to a preselected population, are generally more sensitive but not specific. We did not identify any studies meeting inclusion criteria for unattended AOBP or kiosk blood pressure measurements for screening or diagnostic confirmation. Scant literature is available to inform best practices in blood pressure measurement protocols. Available literature with design limitations suggests that the direct harms of screening and confirmatory blood pressure measurements are minimal and the most notable harm of blood pressure screening is likely misdiagnosis. Future research is needed to determine the best screening and confirmatory algorithms including details on measurement protocols and blood pressure thresholds for clinical practice and to clarify the benefits of treating white coat and masked hypertension.