# Chapter 3 Results

## Literature Search

We reviewed 21,741 abstracts and assessed 544 full-text articles for inclusion (Appendix B Figure 1). Overall, we included 52 studies (reported in 81 articles), representing over 215,000 adults. For KQ 1, we included one study (4 articles); for KQ 2, 20 studies (34 articles); for KQ 3, 18 studies (28 articles); and for KQ 4, 13 studies (16 articles). Thirty-five studies were newly identified in this update, and 18 were carried forward from the preview review.

The lists of included studies and excluded studies (with reasons for exclusion) are available in Appendix C and Appendix D, respectively. Among all KQs, seven studies (reported in 14 articles) were excluded for poor quality and these were all studies of test accuracy. In brief, major risks of bias included a lack of independence between index and reference standards, inappropriate exclusions of participants that would bias accuracy, and unclear or potentially biased participant recruitment methods (Appendix A Table 3).

## KQ1 Does Screening for Hypertension in Adults Improve Health Outcomes?

### Summary of Results

There were no population-based hypertension screening trials. One community-based cluster RCT included in the previous review reported that a multicomponent CVD health promotion program was associated with a reduction in the trial’s primary composite outcome (hospital admissions for acute MI, CHF, or stroke) at one year follow up.

### Detailed Results

There were no population-based screening trials examining the effectiveness of hypertension screening compared with no screening. We identified one good-quality community-based cluster RCT (reported in 4 articles) conducted in Canada examining the effectiveness of a multicomponent CVD health promotion program on CVD health outcomes when hypertension screening was the primary intervention (Appendix E Tables 1 and 2).^89^ The trial comprised 39 clusters and evaluated 140,642 community members; 15,889 unique participants received a total of 27,358 assessments in the intervention group. This study was also included in the previous review. The community clusters received either the CHAP Cardiovascular Health Awareness Program (CHAP) intervention or no intervention. In the CHAP communities, residents age 65 and older were invited to participate in community pharmacy-based BP screenings using an automated instrument (BpTRU®, VSM MedTech, Coquitlam, BC) and complete a standardized risk profile. Blood pressure measurement in this trial could be categorized as an attended AOBP measurement. Intervention participants received their risk profile, risk-specific educational materials, and information about local community resources. An on-call nurse reassessed participants with very high blood pressures (i.e., SBP of 180 or DBP of 110 mm Hg). Blood pressure and risk assessment results were communicated with the participants’ family physicians. The entire program duration was 10 weeks. The mean age of participants was 74.8 years, and 57.2 percent were women. Twelve percent of the participants had a previous history of congestive heart failure (CHF), and 22 percent had diabetes. The primary composite outcome was the relative change in the mean annual rate of hospital admissions for acute MI, CHF, or stroke in all community residents age 65 years or older in the year before compared with the year after CHAP implementation. The intervention communities had a 9 percent relative reduction in the number of hospital admissions per 1,000 for composite events (rate ratio 0.91 [95% CI, 0.86 to 0.97]). There were 3.02 fewer annual hospital admissions for CVD per 1,000 people in the intervention group compared with the control group. For hospitalizations due to individual components of the composite outcome (MI, CHF, stroke), there was a statistically significant reduction seen in admissions due to MI (rate ratio 0.87 [95% CI, 0.79 to 0.97]) and CHF (rate ratio 0.90 [95% CI, 0.81 to 0.99]). When analyzed by number of residents (instead of by number of hospital admissions), the composite outcome did not have a statistically significant difference (rate ratio 0.95 [95% CI, 0.89 to 1.02]), and MI was the only component of the composite that showed statistically significant benefit (rate ratio 0.89 [95% CI, 0.79 to 0.99]). There were no statistically significant differences in all-cause mortality (rate ratio 0.98 [95% CI, 0.92 to 1.03])) or in-hospital CV mortality (rate ratio 0.86 [95% CI, 0.73 to 1.01]). Initiation of antihypertensive treatment was 10 percent higher in the intervention group compared with the control group (rate ratio 1.10 [95% CI, 1.02 to 1.20]).

This large cluster RCT was rated good quality.^89^ While the intervention primarily included systematic hypertension screening, other interventions including risk assessments, education, and self-management likely contributed to the health benefits achieved in the trial. Overall, risk of bias was low for all domains of critical appraisal: randomization, intervention fidelity, attrition, and outcome reporting. Trial limitations included short 10-week intervention and 1-year followup times; furthermore, the outcome measures were derived from administrative records which inherently present some validity concerns although would not have systematically biased results in favor of either study group.

## KQ2 What Is the Accuracy of OBPM During a Single Encounter as Initial Screening for Hypertension Compared With the Reference Standard, ABPM?

### Summary of Results

We identified 20 fair- to good-quality studies (reported in 34 articles) (N=12,614) examining the test accuracy of office-based blood pressure measurement (OBPM) for initial screening for hypertension compared with an ambulatory blood pressure measurement (ABPM) reference standard.^80–82,^ ^90–120^ All studies are newly included in this update because of the new requirement in this review to have an ABPM reference standard.

Meta-analysis of 15 studies using SBP/DBP thresholds and measuring blood pressure at one visit (N=11,309) showed a pooled sensitivity of 0.54 (95% CI, 0.37to 0.70) and a pooled specificity of 0.90 (95% CI, 0.84 to 0.95). Substantial clinical and methodologic heterogeneity among the included studies contributed to considerable statistical heterogeneity not explained by any single participant or test characteristic (Figure 2). Among this set of studies, positive predictive values ranged widely, from 0.35 to 0.97, and negative predictive values ranged from 0.25 to 0.97. False positive and false negative rates likewise ranged widely and were as high as 30 percent for false positive rates and 100 percent for false negative rates (FPR 0 to 30%; FNR 8 to 100%). Evidence for this key question is derived primarily from population-based samples in which participants represent a wide range of demographic and clinical characteristics, including a large range of blood pressures. Index test measurement protocols were heterogeneous and deviated somewhat from commonly performed protocols in U.S. practice in that studies mostly used a mercury sphygmomanometer, had participants rest for 5 minutes prior to measurement, and used the average of multiple measurements.

Figure 2 KQ2: Test Accuracy of Screening Office Blood Pressure Monitoring at a Threshold of ≥140/90 mm Hg* to Identify Hypertension Detected by Ambulatory Blood Pressure Monitoring, by Author

Abbreviations: ABPM = ambulatory blood pressure measurement; AM = daytime; CI = confidence interval; combo = combination; Dx TH = diagnostic threshold; HTN = hypertension; n = number; PM = nighttime; pct = percent; pos scrn = positive screen; 24 = 24-hour

Notes: The ABPM diagnostic threshold for Wojciechowska is ≥130/80 mm Hg for 24 ABPM, ≥135/85 mm Hg for daytime ABPM, and ≥120/70 mm Hg for nighttime ABPM. For Lyamina the diagnostic threshold is ≥135/85mm Hg for daytime ABPM, and ≥120/70 mm Hg for nighttime ABPM.

Sensitivity I^2^=97.8; Specificity I^2^=96.7

*Gourlay used a threshold of ≥150/90 for OBPM.

Figure 2 is a forest plot that shows the test accuracy of screening office blood pressure monitoring at a threshold of ≥140/90 mm Hg* to identify hypertension detected by ambulatory blood pressure monitoring, by author. The overall pooled sensitivity being 0.54 (95% CI, 0.37, 0.70) and the overall pooled specificity of 0.90 (95% CI, 0.84, 0.95).

### Study and Population Characteristics

Included studies were most commonly community-based samples and were conducted in a variety of countries (Table 6; Appendix E Table 3). Five studies were conducted in the U.S.,^80,^ ^90,^ ^100,^ ^103,^ ^104^ two studies each were conducted in Belgium,^91,^ ^105^ Italy,^98,^ ^101^ and Japan,^95,^ ^96^ and one study each was conducted in Australia,^93^ Canada,^102^ Denmark,^94^ Finland,^81^ France,^92^ Ireland,^99^ Poland,^106^ Russia,^97^ and the United Kingdom.^82^ Fourteen studies recruited participants from the community;^81,^ ^90,^ ^92–96,^ ^98,^ ^100–102,^ ^104–106^ three studies recruited from primary care;^82,^ ^91,^ ^99^ one recruited from both the community and primary care;^80^ one recruited participants from local businesses and colleges;^97^ and one recruited employees from multiple organizations.^103^

Table 6 Study and Baseline Population Characteristics of Included Studies for KQ2, by Author

Author, Year; Study name; Quality | Country | Brief population description | Recruitment setting | N analyzed | Mean, OBPM, SBP/DBP (mmHg) | Mean ABPM, SBP/DBP (mmHg) | Age, mean (range) | % female | % white | % DM | Mean BMI, kg/m^2^
Abdalla, 2016^90^; The Improving the Detection of HTN study; Fair | US | Community-based sample of adults aged 20 to 81 | Community-based | 282 | 116.0/75.6 | 124.5/77.7^*^ | 34.9 (20-81) | 58.0 | NR^‡^ | 5.0 | 27.0
Fagard, 2005^91^; Fair | Belgium | Adults ≥60 years from primary care practice | Primary care | 243 | 136.7/76.2 | 128.0/76.6^*^ | 70 (≥60) | 52.4 | NR | 7.2 | 26.7
Gill, 2017^82^; BP-Eth; Fair | UK | Adults 40-75 years not previously identified as hypertensive | Primary care | 211 | NR | NR | 55.8 (40-75) | 53.1 | 46.4 | 5.7 | 28.1
Gosse, 2010^92^; PROOF; Fair | France | Adults ≥65 years | Community-based | 738 | 141.4/87.1 | 122.7/78.8^*^; 118.0/75.8^†^ | 65 (65-65) | 60.0 | NR | 4.3 | 24.9
Gourlay, 1993^93^; Fair | Australia | Untreated adults agreeing to wear ABPM recorder | Community-based | 66 | 133/82.7 | 130.8/75.7^*^ | 45 (21-67) | 37.9 | NR | NR | 25.9
Hanninen, 2010^81^; Fair | Finland | Adults 35-64 years | Community-based | 254 | 121.7/76.6 | 127.2/77.8^*^ | 49.1 (35-64) | 52.1 | NR | NR | 26.5
Hansen, 2006^94^; MONICA; Fair | Denmark | Adults aged 41 to 72 years, without major CVD | Community-based | 1385 | 127.6/81.5 | 130.5/77.7^*^ | 61.3 (41-72) | 52.9 | 100 | 2.4 | 25.6
Ishikawa, 2010^95^; Fair | Japan | Residents ≥20 years | Community-based | 129 | 132/82 | 121/74^†^ | 59.9 (≥20) | 52.7 | NR | 15.5 | 24.0
Kanno, 2010^96^; Ohasama Study; Fair | Japan | Adults ≥40 years | Community-based | 775 | 128.9/71.6 | 130.5/76.2^*^; 124.872.1^†^ | 66.8 (NR) | 72.3 | NR | 12.6 | 23.2
Larkin, 1998^80^; Fair | US | Pts without serious medical disorders (except HTN), psychiatric disorders and those taking antihypertension meds | Community-based Primary care | 65 | 127.8/82.7 | 132.8/81.9^†^ | 45.1 (20-69) | 47.7 | 100 | NR | NR
Lyamina, 2012^97^; Fair | Russia | Young subjects free of CVD, DM or other comorbidities | Cardiology outpatient^§^ | 269 | NR | NR | 25.6 (18-36) | 62.4 | NR | 0 | 25.6
Mancia, 2006^98^; PAMELA; Good | Italy | Adults 25-74 years | Community-based | 2024 | 132.8/83.8 | 120.2/74.4^†^ | 50.9 (25-74) | 49.4 | NR | NR | 25.6
O’Flynn, 2016^99^; Mitchelstown cohort; Fair | Ireland | Adults, aged 50 to 69 years | Primary care | 577 | 134/83 | 131/77^*^; 124/72^†^ | 60 (50-69) | 53 | NR | 9 | 29
Poudel, 2019^100^; CARDIA; Fair | US | African American and White men and women aged 48-60 | Community-based | 432 | 120/73 | 128/81^*^; 123/76^†^ | 54.5 (48-60) | 56 | 48.4 | 7.4 | 29.3
Scuteri, 2016^101^; SardiNIA; Fair | Italy | Residents aged ≥14 years | Community-based | 2955 | 124.3/77.3 | 119.3/74.6^†^ | 49.0 (14-102) | 60.1 | NR | 6.5 | 25.7
Selenta, 2000^102^; Fair | Canada | Presumably healthy students and community members aged 17-68 years not taking cardioactive medications | Community-based | 319 | 117.1/68.8 | 129.2/80.0^*^ | 27 (17-68) | 51.7 | 70 | NR | NR
Shimbo, 2012^103^; Masked Hypertension Study; Fair | US | Untreated adults ≥18 years with screening BP ≤160/105 mm Hg | Employment-based | 813 | 116.3/76.0 (Mean of 3 readings) | 123.1/77.4^*^ | 45.1 (NR) | 58.4 | NR | 3.6 | 27.6
Thomas, 2017^104^; Jackson Heart Study; Fair | US | African American adults aged 20 to 95 years | Community-based | 441 | 124.5/74.6 | 127.1/78.2^*^ | NR (NR) | 63.3 | 0 | 12.1 | 30.0
Wei, 2016^105^; FLEMENGHO; Fair | Belgium | Teen-aged and older household members with a records of ABPM and retinal photography | Community-based | 717 | 120.7/74.8 | 122.8/76.1^*^ | 38.2 (NR) | 51.3 | 100 | 1.0 | 24.7
Wojciechowska, 2016^106^; Fair | Poland | Adults ≥18 years | Community-based | 201 | 125.0/84.3 | 122.9/76.8^*^; 118.9/73.4^†^ | 41.1 (NR) | 53.2 | 100 | NR | 25.0

* Daytime ABPM. Nighttime ABPM: 109/63.7

† 24-hr ABPM

‡ Reported 22% Black

§ Participants were recruited from local colleges and businesses when they presented for annual examinations in an outpatient cardiology clinic.

Abbreviations: ABPM = ambulatory blood pressure measurement; BMI = body mass index; CARDIA = the Coronary Artery Risk Development in Young Adults study; CVD = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellites; FLEMENGHO = the Flemish Study on Environment, Genes and Health Outcomes; HTN = hypertension; kg/m^2^ = kilograms per meter squared; NR = not reported; MONICA = MONItoring of trends and determinants in Cardiovascular Disease study; mm HG = millimeter of mercury; OBPM = office-based BP measurement; PAMELA = Pressioni Arteriose Monitorate e Loro Associazioni study; PROOF = The Prognostic Indicator of Cardiovascular and Cerebrovascular Events study; SBP = systolic blood pressure; UK = United Kingdom; US = United States; yr(s) = year(s)

Participants in included studies exhibited a wide range of demographic and clinical characteristics (Table 6). The number of participants in the studies used for this analysis, which focused on untreated populations, ranged from 65^80^ to 2,955.^101^ Participant ages ranged from 14 years to 102 years, with mean age ranging from 25.6 years^97^ to 70 years.^91^ Percent female ranged from 37.9 percent^93^ to 72.3 percent.^96^ Only nine of 19 studies reported race/ethnicity. Of those, four studies were conducted with 100 percent white populations^80,^ ^94,^ ^105,^ ^106^ and one study, the Jackson Heart Study, had a 100 percent black population.^104^ Less than 10 percent of participants reported history of MI, CVA or previous CVD at baseline in the 11 studies reporting this characteristic.^81,^ ^82,^ ^91,^ ^92,^ ^94–97,^ ^99,^ ^103,^ ^104^

Mean sitting office SBP ranged from 109.1 mm Hg^115^ to 136.7 mm Hg^91^ and mean office DBP ranged from 68.8 mm Hg^102^ to 84.3 mm Hg.^106^ For both SBP and DBP, the lowest values were from young populations with mean ages of 30 or less years;^102,^ ^115^ the highest blood pressures were from a French sample of 65-year-old people in whom the measurement was taken in the supine position.^92^

### Index Test Characteristics

Included index tests applied a wide range of protocols and devices (Table 7). The office-based blood pressure measurement devices in the majority of the studies (14 of 20) used the auscultatory method,^80,^ ^81,^ ^90–94,^ ^96–98,^ ^101,^ ^103–105^ while a few studies used the oscillatory method.^82,^ ^95,^ ^99,^ ^100,^ ^102,^ ^106^ All devices using the auscultatory method were manual, with the exception of an automatic device using the microphone method in one study.^96^ Other manual devices were mercury sphygmomanometers, used in 11 studies,^80,^ ^81,^ ^90–93,^ ^97,^ ^98,^ ^101,^ ^103,^ ^105^ and random-zero mercury sphygmomanometers, used in two studies.^94,^ ^104^ The remaining seven studies used automated devices.^82,^ ^95,^ ^96,^ ^99,^ ^100,^ ^102,^ ^106^ All included studies had attended measurements. One study by Gill and colleagues^82^ could be considered attended AOBP as it used a fully automated BPTru device with a preprogrammed set of 6 measurements.

Table 7 Test Characteristics of Included Studies for KQ2, by Author

Author, Year; Trial name; Quality | OBPM threshold(s), mm Hg | OBPM Device (A or M) | Total # of office measurements in single visit | Method of determination | Interventionist attending | Resting time (min) | ABPM modality reference | Reference threshold, mm Hg
Abdalla, 2016^90^; The Improving the Detection of HTN study; Fair | ≥140/90 | Mercury sphyg (M) | 3 | Mean of 3 | Research nurse/technician | 1 | Combined day and night | ≥135/85 (day) or ≥120/70 (night)
Fagard, 2005^91^; Fair | ≥140/90 | Mercury sphyg (M) | 3 | Mean of 3 | Participants’ usual PCP or assistant physician | 5 | Daytime | ≥135/85
Gill, 2017^82^; BP-Eth; Fair | 140/90^*^ | BpTru (A)^‡^ | 18 | Mean of second and third readings from the 3 visits | Research nurse | 5 | Daytime | 135/85^*^
Gill, 2017^82^; BP-Eth; Fair | 135/85^*^ | BpTru (A)^‡^ | 18 | Mean of second and sixth readings from the 3 visits | Research nurse | 5 | Daytime | 135/85^*^
Gill, 2017^82^; BP-Eth; Fair | 140/90^*^ | BpTru (A)^‡^ | 18 | First reading on the first visit | Research nurse | 5 | Daytime | 135/85^*^
Gosse, 2010^92^; Proof; Fair | SBP ≥140 | Mercury sphyg (M) | 2 | Mean of 2 SBPs while lying down | Physician | 15 | Daytime | SBP ≥135
Gourlay, 1993^93^; Fair | ≥150/90 | Mercury sphyg (M) | 2 | Mean of 2 | Nurse | NR | Daytime | ≥135/85
Gourlay, 1993^93^; Fair | ≥160/95 | Mercury sphyg (M) | 2 | Mean of 2 | Nurse | NR | Daytime | ≥135/85
Hanninen, 2010^81^; Fair | ≥140/90 | Mercury sphyg (M) | 8 | Mean of 8 | Nurse | 15 | Daytime | ≥140/85
Hansen, 2006^94^; MONICA; Fair | ≥140/90 | Random zero mercury sphyg (M) | 2 | Mean of 8 | NR | 5 | 24-hr; Daytime | 24-hr: ≥125/80; Daytime: ≥135/85
Ishikawa, 2010^95^; Fair | ≥140/90 | UA-631; A&D Company, Ltd, Tokyo, Japan (A) | 2 | Mean of 2 | Physician | 5 | 24-hr | ≥130/80
Kanno, 2010^96^; Ohasama Study; Fair | ≥140/90 | USM700F; Ueda Electronic Work Co., Ltd., Tokyo, Japan (A)^†^ | 2 | Mean of 2 | Nurses or technicians | 2 | 24-hr; Daytime | 24-hr: ≥135/85; Daytime: ≥140/85
Larkin, 1998^80^; Fair | 140/90 | Mercury sphyg (M) | 9 | Mean of 9 | Research assistant | 10 | 24-hr; Combined 24-hr, daytime, nighttime ABPM | 24hr: ≥135/85 AND ≥140/90; Combined: ≥139/87 (24-hr) OR ≥143/91 (day) OR ≥127/79 (night)
Lyamina, 2012^97^; Fair | ≥140/90 with breath-hold | Mercury sphyg (M) | 2 | NR | Cardiologist | 20 | Combined day and night | ≥135/85 (day) OR ≥120/70 (night)
Lyamina, 2012^97^; Fair | >120/80 | Mercury sphyg (M) | 2 | NR | Cardiologist | 20 | Combined day and night | ≥135/85 (day) OR ≥120/70 (night)
Lyamina, 2012^97^; Fair | ≥140/90 | Mercury sphyg (M) | 2 | NR | Cardiologist | 20 | Combined day and night | ≥135/85 (day) OR ≥120/70 (night)
Mancia, 2006^98^; PAMELA; Good | ≥140/90 | Mercury sphyg (M) | 3 | Mean of 3 | Physician | 10 | 24-hr | ≥125/79
O’Flynn, 2016^99^; Mitchelstown cohort; Fair | ≥140/90 | Omron Model M7 (A) | 3 | Mean of second and third | NR | ≥5 | 24-hr; Daytime; Nighttime; Combined day and night | 24-hr: ≥130/80; Daytime: ≥135/85; Nighttime: ≥120/70; Combined day and night: ≥135/85 (day) OR ≥120/70 (night)
Poudel, 2019^100^; CARDIA; Fair | ≥130/80 | Omron HEM907XL (A) | 3 | Average of 2^nd^ and 3^rd^ measurements | Trained and certified staff | NR | Daytime | ≥130/80 AND ≥135/85
Poudel, 2019^100^; CARDIA; Fair | ≥140/90 | Omron HEM907XL (A) | 3 | Average of 2^nd^ and 3^rd^ measurements | Trained and certified staff | NR | Daytime | ≥130/80 AND ≥135/85
Scuteri, 2016^101^; SardiNIA; Fair | ≥140/90 | Mercury sphyg (M) | 6 | Mean of second and third of both the right and left arm | NR | 5 | 24-hr ABPM | ≥125/79 AND ≥130/80
Selenta, 2000^102^; Fair | SBP ≥140 | Dinamap 845 Vital Signs Monitor; Critikon Corporation (A) | 5 | Mean of 5 | NR | NR | Daytime | ≥135/85
Selenta, 2000^102^; Fair | DBP ≥90 | Dinamap 845 Vital Signs Monitor; Critikon Corporation (A) | 5 | Mean of 5 | NR | NR | Daytime | ≥135/85
Selenta, 2000^102^; Fair | SBP ≥130 | Dinamap 845 Vital Signs Monitor; Critikon Corporation (A) | 5 | Mean of 5 | NR | NR | Daytime | ≥135/85
Selenta, 2000^102^; Fair | SBP ≥160 | Dinamap 845 Vital Signs Monitor; Critikon Corporation (A) | 5 | Mean of 5 | NR | NR | Daytime | ≥135/85
Selenta, 2000^102^; Fair | DBP ≥80 | Dinamap 845 Vital Signs Monitor; Critikon Corporation (A) | 5 | Mean of 5 | NR | NR | Daytime | ≥135/85
Selenta, 2000^102^; Fair | DBP ≥100 | Dinamap 845 Vital Signs Monitor; Critikon Corporation (A) | 5 | Mean of 5 | NR | NR | Daytime | ≥135/85
Shimbo, 2012^103^; Masked Hypertension Study; Fair | ≥120/80 | Mercury sphyg (M) | 9 | Mean of 9 | Research nurse/ technician | ≥5 | Daytime | ≥135/85
Shimbo, 2012^103^; Masked Hypertension Study; Fair | ≥130/85 | Mercury sphyg (M) | 9 | Mean of 9 | Research nurse/ technician | ≥5 | Daytime | ≥135/85
Shimbo, 2012^103^; Masked Hypertension Study; Fair | ≥120/80 | Mercury sphyg (M) | 3 | Mean of 3 from single visit | Research nurse/ technician | ≥5 | Daytime | ≥135/85
Shimbo, 2012^103^; Masked Hypertension Study; Fair | ≥130/85 | Mercury sphyg (M) | 3 | Mean of 3 from single visit | Research nurse/ technician | ≥5 | Daytime | ≥135/85
Shimbo, 2012^103^; Masked Hypertension Study; Fair | ≥140/90 | Mercury sphyg (M) | 9 | Mean of 9 | Research nurse/ technician | ≥5 | Daytime | ≥135/85
Shimbo, 2012^103^; Masked Hypertension Study; Fair | ≥140/90 | Mercury sphyg (M) | 3 | Mean of 3 from single visit | Research nurse/ technician | ≥5 | Daytime | ≥135/85
Thomas, 2017^104^; Jackson Heart Study; Fair | ≥140/90 | Hawksley random zero sphyg (M) | 2 | Mean of 2 | NR | 5 | Daytime | ≥135/85
Wei, 2016^105^; FLEMENGHO; Fair | ≥140/90 | Mercury sphyg (M) | 5 | Mean of 5 | Nurse | 5 | Daytime | ≥135/85
Wojciechowska, 2016^106^; Fair | ≥140/90 | OMRON 705CP (A) | 5 | Mean of 5 | Observer (not further specified) | 15 | Combined 24-hr, daytime, nighttime ABPM | ≥130/80 (24-hr) OR ≥135/85 (day) OR ≥120/70 (night)

* (NR > or ≥)

† Semiautomatic BP measuring device based on the microphone method

‡ Attended AOBP

Abbreviations: A = automated; ABPM = ambulatory blood pressure measurement; CARDIA = the Coronary Artery Risk Development in Young Adults study; DBP = diastolic blood pressure; FLEMENGHO = the Flemish Study on Environment, Genes and Health Outcomes; HTN = hypertension; hr = hour; M = manual; MONICA = MONItoring of trends and determinants in Cardiovascular Disease study; mm HG = millimeter of mercury; NR = not reported; OBPM = office-based BP measurement; PAMELA = Pressioni Arteriose Monitorate e Loro Associazioni study; PCP = primary care provider; PROOF = The Prognostic Indicator of Cardiovascular and Cerebrovascular Events study; SBP = systolic blood pressure; sphyg = sphygmomanometer

Per inclusion criteria, all initial blood pressure screening measurements occurred in office-based settings. We initially included only screening protocols occurring at one clinical encounter; however, we later expanded our criteria to include studies measuring blood pressure over multiple visits to be consistent with guidelines.^20,^ ^121^ Two additional studies were included based on this expansion; these were included in the sensitivity analysis. One measured blood pressure over three visits occurring at 1-week intervals,^80^ and the other measured blood pressure at four visits occurring over a 3-week period.^81^ Several studies measured blood pressure over several visits but reported accuracy for protocols using measures from just the first visit as well as multiple visits;^82,^ ^102,^ ^103^ the comparative accuracy of different protocols is discussed further in KQ2a. The number of measurements used to calculate blood pressure ranged from one^82^ to nine^80,^ ^103^ but was most commonly two (9 studies).^92–97,^ ^99,^ ^100,^ ^104^ Typically, all measures were averaged to calculate the blood pressure value, but in some studies the first measurement was dropped before calculating the mean.^82,^ ^99–101^

For most protocol characteristics, there was wide variation in the specificity of the index test-protocol description (Table 7). More than half of studies did not report which arm was used for blood pressure measurement,^81,^ ^90,^ ^92–96,^ ^102,^ ^103,^ ^105,^ ^106^ and arm position was rarely noted. None of the studies reported whether the cuff was placed over clothing or bare skin. Eight studies reported no information about cuff size,^82,^ ^92,^ ^95–97,^ ^99,^ ^102,^ ^106^ while the remaining studies provided some variable detail on cuff-size^80,^ ^81,^ ^90,^ ^91,^ ^93,^ ^94,^ ^98,^ ^100,^ ^101,^ ^103–105^ Only two studies reported leg position; both reported leg position as flat feet on the floor^100,^ ^104^ and one further specified uncrossed legs.^104^ The protocol characteristics of body position, resting time, and attendance of measurements (i.e. presence of personnel during measurement) were well reported and showed similarities spanning all studies, including use of the seated position and resting time that was most commonly 5 minutes or at least 5 minutes.^82,^ ^90,^ ^91,^ ^94,^ ^95,^ ^98–101,^ ^103–105^ Avoidance of distraction was mentioned in a few studies; two studies noted that the rest period was quiet,^80,^ ^101^ and one study specifically instructed observers not to speak during blood pressure measurements.^102^ Blood pressure measurements in all studies were attended by the personnel performing measurements, but there was a wide variety of personnel taking measurements, including physicians,^92,^ ^95,^ ^98^ participants’ usual primary care physicians,^91^ cardiologists,^97^ nurses or research nurses,^81,^ ^82,^ ^90,^ ^93,^ ^105^ nurses or technicians,^96,^ ^103^ research assistants,^80^ or trained and certified staff without further specification.^100,^ ^106^ Most commonly, studies did not report how personnel were trained or noted only that personnel were trained.

Studies most commonly used an office BP of ≥140/90 mm Hg as the diagnostic threshold for the index test (15 of 20 studies).^81,^ ^90,^ ^91,^ ^94–101,^ ^103–106^ An additional two studies used a threshold of 140/90 mm Hg; however, it was not reported whether the threshold was operationalized as greater than or equal to 140/90 mm Hg or greater than this value.^80,^ ^82^ Of the studies using a combination SBP/DBP threshold, only one did not use a cutpoint of 140/90 mm Hg; instead it used thresholds of ≥150/90 mm Hg and ≥160/95 mm Hg.^93^ Several studies also reported accuracy for other thresholds in addition to ≥140/90 mm Hg (i.e., ≥ or >120/80 mm Hg^97,^ ^103^ and ≥130/85 mm Hg^103^). Two studies used SBP-alone or DBP-alone thresholds.^92,^ ^102^ One study^100^ reported accuracy for an OBPM threshold of ≥130/80 mm Hg, the diagnostic threshold recommended in the 2017 ACC/AHA guideline.^20^ However, because this study reported accuracy compared to a reference standard threshold that was also lowered, no information is available about the comparative accuracy of ≥130/80 mm Hg vs ≥140/90 mm Hg using the same reference standard threshold.

### Reference Test Characteristics

While all but one study^102^ reported that 24-h ABPM was conducted, most studies (k=13) used daytime ABPM as their reference standard (Table 7). Seven studies used 24-h ABPM as the reference standard,^80,^ ^94–96,^ ^98,^ ^99,^ ^101^ and five studies used combination thresholds for 24-h, daytime, and/or nighttime, and required one period to be abnormal to diagnose hypertension.^80,^ ^90,^ ^97,^ ^99,^ ^106^ Four studies reported results for multiple reference standard tests (e.g., daytime and 24-h ABPM).^80,^ ^94,^ ^96,^ ^99^

Consistent with guidelines,^31,^ ^34,^ ^68,^ ^79^ the diagnostic threshold most commonly used for daytime ABPM was ≥135/85 mm Hg.^82,^ ^90,^ ^91,^ ^93,^ ^94,^ ^99,^ ^100,^ ^102–105^ Two studies used a daytime ABPM cutpoint of ≥140/85 mm Hg,^81,^ ^96^ while another used a daytime ABPM cutpoint using systolic blood pressure only (SBP ≥135 mm Hg).^92^ The 24-hr ABPM threshold values showed more variation, with thresholds ranging from ≥125/79 mm Hg^98,^ ^101^ to ≥140/90 mm Hg.^80^ The remaining studies used combination definitions for hypertension involving blood pressure elevation for 24-hr, daytime, and/or nighttime with various thresholds.^80,^ ^97,^ ^99,^ ^106^ Three studies reported multiple thresholds for the same type of ABPM.^80,^ ^100,^ ^101^

Timing to start daytime ABPM measurement varied, but nearly all studies reported beginning times of 0600 to 1000 and ending times ranging from 2000 to 2300.^81,^ ^82,^ ^91,^ ^93,^ ^101,^ ^104–106^ Measurements occurred every 15 to 30 minutes during the daytime period and 15 to 60 minutes during the nighttime period. Most studies (k=13) required a minimum number of measurements to consider the ABPM complete.^80,^ ^82,^ ^90,^ ^92,^ ^94,^ ^96,^ ^98–101,^ ^104–106^ Most commonly, ABPM values were determined by calculating simple means,^80–82,^ ^90,^ ^92,^ ^95–98,^ ^101–104,^ ^106^ but in some cases, means were weighted.^91,^ ^93,^ ^94,^ ^100,^ ^105^

Other protocol details about the arm measured, cuff size, and instructions provided to participants were sparsely reported.

### Quality

Only one of the included studies was rated as good quality.^98^ This study was a random population-based sample of residents of an Italian town with low risk of bias for all four domains evaluated during critical appraisal. Several studies had at least medium risk of bias for patient selection, conduct of the index test, and conduct of the reference test. Fifteen of the 20 included studies had medium risk of bias in the domain of patient selection.^80,^ ^82,^ ^90,^ ^93,^ ^97,^ ^103,^ ^106^ to high^94–96,^ ^99–102,^ ^104^ Potential for bias for the patient selection domain was introduced because of lack of reporting of initial recruitment strategy^80,^ ^90,^ ^97,^ ^103,^ ^106^ or self- or clinician-selected volunteers,^80,^ ^82,^ ^99,^ ^100^ or because the sample was a subset of a larger population without details of how the subset was achieved or without assurance that the subsample was representative of larger population.^93–95,^ ^101,^ ^104^ Some studies excluded participants with higher blood pressures^103^ or those on cardiovascular medications,^102^ which may have removed higher risk participants from samples, potentially underestimating accuracy. Studies rarely provided details on all relevant OBPM protocol characteristics; however, most studies reported sufficient detail to achieve a low risk of bias for this domain. Six studies had medium risk of bias for conduct of the reference test because they did not report fidelity to the gold-standard ABPM measurements (e.g., there were no reports of minimum required ABPM measurements or mean number of ABPM values obtained)^81,^ ^91,^ ^93,^ ^95,^ ^97,^ ^102^ or issues with calibration and use of visual inspection of ABPM reports.^80^ Five studies had medium risk of bias for the patient flow domain due to lack of reporting about the nature of missing data or disproportionate exclusions from data analysis.^82,^ ^90,^ ^93,^ ^94,^ ^105^

### Detailed Results

#### Prevalence and Screen Positivity

The prevalence of hypertension as defined by ABPM in the included studies reflected population heterogeneity and ranged from 12.6 percent^97^ to 88.9 percent.^100^ Percent positive screens defined by elevated OBPM ranged from 0 percent^97^ in the cardiology outpatient setting with young participants (mean age 25.6 years) to as high as 62.5 percent^100^ in a study of African-American and white men and women (aged 48 to 60 years old) (Table 8).

Table 8 Test Accuracy Results of Included Studies for KQ2, by Author

Author, Year | N analyzed | ABPM method | ABPM threshold, mm Hg | OPBM threshold, mm Hg | Positive index test | Prev HTN (%) | Se (95% CI) | Sp (95% CI) | FPR (95% CI) | FNR (95%CI) | In MA
Abdalla, 2016^90^; The Improving the Detection of HTN study | 282 | Combined day and night | ≥135/85 (day) or ≥120/70 (night) | ≥140/90 | 12.8 | 34.4 | 0.33 (0.24, 0.43) | 0.98 (0.95, 0.99) | 0.02 (0.01, 0.05) | 0.67 (0.57, 0.76) | X
Fagard, 2005^91^ | 243 | Daytime | ≥135/85 | ≥140/90 | 42.8 | 31.3 | 0.71 (0.60, 0.80) | 0.70 (0.63, 0.76) | 0.30 (0.24, 0.37) | 0.29 (0.20, 0.40) | X
Gill, 2017^82^ | 211 | Daytime | 135/85 | 140/90 (Clinic23)^*,,§^ | NR | NR | 0.40 (0.29, 0.51) | 0.90 (0.84, 0.95) | NR | NR
Gill, 2017^82^ | 211 | Daytime | 135/85 | 135/85 (Clinic26)^†,§^ | NR | NR | 0.58 (0.47, 0.69) | 0.83 (0.76, 0.89) | NR | NR
Gill, 2017^82^ | 211 | Daytime | 135/85 | 140/90 (ClinicD1R1)^‡,§^ | NR | NR | 0.65 (0.54, 0.75) | 0.74 (0.66, 0.82) | NR | NR
Gosse, 2010^92^ | 738 | Daytime SBP | SBP ≥135 | SBP ≥140 | 57.7 | 20.2 | 0.85 (0.79, 0.90) | 0.49 (0.45, 0.53) | 0.51 (0.47, 0.55) | 0.15 (0.10, 0.21)
Gourlay, 1993^93^ | 66 | Daytime | ≥135/85 | ≥150/90 | 30.3 | 28.8 | 0.74 (0.51, 0.88) | 0.87 (0.75, 0.94) | 0.13 (0.06, 0.25) | 0.26 (0.14, 0.49) | X
Gourlay, 1993^93^ | 66 | Daytime | ≥135/85 | ≥160/95 | 18.2 | 28.8 | 0.47 (0.28, 0.68) | 0.94 (0.93, 0.98) | 0.06 (0.02, 0.17) | 0.53 (0.32, 0.73)
Hanninen, 2010^81^ | 254 | Daytime | ≥140/85 | ≥140/90 | 22.0 | 13.4 | 0.48 (0.36, 0.61) | 0.96 (0.93, 0.98) | 0.04 (0.02, 0.07) | 0.52 (0.39, 0.64)
Hansen, 2006^94^ | 1385 | 24-hr | ≥125/80 | ≥140/90 | 31.6 | 46.7 | 0.56 (0.52, 0.60) | 0.90 (0.87, 0.92) | 0.10 (0.08, 0.13) | 0.44 (0.40, 0.48) | X
Hansen, 2006^94^ | 1385 | Daytime | ≥135/85 | ≥140/90 | 32.9 | 36.8 | 0.66 (0.62, 0.69) | 0.86 (0.84, 0.88) | 0.14 (0.12, 0.16) | 0.34 (0.31, 0.38)
Ishikawa, 2010^95^ | 129 | 24-hr | ≥130/80 | ≥140/90 | 32.6 | 34.1 | 0.70 (0.56, 0.82) | 0.87 (0.78, 0.93) | 0.13 (0.07, 0.22) | 0.30 (0.18, 0.44) | X
Kanno, 2010^96^ | 775 | 24-hr | ≥135/85 | ≥140/90 | 19.4 | 13.9 | 0.48 (0.39, 0.57) | 0.85 (0.82, 0.88) | 0.15 (0.12, 0.18) | 0.52 (0.43, 0.61) | X
Kanno, 2010^96^ | 775 | Daytime | ≥140/85 | ≥140/90 | 22.3 | 21.3 | 0.40 (0.33, 0.47) | 0.82 (0.79, 0.85) | 0.18 (0.15, 0.21) | 0.60 (0.53, 0.67)
Larkin, 1998^80^ | 65 | 24-hr | ≥135/85 | ≥140/90 | 33.8 | 55.4 | 0.50 (0.34, 0.66) | 0.86 (0.69, 0.95) | 0.14 (0.05, 0.31) | 0.50 (0.34, 0.66)
Larkin, 1998^80^ | 65 | 24, Daytime, Nighttime | ≥139/87 24, ≥143/91 AM, ≥127/79 PM | ≥140/90 | 33.8 | 49.2 | 0.53 (0.36, 0.69) | 0.85 (0.69, 0.93) | 0.15 (0.07, 0.31) | 0.47 (0.31, 0.64)
Larkin, 1998^80^ | 65 | 24-hr | ≥140/90 | ≥140/90 | 33.8 | 38.5 | 0.52 (0.33, 0.70) | 0.78 (0.62, 0.88) | 0.22 (0.12, 0.38) | 0.48 (0.30, 0.67)
Lyamina, 2012^97^ | 269 | Daytime, Nighttime | ≥135/85 AM, ≥120/70 PM | >120/80 | 16.0 | 12.6 | 0.65 (0.48, 0.79) | 0.91 (0.87, 0.94) | 0.09 (0.06, 0.13) | 0.35 (0.21, 0.52)
Lyamina, 2012^97^ | 269 | Daytime, Nighttime | ≥135/85 AM, ≥120/70 PM | ≥140/90 with BH | 19.7 | 12.6 | 1.00 (0.90, 1.00) | 0.92 (0.88, 0.95) | 0.08 (0.05, 0.12) | 0.00 (0.00, 0.10)
Lyamina, 2012^97^ | 269 | Daytime, Nighttime | ≥135/85 AM, ≥120/70 PM | ≥140/90 | 0.0 | 12.6 | 0.00 (0.00, 0.10) | 1.00 (0.98, 1.00) | 0.00 (0.00, 0.02) | 1.00 (0.90, 1.00) | X
Mancia, 2006^98^ | 2024 | 24-hr | ≥125/79 | ≥140/90 | 42.0 | 33.0 | 0.74 (0.71, 0.77) | 0.74 (0.71, 0.76) | 0.26 (0.24, 0.29) | 0.26 (0.23, 0.29) | X
O’Flynn, 2016^99^ | 577 | Daytime, Nighttime | ≥135/85 AM, ≥120/70 PM | ≥140/90 | 37.6 | 42.5 | 0.67 (0.61, 0.73) | 0.84 (0.80, 0.88) | 0.16 (0.12, 0.20) | 0.33 (0.27, 0.39)
O’Flynn, 2016^99^ | 577 | 24-hr | ≥130/80 | ≥140/90 | 37.6 | 21.0 | 0.77 (0.69, 0.83) | 0.73 (0.69, 0.77) | 0.27 (0.23, 0.31) | 0.23 (0.17, 0.31) | X
O’Flynn, 2016^99^ | 577 | Daytime | ≥135/85 | ≥140/90 | 37.6 | 39.9 | 0.68 (0.62, 0.74) | 0.82 (0.78, 0.86) | 0.18 (0.14, 0.22) | 0.32 (0.26, 0.38)
| 577 | Nighttime | ≥120/70 | ≥140/90 | 37.6 | 24.4 | 0.69 (0.61, 0.76) | 0.72 (0.68, 0.76) | 0.28 (0.24, 0.32) | 0.31 (0.24, 0.39)
Poudel, 2019^100^; CARDIA | 432 | Daytime | ≥130/80 | ≥130/80 | 42.1 | 69.9 | 0.56 (0.50, 0.61) | 0.89 (0.83, 0.93) | 0.11 (0.07, 0.17) | 0.44 (0.39, 0.50)
Poudel, 2019^100^; CARDIA | 432 | Daytime | ≥135/85 | ≥140/90 | 62.5 | 88.9 | 0.68 (0.63, 0.73) | 0.83 (0.70, 0.91) | 0.17 (0.09, 0.30) | 0.32 (0.27, 0.37) | X
Scuteri, 2016^101^ | 2955 | 24-hr | ≥130/80 | ≥140/90 | 34.6 | 27.2 | 0.92 (0.90, 0.94) | 0.87 (0.86, 0.88) | 0.13 (0.12, 0.14) | 0.08 (0.06, 0.10) | X
Scuteri, 2016^101^ | 2955 | 24-hr | ≥125/79 | ≥140/90 | 36.9 | 35.6 | 0.86 (0.84, 0.88) | 0.90 (0.89, 0.91) | 0.10 (0.09, 0.11) | 0.14 (0.12, 0.16)
Selenta, 2000^102^ | 319 | Daytime | ≥135/85 | SBP ≥140 | 4.4 | 26.6 | 0.14 (0.08, 0.23) | 0.99 (0.97, 1.00) | 0.01 (0.00, 0.03) | 0.86 (0.77, 0.92)
Selenta, 2000^102^ | 319 | Daytime | ≥135/85 | DBP ≥90 | 3.1 | 27.6 | 0.11 (0.06, 0.20) | 1.00 (0.98, 1.00) | 0.00 (0.00, 0.02) | 0.89 (0.80, 0.94)
Selenta, 2000^102^ | 319 | Daytime | ≥135/85 | SBP ≥130 | 10.7 | 26.6 | 0.28 (0.20, 0.39) | 0.96 (0.92, 0.98) | 0.04 (0.02, 0.08) | 0.72 (0.61, 0.80)
Selenta, 2000^102^ | 319 | Daytime | ≥135/85 | DBP ≥80 | 11.9 | 27.6 | 0.38 (0.28, 0.48) | 0.98 (0.95, 0.99) | 0.02 (0.01, 0.05) | 0.63 (0.52, 0.72)
Selenta, 2000^102^ | 319 | Daytime | ≥135/85 | DBP ≥100 | 0.9 | 27.6 | 0.03 (0.01, 0.10) | 1.00 (0.98, 1.00) | 0.00 (0.00, 0.02) | 0.97 (0.90, 0.99)
Selenta, 2000^102^ | 319 | Daytime | ≥135/85 | SBP ≥160 | 0.3 | 26.6 | 0.01 (0.00, 0.06) | 1.00 (0.98, 1.00) | 0.00 (0.00, 0.02) | 0.99 (0.94,1.00)
Shimbo, 2012^103^ | 813 | Daytime | ≥135/85 | ≥140/90 (Mean of 3 readings) | 8.9 | 18.8 | 0.33 (0.26, 0.40) | 0.97 (0.95, 0.98) | 0.03 (0.02, 0.05) | 0.67 (0.60, 0.74) | X
Shimbo, 2012^103^ | 813 | Daytime | ≥135/85 | ≥120/80 (Mean of 3 readings) | 45.9 | 18.8 | 0.84 (0.77, 0.89) | 0.63 (0.59, 0.66) | 0.37 (0.34, 0.41) | 0.16 (0.11, 0.23)
Shimbo, 2012^103^ | 813 | Daytime | ≥135/85 | ≥130/85 (Mean of 3 readings) | 21.2 | 18.8 | 0.56 (0.48, 0.64) | 0.87 (0.84, 0.89) | 0.13 (0.11, 0.16) | 0.44 (0.36, 0.52)
Shimbo, 2012^103^ | 813 | Daytime | ≥135/85 | ≥140/90 (Mean of 9 readings) | 5.4 | 18.8 | 0.24 (0.18, 0.31) | 0.99 (0.98, 0.99) | 0.01 (0.01, 0.02) | 0.76 (0.69, 0.82)
Shimbo, 2012^103^ | 813 | Daytime | ≥135/85 | ≥120/80 (Mean of 9 readings) | 40.7 | 18.8 | 0.88 (0.81, 0.92) | 0.70 (0.67, 0.74) | 0.30 (0.26, 0.33) | 0.12 (0.08, 0.19)
Shimbo, 2012^103^ | 813 | Daytime | ≥135/85 | ≥130/85 (Mean of 9 readings) | 16.1 | 18.8 | 0.53 (0.45, 0.61) | 0.92 (0.90, 0.94) | 0.08 (0.06, 0.10) | 0.47 (0.39, 0.55)
Thomas, 2017^104^ | 441 | Daytime | ≥135/85 | ≥140/90 | 14.3 | 31.7 | 0.31 (0.24, 0.40) | 0.94 (0.90, 0.96) | 0.06 (0.04, 0.10) | 0.69 (0.60, 0.76) | X
Wei, 2016^105^ | 717 | Daytime | ≥135/85 | ≥140/90 | 10.5 | 15.5 | 0.34 (0.26, 0.43) | 0.94 (0.92, 0.96) | 0.06 (0.04, 0.08) | 0.66 (0.57, 0.74) | X
Wojciechowska, 2016^106^ | 201 | 24-hr, Daytime, Nighttime | ≥130/80 24, ≥135/85 AM, ≥120/70 PM | >140/90 | 30.3 | 32.8 | 0.62 (0.50, 0.73) | 0.85 (0.78, 0.90) | 0.15 (0.10, 0.22) | 0.38 (0.27, 0.50) | X

* Mean of second and third readings from the three visits

† Mean of second and sixth readings from the 3 visits

‡ First reading of the first visit

§ Attended AOBP

Abbreviations: ABPM = ambulatory blood pressure measurement; BH = breath hold; CI = confidence interval; DBP = diastolic blood pressure; FNR = false negative rate; FPR = false positive rate; hr = hour; HTN = hypertension; MA = meta-analysis; mm HG = millimeter of mercury; NR = not reported; OBPM = office-based BP measurement; Prev = prevalence; Se = sensitivity; Sp = specificity

#### Sensitivity/Specificity

Meta-analysis of 15 studies reporting SBP/DBP thresholds (N=11,309) showed a pooled sensitivity of 0.54 (95% CI, 0.37 to 0.70) and a pooled specificity of 0.90 (95% CI, 0.84 to 0.95) with considerable heterogeneity (I^2^ sensitivity=97.8%; I^2^ specificity=96.7%) (Figure 2; Table 8). Sensitivity varied widely among pooled studies. The lowest sensitivity was 0.00 in a sample of young participants (mean age 25.6 years) where 0 percent had a positive screen by OBPM, but 12.6 percent had hypertension by daytime or nighttime ABPM.^97^ The highest sensitivity was 0.92 reported in a large population-based study conducted in an Italian town with mean age of 49 years.^101^ Specificity varied less among pooled studies. The lowest specificity of 0.70 was reported in a study of adults 60 years or older recruited from primary care in Belgium, of whom 42.8 percent had a positive screen by OBPM.^91^ The highest specificity of 1.00 occurred in a sample of young adults of whom 0 percent had a positive screen by OBPM—this is the same study that reported a sensitivity of 0.00.^97^

Five studies did not contribute to the meta-analysis. The study by Gill and colleagues^82^ could not be included due to insufficient reporting; results for sensitivity were within the confidence intervals of the pooled analysis, but specificity was lower [0.74 (95% CI, 0.66 to 0.82)]. Two studies reported SBP-only or DBP-only thresholds that are not relevant to current clinical practice and showed widely varying accuracy.^92,^ ^102^ Based on recommendations from ACC/AHA to average measurements obtained on at least two visits,^20,^ ^31^ we conducted a sensitivity analysis to add two studies measuring blood pressure at three or four visits.^80,^ ^81^ This sensitivity analysis rendered the same point estimate, but with slightly narrower confidence intervals (sensitivity: 0.53 [95% CI, 0.37 to 0.68]; specificity: 0.91 [95% CI, 0.85 to 0.95]) (I^2^ sensitivity=97.5%; I^2^ specificity=96.8%)]. Exploration of heterogeneity using visual inspection of forest plots did not yield any decisive trends regarding participant or index test characteristics.

We conducted an exploratory analysis restricted to the preferred 24-h ABPM modality. Meta-analysis of 6 studies with a 24-hr ABPM reference standard (N=7,845) showed a pooled sensitivity of 0.72 (95% CI, 0.58 to 0.84) and specificity of 0.83 (95% CI, 0.78 to 0.88), again with considerable statistical heterogeneity (I^2^ sensitivity=98.2%; I^2^ specificity=96.9%) (Appendix F Figure 1). While the point estimate for sensitivity of OBPM compared to the 24-h ABPM reference standard was higher when compared to the sensitivity against all ABPM reference standards (0.72 vs 0.53), confidence intervals did overlap, as they did for specificity. Furthermore, we consider this analysis exploratory as there exists population heterogeneity in addition to reference standard heterogeneity in these studies, and this represents a subset of less than half of the studies included in our main analysis. Three studies reported results for the accuracy of OBPM versus both 24-h and daytime ABPM reference standards.^94,^ ^96,^ ^99^ Differences in accuracy of OBPM when compared with 24-hr and daytime ABPM reference standard showed no consistent pattern.

Four studies reported results for multiple OBPM thresholds.^93,^ ^97,^ ^102,^ ^103^ These studies consistently showed increased sensitivity and decreased specificity as thresholds are lowered. For example, in the study by Shimbo and colleagues,^103^ which reported OBPM thresholds of ≥140/90 mm Hg, ≥130/85 mm Hg, and ≥120/80 mm Hg, the respective sensitivities and specificities were: 0.33 and 0.97, 0.56 and 0.87, and 0.84 and 0.63. One study^100^ reported accuracy for an OPBM threshold of ≥130/80 mm Hg but also lowered the reference standard (daytime ABPM) to ≥130/80 mm Hg with a resulting sensitivity of 0.56 (95% CI, 0.50 to 0.61) and specificity of 0.89 (95% CI, 0.83 to 0.93).

No studies reported the area under the curve.

#### Positive Predictive Value/Negative Predictive Value (PPV/NPV)

For studies using SBP/DBP thresholds and in which measurement occurred at one visit, PPV ranged widely from 0.35 to 0.97. The lowest PPV of 0.35 is from a community-based study in Japan where 19.4 percent screened positive by OBPM and 13.9 percent were hypertensive based on 24-h ABPM.^96^ The highest PPV of 0.97 is from a subset of the CARDIA study (n=432),^100^ a U.S. community-based trial where 62.5 percent screened positive by OBPM and 88.9 percent were hypertensive based on Daytime ABPM. NPVs were less variable and ranged from 0.25 to 0.97 among studies using SBP/DBP thresholds and where measurement occurred at 1 visit. The NPV of 0.25 was from a community-based study in the U.S. where 62.5 percent screened positive on OBPM and 88.9 percent were hypertensive based on a 24-h ABPM threshold of ≥135/85 mm Hg. The NPV of 0.97 was from a large community-based study conducted in Italy where 34.6 percent screened positive on OBPM and 27.7 percent had hypertension based on a 24-h ABPM threshold of ≥130/80 mm Hg.^101^

#### False Positive Rates/False Negative Rates (FPR/FNR)

For studies using SBP/DBP thresholds and in which measurement occurred at a single visit, false positive rates had a wide range among studies. The lowest occurrence of false positives, 0 percent, occurred in a study of young participants (mean age 25.6 years) in which no one screened positive by OBPM ≥140/90 mm Hg and the protocol involved 2 measurements after a 20 minute rest period.^97^ The highest false positive rate, 30 percent, occurred in a cohort recruited from primary care in Belgium; the mean age was 70 years and the mean OBPM was 136.7/76.2 mm Hg.^91^ The protocol in this study averaged three readings after a rest period of at least 5 minutes.

False negative rates showed a similar wide range among included studies. The lowest false negative rate of 8 percent was reported in a large, Italian, community-based study in which the mean age was 49.0 years and the mean OBPM was 124.3/77.3 mm Hg.^101^ The protocol in this study used the mean of second and third measurements on both arms after 5 minutes rest. The highest false negative rate, 100 percent, occurred in the study with young participants described above where no one screened positive by OBPM ≥140/90 mm Hg.^97^

## KQ2a What Screening Protocol Characteristics Define the Best Test Accuracy?

### Summary of Results

Only four of the 20 included KQ2 studies compared the accuracy of different protocols in a single study.^82,^ ^97,^ ^102,^ ^103^ Three studies reported accuracy for protocol variations using different numbers of measures and visits and showed mixed results: two studies showed no difference in accuracy,^102,^ ^103^ while one study showed a higher sensitivity and lower specificity with single compared with multiple measurements.^82^ One unique study reported that adding a breath-holding maneuver to a blood pressure measurement protocol improves overall accuracy of screening in a young population, with substantially higher sensitivity and slightly lower specificity, but these results have not been replicated.^97^

### Detailed Results

Substantial clinical and methodological heterogeneity among the 20 included studies precluded analysis of protocol differences among studies as explanations for differences in accuracy. Four of the 20 included KQ2 studies reported within-study comparisons of protocol characteristics on accuracy^82,^ ^97,^ ^102,^ ^103^ (Table 7; Appendix E Table 4). Overall, results of the three studies that evaluated the effect of additional measurements from additional visits were mixed, showing either no difference in accuracy or higher sensitivity and lower specificity with single compared with multiple measurements.^82,^ ^102,^ ^103^

Three studies reported accuracy for protocol variations using different numbers of measures and visits. One study by Selenta et al reported nearly identical accuracy for a primary analysis using an average of five OBPMs from a single visit for the index test, to a sensitivity analysis using the average of two OBPMs from a single visit.^102^ A second study by Shimbo et al reported accuracy for an index test of a mean of three readings from a single visit and an index test of a mean of nine readings from three visits and found similar results with overlapping confidence intervals.^103^ For OBPM ≥140/90 mm Hg with a reference standard of daytime ABPM of ≥135/85 mm Hg, sensitivity for three readings and nine readings, respectively, were 0.33 (95% CI, 0.26 to 0.40) and 0.24 (95% CI, 0.18 to 0.31), and specificity was 0.97 (95% CI, 0.95 to 0.98) and 0.99 (95% CI, 0.98 to 0.99). A third study by Gill et al reported accuracy for three variations of an attended AOBP index test: the first reading on the first visit (1 measurement), the mean of second and third readings from three visits (6 measurements), and the mean of second and sixth readings from three visits (6 measurements).^82^ The first reading from the first visit showed the highest sensitivity and lowest specificity of all three protocols. The sensitivity of the single reading was 0.65 (95% CI, 0.54 to 0.75), while the sensitivity from the mean of the second and third BPs from three visits was 0.40 (95% CI, 0.29 to 0.51). The specificity from the single visit was 0.74 (95% CI, 0.66 to 0.82), while the specificity from the mean of the second and third BPs from 3 visits was 0.90 (95% CI, 0.84 to 0.95). The mean of second and sixth readings from 3 visits had sensitivity and specificities that overlapped with the other 2 protocols.

One study evaluated whether adding a breath-hold to a blood pressure measurement protocol could serve as a simple test for masked hypertension. This Russian study by Lyamina and colleagues^97^ (N=269) recruited young participants with a mean age of 25.6 years from local colleges and businesses and compared the mean of two BP measurements in a single visit measured with and without a breath-hold. The index test had a threshold of ≥140/90 mm Hg and the reference test used a combined day and nighttime ABPM threshold. Sensitivity and specificity with breath-holding were 1.00 (95% CI, 0.90 to 1.00) and 0.92 (95% CI, 0.88 to 0.95), respectively. Sensitivity and specificity without breath-holding were 0 (95% CI, 0 to 0.10) and 1.00 (95% CI, 0.98 to 1.00), respectively. Such results suggest that breath-holding may improve accuracy; however, such results would need to be replicated in a larger, more generalizable, and older target population with a higher prevalence of hypertension as no participant in this study screened positive by OBPM without breath-holding.

## KQ3 What Is the Accuracy of Confirmatory Blood Pressure Measurement in Adults Who Initially Screen Positive for Hypertension Compared With the Reference Standard (ABPM)?

### Summary of Results

We identified 18 fair- to good-quality studies (reported in 27 articles) (N=57,128) examining the test accuracy of confirmatory blood pressure measurements (office, home, self-OBPM, truncated ABPM) compared with an ambulatory blood pressure measurement (ABPM) reference standard in adults with a previous elevated OBPM.^73,^ ^74,^ ^122–146^ Twelve of these studies are new since the previous review.^73,^ ^74,^ ^122,^ ^124,^ ^130–133,^ ^135,^ ^136,^ ^139,^ ^142^

In contrast to KQ2 results, which showed that initial screening with OBPM is not sensitive but is specific in an unselected population, KQ3 showed that confirmatory modalities, when applied to a preselected population, are generally sensitive but not specific. All results showed considerable heterogeneity without apparent explanation based on any patient or test characteristics.

#### OBPM

Meta-analysis of eight OBPM confirmation studies (N=53,183) reporting SBP/DBP thresholds showed a pooled sensitivity of 0.80 (95% CI, 0.68 to 0.88) and a pooled specificity of 0.55 (95% CI, 0.42 to 0.66), with considerable heterogeneity (I^2^ sensitivity=99.2%; I^2^ specificity=98.6%). Among this set of studies, positive predictive values ranged from 0.59 to 0.88 and negative predictive values ranged from 0.30 to 0.82. False positive rates ranged from 15 to 65 percent. False negative rates ranged from 10 to 65 percent.

#### HBPM

Meta-analysis of four HBPM confirmation studies with threshold of ≥135/85 mm Hg (N=1,001) showed a pooled sensitivity of 0.84 (95% CI, 0.76 to 0.90), and pooled specificity of 0.60 (95% CI, 0.48 to 0.71), with considerable heterogeneity (I^2^ sensitivity=85.1%; I^2^ specificity=77.8%). Among this set of studies, positive predictive values ranged from 0.68 to 0.94 and negative predictive values ranged from 0.46 to 0.86. False positive rates ranged from 22 to 50 percent, and false negative rates ranged from 7 to 24 percent.

#### Self-OBPM

Two studies (N=698) examined self-OBPM as a confirmation method.^135,^ ^139^ Only one of these studies used SBP/DBP thresholds relevant to current clinical practice; it found high sensitivity and low specificity (0.92 [95% CI, 0.85 to 0.96]; 0.25 [95% CI, 0.16 to 0.35]).^135^ The PPV and NPV in this study were 0.59 and 0.72, respectively. The false positive rates in the two self-OBPM studies were 43 and 75 percent, and false negative rates were 8 and 14 percent.

#### Truncated ABPM

One study reported accuracy for a truncated ABPM (6-h ABPM) and results were reported separately based on ABPM indication.^124^ Sensitivity and specificity were 0.94 and 0.76, respectively, in a population (N=126) for whom the ABPM indication was borderline hypertension. The sensitivity and specificity were 0.89 and 0.70, respectively, for the population (N=137) with suspected white coat hypertension. Confidence intervals in this study were not calculable.

### Study and Population Characteristics

Included studies were conducted in a variety of countries among participants from several different population sources (Table 9; Appendix E Table 5). Two studies were conducted in the United States,^124,^ ^130^ three studies each were conducted in Italy,^126,^ ^142,^ ^143^ Greece,^132–134^ and Korea;^73,^ ^131,^ ^136^ two studies were conducted in Spain;^74,^ ^122^ and one study each was conducted in Argentina,^139^ Denmark,^128^ Israel,^145^ Switzerland,^127^ and the United Kingdom.^135^ Three studies recruited participants solely from primary care,^122,^ ^127,^ ^135^ and an additional five studies recruited at least partly from primary care.^74,^ ^126,^ ^130,^ ^132,^ ^139^ Eight studies recruited patients solely from a cardiology and/or blood pressure clinic.^73,^ ^128,^ ^133,^ ^134,^ ^136,^ ^142,^ ^143,^ ^145^ One study recruited participants from an ABPM referral service of a university-affiliated primary care center.^124^ Finally, two studies were ABPM registries: Kor-ABP^73^ and the Spanish ABPM Registry.^74^ While the Kor-ABP registry, conducted in Korea, was of modest size (N=1,262), the Spanish ABPM Registry analysis used for our review included 45,020 untreated individuals, which makes up much of the included evidence for this question.^74^

Table 9 Study and Baseline Population Characteristics of Included Studies for KQ 3, by Author

Author, Year; Study name; Quality | Country | Brief population description | Recruitment setting | N analyzed (Untx) | Mean OBPM, SBP/DBP (mm, Hg) | Mean ABPM, SBP/DBP (mm, Hg) | Age, mean (range) | % female | % white | % DM | Mean BMI, kg/m^2^
Bayo, 2006^122^; Fair | Spain | Patients aged 18 to 80 years with mild–moderate HTN, without previous antihypertensive tx | Primary care | 181 | 152.3/89.2 | 134.8/81.3^*^; 137.4/82.1^†^ | 58.4 (18-80) | 58.9 | NR | 9.5 | 28.2
de la Sierra, 2017^74^; Spanish ABPM Registry; Fair | Spain | Participants from an ongoing ABPM registry | BP Clinic, Primary care | 45020 | 145.9/88.2 | 132.3/81.6^*^; 128.7/78.4^†^ | 53.5 (NR) | 45.9 | >99 | 12.7 | 28.8
Ernst, 2011^124^; Fair | US | Pts referred for ABPM for evaluation of (1) borderline HTN (not currently treated but with a series of variable office BPs in both the normal and elevated range), (2) evaluation of BP control on therapy, (3) suspected WCH, or (4) treatment resistance | ABPM Referral Service | 263 | NR | 6-hr: NR | 52.7 (NR) | 50 | NR | NR | 29.5
Fogari, 1996^126^; Fair | Italy | Pts with newly diagnosed new-treated essential HTN (DBP>90 mm Hg) | Cardiology outpatient | 221 | 164.1/103.5 | 144.0/94.5^*^ | NR (31-60) | 0 | NR | 0 | NR
Gerc, 2000^127^; Fair | Switzerland | Pts with an elevated office BP referred to hypertension clinic for confirmation of hypertension diagnosis | Primary care | 1466 | 140.6/91.4 | 142.2/90.7^*^ | 46.9 (13-85) | 41.6 | NR | NR | NR
Hoegholm, 1992^128^; Fair | Denmark | Untreated pts with newly diagnosed essential HTN (with BP under observation for a median of 4 months prior to diagnosis) | Primary care | 153 | 156.8/99.8 | 145.2/95.9^*^ | 47^¶^ (17-76) | 54.1 | NR | NR | NR
Husain, 2017^130^; Fair | US | Participants with recent office BP measurements between SBP 120-149 and/or DBP 80-95, and not greater than 149/95. | BP Clinic | 404 | Visit 1: 129.6/81.0; Visit 2: 128.7/80.7 | NR | 47.9 (NR) | 56.8 | 77.7 | NR | 29.3
Kim, 2018^131^; Fair | Korea | All ambulatory pts who underwent OBP and ABP measurements during 2013 | Primary care | 565 | 138.3/84.1 | 124.3/79.1^†^ | 56.7 (NR) | 49.9 | NR | 11.5 | NR
Kotsis, 2008^132^; Fair | Greece | Pts referred to participating HTN clinics for possible hypertension from either primary health care providers, or from a hospital outpatient clinic for a routine BP check up between 2000-2006 | Self-selected | 1535 | 141.4/88.5 | 128.1/77.6^†^ | 51.1 (NR) | 50.5 | NR | 9.1 | 27.4
Manios, 2008^133^; Fair | Greece | Pts referred from primary physician to outpatient HTN unit for conventional clinical indications during specified time | NR | 2004 | 141/89 | 132/82^*^ | 50.9 (NR) | 53.4 | NR | 10.6 | 24.8
Nasothimiou, 2012^134^; Good | Greece | Pts referred for elevated BP and assessed with clinic BP, ABP and HBP | Cardiology outpatient | 361 | 143/94 | 140/90^*^; 138/88^‡^ | 49 (NR) | 41 | NR | 2.9 | 28
Nunan, 2015^135^; Fair | United Kingdom | Untreated adults aged 40-85 years with an SBP between 130-179 mm Hg who were willing to perform 24h ABPM | Primary care | 203 | Self-monitored OBPM: 145.0/14.4; HBPM: 141.1/87.0^§^ | 133.6/82.6^*^ | 56.4 (40-85) | 47.3 | 90.4 | 5.4 | 28.2
Park, 2017^136^; Fair | Korea | Untreated pts with high OBPM (≥140/90mm Hg) | BP Clinic | 256 | 141.0/91.6 | 132.8/88.5^†^; Combo: 134.6/87.8^ǁ^ | 51.8 (NR) | 53.5 | NR | NR | 25.4
Salazar, 2018^139^; Fair | Argentina | Consecutive pts referred from clinics, cardiologists and general practices in order to perform an ABPM for diagnostic or therapeutic purposes during a specified time period. | BP Clinic | 466 | 138/82 | 135/84^*^ | 51 (NR) | 61.0 | NR | 9.2 | 29.7
Shin, 2015^73^; Kor-ABP; Fair | Korea | Pts undergoing ABPM for the evaluation of high BP | Primary care | 1262 | 141.6/88.2 | 135.4/86.4^*^ | 52.1 (NR) | 48 | NR | NR | 24.5
Tocci, 2018^142^; Fair | Italy | Untreated pts, aged ≥18 years, referred to HTN outpatient clinic. | Cardiology outpatient | 2209 | 144.3/93.9 | 130.7/81.1^†^ | 52.5 (NR) | 47.5 | NR | 5.1 | 26.1
Ungar, 2004^143^; Good | Italy | Consecutive pts that were referred to HTN clinic during a designated time period. | Cardiology outpatient | 388 | 151/93 | 141/86^*^; 137/83^†^ | 60 (20-95) | 51.2% | NR | NR | 26
Zabludowski, 1992^145^; Fair | Israel | Patients with untreated borderline hypertension referred for ABPM | Primary care | 171 | 158.9/90.7 | 150.5/85.4^*^ | 48.0 (NR) | 66.7 | NR | NR | NR

* Daytime ABPM

† 24-hr ABPM

‡ Home monitoring on 6 working days within 2 weeks; measurements taking twice in the AM and in the PM; average of all readings

§ Mean of days 2-7 of self-monitored BP (2 measures taken in the AM and 2 in the PM)

ǁ Automated measurement; average of 42 measurements (6 per day; 3AM, 3PM) for 7 days

¶ Median

Abbreviations: ABPM = ambulatory blood pressure measurement; BMI = body mass index; BP = blood pressure; DBP = diastolic blood pressure; DM = diabetes mellites; HBPM = home blood pressure measurement; HTN = hypertension; kg/m^2^ = kilograms per meter squared; mm HG = millimeter of mercury; NR = not reported; OBPM = office-based blood pressure measurement; Pts = patients; SBP = systolic blood pressure; tx = treatment; Untx = untreated; US = United States; WCH = white coat hypertension

Eligible populations for KQ3 were preselected, with at least one elevated BP measurement identified by clinic-based screening. As such, included studies are samples of patients referred by primary care physicians to blood pressure clinics because of borderline or elevated blood pressures, consecutive patients referred to ABPM or hypertension clinics, or individuals who were newly diagnosed as hypertensive by OBPM and not yet treated.

Participants in the included studies exhibited a wide range of demographic and clinical characteristics (Table 9). The number of untreated participants analyzed ranged from 159^128^ to 45,020 participants in a registry.^74^ Participant ages ranged from 13 to 95 years, with mean age ranging from 46.9^127^ to 60 years. Percent female ranged from 0^126^ to 66.7 percent.^145^ Only three studies reported race/ethnicity, and of those, participants were largely white.^130,^ ^135,^ ^147^ One U.S. study conducted in the Southeast included 22.3 percent black participants.^130^

Mean blood pressures showed a substantial range across all measurement modalities with the exception of HBPM which showed a tighter clustering in the high-normal range (Table 9). For example, mean OBPM values ranged from 129.6/81.0 mm Hg^130^ to 164.1/103.5 mm Hg.^126^ Mean HBPMs for SBP ranged from 134.6 mm Hg^136^ to 141.1 mm Hg^135^ and 82.1 mm Hg^122^ to 88 mm Hg^134^ for DBP.

### Quality

Two of the included studies were rated as good quality, with low risk of bias for all domains.^134,^ ^143^ Both good-quality studies evaluated repeat OBPM as a confirmation method and studied consecutive patients referred to outpatient hypertension clinics for evaluation of elevated blood pressure. The protocols in these studies were well-described, reporting the fidelity of measurement and accounting for all participants in the analysis. Eleven of the 18 included studies had medium risk of bias for the domain of patient selection.^73,^ ^74,^ ^122,^ ^124,^ ^126,^ ^127,^ ^132,^ ^133,^ ^135,^ ^136,^ ^145^ Potential for bias for the patient selection domain was introduced because some were studies convenience samples from ABPM or hypertension clinics,^73,^ ^124,^ ^127,^ ^132,^ ^133,^ ^145^ involved self- or clinician referral,^135^ had exclusions threatening spectrum of disease representativeness,^122,^ ^126^ or reported limited detail on enrollment.^74,^ ^136^ One study had high risk of bias for patient selection because it specified a narrow range of eligible blood pressures, was not a consecutive or random sample, and lacked details on the process of patient selection; however, all other domains were rated as low risk of bias.^130^ One study had medium risk for the conduct or interpretation of index test domain because of multiple exploratory thresholds.^139^ Four studies had a medium risk of bias for the reference standard domain because of unusual adjustments to office and ambulatory devices, which may have influenced independence of measures in one study,^128^ and three studies did not report the required minimum or average number of ABPM measurements.^131,^ ^142,^ ^145^ It was extremely rare for studies to report any details about quality assurance for the index or reference standard device, such as calibration or maintenance.^122,^ ^133^ Four studies had a medium risk of bias for the patient flow domain due to lack of reporting of details about which recruited patients were not analyzed.^73,^ ^74,^ ^133,^ ^145^

### OBPM Confirmatory Studies: Index Text Characteristics

Thirteen studies examined OBPM measured by medical personnel as the index test against the ABPM reference standard.^73,^ ^74,^ ^126–128,^ ^130–134,^ ^142,^ ^143,^ ^145^ In most studies, the OBPM confirmations were performed in different locations with different personnel and possibly different protocols than the initial OBPM screening (that often occurred in primary care clinics) triggering the referral for this further confirmatory testing. Most OBPM confirmatory measurements were taken with patients seated for at least 5 minutes of rest and attended by personnel, were taken with a mercury sphygmomanometer, had a diagnostic threshold of ≥140/90 mm Hg, and were conducted at one visit; however, other protocol details varied widely (Table 10). The office-based blood pressure measurement devices in most studies (9 studies) used the auscultatory method with manual technique;^126–128,^ ^131–134,^ ^143,^ ^145^ all but one^145^ were mercury sphygmomanometers. One of the mercury sphygmomanometers was a Hawksley random zero device which is an older device that intends to eliminate digit preference by masking values during measurment.^128^ Four studies used the oscillatory method with automated technique.^73,^ ^74,^ ^130,^ ^142^

Table 10 OBPM Test Characteristics of Included Studies for KQ 3, by Author

Author, Year; Trial name; Quality | OBPM threshold(s), mm Hg | Index Device (A or M) | Total # of OBPM measurements | Method of determination | Interventionist attending | Resting time (min) | ABPM reference | Reference threshold, mm Hg
de la Sierra, 2017^74^; Spanish ABPM Registry; Fair | ≥140/90 | NR (validated oscillometric device) (A) | 2 | Mean of 2 | NR | 5 | 24-hr; Daytime; Combined | 24-hr: ≥130/80; Daytime: ≥135/85; Combined: Daytime ≥135/85 OR nighttime ≥120/70 OR 24-hr ≥130/80
Fogari, 1996^126^; Fair | DBP >90 | Standard mercury sphyg (M) | 14 | Average of measurements | Physician | 2 | Daytime | ≥134/90
Gerc, 2000^127^; Fair | >160/95 | Mercury sphyg (M) | 3 | Average of measurement | Nurse | NR | Daytime | >140/90
Gerc, 2000^127^; Fair | >135/85 | Mercury sphyg (M) | 3 | Average of measurement | Nurse | NR | Daytime | >140/90
Gerc, 2000^127^; Fair | >140/90 | Mercury sphyg (M) | 3 | Average of measurement | Nurse | NR | Daytime | >140/90
Gerc, 2000^127^; Fair | >160/100 | Mercury sphyg (M) | 3 | Average of measurement | Nurse | NR | Daytime | >140/90
Hoegholm, 1992^128^; Fair | DBP >90 | Hawksley random zero sphyg (M) | 5 | Average of measurements | Physician (male) | ≥15 | Daytime | DBP >90
Husain, 2017^130^; Fair | ≥140/90 (Visit 1) | Welch Allyn Vital Signs (A) | 3 | Average of the second and third measurement | NR | 5 | 24-hr | ≥135/85
Husain, 2017^130^; Fair | ≥140/90 (Visit 2) | Welch Allyn Vital Signs (A) | 3 | Average of the second and third measurement | NR | 5 | 24-hr | ≥135/85
Kim, 2018^131^; Fair | SBP ≥140 | Mercury sphyg (Baumanometer Desk model, W.A. Baum Co. Inc., Copiague, NY, USA) (M) | 1 | NA | NR | 5 | 24-hr | SBP ≥130
Kotsis, 2008^132^; Fair | ≥140/90 | Mercury sphyg (M) | 6 | Average of the six BP measurements (from 2 visits) | Physician | 10 | 24-hr | ≥135/85
Manios, 2008^133^; Fair | ≥140/90 | Mercury sphyg (M) | 6 | Average of 3 BP values; unclear which 3 measures are being used. Assuming that measures from dominant arm are dropped. | Physician | NR | Daytime | ≥135/85
Nasothimiou, 2012^134^; Good | ≥140/90 | Standard mercury sphyg (M) | 9 | Average of the second and third clinic BP reading of the three study visits | Physician | 5 | Daytime | ≥135/85
Shin, 2015^73^; Kor-ABP; Fair | ≥140/90 | A&D UA-767 (A&D Co., Ltd., Tokyo, Japan) (A) | 2 | Average of measurements | NR | 5 | Daytime | ≥135/85
Tocci, 2018^142^; Fair | ≥ 140/90 | Omron 705 IT (Omron Healthcare Europe BV, Hoofddorp, The Netherlands) (A) | 3 | Average of 3 consecutive BP measurements | ESH HTN specialist | 10 | 24-hr | ≥130/80
Ungar, 2004^143^; Good | ≥140/90 | Mercury sphyg (M) | 8-12 | All measurements averaged | Physician | ≥10 | Daytime | ≥135/85
Zabludowski, 1992^145^; Fair | DBP >90 | Accutracker I (Suntech Medical Instruments) (A) | 3 | Average of measurements | Physician or nurse | 5 | Daytime | DBP >90

Abbreviations: A = automated; ABPM = ambulatory blood pressure measurement; BP = blood pressure; DBP = diastolic blood pressure; HTN = hypertension; hr = hour; M = manual; mm HG = millimeter of mercury; NA = not applicable; NR = not reported; OBPM = office-based blood pressure measurement; PCP = primary care provider; SBP = systolic blood pressure; sphyg = sphygmomanometer; USA = United States of America

The number of office measurements used to calculate blood pressure ranged from 1^131^ to 12,^143^ with most studies (9 of 13) conducting OBPM at one visit. The remaining studies measured office BP at different visits separated by 1 day,^132,^ ^143^ 6 weeks,^134^ or 8 weeks.^126^ The time between measurements on single occasions was only reported in four studies and in all cases was 1 minute.^73,^ ^126,^ ^134,^ ^142^

Protocol details relating to the arm and arm position, cuff, and timing of measurement were sparsely reported. Three studies reported the arm used for the measurement as the nondominant arm.^130,^ ^132,^ ^133^ Three studies reported arm positioning as supported at heart level, and no studies mentioned whether the cuff was applied under or over clothing.^132,^ ^133,^ ^143^ Cuff-size was rarely described with any detail.^126,^ ^130,^ ^132–134,^ ^143^ Only two studies mentioned the time of day when these office measurements were taken: between 0800 and 1000 in one study^142^ and morning in the other.^126^

Body position and resting time were commonly reported and generally consistent among studies. All studies reported that measurements were taken in the seated position except two studies in which body position was not reported.^73,^ ^130^ Leg position was not reported in any study. All but two studies^127,^ ^133^ reported resting time before the initial measurement; this rest time was most commonly 5 minutes.^73,^ ^74,^ ^130,^ ^131,^ ^134,^ ^145^ Less commonly reported rest times were 10 or ≥10 minutes^132,^ ^142,^ ^143^ and as long as ≥15 minutes in one study.^128^ Only three studies reported avoidance of distraction.^130,^ ^142,^ ^145^

Nine studies specified the personnel taking the measurement. These were nurses,^127^ nurses or physicians,^145^ physicians,^126,^ ^128,^ ^132–134,^ ^143^ or hypertension specialists.^142^ Another study reported that the measurement was attended but did not identify the type of personnel.^131^ In three studies, neither the interventionist nor attendance of the measurement was reported.^73,^ ^74,^ ^130^

Studies most commonly used an office BP of ≥ or >140/90 mm Hg as the diagnostic threshold for the index test.^73,^ ^74,^ ^127,^ ^130,^ ^132–134,^ ^142,^ ^143^ One study reported accuracy data for other thresholds in addition to >140/90 mm Hg. These included: >135/85 mm Hg, >160/95 mm Hg, and >160/100 mm Hg.^127^ An additional four studies used SBP-only or DBP-only thresholds.^126,^ ^128,^ ^131,^ ^145^

### OBPM Confirmatory Studies: Reference Test Characteristics

While all but two of the 13 OBPM confirmation studies^73,^ ^127^ reported that 24-h ABPM was conducted, most studies (k=9) used daytime ABPM as their reference standard (Table 10).^73,^ ^74,^ ^126–128,^ ^133,^ ^134,^ ^143,^ ^145^ Five studies used 24-h ABPM as the reference standard,^74,^ ^130–132,^ ^142^ and one study reported multiple reference standards, including daytime, 24-h, and a combination threshold requiring one period (24-h, daytime, or nighttime) to be abnormal in order for a hypertension diagnosis to be made.^74^

While ABPM cutoffs varied, the diagnostic threshold most commonly used for daytime ABPM was ≥135/85 mm Hg,^73,^ ^133,^ ^134,^ ^143^ which is consistent with guidelines.^31,^ ^34,^ ^68,^ ^79^ One study each used thresholds of ≥134/90 mm Hg^126^ and >140/90 mm Hg.^127^ Two studies used the diastolic-only threshold of >90 mm Hg.^128,^ ^145^ The studies using a 24-hr ABPM reference standard reported thresholds ranging from ≥125/80 mm Hg^132^ to ≥135/85 mm Hg,^130^ with one study using a SBP-only threshold.^131^ The very large Spanish ABPM registry reported accuracy using multiple reference standards including daytime ABPM alone, 24-hr ABPM alone, and a combination definition involving blood pressure elevation for 24-hr, daytime, or nighttime periods.^74^

Most studies used a fixed time period to define the daytime ABPM period.^73,^ ^126,^ ^128,^ ^132,^ ^133,^ ^142,^ ^143,^ ^145^ Most studies (9 of 13) required a minimum number of ABPM measurements.^73,^ ^74,^ ^127,^ ^128,^ ^130,^ ^132–134,^ ^143^ The minimum required number of measures were variable but were usually at least 10 measures or greater than 75 percent of planned measures. The range of reported maximum measurements for 24-hr ABPM reference was 40-96 measurements^74,^ ^130,^ ^132,^ ^142^ and for daytime ABPM was 36-72 measurements.^73,^ ^126–128,^ ^133,^ ^143,^ ^145^ Most commonly, ABPM values were determined by calculating simple means.

Other protocol details about the arm measured, cuff size, and instructions provided to participants were sparsely reported.

### OBPM Confirmatory Studies: Detailed Results

#### Prevalence and Screen Positivity

The prevalence of hypertension in the 13 OBPM confirmation studies ranged from 47 percent^145^ to 77 percent^134^ using a variety of ABPM definitions for hypertension. The lowest prevalence was reported in a study using a DBP-only diagnostic threshold of >90 mm Hg for the daytime ABPM reference standard.^145^ The highest prevalence was reported in a population with a similar mean age and recruitment from primary care as the study with the lowest prevalence, but daytime ABPM reference threshold was ≥135/85 mm Hg^134^ (Table 11).

Table 11 OBPM Test Accuracy Results of Included Studies for KQ 3, by Author

Author, Year | N analyzed | ABPM method | ABPM threshold, mm Hg | Index threshold, mm Hg | Positive index test | Prev HTN | Se (95% CI)^*^ | Sp (95% CI)^*^ | FPR (95% CIs)^*^ | FNR (95%CIs)^*^ | In MA
de la Sierra, 2017^74^ | 45020 | 24-hr | ≥130/80 | ≥140/90 | 75.2 | 57.2 | 0.85 (0.85, 0.86) | 0.38 (0.38, 0.39) | 0.62 (0.61, 0.62) | 0.15 (0.14, 0.15) | X
de la Sierra, 2017^74^ | 45020 | Daytime | ≥135/85 | ≥140/90 | 75.2 | 51.0 | 0.87 (0.86, 0.87) | 0.37 (0.36 0.37) | 0.63 (0.63, 0.64) | 0.13 (0.13, 0.14) | -
de la Sierra, 2017^74^ | 45020 | 24, Daytime, Nighttime | Daytime ≥135/85 OR nighttime ≥120/70 OR 24-h ≥130/80 | ≥140/90 | 75.2 | 67.3 | 0.83 (0.82, 0.83) | 0.40 (0.39, 0.41) | 0.60 (0.59, 0.61) | 0.17 (0.17, 0.18) | -
Fogari, 1996^126^ | 221 | Daytime | ≥134/90 | DBP >90 | 82.4 | 76.0 | 0.95 (0.90, 0.97) | 0.57 (0.43, 0.69) | 0.43 (0.31, 0.57) | 0.05 (0.03, 0.10) | -
Gerc, 2000^127^ | 1466 | Daytime | > 140/90 | >140/90 | NR^†^ | NR | 0.80 (NR) | 0.68 (NR) | NR^†^ | NR^†^ | -
Gerc, 2000^127^ | 1466 | Daytime | > 140/90 | >135/85 | NR | NR | 0.87 (NR) | 0.59 (NR) | NR^†^ | NR^†^ | -
Gerc, 2000^127^ | 1466 | Daytime | > 140/90 | >160/95 | NR | NR | 0.74 (NR) | 0.79 (NR) | NR^†^ | NR^†^ | -
Gerc, 2000^127^ | 1466 | Daytime | > 140/90 | >160/100 | NR | NR | 0.67 (NR) | 0.84 (NR) | NR^†^ | NR^†^ | -
Hoegholm, 1992^128^ | 153 | Daytime | DBP >90 | DBP >90 | 81.7 | 64.7 | 0.95 (0.89, 0.98) | 0.43 (0.30, 0.56) | 0.57 (0.44, 0.70) | 0.05 (0.02, 0.11) | -
Husain, 2017^130^ | 404 | 24-hr V1^‡^ | ≥135/85 | ≥140/90 | 30.0 | 75.0 | 0.35 (0.30, 0.41) | 0.85 (0.77, 0.91) | 0.15 (0.09, 0.23) | 0.65 (0.59, 0.70) | X
Husain, 2017^130^ | 404 | 24-hr V2^‡^ | ≥135/85 | ≥140/90 | 29.2 | 71.5 | 0.35 (0.30, 0.41) | 0.86 (0.79, 0.91) | 0.14 (0.09, 0.21) | 0.65 (0.59, 0.70) | -
Kim, 2018^131^ | 565 | 24-hr | SBP≥ 130 | SBP ≥140 | 45.8 | 49.0 | 0.52 (0.46, 0.58) | 0.60 (0.55,0.66) | 0.40 (0.34, 0.45) | 0.48 (0.42, 0.54) | -
Kotsis, 2008^132^ | 1535 | 24-hr | ≥ 125/80 | ≥140/90 | 51.1 | 47.8 | 0.70 (0.66, 0.73) | 0.66 (0.62, 0.69) | 0.34 (0.31, 0.38) | 0.30 (0.27, 0.34) | X
Manios, 2008^133^ | 2004 | Daytime | ≥135/85 | ≥140/90 | 71.5 | 48.6 | 0.89 (0.87, 0.91) | 0.45 (0.42, 0.48) | 0.55 (0.52, 0.58) | 0.11 (0.09, 0.13) | X
Nasothimiou, 2012^134^ | 361 | Daytime | ≥135/85 | ≥140/90 | 78.1 | 77.0 | 0.85 (0.80, 0.88) | 0.43 (0.33, 0.54) | 0.57 (0.46, 0.67) | 0.15 (0.12, 0.20) | X
Shin, 2015^73^; Kor-ABP | 1262 | Daytime | ≥135/85 | 140/90 | 58.8 | 61.5 | 0.71 (0.68, 0.74) | 0.61 (0.57, 0.66) | 0.39 (0.34, 0.43) | 0.29 (0.26, 0.32) | X
Tocci, 2018^142^ | 2209 | 24-hr | ≥ 130/80 | ≥ 140/90 | 76.2 | 67.0 | 0.90 (0.88, 0.91) | 0.52 (0.48, 0.55) | 0.48 (0.45, 0.52) | 0.10 (0.09, 0.12) | X
Ungar, 2004^143^ | 388 | Daytime | ≥135/85 | ≥140/90 | 82.5 | 74.0 | 0.89 (0.84, 0.92) | 0.35 (0.26, 0.44) | 0.65 (0.56, 0.74) | 0.11 (0.08, 0.16) | X
Zabludowski, 1992^145^ | 171 | Daytime DBP | DBP >90 | DBP >90 | 66.7 | 47.4 | 0.81 (0.72, 0.88) | 0.47 (0.37, 0.57) | 0.53 (0.43, 0.63) | 0.19 (0.12, 0.28) | -

* Calculated

† 2x2 data unavailable, unable to calculated CIs or FPR and FNR

‡ ABPM taken at the conclusion of the initial visit (V1) and one week later (V2)

Abbreviations: ABPM = ambulatory blood pressure measurement; CI = confidence interval; DBP = diastolic blood pressure; FNR = false negative rate; FPR = false positive rate; hr = hour; HTN = hypertension; MA = meta-analysis; mm HG = millimeter of mercury; NR = not reported; OBPM = office-based BP measurement; Prev = prevalence; Se = sensitivity; sp = specificity

The percent of individuals with a positive confirmatory OBPM ranged from 29 percent^130^ to 82 percent.^126,^ ^128,^ ^143^ The lowest rate of positive screens was in a population with a mean age of 47.9 years who were volunteers or recruited from primary care.^130^ This study used an OBPM threshold of ≥140/90 mm Hg. The highest rate of positive screens was 82 percent; this prevalence was reported in three studies. The populations in these studies were also referred from primary care and represented a wide range of ages.^126,^ ^128,^ ^143^ Two of these studies had DBP-only diagnostic thresholds of >90 mm Hg^126,^ ^128^ and the third used a ≥140/90 mm Hg threshold.

#### Sensitivity/Specificity

Meta-analysis of eight OBPM confirmation studies (N=53,183) reporting SBP/DBP thresholds showed a pooled sensitivity of 0.80 (95% CI, 0.68 to 0.88) and a pooled specificity of 0.55 (95% CI, 0.42 to 0.66) with considerable heterogeneity (I^2^ sensitivity=99.2%; I^2^ specificity=98.6%) (Figure 3; Table 11). Most commonly, these studies averaged two or three blood pressure measurements during a single visit.^73,^ ^74,^ ^130,^ ^133,^ ^142^ Other studies averaged six to 12 measures taken over two to three visits.^132,^ ^134,^ ^143^ Sensitivity and specificity varied widely among pooled studies; sensitivity ranged from 0.35^130^ to 0.90^142^ and specificity ranged from 0.35^143^ to 0.85.^130^ The Spanish ABPM registry, with a sample size of 45,020, makes up most of the body of evidence for OBPM confirmation, which had a total sample size of 57,128.^74^ When this study is removed from the pooled result in a sensitivity analysis, results are similar (sensitivity: 0.79 [95% CI, 0.65 to 0.89], specificity: 0.57 [95% CI, 0.45 to 0.69]). No patient or index test characteristics explaining heterogeneity were revealed upon visual inspection of the forest plots.

Figure 3 KQ3: Test Accuracy of Confirmatory Office Blood Pressure Monitoring at a Threshold of ≥140/90 mm Hg to Identify Hypertension Detected by Ambulatory Blood Pressure Monitoring, by Author

Note: Sensitivity I^2^=99.2; Specificity I^2^=98.6

Figure 3 is a forest plot that shows the test accuracy of confirmatory office blood pressure monitoring at a threshold of ≥140/90 mm Hg to identify hypertension detected by ambulatory blood pressure monitoring, by author. The overall pooled sensitivity is 0.80 (95% CI, 0.68, 0.88) and the pooled specificity is 0.55 (95% CI, 0.42, 0.66)

We conducted an exploratory analysis of studies using only the preferred 24-h ABPM reference standard. Meta-analysis of 4 studies with a 24-hr ABPM reference standard (N=49,168) showed a pooled sensitivity of 0.74 (95% CI, 0.50 to 0.89) and specificity of 0.62 (95% CI, 0.42 to 0.79), again with considerable statistical heterogeneity (I^2^ sensitivity=99.6%; I^2^ specificity=99.4%) (Appendix F Figure 2). The point estimate for sensitivity showed a small decrement compared to the main analysis, and specificity showed a small improvement, however, confidence intervals overlapped. Furthermore, we consider this analysis exploratory as there exists population heterogeneity in addition to reference standard heterogeneity in these studies and these studies represent a subset of only half of studies from the main analysis. The Spanish ABPM registry was the only study that reported accuracy results for OBPM against multiple ABPM reference standards, including 24-hr ABPM, daytime ABPM, and a combination of daytime, nighttime, and 24-hr ABPM showing similar accuracy results. One study reported accuracy for multiple OBPM thresholds against the same daytime ABPM reference standard.^127^ This study showed increased sensitivity and decreased specificity as thresholds are lowered. No included study reported accuracy for an OBPM threshold of ≥130/80 mm Hg.

Five studies did not contribute to the meta-analysis; these studies similarly reported large variations in accuracy (Table 11).^126–128,^ ^131,^ ^145^ Four of these studies had SBP-only or DBP-only index and/or reference test thresholds that are not relevant to current clinical practice.^126,^ ^128,^ ^131,^ ^145^ One study did not provide sufficient data for pooling.^127^ The sensitivity point estimate in this study of 0.80 was identical to our pooled result, and the specificity point estimate of 0.68 was slightly higher than the upper confidence limit in our pooled analysis.

No studies of OBPM confirmation reported area under the curve.

#### PPV/NPV

Among the eight studies using SBP/DBP thresholds from the pooled analysis, the PPVs ranged from 0.61^133^ to 0.88.^130^ The lowest PPV was in a Greek study of patients referred to a hypertension clinic from primary care who had a 49 percent prevalence by daytime ABPM and 72 percent OBPM positivity.^133^ The highest PPV, along with the lowest sensitivity and lowest index test positivity, was in the Husain et al study which recruited participants with recent office BPs between 120-149/80-95 mm Hg from primary care and who had a 75 percent prevalence by 24-hr ABPM and a 30 percent OBPM positivity.^130^ The NPVs were more variable than the PPVs and ranged from 0.30^130^ to 0.82.^133^ The lowest NPV was in the study with the highest PPV^130^ and the highest NPV was in the study with the lowest PPV.^133^ The ranges of PPVs and NPVs in the five studies not included in the pooled analysis^126–128,^ ^131,^ ^145^ were similar to the ranges of those in the pooled analysis.

#### FPR/FNR

Among the eight studies using SBP/DBP thresholds from the pooled analysis, false positive rates had a wide range among studies. Point estimates from the studies ranged from 15 percent^130^ to 65 percent.^74^ The lowest occurrence of false positives, 15 percent, occurred in the study with the highest PPV (and lowest NPV); participants were self-selected or recruited from primary care, with a young mean age (47.9 years) and the lowest index test positivity (30%).^130^ The highest occurrence of false positives, 65 percent, was seen in an Italian study of individuals referred to an outpatient hypertension clinic and 82.5 percent, screened positive on OBPM.^143^ False negative rates were likewise variable, with estimates ranging from 10 percent^142^ to as high as 65 percent.^130^ The occurrence of false negatives was as low as 10 percent in an Italian study where 24 percent screened negative on OBPM^142^ to as high as 65 percent in a study where 70 percent screened negative on OBPM.^130^ The range of false positivity in the non-pooled studies was generally similar to that seen in the pooled studies.

### Home-Based Blood Pressure: Index Test Characteristics

Four studies examined the accuracy of HBPM against the ABPM reference standard (Table 12).^122,^ ^134–136^ These studies represent a reasonably homogeneous index test wherein studies used the same diagnostic threshold, similar automated, oscillometric HBPM devices, and comparable basic protocol characteristics. In these studies, participants were instructed to measure blood pressure for 3 to 7 days in the morning and evening in the seated position after a rest period of usually 5 minutes.

Table 12 HBPM Test Characteristics of Included Studies for KQ 3, by Author

Author, Year; Trial name; Quality | HBPM threshold(s), mm Hg | HBPM Device (A or M) | Measurement time | Number of screens | Total # of measurements | Method of determination | Pt training | Body position | ABPM modality reference | Reference threshold, mm Hg
Bayo, 2006^122^; Fair | ≥130/80 | Omron HEM-705CP (Tokyo, Japan) (A) | Morning (0600 to 1000) and evening (2000 to 0000) | 6 (3 days × 2 per day) | 18 (max) | Readings of first day excluded; first and second readings of each morning–night period of second and third days used | Instructed by his physician or nurse on the working of the units and the BP measuring technique and provided with written information. | NR | Daytime | ≥135/85
Bayo, 2006^122^; Fair | ≥135/85 | Omron HEM-705CP (Tokyo, Japan) | Morning (0600 to 1000) and evening (2000 to 0000) | 6 (3 days × 2 per day) | 18 (max) | Readings of first day excluded; first and second readings of each morning–night period of second and third days used | Instructed by his physician or nurse on the working of the units and the BP measuring technique and provided with written information. | NR | Daytime | ≥135/85
Nasothimiou, 2012^134^; Good | ≥135/85 | Omrom HEM-705CP, IC, or 705IT (Omron Healthcare, The Netherlands) | Morning (0600-1000h) and evening (1800-2200h) | 12 (6 days × 2 per day) | 24 | Average of all measurements | Trained in the conditions of HBP measurement and the use of the devices | Seated | Daytime | ≥135/85
Nunan, 2015^135^; Fair | ≥135/85 | Stabliograph bluetooth-enabled automated sphyg (Stabilograph; I.E.M, Stolberg, Germany) | Morning (preferably upon waking) and evening (before going to bed) | 10 (5 days × 2 per day) | 20 | Average of days 2-5 | NR | Seated | Daytime | ≥135/85
Nunan, 2015^135^; Fair | ≥135/85 | Stabliograph bluetooth-enabled automated sphyg (Stabilograph; I.E.M, Stolberg, Germany) | Morning (preferably upon waking) and evening (before going to bed) | 10 (5 days × 2 per day) | 20 | Average of days 1-5 | NR | Seated | Daytime | ≥135/85
Nunan, 2015^135^; Fair | ≥135/85 | Stabliograph bluetooth-enabled automated sphyg (Stabilograph; I.E.M, Stolberg, Germany) | Morning (preferably upon waking) and evening (before going to bed) | 14 (7 days × 2 per day) | 28 | Readings from a minimum of 4 (preferably 7) consecutive days with readings from the first day dropped | NR | Seated | Daytime | ≥135/85
Nunan, 2015^135^; Fair | ≥135/85 | Stabliograph bluetooth-enabled automated sphyg (Stabilograph; I.E.M, Stolberg, Germany) | Morning (preferably upon waking) and evening (before going to bed) | 14 (7 days × 2 per day) | 28 | Readings from a minimum of 4 (preferably 7) consecutive days with readings from the first day dropped | NR | Seated | Daytime | ≥135/85
Park, 2017^136^; Fair | ≥130/85 | WatchBP Home (Microlife, Taiwan) | Morning (betwen 0700/waking and 0900) and evening (2100-2300/bedtime) | 14 (7 days × 2 per day) | 42 (max); 40.1 (2.7) (mean) | Avg of valid measurements; First evening and morning BP measurements were discarded, first and second reading of the morning and evening were averaged | Received instructions from study nurse on first visit day | Seated | 24-hr | ≥130/80
Park, 2017^136^; Fair | ≥130/80 | WatchBP Home (Microlife, Taiwan) | Morning (betwen 0700/waking and 0900) and evening (2100-2300/bedtime) | 14 (7 days × 2 per day) | 42 (max); 40.1 (2.7) (mean) | Avg of valid measurements; First evening and morning BP measurements were discarded, first and second reading of the morning and evening were averaged | Received instructions from study nurse on first visit day | Seated | 24-hr | ≥130/80
Park, 2017^136^; Fair | ≥135/85 | WatchBP Home (Microlife, Taiwan) | Morning (betwen 0700/waking and 0900) and evening (2100-2300/bedtime) | 14 (7 days × 2 per day) | 42 (max); 40.1 (2.7) (mean) | Avg of valid measurements; First evening and morning BP measurements were discarded, first and second reading of the morning and evening were averaged | Received instructions from study nurse on first visit day | Seated | 24-hr | ≥130/80

Abbreviations: A = automated; ABPM = ambulatory blood pressure measurement; BP = blood pressure; DBP = diastolic blood pressure; HBPM = home blood pressure measurement; HTN = hypertension; hr = hour; M = manual; mm HG = millimeter of mercury; NA = not applicable; NR = not reported; OBPM = office-based blood pressure measurement; PCP = primary care provider; SBP = systolic blood pressure; sphyg = sphygmomanometer; USA = United States of America

All HBPM devices applied an automated oscillometric technique. Three studies explicitly reported that devices had printing capabilities for recording blood pressures or that data could be electronically transmitted to researchers.^122,^ ^134,^ ^135^ The method of recording BP was unclear in the other study.^136^ Only one study reported calibration, which was done annually.^122^ Another study reported that the accuracy of the HBPM device was tested in each individual against a standard mercury sphygmomanometer.^134^

The monitoring period ranged from 3 days^122^ to 7 days.^135,^ ^136^ All studies instructed participants to measure BP in two sittings per day, occurring in the morning and evening, taking two to three measurements at each sitting with 1 to 2 minutes between measurements. Three of the four studies explicitly reported training participants how to perform the blood pressure measurement.^122,^ ^134,^ ^136^ The total maximum number of measurements ranged from 18^122^ to 42,^136^ and the number of measurements used to calculate the mean HBPM ranged from 8^122^ to 28.^135,^ ^136^ Two studies excluded initial measurements as follows: one study excluded first-day readings and the first and second readings of each morning^122^ and one study discarded the first morning and evening BPs.^136^ Three studies required a minimum number of readings, which ranged from eight^134^ to 30.^136^

Three of four studies reported that measurements were taken seated and after a 5-minute rest;^134–136^ however, only one study mentioned the provision of a quiet place for measurement.^136^ Protocol details relating to the arm, arm position, and cuff were sparsely reported. No study mentioned arm position, leg position, or whether the cuff was placed under or over clothing. Only one study reported that the nondominant arm was used.^135^ Half of the studies mentioned that different-sized cuffs could be used based on patient size.^122,^ ^134^

All four studies used an HBPM diagnostic threshold of ≥135/85 mm Hg,^122,^ ^134–136^ and two of these studies additionally reported test accuracy of other thresholds, including ≥130/85 mm Hg and ≥130/80 mm Hg.^122,^ ^136^

### Home-Based Blood Pressure: Reference Test Characteristics

While all four HBPM confirmation studies performed 24-h ABPM, daytime ABPM was used as the reference standard and the daytime ABPM threshold was ≥135/85 mm Hg (Table 12).^122,^ ^134–136^ One study additionally reported test accuracy of HBPM using 24-hr and nighttime ABPM as reference standards.^136^ Three studies used a fixed time period to define the daytime ABPM period,^122,^ ^135,^ ^136^ and one study used participant diaries to determine awake hours.^134^ Blood pressures were measured every 20 to 30 minutes. All studies required a minimum number of measurements: at least 14 measures or greater than 70 percent of planned readings. The maximum number of daytime measurements ranged from 20^136^ to 48 measurements.^122^ Where reported, daytime blood pressures were calculated as the mean of valid measurements. Other protocol details about the arm measured, cuff size, and instructions provided to participants were sparsely reported.

### Home-Based Blood Pressure: Detailed Results

#### Prevalence and Screen Positivity

The prevalence of hypertension as defined by daytime ABPM of ≥135/85 mm Hg or 24-hr ABPM ≥130/80 mm Hg in the four HBPM confirmation studies ranged from 54 percent^135^ to 80 percent.^136^ The study with the lowest prevalence of 54 percent was set in U.K. primary care clinics.^135^ The study with the highest hypertension prevalence of 80 percent was a Korean study set in an outpatient cardiology clinic^136^ (Table 13).

Table 13 HBPM Test Accuracy Results of Included Studies for KQ 3, by Author

Author, Year | N analyzed | ABPM method | ABPM threshold, mm Hg | Index threshold, mm Hg | Positive index test^*^ | Prev HTN^*^ | Se (95% CI)^*^ | Sp (95% CI)^*^ | FPR (95% CIs)^*^ | FNR (95%CIs)^*^ | In MA
Bayo, 2006^122^ | 181 | Daytime | ≥135/85 | ≥130/80 | 79.0 | 59.1 | 0.88 (0.80, 0.93) | 0.34 (0.24, 0.45) | 0.66 (0.55, 0.76) | 0.12 (0.07, 0.20) | -
Bayo, 2006^122^ | 181 | Daytime | ≥135/85 | ≥135/85 | 65.2 | 59.1 | 0.76 (0.66, 0.83) | 0.50 (0.38, 0.62) | 0.50 (0.39, 0.61) | 0.24 (0.17, 0.33) | X
Nasothimiou, 2012^134^ | 361 | Daytime | ≥135/85 | ≥135/85 | 76.2 | 77.0 | 0.87 (0.83, 0.91) | 0.61 (0.51, 0.71) | 0.39 (0.29, 0.49) | 0.13 (0.09, 0.17) | X
Nunan, 2015^135^ | 203 | Daytime (Days 1-7) | ≥135/85 | ≥135/85 | 73.0 | 53.7 | 0.93 (0.86, 0.97) | 0.50 (0.40, 0.61) | 0.50 (0.40, 0.60) | 0.07 (0.04, 0.14) | X
Nunan, 2015^135^ | 203 | Daytime (Days 1-5) | ≥135/85 | ≥135/85 | NR | 53.7 | 0.93 (0.86, 0.97) | 0.53 (0.43, 0.64) | NR^†^ | NR^†^ | -
Nunan, 2015^135^ | 203 | Daytime (Days 2-7) | ≥135/85 | 135/85 | 72.9 | 53.7 | 0.94 (0.87, 0.97) | 0.51 (0.41, 0.62) | NR^†^ | NR^†^ | -
Nunan, 2015^135^ | 203 | Daytime (Days 2-5) | ≥135/85 | ≥135/85 | NR | 53.7 | 0.94 (0.87, 0.97) | 0.53 (0.43, 0.64) | NR^†^ | NR^†^ | -
Park, 2017^136^ | 256 | Daytime | ≥135/85 | ≥130/80 | 79.7 | 73.4 | 0.92 (0.87, 0.95) | 0.53 (0.40, 0.65) | 0.47 (0.36, 0.59) | 0.09 (0.05, 0.13) | -
Park, 2017^136^ | 256 | 24-hr | ≥130/80 | ≥130/80 | 79.7 | 80.1 | 0.90 (0.85. 0.94) | 0.63 (0.48, 0.76) | 0.37 (0.25, 0.51) | 0.10 (0.03, 0.15) | -
Park, 2017^136^ | 256 | Nighttime | ≥120/70 | ≥130/80 | 79.7 | 87.1 | 0.85 (0.90, 0.90) | 0.58 (0.39, 0.75) | 0.42 (0.27, 0.59) | 0.15 (0.11, 0.20) | -
Park, 2017^136^ | 256 | Daytime | ≥135/85 | ≥130/85 | 70.7 | 73.4 | 0.82 (0.76, 0.88) | 0.62 (0.49, 0.73) | 0.38 (0.28, 0.50) | 0.18 (0.13, 0.24) | -
Park, 2017^136^ | 256 | 24-hr | ≥130/80 | ≥130/85 | 70.7 | 80.1 | 0.81 (0.75, 0.86) | 0.71 (0.56, 0.83) | 0.29 (0.19, 0.43) | 0.19 (0.14, 0.25) | -
Park, 2017^136^ | 256 | Nighttime | ≥120/70 | ≥130/85 | 70.7 | 87.1 | 0.77 (0.71, 0.82) | 0.70 (0.51, 0.84) | 0.30 (0.17, 0.47) | 0.23 (0.18, 0.29) | -
Park, 2017^136^ | 256 | Daytime | ≥135/85 | ≥135/85 | 66.0 | 73.4 | 0.79 (0.72, 0.84) | 0.69 (0.57, 0.80) | 0.31 (0.21, 0.43) | 0.21 (0.16, 0.28) | -
Park, 2017^136^ | 256 | 24-hr | ≥130/80 | ≥135/85 | 66.0 | 80.1 | 0.77 (0.71, 0.83) | 0.78 (0.65, 0.89) | 0.22 (0.12 (0.35) | 0.23 (0.18, 0.29) | X
Park, 2017^136^ | 256 | Nighttime | ≥120/70 | ≥135/85 | 66.0 | 87.1 | 0.74 (0.67, 0.79) | 0.85 (0.68, 0.95) | 0.15 (0.07, 0.31) | 0.26 (0.21, 0.33) | -

* Calculated

† 2x2 data unavailable, unable to calculated CIs or FPR and FNR

Abbreviations: ABPM = ambulatory blood pressure measurement; CI = confidence interval; DBP = diastolic blood pressure; FNR = false negative rate; FPR = false positive rate; HBPM = home blood pressure measurement; hr = hour; HTN = hypertension; MA = meta-analysis; mm HG = millimeter of mercury; NR = not reported; OBPM = office-based BP measurement; Prev = prevalence; Se = sensitivity; sp = specificity

Percent positive screens on HBPM ranged from 65 percent^122^ to 76 percent.^134^ The study with the lowest positive HBPM prevalence recruited participants from Spanish primary care health care centers.^122^ The highest HBPM test positivity of 76 percent occurred in a Greek study in which participants were recruited from a hospital blood pressure clinic.^134^

#### Sensitivity/Specificity

All four HBPM confirmation studies could be pooled, and meta-analysis of an HBPM threshold of ≥135/85 mm Hg (N=1,001) showed a pooled sensitivity of 0.84 (95% CI, 0.76 to 0.90) and pooled specificity of 0.60 (95% CI, 0.48 to 0.71) with considerable heterogeneity (I^2^ sensitivity=85.1%; I^2^ specificity=77.8%) (Figure 4; Table 13). The range of sensitivities was 0.76^122^ to 0.93.^135^ The range of specificities was 0.50^122,^ ^135^ to 0.78.^136^ Exploration of heterogeneity via visual inspection of forest plots sorted by participant and test characteristics showed no pattern.

Figure 4 KQ3: Test Accuracy of Confirmatory Home Blood Pressure Monitoring at a Threshold of ≥135/85 mm Hg to Identify Hypertension Detected by Ambulatory Blood Pressure Monitoring, by Author

Abbreviations: ABPM = ambulatory blood pressure measurement; AM = daytime; CI = confidence interval; Dx TH = diagnostic threshold; HTN = hypertension; n = number; pct = percent; pos scrn = positive screen; 24 = 24-hour

Notes: Sensitivity I^2^=85.1; Specificity I^2^=77.8

The pooled analysis for Nunan, 2015 used accuracy for HBPM measured over 1-7 days; analyses for alternate intervals reported in KQ3a

Figure 4 is a forest plot that shows the test accuracy of confirmatory home blood pressure monitoring at a threshold of ≥135/85 mm Hg to identify hypertension detected by ambulatory blood pressure monitoring, by author. The overall pooled sensitivity is 0.84 (95% CI, 0.76, 0.90) and the pooled specificity is 0.60 (95% CI, 0.48, 0.71)

One study reported the accuracy of the HBPM threshold of ≥135/85 mm Hg against 24-h, daytime, and nighttime ABPM reference standards.^136^ Accuracy was reasonably similar across all reference standard comparisons, with sensitivity ranging from 0.77 to 0.79 and specificity ranging from 0.69 to 0.85. Two studies reported accuracy for multiple HBPM thresholds.^122,^ ^136^ These studies consistently showed increased sensitivity and decreased specificity as thresholds are lowered.

One study reported AUC. The U.K. primary care practice study reported an AUC of 0.71 (95% CI, 0.66 to 0.77) for HBPM confirmation conducted over 7 days.^135^

#### PPV/NPV

The PPV for individual studies ranged from 0.68^135^ to 0.94^136^ (Table 13). The lowest PPV was in a population recruited from primary care in the United Kingdom,^135^ and the highest PPV was in a Korean study that recruited participants from cardiology clinics.^136^ The NPV ranged from 0.46^136^ to 0.86.^135^ The lowest NPV was in the aforementioned Korean study with the highest PPV.^136^ The highest NPV was in the aforementioned U.K. primary care study with the lowest PPV.^135^

#### FPR/FNR

False positive rates in analyses using the preferred 135/85 mm Hg HBPM threshold ranged from 22 percent^136^ to 50 percent.^122,^ ^135^ False negative rates ranged from 7 percent^135^ to 24 percent.^122^

### Self-OBPM: Index Test Characteristics

Two studies evaluated an index test for which participants used an HBPM device to take their own blood pressure in an office setting, which we refer to as “self-OBPM”^135,^ ^139^ (Table 14). While many fundamental device and protocol characteristics were similar in these two studies, thresholds were not comparable and measurements were unattended by staff in one of the studies.^139^

Table 14 Self-OBPM Test Characteristics of Included Studies for KQ 3, by Author

Author, Year; Trial name; Quality | OBPM threshold(s), mm Hg | Index Device (A or M) | Total # of OBPM measurements | Method of determination | Interventionist attending | Resting time (min) | ABPM reference | Reference threshold, mm Hg
Nunan, 2015^135^; Fair | ≥135/85 | Stabliograph bluetooth-enabled automated sphyg | 6 | Average of 5 (unclear which measure is being dropped as 6 measures are taken) | Self-monitored (Attended) | ≥5 | Daytime | ≥135/85
Salazar, 2018^139^; Fair | SBP ≥160 | OMRON HEM 705 CP (A) | 5 | Average of the first three measurements | Self-monitored (Unattended): A nurse performed a training measurement for the patient; these data were discarded. Then the nurse retired and the patient triggered five measurements. | NR | Daytime | ≥135/85
Salazar, 2018^139^; Fair | DBP ≥80 | OMRON HEM 705 CP (A) | 5 | Average of the first three measurements | Self-monitored (Unattended): A nurse performed a training measurement for the patient; these data were discarded. Then the nurse retired and the patient triggered five measurements. | NR | Daytime | ≥135/85
Salazar, 2018^139^; Fair | DBP ≥90 | OMRON HEM 705 CP (A) | 5 | Average of the first three measurements | Self-monitored (Unattended): A nurse performed a training measurement for the patient; these data were discarded. Then the nurse retired and the patient triggered five measurements. | NR | Daytime | ≥135/85
Salazar, 2018^139^; Fair | SBP ≥130 | OMRON HEM 705 CP (A) | 5 | Average of the first three measurements | Self-monitored (Unattended): A nurse performed a training measurement for the patient; these data were discarded. Then the nurse retired and the patient triggered five measurements. | NR | Daytime | ≥135/85

Abbreviations: A = automated; ABPM = ambulatory blood pressure measurement; BP = blood pressure; DBP = diastolic blood pressure; HTN = hypertension; hr = hour; M = manual; mm HG = millimeter of mercury; NA = not applicable; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure; sphyg = sphygmomanometer

Both studies used automated oscillometric HBPM devices. One of the two self-OBPM studies also evaluated the accuracy of the HBPM device in the home environment.^135^ While the two studies shared some protocol characteristics, they differed with respect to attendance of staff during measurements. In both studies, participants were seated and took multiple measurements (5^139^ or 6^135^) in one sitting with at least 1 minute between measurements. One study averaged the first three measurements to determine the self-OBPM^139^ while the second study averaged five of the six measurements.^135^ In one study, a nurse performed a training measurement for the participant before they left the room and the participant then triggered five measurements to perform alone; training measurement data were discarded. In the other study, clinic staff took measurements after a 5-minute seated rest with the same device before the patients took their own measurement; patient measurements were attended by a member of the practice administrative staff.^135^

Other protocol details such as cuff size and arm position were sparsely or inconsistently reported in the two studies. Cuff size was not reported in either study. One study reported that the nondominant arm was measured unless the difference between arms was ≥10 mm Hg, then the highest reading was used.^135^ The other study that had the fully unattended measurement reported that the participant was in an isolated room not speaking, with the arm supported at the heart level, the cuff applied to an uncovered arm, legs uncrossed with feet on the floor, and the back supported.^139^

The diagnostic thresholds were heterogeneous, with one using ≥135/85 mm Hg^135^ and the other reporting accuracy for various SBP-only and DBP-only thresholds that are not currently used in practice (SBP ≥130 mm Hg, SBP ≥160 mm Hg, DBP ≥80 mm Hg, and DBP ≥90 mm Hg).^139^

### Self-OBPM: Reference Test Characteristics

The two studies of confirmatory self-OBPM conducted 24-h ABPM but used daytime ABPM of ≥135/85 mm Hg as the reference standard for hypertension diagnosis^135,^ ^139^ (Table 14). One study specified the daytime monitoring period,^135^ while the other defined daytime per patient report.^139^ Blood pressures were measured every 15 minutes^139^ and 30 minutes.^135^ One study required at least 70 percent of planned measures and one record per hour to be considered valid, and the other did not report minimum measures needed. One study reported a maximum number of measurements of 32 and specified that the ABPM values were calculated based on a simple mean.^135^ The other study did not report how ABPM values were calculated, and maximum measures varied.^139^ Neither study reported information on arm position, leg position, cuff size, or instructions provided to participants.

Two studies used self-OBPM as a confirmation method (N=698). The prevalence of hypertension by ABPM in these studies were 47 percent^139^ and 54 percent.^135^ The percent with positive screens by self-OBPM was 84 percent in the one study that applied an SBP/DBP threshold.^135^

### Self-OBPM: Detailed Results

#### Prevalence/Test Positivity

The two studies reported prevalence rates 47 percent^139^ and 54 percent^135^ for hypertension based on the daytime ABPM of ≥135/85 mm Hg. The index test positivity was 63 percent^139^ and 84 percent,^135^ respectively.

#### Sensitivity/Specificity

Sensitivity and specificity were 0.92 (95% CI, 0.85 to 0.96) and 0.25 (95% CI, 0.16 to 0.35), respectively, in the study using an SBP/DBP threshold (≥135/85 mm Hg).^135^ This study recruited participants from primary care practices in the United Kingdom. The other study reported accuracy for various SBP-only and DBP-only thresholds that are not relevant to current clinical practice, and because results ranged widely, results are not discussed in detail here (see Table 15).

Table 15 Self-OBPM Test Accuracy Results of Included Studies for KQ 3, by Author

Author, Year | N analyzed | ABPM method | ABPM threshold, mm Hg | Index threshold, mm Hg | Positive index test^*^ | Prev HTN^*^ | Se (95% CI)^*^ | Sp (95% CI)^*^ | FPR (95% CIs)^*^ | FNR (95% CIs)^*^ | In MA
Nunan, 2015^135^ | 203 | Daytime | ≥135/85 | ≥135/85 | 84.2 | 54.0 | 0.92 (0.85, 0.96) | 0.25 (0.16, 0.35) | 0.75 (0.66, 0.83) | 0.08 (0.04, 0.15) | -
Salazar, 2018^139^ | 466 | Daytime | ≥135/85 | SBP ≥130 | 63.0 | 47.0 | 0.86 (0.81, 0.90) | 0.57 (0.51, 0.63) | 0.43 (0.37, 0.49) | 0.14 (0.10, 0.19) | -
Salazar, 2018^139^ | NR | Daytime | ≥135/85 | SBP ≥160 | 63.0 | 47.0 | 0.20 (NR)^†^ | 0.97 (NR)^†^ | NR^†^ | NR^†^ | -
Salazar, 2018^139^ | NR | Daytime | ≥135/85 | DBP ≥80 | 63.0 | 47.0 | 0.84 (NR)^†^ | 0.65 (NR)^†^ | NR^†^ | NR^†^ | -
Salazar, 2018^139^ | NR | Daytime | ≥135/85 | DBP ≥90 | 63.0 | 47.0 | 0.46 (NR)^†^ | 0.95 (NR)^†^ | NR^†^ | NR^†^ | -

* Calculated

† 2x2 data unavailable, unable to calculate CIs or FPR and FNR

Abbreviations: ABPM = ambulatory blood pressure measurement; CI = confidence interval; DBP = diastolic blood pressure; FNR = false negative rate; FPR = false positive rate; hr = hour; HTN = hypertension; MA = meta-analysis; mm HG = millimeter of mercury; NR = not reported; OBPM = office-based BP measurement; Prev = prevalence; Se = sensitivity; sp = specificity

AUC for the U.K. primary care practice study with an SBP/DBP threshold was 0.58 (95% CI, 0.53 to 0.63).^135^

#### PPV/NPV

The PPV for the U.K. primary care practice study using an SBP/DBP threshold was 0.59 and the NPV was 0.72.^135^ PPVs and NPVs were variable in the study reporting SBP-only and DBP-only thresholds. False positive rates were 43^139^ and 75^135^ percent and false negative rates were 8^135^ and 14^139^ percent.

### Truncated ABPM: Index Test Characteristics

One study reported the accuracy of a truncated (6-hour) ABPM compared with 24-h ABPM (Table 16).^124^ In this study, just one ABPM test was conducted and results from the first 6 hours (minus a 1-hour “white coat window”) were compared with the full 24-h reference standard (minus a 1-hour white coat window). The ABPM test was initiated in the morning for almost all participants. Measurements were taken every 20 minutes during the day for a maximum of 18 measurements, 15 of which were used to calculate BP because of the white coat window. Participants received standardized education about the ABPM session and were fit with appropriately sized cuffs based on AHA standards.

Table 16 Truncated ABPM Test Characteristics of Included Studies for KQ 3, by Author

Author, Year; Trial name; Quality | ABPM Index threshold(s), mm Hg | Index Device (A or M) | Total # of measurements | Method of determination | Interventionist (attended) | Resting time (min) | ABPM modality reference | Reference threshold, mm Hg
Ernst, 2011^124^; Fair | 6-hr ABPM SBP >130 | SpaceLabs 90217 | 18 (max, daytime-only window) | 6 hours, initiated in morning for almost all participants | NA | NA | 24-hr | SBP >130

Abbreviations: A = automated; ABPM = ambulatory blood pressure measurement; hr = hour; M = manual; min = minute; mm Hg = millimeters of mercury; NA = not applicable; SBP = systolic blood pressure

The diagnostic threshold for this 6-hour ABPM was SBP >130 mm Hg.

### Truncated ABPM: Reference Test Characteristics

The single study (N=263) of a truncated ABPM index test evaluated a 6-hour ABPM compared with a 24-hr ABPM reference standard with an SBP-only threshold of >130 mm Hg for hypertension diagnosis (Table 16).^124^ The device obtained measurements every 20 minutes during the daytime and every 30 minutes during the nighttime. The total number of measurements over 24 hours ranged from 57 to 61. The reference value was calculated as the average of measurements with the first hour excluded as the white coat window. The study reports that staff met with the patient to provide standardized education about the session and to fit the patient with the appropriately sized cuff, which was determined by arm circumference according to AHA guidelines; no other details were reported.

### Truncated ABPM: Detailed Results

#### Sensitivity/Specificity

The sensitivity and specificity were 0.94 (CIs not reported) and 0.76 (CIs not reported), respectively, in a population (N=126) for whom the ABPM indication was borderline hypertension (Table 17). The sensitivity and specificity were 0.89 and 0.70, respectively, for the population (N=137) with suspected white coat hypertension.

Table 17 Truncated ABPM Test Accuracy Results of Included Studies for KQ 3, by Author

Author, Year | Group | N analyzed | ABPM method | ABPM threshold, mm Hg | Index threshold, mm Hg | Positive index test | Prev HTN | Se (95% CI)^*^ | Sp (95% CI)^*^ | FPR (95% CIs)^*^ | FNR (95%CIs)^*^ | In MA
Ernst, 2011^124^ | Borderline HTN | 126 | 24-hr | SBP >130 | SBP >135 | NR | NR | 0.94 (NR) | 0.76 (NR) | NR^†^ | NR^†^ | -
Ernst, 2011^124^ | Suspected WC | 137 | 24-hr | SBP >130 | SBP >135 | NR | NR | 0.89 (NR) | 0.70 (NR) | NR^†^ | NR^†^ | -

* Calculated

† 2x2 data unavailable, unable to calculated CIs or FPR and FNR

Abbreviations: ABPM = ambulatory blood pressure measurement; CI = confidence interval; FNR = false negative rate; FPR = false positive rate; HTN = hypertension; hr = hour; MA = meta-analysis; NR = not reported; Prev = prevalence; SBP = systolic blood pressure; WC = white coat

#### FPR/FNR

Sparse data were reported in this study, precluding calculations of prevalence, percent positivity, FPR, FNR, PPV, and NPV. AUCs were high in both populations, with values of 0.932 in those with borderline hypertension and 0.901 in those with suspected white coat hypertension.

### Comparative Accuracy

Two studies reported the accuracy of multiple confirmation methods against the same ABPM reference standard. Nasothimiou et al reported the accuracy of repeat OPBM and HBPM compared with a daytime ABPM reference standard.^134^ Sensitivity was high and similar for both index tests (0.85 [95% CI, 0.80 to 0.88] for OBPM and 0.87 [95% CI, 0.83 to 0.91] for HBPM). Specificity was much lower for both modalities. Specificity trended higher for HBPM, but there was some overlap of confidence intervals (0.43 [95% CI, 0.33 to 0.54] for OBPM and 0.61 [95% CI, 0.51 to 0.71] for HBPM). Nunan et al reported the accuracy of HBPM and self-OBPM compared with a daytime ABPM reference standard.^135^ Sensitivity was high and similar for both index tests (0.93 [95% CI, 0.86 to 0.97] for HBPM and 0.92 [95% CI, 0.85 to 0.96] for self-OBPM). Specificity was much lower for both modalities, with self-OBPM being significantly worse (0.50 [95% CI, 0.40 to 0.61] for HBPM and 0.25 [95% CI, 0.16 to 0.35] for self-OBPM).

## KQ3a What Confirmation Protocol Characteristics Define the Best Test Accuracy?

### Summary of Results

Five of 18 confirmation studies reported within-study comparisons of protocol characteristics on accuracy.^126,^ ^130,^ ^135,^ ^136,^ ^139^ Evidence on protocol variations for any one confirmation modality was sparse, but very limited evidence may suggest that for HBPM, additional days of measurement beyond 5 do not improve accuracy. Two studies reported accuracy for confirmatory OBPM protocols using multiple visits, but each study had a different design and aim. While one study exploring whether the prevalence of white coat hypertension would decrease over a series of measurements found some evidence to support that hypothesis,^126^ another study found that ABPM phenotypes had fair reproducibility when taken one week apart.^130^ Two studies of confirmatory HBPM found no improvement in accuracy for a 7-day protocol compared with a 5-day protocol.^135,^ ^136^ Similarly, one study of self-OBPM reported similar accuracy for the average of five and the average of three measurements taken on a single visit compared with ABPM.^139^

### Detailed Results

#### OBPM

Two studies reported accuracy for confirmatory OBPM protocols based on measurements performed at multiple visits but had different aims (Appendix E Table 6).^126,^ ^130^ The study by Fogari et al explored whether repeated OBPMs taken at several visits would reduce the prevalence of white coat hypertension. OBPMs were taken at office visits occurring every 2 weeks for a total of five visits. Complete accuracy results are only reported at week 8; however, results suggested that there are fewer screen positives over time with repeated visits. The other study, by Husain et al, examined the reproducibility of ABPM phenotypes (sustained, masked, white coat, normotensive), which were evaluated by comparing repeated sets of OBPMs and ABPMs taken 1 week apart. Sensitivity and specificity were nearly identical in the first and second comparisons, and short-term reproducibility was characterized as fair.^144^

#### HBPM

Two studies of confirmatory HBPM evaluated protocol variations involving a different number of days of HBPM (Appendix E Table 6).^135,^ ^136^ The U.K. primary care practice study by Nunan et al compared HBPM protocols, averaging measures taken in the morning and evening on days 1-7 (28 measures), days 2-7 (24 measures), days 1-5 (20 measures), and days 2-5 (16 measures). Sensitivities and specificities for the various protocols were similar: sensitivity point estimates ranged from 0.93 to 0.94, specificity point estimates ranged from 0.50 to 0.53, and confidence intervals were nearly identical. Another study by Park tested protocol variations involving the number of days of measured and which measures, out of three taken each in the morning and evening, to include in the averaged value.^136,^ ^138^ This study found similar accuracy for HBPM taken over 5 days versus 6 or 7 days, with sensitivity ranging from 0.74 to 0.75 and specificity ranging from 0.75 to 0.78, each with overlapping confidence intervals. Similar accuracy was found for each averaging method.

#### Self-OBPM

One study by Salazar et al of self-OBPM using SBP-only or DBP-only index test thresholds reported accuracy for an average of three compared with 5 measures in one sitting separated by 1 or more minutes (Appendix E Table 6).^139^ Authors reported that the use of five measures instead of three did not significantly improve correlations or AUCs of self-OBPM compared with the ABPM reference standard.

## KQ4 What Are the Harms of Screening for Hypertension in Adults?

### Summary of Results

We identified 13 fair- to good-quality studies (reported in 16 articles) (N=5,150) examining the harms of screening and diagnosis of hypertension.^148–161^ Most of these studies were performed 2 or more decades ago. Four studies addressing absenteeism,^151^ ABPM tolerability,^161,^ ^162^ and sleep quality^163^ are newly included since the previous review. Evidence for KQ4 is derived from heterogeneous populations and studies of limited quality. The limited existing evidence suggests that screening is associated with no decrement in quality of life or psychological distress, and the scant evidence on screening’s effect on absenteeism is mixed. ABPM followup testing is associated with minor adverse events including temporary sleep disturbance and bruising.

Inaccurate diagnoses (false positives and false negatives) are considered harms of screening and confirmation and have been discussed in detail under the KQ2 and KQ3 results. In brief, false positive and false negative rates varied widely for OBPM screening (KQ2) and for various confirmation modalities (KQ3). For screening OBPM (KQ2), false positive rates ranged from 0 to 30 percent and false negative rates ranged from 8 to 100 percent among studies included in the main pooled analysis. For confirmatory OBPM in KQ3, false positive rates ranged from 15 to 65 percent and false negative rates ranged from 10 to 65 percent. For confirmatory HBPM, false positive rates ranged from 22 to 50 percent and false negative rates ranged from 7 to 24 percent.

### Study and Population Characteristics

The 13 harms studies had heterogenous designs and measured various outcomes in different populations (Table 18). The included analyses for harms are embedded within studies originally designed to address various aims; however, for the purpose of addressing harms, the data are derived from analyses consisting of two RCTs,^155,^ ^157^ two prospective cohorts,^162,^ ^163^ four cohorts derived from RCTs,^148–151^ and five cross-sectional analyses.^156,^ ^158–161^ Nearly half of the studies were conducted in North America: five in the United States,^151,^ ^155,^ ^157,^ ^158,^ ^163^ and one in Canada.^149^ Three studies were conducted in the United Kingdom,^150,^ ^159,^ ^162^ and one study each in Italy,^156^ Greece (297), Japan,^161^ and the Netherlands.^148^ The study sizes ranged from a small Japanese study by Kuwajima et al with 24 participants^161^ to the largest Italian study by Verdecchia with 2,934 participants.^156^ The studies recruited participants from heterogenous settings, including hypertension treatment trials,^150^ medical clinics or academic research centers,^148,^ ^155,^ ^157,^ ^158,^ ^160,^ ^162^ hospital-based registry,^156^ and occupational settings,^149,^ ^151^ and in some studies was not reported.^159,^ ^161^

Table 18 High-Level Summary of Included Studies for KQ 4, by Outcome

Category (number of studies) | Author, Year; Quality | Country | Study Design | N analyzed | Sample | Comparison | Outcome measurement | Study conclusions
QoL /psychological outcomes(k=4) | Ameling, 1991^148^; Fair | NL | Prospective Cohort (prior to randomization into treatment trial) | 331 | Newly diagnosed hypertensives identified via case-finding in general practice | Pre-post labeling as hypertensive (1 week follow up) | Unvalidated set of QOL-related items on physical symptoms, sexual functioning, and sleep. Also reported validated Amsterdam Mood List. | No effects of labeling hypertension on quality of life.
QoL /psychological outcomes(k=4) | Mann, 1977^150^; Fair | UK | Prospective Cohort (prior to randomization into treatment trial) | 654 | Participants screened for hypertension for eligibility for the MRC trial | Pre-post screening (timing NR) | GHQ | Informing asymptomatic people about their raised blood pressure and enrollment in a trial caused no undue psychological response.
QoL /psychological outcomes(k=4) | Spruill, 2013^155^; Good | US | RCT | 100 | Adults previously unaware of prehypertensive status identified in internal medicine practices and advertised BP screenings | No label (informed of BP only) vs. labeled (discussed prehypertension) 3 months post labeling | SF-12 (physical and mental health) | Prehypertension labeling did not significantly influence self-reported physical or mental health
QoL /psychological outcomes(k=4) | Tompson, 2019^162^; Fair | UK | Prospective Cohort | 140 | Consecutive pts, aged 40-85, presenting with a single office SBP between 130 and 179 mmHg | Pre-post evaluation assessing psychological impact of 28 days of self-monitoring followed by 24-hr ABPM | HADS scores | Out-of-office BP monitoring does not appear to be harmful though it may induce feelings of anxiety in some pts.
QoL /psychological outcomes(k=4) | Viera, 2010^157^; Fair | US | RCT | 97 | Adults with prehypertension recruited via flyers in examination rooms | No label (standard lifestyle counseling only) vs. labeled (discussed prehypertension) 3 months post labeling | SF-36 (physical and mental health); self-rated health questions of improvement or no-change | Being labeled as prehypertensive seems to exert neither harmful or helpful effects.
Absenteeism after labeling (k=2) | Haynes, 1978^149^; Fair | Can | Prospective cohort derived from treatment trials | 208 | Male employees with screen-detected untreated hypertension recruited via the workplace | Pre-post labeling (12 months before labeling versus 12-48 months after labeling); results stratified by previously aware (known hypertensive subgroup) versus previously unaware (screened subgroup) | Work absenteeism | Men previously unaware of their hypertension had a statistically significant rise in absenteeism which persisted to the end of 4 years of followup.
Absenteeism after labeling (k=2) | Rudd, 1987^151^; Fair | US | Prospective cohort derived from randomized trial | 294 | Employees with screen-detected untreated hypertension recruited via the workplace | Pre-post labeling (12 months before labeling versus 12 months after labeling) | Work absenteeism | No significant increase in absenteeism in aware and previous unaware hypertensives after statistical correction.
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Kuwajima, 1998^161^; Fair | Japan | Cross-sectional | 24 | Volunteers aged 22-96; recruitment setting not reported | 24-hour ABPM with no comparator | Unvalidated questionnaire: Tolerability (including sleep disturbance) | Sleep disturbance reported in 29% of individuals and was associated with some upper arm pain.
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Manning, 2000^159^; Fair | UK | Cross-sectional | 79 | Borderline hypertensives and normotensives, aged 18 to 70; recruitment setting not reported | 24-hour ABPM with no comparator | Unvalidated questionnaire: Perception of sleep quality | Sleep disturbance reported in 37% of individuals.
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Nasothimiou, 2013^134^; Fair | Greece | Cross-sectional data from within a prospective cohort study | 104 | Consecutive untreated adults referred for evaluation at an outpatient hypertension clinic | 7 days of HBPM vs 24-hour ABPM | Unvalidated questionnaire: Tolerability of using both ABPM and HBPM | HBPM was viewed more favorably than ABPM by participants (82% vs 63%) due to ease, discomfort, and restriction of activities.
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Sherwood, 2019^163^ | US | Prospective cohort | 121 | Volunteersaged30-60, with untreated stage 1 or 2 hypertension^*^ | BL (average of 7 non-ABPM nights) vs three 24-hr ABPM sessions | Wrist actigraphy (Mini-Mitter Actiwatch): sleep efficiency and total sleep duration | Found no evidence that ABPM had an adverse effect on sleep quality
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Tompson, 2019^162^; Fair | UK | Cross-sectional data within a prospective Cohort | 183 | Consecutive pts, aged 40-85, presenting with a single office SBP between 130 and 179 mmHg | 28 days of HBPM vs 24-hour ABPM | Unvalidated questionnaire: acceptability of self-monitoring and ABPM | Self-monitoring may be preferable to ABPM
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Verdecchia, 2007^156^; Fair | Italy | Cross-sectional data from within a prospective registry | 2934 (rand) | Untreated subjects with hypertension from hospital-based registry. | 24-hour ABPM with no comparator | Unvalidated questionnaire: Perceived sleep duration | Sleep deprivation of ≥2 hours was reported by 14% of individuals.
ABPM tolerability and ABPM-attributed sleep disturbance (k=6) | Viera, 2011^158^; Fair | US | Cross-sectional | 60 | Adults with borderline hypertension recruited via flyers in primary care clinics and a clinical research center. | 24-hour ABPM with no comparator | Unvalidated questionnaire: AEs of monitor wear | 20% reported the monitor stopped them from falling asleep and 70% reported being awoken by the monitor. Commonly reported adverse events included pain, skin irritation, and bruising.

* Clinic SBP between 130-159 and/or DBP of 85-99 mmHg

Abbreviations: ABPM = ambulatory blood pressure measurement; Can = Canada; GHQ = General Health Questionnaire; HADS = hospital anxiety and depression scale; HBPM = home blood pressure measurement; NL = the Netherlands; QoL = quality of life; RCT = randomized controlled trial; SF = short form; UK = United Kingdom; US = United States

The mean participant age ranged from 37.9 years^151^ to 74 years.^161^ One study^149^ solely recruited men, while the remaining recruited 38 percent^151^ to 57 percent^159^ women. Other participant characteristics were rarely reported. Mean office SBP/DBP was reported in six of the studies and ranged from 126.4/79.9 mm Hg^155^ to as high as 167.4/104.7 mm Hg.^148^

### Quality

In general, this literature is limited by heterogeneous populations, comparators, and outcomes. Only one study was rated as good quality; the remaining studies were rated as fair. The single good-quality study was an RCT reporting adequate randomization and allocation concealment; there was similar attrition between the groups; and validated scales were used to assess outcomes with adjustment for confounding.^155^ For the remaining fair quality studies, quality issues included pre-post cohort designs or cross sectional designs with lack of comparators and use of unvalidated measures. These design flaws contribute to a body of evidence on screening and confirmation harms with limited internal and external validity.

### Detailed Results

There were no population-based RCTs of harms of screening for hypertension compared with no screening.

#### Screening Effects on Quality of Life and Psychological Outcomes

The two included RCTs (N=197), one prospective cohort (N=139), and two cohorts derived from RCTs (N=985) examined the effects of screening on various measures of quality of life, mood, and psychological distress; the validated QOL scales included GHQ,^150^ SF-12,^155^ and SF-36,^157^ and the validated mood scale used was the Amsterdam Mood List^148^ and the hospital anxiety and depression scale (HADS)^162^ (Appendix E Table 7). The two RCTs compared the effects of labeling individuals as prehypertensive versus generic counseling without reference to their prehypertensive status.^155,^ ^157^ In both trials, labeling individuals as prehypertensive was not found to have any adverse effects on physical or mental health after 3 months. Two prospective cohort studies of individuals being evaluated for inclusion in hypertension treatment trials examined the short-term quality-of-life impact of the identification of hypertensive status.^148,^ ^150^ One of these cohorts evaluated a validated mood scale and unvalidated QOL-related item results comparing scores before and after hypertension diagnosis,^148^ while the second cohort compared validated QOL scale results before and after screening.^150^ Similar to the results of the RCTs, these studies found no effects of screening or labeling on participant quality of life. One cohort assessed the psychological impact of 28 days of self-monitoring, followed by 24-hr ABPM using the HADS. This study found that the proportion of participants anxious or depressed at baseline decreased after monitoring. The authors concluded that out-of-office BP monitoring may induce feelings of anxiety in some patients but does not appear to be harmful.^162^ (Appendix E Table 7)

#### Absenteeism

The two studies report mixed results on hypertension diagnosis on absenteeism (Appendix E Table 8). One industrial worksite-based cohort study by Haynes et al (N=208) compared the rates of absenteeism among individuals with hypertension with their absenteeism during the year prior to screening and then stratified results by previously aware and previously unaware subgroups. Overall, compared with the year before screening, days of absenteeism increased 80 percent, with the largest rise among individuals who reported being previously unaware of their hypertensive status.^149^ This increase in absenteeism continued over 4 years for previously unaware individuals, while those who reported being aware of their hypertension previously remained relatively stable.^152^ A second worksite study by Rudd et al (N=294) reported no statistically significant differences in absenteeism due to illness (days/year) in the sustained hypertensive group between the previously aware and previously unaware participants after correction for matched controls^151^ (Appendix E Table 8).

#### Sleep Disturbance and Tolerability Associated With ABPM

Six cross-sectional studies^156,^ ^158–162^ and one prospective cohort study^163^ reported ABPM tolerability or sleep disturbance in different populations (Appendix E Table 9). Four studies addressed sleep disturbance attributed to the ABPM through the use of unvalidated participant questionnaires^156,^ ^158,^ ^159,^ ^161^ and one study assessed sleep efficiency objectively in men and women with untreated hypertension using wrist actigraphy^163^ (Appendix E Table 9). The definitions of sleep disturbance varied among studies, with self-reported rates ranging from 14 percent^156^ in the largest study (N=2934) (defined as sleep deprivation ≥2 hours) to 70 percent^158^ (defined as being awoken by the monitor). In one study, 9 percent of individuals reported their sleep was disrupted enough that they removed the monitor during the night.^158^ A prospective cohort study (N=121) measured sleep efficiency and total sleep time on seven days of non-ABPM days and three subsequent days of ABPM-monitoring.^163^ This study found no evidence that ABPM had an adverse effect on sleep quality (Appendix E Table 9).^163^ Three studies reported other adverse effects of ABPM, with mixed results.^158,^ ^160,^ ^161^ Reported adverse events included pain/discomfort, bruising, and skin irritation (Appendix E Table 9). In one study comparing tolerability of HBPM and ABPM, participants reported moderate to severe daily restriction in the ABPM group compared with the HBPM group; HBPM was viewed more favorably than ABPM by participants (82% vs. 63%) due to ease of use, comfort, and less activity restriction.^160^

One study (N=183) used an unvalidated questionnaire to measure the acceptability of self-monitoring and ABPM and found that self-monitoring was preferable to ABPM (Appendix E Table 9).^162^