# Chapter 2 Methods

## Scope and Purpose

Screening for hypertension in adults has been standard of care in the United States for decades,^59^ and the USPSTF has maintained an A recommendation for the service from its 1996 inception.^1,^ ^60–63^ Beginning with the 2015 evidence review,^64^ the test accuracy of initial screening and confirmatory measurements has been systematically reviewed as part of the USPSTF process due to growing interest and availability of out-of-office blood pressure measurement modalities. The USPSTF will use this review to update its 2015 recommendation statement on screening for hypertension in adults, with a focus on test accuracy and identification of the best methods for screening and confirmation of hypertension.^1^

## Key Questions and Analytic Framework

In consultation with members of the USPSTF, we developed an analytic framework (Figure 1) and four Key Questions (KQs) to guide our review.

Figure 1 Analytic Framework

Abbreviations: BP = blood pressure; CVD = cardiovascular disease; ESRD = end-stage renal disease; HF = heart failure; QoL = quality of life; PAD = peripheral artery disease.

Figure 1 is the analytic framework that depicts the four Key Questions to be addressed in the systematic review. The figure illustrates how primary care screening for high blood pressure in adults may result in improved health outcomes, including all-cause mortality, cardiovascular disease mortality and events, heart failure, end-stage renal disease, symptomatic peripheral arterial disease, quality of life, and vascular dementia (KQ1). Additionally, the figure illustrates the accuracy of office-based blood pressure measurements in an initial screening for high blood pressure compared with the reference standard (ambulatory blood pressure measurement) (KQ2), and the accuracy of confirmatory blood pressure measurements in adults who initially screen positive for high blood pressure compared with the reference standard (KQ3). Lastly, the figure illustrates what harms may be associated with screening for high blood pressure in adults (KQ4).

1. Does screening for hypertension in adults improve health outcomes?
2. What is the accuracy of office-based blood pressure measurement (OBPM) during a single encounter as initial screening for hypertension compared with the reference standard, ambulatory blood pressure measurement (ABPM)?
  a. What screening protocol characteristics define the best test accuracy?
3. What is the accuracy of confirmatory blood pressure measurement in adults who initially screen positive for hypertension compared with the reference standard (ABPM)?
  a. What confirmation protocol characteristics define the best test accuracy?
4. What are the harms of screening for hypertension in adults?

### Changes in Scope From the Previous Review

Consistent with the previous review, we evaluated the test accuracy of initial screening for hypertension and the test accuracy of confirmatory measurement in separate KQs. However, some scope changes were made for the test accuracy questions in this update. For both initial screening and confirmation questions, we required ABPM to serve as the reference standard. Based on a finding from a systematically reviewed question in the last review that ABPM predicts long-term cardiovascular outcomes independently of OBPM, the USPSTF determined that ABPM should serve as the reference standard for blood pressure measurement.^1^ This prognosis question was not updated in the present review. Additionally, the previous review systematically evaluated evidence on the appropriate rescreening interval for patients who had been found to have normal blood pressure in previous screening. This question was also not updated in the present review, but rescreening is addressed contextually in the Discussion section.

For the accuracy of confirmation question, we required studies to have a population whose selection was based upon having elevated blood pressure previously, then had that entire pre-selected population undergo another confirmation measurement and ABPM. The scope of all questions was expanded to include individuals with diabetes as they comprise a substantial proportion of patients seen in the primary care setting.

## Data Sources and Searches

We conducted a search to identify literature published since the previous review for the USPSTF through August 2019. We worked with a research librarian to develop our search strategy, which included the following databases: MEDLINE, PubMed (published-supplied records only), the Cochrane Central Register of Controlled Trials (CENTRAL), and the Cumulative Index of Nursing and Allied Health (CINAHL) (Appendix A). Additionally, due to an expansion in the scope of the current review to include individuals with diabetes, we performed a targeted search of the bibliographic database for the previous review for terms related to this condition; this database included results of a comprehensive literature search from 1992 through February 2014.

We evaluated all previously included studies from the prior review for the USPSTF as well as studies that were previously excluded based on their reference standard or because the populations included a large proportion with diabetes; these reflected areas of scope change in this update. Additionally, we reviewed reference lists of other systematic reviews,^65,^ ^66^ individual patient-data meta analyses,^67^ recent guidelines^31,^ ^68^ and table-of-content alerts such as those produced by the USPSTF Scientific Resource Center LitWatch activity to identify additional studies not identified in our literature searches. We conducted ongoing surveillance through March 26, 2021. We also searched ClinicalTrials.gov and WHO International Clinical Trials Registry Platform (ICTRP), for relevant ongoing trials. We managed all literature search results using EndNote^TM^ version 7.3.1 (Thomson Reuters, New York, NY).

## Study Selection

One investigator independently prescreened titles and abstracts of a subset of studies with keywords (identified electronically) pertaining to an excluded setting, population, or condition in the title, abstract, or keyword fields of EndNote (Appendix A Table 1). Abstracts deemed potentially relevant during single review were advanced for dual review. Of the 21,741 citations screened, 10,473 were prescreened by a single reviewer; of these, 297 were identified as potentially relevant and moved forward for dual review. Two investigators independently reviewed 544 full-text articles against prespecified inclusion criteria (Appendix A Table 2). We used DistillerSR (Evidence Partners, Ottawa, Canada) to conduct abstract and full-text review.

### Population

For all KQs, we required studies to be conducted in adults who were not already taking antihypertensive medications, the reason being that treatment with antihypertensive medication has been shown to reduce blood pressure variability, which would limit the generalizability of accuracy results in a screening population.^69,^ ^70^ We accepted studies in which less than 20 percent of the population was treated for hypertension; otherwise we required analyses to be stratified by treatment status or when we were able to isolate results based on the untreated population. We excluded populations derived from treatment trials or ABPM centers in which the population was previously treated with subsequent wash-out period and the aim of the study was other than test accuracy. We excluded studies specifically recruiting pregnant individuals, institutionalized persons, inpatients, and persons with secondary hypertension. We excluded studies that enrolled a highly selected group of participants, such as renal transplant recipients or those with chronic kidney disease.

Eligible populations for KQ2 (initial screening) were unselected, whereas KQ3 populations (confirmatory screening) were preselected, with a criterion of at least one elevated BP measurement identified by clinic-based screening. If a KQ3 population was described as being “referred for ABPM,” we accepted this as relevant as long as no more than 20 percent of the population was treated or results were stratified by treatment status. Unless an APBM registry had the specific aim of screening, we considered an ABPM registry to be a preselected population and thus appropriate for KQ3 (and not KQ2). We acknowledge that there is a wide range of potential indications for ABPM and considered a lack of treatment a proxy for an ABPM indication of confirmation of diagnosis.

### Intervention and Comparators

For all KQs, we required BP measurements to be taken on the upper arm. Consistent with the previous review, we excluded forearm cuffing as well as wrist, ankle, finger, and toe BP monitors and measurements due to limitations in their accuracy.^31^ We also excluded any BP measurement methods not commonly used in routine screening, such as invasive methods (e.g., intra-arterial measures) or noninvasive central BP measurements. For all KQs, we accepted any SBP/DBP threshold (where either SBP or DBP or both are elevated), SBP-alone, or DBP-alone threshold to diagnose hypertension (HTN) in order to be as inclusive as possible; however, SBP/DBP thresholds were preferred because of their relevance to current clinical practice. We also accepted any threshold for “elevated BP” to qualify for a confirmation study and abstracted the threshold values as reported in these studies. However, for test accuracy questions, we did not accept hypertension defined as use of anti-hypertension medication. AOBP was an eligible type of OBPM for all KQs; descriptions of the conduct of AOBP were closely evaluated to confirm whether the measurements were unattended by a clinician or other staff. When the presence or absence of personnel during blood pressure measurement was unclear from the study publication, we contacted the study’s corresponding author. Because of variation in the reporting of AOBP protocols and device characteristics, we sought to consistently define measurement methods by distinguishing who triggered the device and whether or not the measurement was attended or unattended. For cases where serial measurements are triggered by the patient, this is categorized as self-OBPM. If serial measurements are automated, we have categorized as AOBP.

For KQ1, we included RCTs that reported changes in health outcomes as a result of screening for hypertension compared with no screening. Screening had to occur during a single encounter and be performed by trained personnel. Screening could have been conducted as part of a multicomponent CVD risk assessment as long as the blood pressure measurement was the primary intervention.

For KQ2, we included test accuracy studies that compared OBPM to an ABPM reference standard for initial screening for hypertension using any common device or screening protocol as long as it was office-based. We initially accepted only screening measurement(s) occurring at a single encounter and then conducted a sensitivity analysis to include screening over multiple visits based on practice guidelines.^20^ We accepted any ABPM method for the reference standard, including 24-hr, daytime, and nighttime. We then conducted an exploratory analysis restricted to the 24-hr ABPM reference standard. For KQ2a, we included studies reporting accuracy of different OBPM protocol characteristics compared with an ABPM reference standard (e.g., more vs. fewer OBPM measures, shorter vs. longer resting time or time between measures, different sitting positions, attended vs. unattended measures).

For KQ3, we included test accuracy studies of clinic-based or out-of-office noninvasive blood pressure measurement modalities to confirm an initial elevated blood pressure result compared with any ABPM reference standard. As with KQ2, we conducted an exploratory analysis restricted to 24-hr ABPM reference standards only. Eligible confirmatory methods included repeated OBPM, HBPM, or kiosk (public use blood pressure stations). Eligible studies needed to report a confirmatory measure and ABPM for participants with a previous elevated OBPM in order to create a 2x2 table; studies only conducting ABPM in these participants were not eligible as only a 1x2 table could be generated. For KQ3a, we included studies reporting accuracy of different confirmation protocol characteristics compared with an ABPM reference standard (e.g., more vs. fewer days of HBPM).

For KQ4, we included RCTs comparing harms in screened versus unscreened groups as well as RCTs and cohort studies that reported on the harms of screening, including absenteeism or any psychological effects or changes in quality of life as a result of being labeled hypertensive. We also included studies that examined the adverse effects of subsequent BP measurement methods to confirm the initial diagnosis (i.e., ABPM or HBPM), such as sleep disturbance or discomfort in continuously wearing a BP monitor.

### Outcomes

For KQ1, eligible outcomes were: all-cause and cardiovascular mortality; cardiovascular disease events, including myocardial infarction, sudden cardiac death, stroke, heart failure, and hospitalization for coronary heart disease; symptomatic PAD; vascular dementia; end-stage renal disease; and quality of life. For KQs 2 and 3, we required sensitivity, specificity, positive and negative predictive values, or enough data to create 2x2 tables so sensitivity and specificity could then be calculated. We excluded test accuracy studies only reporting kappas or other measures of concordance but not sensitivity and specificity. KQ4 studies needed to report outcomes on the harms of screening, which could include psychological effects of labeling, absenteeism, quality of life, or tolerability of ABPM devices. For ABPM tolerability outcomes pertaining to sleep disturbance, we required that measures use some type of comparator, such as a comparison to usual sleep, to avoid bias from any poor general sleep outcome being attributed to ABPM.

### Setting

For KQs 1 and 2, to be included, studies must have been conducted in eligible primary care settings, which we defined as sites with personnel trained in BP measurement, established BP measurement protocols, and ongoing documentation procedures for each. For KQ2, studies that recruited from workplace settings were eligible as long as OBPMs were conducted in an eligible primary care setting. For KQ3, allowable settings also included those for out-of-office BP measurement.

For all KQs, we excluded inpatient and residential facilities and restricted studies to those conducted in countries rated as “Very High” on the 2015 Human Development Index.^71^

### Study Design

For KQ1, we included RCTs and CCTs of screening compared with no screening. For KQs 2 and 3, we accepted test accuracy studies comparing an initial or confirmatory BP measurement modality compared with an ABPM reference standard. For KQ4, we accepted RCTs, CCTs, and cohort studies for the outcomes of quality of life, physiological effects of labeling, and absenteeism; for the outcome of ABPM tolerability we additionally allowed cross-sectional studies given that tolerability was measured at one point in time.

Individual patient-data meta-analyses and registries were evaluated for inclusion. We required contributing populations to these studies to meet our other inclusion criteria, and we carefully evaluated their source populations to ensure that they did not overlap with populations in other included studies to avoid duplication. Publications from the International Database on Ambulatory Blood Pressure in Relation to Cardiovascular Outcomes (IDACO) were ultimately excluded because several contributing cohorts conducted OBPM during home visits, which did not meet our setting criteria.^32,^ ^37,^ ^67,^ ^72^ Additionally, several cohorts were from non-very-High HDI countries. Similarly, the Ambulatory blood pressure Registry TEleMonitoring of hypertension and cardiovascular rISk (ARTEMIS) was excluded because contributing hypertension clinics included those from non-very-High HDI countries, and furthermore, we concluded that there was overlap with already included populations based on the author list.^33^ We prioritized the individual primary publications which reported additional protocol details which could be used for critical appraisal and data abstraction. Two other registries met inclusion criteria for KQ3—the Spanish ABPM Registry and the Korean ABPM Registry for Evaluation of the Prognostic Threshold in Hypertension (Kor-ABP).^73,^ ^74^

## Quality Assessment

Two reviewers critically appraised articles meeting inclusion criteria. We assigned each study a quality rating of “good,” “fair,” or “poor” according to the USPSTF’s study design-specific criteria.^75^ We supplemented these criteria with items from the Newcastle-Ottawa Scale for cohort studies^76^ and the Quality Assessment of Diagnostic Accuracy Studies for studies of test accuracy^77,^ ^78^ (Appendix A Table 3). Disagreements were resolved by consensus and, if needed, consultation with a third independent reviewer. Because of several important changes to the scope of test accuracy KQs in this update (KQ2 and KQ3), we repeated critical appraisal of previously included test accuracy studies. Critical appraisal of previously included studies was carried forward from the previous review for KQ1 and KQ4 because there were no changes to the scope of these questions and this was an update of our own work. Detailed methods for quality rating of test accuracy studies are available in Appendix A.

## Data Abstraction

For studies about the benefits and harms of screening (KQs 1 and 4), we extracted details about each study’s design (e.g., recruitment and inclusion criteria, number of participants recruited and analyzed); patient characteristics (e.g., age, sex, race/ethnicity, comorbidities and CVD history, baseline blood pressure); and intervention characteristics and control groups. Outcomes specified in inclusion criteria were abstracted.

For test accuracy studies (KQs 2 and 3), we extracted details about each study’s screening test (e.g., device, number of blood pressure measurements, other protocol characteristics); recruitment and inclusion criteria; number of participants approached and analyzed; patient characteristics (i.e., age, sex, race/ethnicity, comorbidities and CVD history, and baseline blood pressure); reference standard details; and diagnostic outcomes (i.e., contingency table, sensitivity, specificity, positive and negative predictive values, and area under the curve). Outcomes from multiple clinically relevant diagnostic thresholds were abstracted if reported. We contacted authors for additional information about protocol characteristics or diagnostic thresholds if information was missing or unclear.

## Data Synthesis and Analysis

### KQs 1 and 4 (Benefits and Harms of Screening)

For KQs 1 and 4, we described results qualitatively because of the small number of included studies.

### KQ2 (Test Accuracy of Initial Screening Using OBPM)

Our primary outcomes of interest were sensitivity, specificity, positive predictive value, and negative predictive value. We synthesized results in summary tables and figures organized by ABPM method and OBPM and ABPM diagnostic threshold. Test performance was either directly extracted from individual study results or calculated using study-reported contingency tables compiled from study-reported data.

For KQ2, our main analysis was a quantitative synthesis of test performance of OBPM using any ABPM modality as the reference standard. We pooled reference standards using 24-hr, daytime, and combinations of 24-hr and daytime ABPM together based on findings from the previous review that the prognostic value of different ABPM time periods to predict CVD events is similar, after adjusting for OBPM.^28^ That finding was also the basis for allowing all ABPM reference standards in our review’s inclusion criteria. When a study reported both 24-h and daytime ABPM as the reference standard, we preferentially included 24-h ABPM in our meta-analysis because this method includes more measures. Studies using nighttime ABPM as a reference standard were eligible, but no study exclusively used this method. We conducted exploratory analyses restricting to studies using a 24-h ABPM reference standard.

In our quantitative pooling, we only included studies that used both SBP and DBP in their definition of hypertension because of relevance to current clinical practice. Studies using thresholds based on SBP alone or DBP alone are discussed separately in the results. While we extracted data from multiple thresholds if reported, we preferentially selected those for pooling that are based on international guidelines,^31,^ ^34,^ ^68,^ ^79^ which include 140/90 mm Hg for OBPM, 135/85 mm Hg for daytime ABPM, and 130/80 for 24-h ABPM. Because there was some variability of thresholds, we established a priori that we would pool thresholds within 0.5 standard deviation of the preferred threshold. We established the standard deviation of blood pressure using results from a large individual patient-data meta-analysis of population-based studies conducting both OBPM and ABPM in untreated populations (Appendix A Table 4).^37^ No studies were excluded from quantitative synthesis on this basis. We acknowledge that the ACC/AHA currently recommends OBPM of 130/80 mm Hg as a threshold to diagnose hypertension.^20^ We planned to include and discuss test accuracy studies using this threshold; however, none were reported in the primary literature for KQ2.

In our quantitative analysis, we included studies measuring OBPM at one visit only. Two studies measuring blood pressure at multiple visits were included in a sensitivity analysis.^80,^ ^81^ KQ2a examines differences in accuracy within studies when multiple protocols are reported. This question was synthesized qualitatively due to a small number of studies and heterogeneity in the types of protocol differences evaluated.

We used a bivariate model for quantitative synthesis, which modeled sensitivity and specificity simultaneously, thus accounting for the correlation between these variables. One study reported insufficient data for this approach and was not included in pooled analyses.^82^ We used visual inspection of forest plots arranged by various study, population, and test characteristics to explore heterogeneity. No discernible patterns were identified. The I^2^ statistic and accepted thresholds (which purposefully overlap) were used to interpret statistical heterogeneity, where 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 to 100 percent shows considerable heterogeneity.^83^

In our Discussion section, we present a hypothetical population of 1,000 individuals to illustrate the flow and clinical consequences of screening using our pooled sensitivity and specificity for initial and confirmatory screening. We additionally estimated how confidence interval upper and lower bounds would alter positive and negative predictive values (PPV and NPV). PPV and NPV were calculated by applying pooled sensitivity and specificity point estimates to the prevalence of hypertension as defined by 24-h ABPM in three age strata from the International Database on Ambulatory blood pressure in relation to Cardiovascular Outcomes (IDACO).^32^ These international prevalence estimates were used because U.S. population-based prevalence estimates of hypertension as defined by ABPM are not available. Additional limitations of U.S. epidemiologic data on the prevalence of hypertension include condition definitions that also include treatment and would thus not reflect a screening-relevant population, and use of self-report instead of measured blood pressure.^84–86^

### KQ3 (Test Accuracy of Confirmatory BP Measurement)

Analyses were stratified by type of confirmatory measure: repeat OBPM, HBPM, “self-OBPM,” AOBP, and kiosk. Data were sufficient for quantitative syntheses for OBPM and HBPM modalities only; other modalities were qualitatively synthesized. Decisions regarding preferred thresholds for OBPM and ABPM are the same as for KQ2. For HBPM, our preferred threshold was ≥135/85 mm Hg, based on its correspondence to the most commonly reported OBPM threshold of 140/90 mm Hg.^20^

We used Stata version 15.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was two-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^87^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^88^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual studies and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall KQ.

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF Web site from June 7, 2018, to July 5, 2018. The USPSTF received comments regarding the selection of outcomes, the importance of addressing the prevalence and prognosis of both masked and white coat hypertension, and the categories of blood pressure identified in the Analytic Framework. In response, the USPSTF added symptomatic peripheral artery disease and vascular dementia as health outcomes and retained end-stage renal disease as the renal outcome. The USPSTF also added a contextual question about the prevalence and prognosis of white coat hypertension. One organization suggested adding more blood-pressure classification categories to the Analytic Framework. The USPSTF kept the dichotomous classifications of “normal” and “elevated blood pressure,” referring to the initial office-based screening step, without limiting included studies to specific thresholds. A draft version of this report was reviewed by five invited experts and two 2 USPSTF Federal Partners. Experts were selected based on their expertise in fundamental methodologic and content aspects of the review (i.e., blood pressure measurement modalities, test accuracy, CVD epidemiology and population health) and were selected to obtain diverse informed perspectives, including those of professional organizations. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Based on reviewer comments, methods and discussion text around AOBP were extended, selected Introduction text was edited for clarity, and additional assumptions and clarifications related to figures were added. Additionally, a draft version of this report was posted for public comment on the USPSTF Web site from May 26, 2020 to June 23, 2020. All comments were reviewed and considered for inclusion. Text was updated or clarified in the introduction section but no changes were made to the results or overall conclusions.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions were made that reflected responses to the public comments. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.