# Chapter 1 Introduction

## Purpose

The Agency for Healthcare Research and Quality (AHRQ) has requested an updated evidence report on screening for hypertension in adults. This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2015 recommendation on this topic.^1^

## Topic Importance

### Natural History

Blood pressure (BP) is the pressure the blood exerts against arterial walls as it circulates through the body. It is generally estimated by measuring systolic and diastolic components. Systolic blood pressure (SBP) is the maximal pressure in blood vessels during systole (heart contraction), and diastolic blood pressure (DBP) is the minimal pressure in blood vessels during diastole (heart relaxation between contractions).^2–6^ BP is measured routinely as a “vital sign.” Primary (or essential or idiopathic) hypertension is defined as high BP in the absence of a known secondary cause and accounts for 95 percent of all cases of hypertension.^7^

Hypertension is one of the most important risk factors for cardiovascular disease (CVD).^8^ Although hypertension is often discussed as though it is a disease entity, it is more appropriately categorized as a continuous risk factor that is a strong predictor of poor health.^9,^ ^10^ The natural history of uncontrolled hypertension is progression to end-organ damage, including the heart, brain, kidneys, eyes and arteries with clinical sequelae including myocardial infarction, stroke, vascular dementia, renal failure, blindness, and peripheral artery disease.^11,^ ^12^ Long term uncontrolled hypertension can eventually lead to arterial and renal damage and eventually contribute to a treatment-resistant state of hypertension.^4^

### Rationale for Screening

Hypertension is generally asymptomatic;^13^ therefore, it is most commonly identified through screening. BP can be modified with lifestyle interventions,^14–16^ and good-quality randomized, controlled trials (RCTs) demonstrate the effectiveness of antihypertensive pharmacological treatments to reduce CVD and total mortality.^17,^ ^18^

## Condition Background

### Definition of Hypertension

The definition of hypertension has changed over time. Until recently, hypertension was most commonly defined as SBP 140 mm Hg or greater and/or DBP 90 mm Hg or greater (hereafter referred to as ≥140/90 mm Hg).^2^ Largely based on the results of the SPRINT trial,^19^ the 2017 AHA/ACC guidelines redefined hypertension for adults as SBP ≥130 mm Hg or DBP ≥80 mm Hg, with treatment thresholds based on both blood pressure and 10-year CVD risk (Table 1).^20^ Based on 2017 to 2018 data, the overall age-adjusted prevalence of hypertension among U.S. adults age 18 years or older was 45.4 percent when defined as BP ≥130/80 mm Hg by conventional measurement or use of antihypertensive medication.^21^

Table 1 Blood Pressure Classifications

JNC7 Blood Pressure Classification^2^ | SBP (mm Hg) | DBP (mm Hg) | ACC/AHA HTN categories^20^,^†^ | SBP (mm Hg) | DBP (mm Hg)
Normal | <120 | and <80 | Normal | <120 | and <80
Prehypertension | 120-139 | or 80-89 | Elevated | 120-129 | and <80
Stage 1 hypertension | 140-159 | or 90-99 | Stage 1 hypertension | 130-139 | or 80-89
Stage 2 hypertension^*^ | ≥160 | or ≥100 | Stage 2 hypertension | ≥140 | ≥90

* Previous definitions of Stage 2 and Stage 3 hypertension have been combined under Stage 2 hypertension

† Individuals with SBP and DBP in 2 categories should be designated to the higher BP category. BP indicates blood pressure (based on an average of ≥2 careful readings obtained on ≥2 occasions, as detailed in Section 4); DBP, diastolic blood pressure; and SBP systolic blood pressure.

Abbreviations: ACC = American College of Cardiology; AHA = American Heart Association; DBP = diastolic blood pressure; HTN = hypertension; JNC 7 = Seventh report of the Joint National Committee on Prevention on Detection, Evaluation, and Treatment of High Blood Pressure; mm Hg = millimeters of Mercury; SBP = systolic blood pressure

BP control rates remain low despite substantial improvements since the 1970s in the awareness and treatment of hypertension.^2^ In 2017-2018, only 44.6 percent of men and 43.9 percent of women with hypertension and had their BP controlled to ≤140/90 mm Hg.^22^ Disparities exist for the control of hypertension by race/ethnicity, as well as socioeconomic factors. The highest rates of BP control are among whites (45.2%) with the lowest control rates among Hispanics (36.8%). Control rates are higher among college graduates (47.1%), those with greater income (48.9% with annual household income ≥75,000), and health insurance. The BP control rate among those with no health insurance is exceedingly low at 22.2 percent.^22^

Robust data from both prospective cohort studies and contemporary clinical databases show a strong continuous relationship between blood pressure and cardiovascular disease spanning a wide range of blood pressures.^23,^ ^24^ A 2019 analysis of over 1.3 million adults in the United States using BP measurements obtained during routine clinical practice showed that both systolic and diastolic hypertension independently predict adverse outcomes, and that this relationship is not altered by choice of hypertension threshold (≥140/90 mm Hg vs. ≥130/80 mm Hg).^24^ In the absence of a clear threshold, hypertension may be defined pragmatically as the level of BP at which there is either experimental or epidemiological evidence that therapeutic interventions reduce cardiovascular (CV) event rates.^25^ On the other hand, since foundational evidence suggests no threshold effect and a continuous association between blood pressure and mortality down to 115/75 mm Hg, it could be argued that the definition could be based on the threshold at which this prognostic mortality association exists.^23^

### Etiology and Risk Factors

The pathogenesis of primary hypertension is multifactorial and imprecisely understood. A number of risk factors for hypertension have been identified, including: age, African American race, family history of hypertension and genetic factors, excess weight and obesity, lifestyle habits (including lack of physical activity, stress, and tobacco use), and dietary factors (including dietary fats, higher sodium intake, lower potassium intake, and excessive alcohol intake).^26^ Hypertension commonly coexists with other CVD risk factors, such as diabetes, dyslipidemia, and obesity. Table 2 shows the odds ratios for prevalent hypertension for selected demographic and clinical characteristics.

Table 2 Risk of Hypertension by Selected Demographic and Clinical Characteristics, NHANES 1999-2012^217^

Demographic or Clinical Characteristic | Odds Ratio (95% CI) for Prevalent Hypertension
Age <45 vs ≥65 | 0.08 (0.07–0.10)
Age 45-64 vs ≥65 | 0.35 (0.32–0.39)
Black vs white | 1.86 (1.64–2.12)
Hispanic vs white | 0.87 (0.74–1.03)
Male vs female | 1.10 (1.01–1.22)
Diabetes vs no diabetes | 1.58 (1.38–1.79)
Increase of BMI by 5 kg/m^2^ | 1.44 (1.38–1.49)
Smoker vs nonsmoker | 0.96 (0.85–1.08)
Treated vs untreated for cholesterol | 2.29 (2.00–2.63)

Abbreviations: CI = confidence interval; kg/m^2^ = kilogram per square meter; NHANES = National Health and Nutrition Examination Survey; vs = versus

As shown in Table 3, the prevalence of high BP is age-dependent. BP increases progressively with age^21^ and hypertension develops in a high proportion of adults in the United States living into their 80s or 90s.^27^ In a younger population, hypertension can develop over a relatively short period when BP is near the threshold for defining hypertension.^28^ According to a recent analysis of 2017-2018 NHANES data, the overall prevalence of high BP was greater among men (51.0%) than women (39.7%), and disparities were also seen among different races and ethnicities.^21^ High BP was significantly more common in black adults (51.7%) than in whites (43.6%), and Hispanics (43.7%).^21^ Data for BP were limited for Asians and Native Americans and Alaska Natives in the 2017-2018 survey period, but previous estimates from 2015-2016 NHANES survey data, which used a threshold of ≥140/90, reported that Asians had the lowest prevalence of high BP among any racial or ethnic group (25%).^29^ The prevalence of high BP as defined by ambulatory blood pressure monitoring (ABPM)—the currently accepted reference standard—is unknown in the United States for the general population.

Table 3 Prevalence of Hypertension (≥130/80 mm Hg or Taking Anti-Hypertensive Medication) Among Adults Aged 18 Years and Older in the United States, 2017-2018^21^

Demographic | Characteristic | Men, % | Women, %
Overall | All individuals | 51.0 | 39.7
Age (years) | 18-39 | 31.2 | 13.0
Age (years) | 40-59 | 59.4 | 49.9
Age (years) | ≥60 | 75.2 | 73.9
Race | Non-Hispanic White | 50.2 | 36.7
Race | Non-Hispanic Black | 57.2 | 56.7
Race | Hispanic | 50.1 | 36.8
Race | Asian | NR | NR
Race | American Indian/Alaska Native | NR | NR

Since 1999, BP in NHANES has been measured in a mobile examination center by a physician by taking 3 consecutive blood pressure readings in the same arm which are then averaged.

Abbreviations: BP = blood pressure; mm Hg = millimeters of mercury; NHANES = National Health and Nutrition Examination Survey; NR = not reported

## Blood Pressure Measurement

### Office-Based Blood Pressure Measurement

Office-based measurement of BP is the standard of care for initial screening. Measurement methods include the manual auscultatory method using a stethoscope to detect Korotkoff sounds or the oscillometric method where a pressure transducer assesses the oscillations of the pressure in a cuff during gradual inflation or deflation. The diagnosis of hypertension typically involves a confirmatory measurement of an initial elevated office BP measurement.

During office-based measurement, measurement accuracy depends on a considerable number of patient-related, device-related, protocol-related, or observer-related factors.^30^ Additionally, BP can increase substantially in the medical setting and in the presence of medical personnel.^30^ “White coat hypertension” refers to BP of untreated individuals that is in the hypertensive range when measured in the clinic setting but not in that range when measured out of office.^31^ Estimates from population-based samples of adults not treated for hypertension suggest that the prevalence of white coat hypertension is 7.9 percent when defined by 24-h ABPM.^32^ In untreated populations with previous office BP elevation, the prevalence of white coat hypertension may be considerably higher (22.6% in an international registry of hypertension clinics).^33^ One proposed approach is the use of automated office BP (AOBP) during which repeated measurements are taken while the patient is alone in a quiet room.^34–36^

The reverse phenomenon of white coat hypertension, sometimes called “masked hypertension,” occurs in individuals whose BP levels are apparently nonhypertensive when measured at clinic visits but are elevated when measured outside of the medical setting.^6^ Masked hypertension has clinical significance as it has been associated with increased CV risk.^37,^ ^38^ A 2017 analysis has estimated the prevalence of masked hypertension in the U.S. at 12.3 percent of the adult population, or over 17 million adults.^39^ Masked hypertension is an important public health issue as it represents the failure to identify individuals with increased CVD risk.

### Out-of-Office Measurements for Screening Confirmation

To confirm a diagnosis of hypertension, many health systems recommend several office-based blood pressure measurements performed on different days among patients with an initial elevated blood pressure. Repeat office measurements tend to be lower than initial measurements, but are subject to the same patient-related, device-related, protocol-related, and observer-related limitations as the initial measurement.^30^ Office-based confirmation also does not capture BP variations throughout the day or during the course of a person’s normal activities. Major guideline bodies and health systems are increasingly recommending the use of AOBP or out-of-office measurement to overcome some of the limitations of conventional OBPM (Table 4).

Table 4 Recommendations of Others for Screening and Confirmation of a Hypertension Diagnosis

Organization, | Frequency | Initial Screening | Confirmation
2017 American College of Cardiology/ American Heart Association (ACC/AHA) Guideline for the Prevention, Detection, Evaluation and Management of High Blood Pressure and Adults^20^ | In adults with white coat HTN, annual monitoring with either ABPM or HBPM is reasonable to detect transition to sustained hypertension | Proper methods are recommended for accurate measurement and documentation of BP in the office, including: having the patients sit in a chair with feet on the floor and back supported for >5 mins ; no caffeine, exercise, or smoking for at least 30 minutes before measurement; ensure patient has emptied bladder; no talking during the rest period or measurement; remove all clothing in location of cuff placement; using a validated and calibrated device; supporting the patient’s arm; positioning cuff at the midpoint of the sternum; using the correct size cuff; record BP in both arms during first visit, using the arm with the higher reading for subsequent readings; separate repeated measurements by 1-2 minutes; use proper deflation speed for auscultatory readings; properly document the readings; average at least 2 readings obtained on at least 2 occasions to estimate BP; and provide patient SBP and DBP both verbally and in writing | Out-of-office BP measurements are recommended to confirm the diagnosis of hypertension; In adults with an untreated SBP 130-160 mm Hg or DBP 80-100 mm Hg it is reasonable to screen for the presence of white coat hypertension by using either daytime ABPM or HBPM before diagnosis of hypertension; In adults with untreated office BPs that are consistently between 120-129 mm Hg SBP or between 75-79 mm Hg DBP, screening for masked hypertension with daytime ABPM or HBPM is reasonable
VA/DoD, 2020^218^ | Periodic (not further specified) | Use attended or unattended, fully automated office blood pressure measurement (programmed to wait five minutes and record the average of three measurements separated by at least 30 seconds). When fully automated blood pressure measurement is not available, measure blood pressure using a standard technique and a properly calibrated and validated sphygmomanometer. | If BP is ≥130/80 mm Hg, measure again after 1-4 weeks; Use out-of-office blood pressure monitoring methods (ambulatory 24-hour monitoring or home blood pressure measurements) to inform the diagnosis and management of hypertension in select patients (masked HTN should be suspected in individuals with normal or controlled OBPM if they report higher HBPM, and in the presence of target organ damage and certain chronic conditions such as CKD)
2019 National Institute for Health and Clinical Excellence^68,*^ | Recheck every 5 years for adults with normal BP and consider rechecking more frequently for adults with BP close to 140/90 mm Hg; Measure BP at least annually in adults with DM without previously diagnosed HTN or renal disease | Ensure that healthcare professionals taking blood pressure measurements have adequate initial training and periodic review of their performance. Because automated devices may not measure BP accurately if there is pulse irregularity (for example, due to atrial fibrillation), palpate the radial or brachial pulse before measuring BP. If pulse irregularity is present, measure blood pressure manually using direct auscultation over the brachial artery. Healthcare providers must ensure that devices for measuring BP are properly validated, maintained and regularly recalibrated according to manufacturers’ instructions.; When measuring blood pressure in the clinic or in the home, standardize the environment and provide a relaxed, temperate setting, with the person quiet and seated, and their arm outstretched and supported. Use an appropriate cuff size for the person’s arm.; When considering a diagnosis of hypertension, measure BP in both arms. If the difference in readings between arms is >15 mm Hg, repeat the measurements. If the difference in readings between arms remains >15 mm Hg on the second measurement, measure subsequent BPs in the arm with the higher reading.; If blood pressure measured in the clinic is ≥140/90 mm Hg, take a second measurement. If the second measurement is substantially different from the first, take a third measurement. Record the lower of the last two measurements as the clinic blood pressure | If the clinic blood pressure is between 140/90 and180/110 mm Hg, offer ABPM to confirm the diagnosis of hypertension (use average of ≥14 measurement taken during the person’s usual waking hours). ABPM diagnostic threshold: ≥135/85 (daytime); If a person is unable to tolerate ABPM, HBPM is a suitable alternative to confirm the diagnosis of hypertension (twice in morning and evening for at least 4 days, ideally 7 days and discard first day measurements to obtain average value). HBPM diagnostic threshold: ≥135/85; If the person has severe hypertension and target organ damage is identified, consider starting antihypertensive drug treatment immediately, without waiting for the results of ABPM or HBPM. If no target organ damage is identified, repeat clinic blood pressure measurement within 7 days.
Hypertension Canada (formerly the Canadian Hypertension Education Program [CHEP])^195^ | At all appropriate visits, which is left to the discretion of each practitioner | Measurement should be taken by health care professionals who have been specifically trained to measure blood pressure accurately using standardized measurement techniques and validated equipment for all methods.; AOBP is the preferred method of performing in-office measurement. When using AOBP, a displayed mean SBP ≥135 or DBP ≥85 mm Hg is considered high. When using non-AOBP, a mean SBP ≥140 or DBP ≥90 mm Hg is considered high. SBP between 130-139 and DBP 85-89 is considered high-normal. If non-AOBP used, at least 3 readings should be taken, and the mean calculated after discarding the first measurement. | Diagnosis should be confirmed by performing out-of-office measurement, if possible. ABPM is the recommended measurement method; HBPM is recommended if ABPM is not tolerated, not readily available, or because of patient preference.; Using ABPM, patients can be diagnosed as hypertensive if mean awake SBP is ≥135 or DBP is ≥85 mm Hg or if the mean 24-hr SBP is ≥130 mm Hg or DBP ≥80 mm Hg; Using HBPM, patients can be diagnosed as hypertensive if mean awake SBP is ≥135 or DBP is ≥85 mm Hg. Duplicate measurement should be done in the morning and evening for 7 days, and results should be averaged after excluding the first day’s readings. If OBPM is high and mean HBPM is <135/85 mm Hg, either repeat HBPM to confirm that HBPM is <135/85 mm Hg or perform 24-hr ABPM to confirm that mean 24-hr ABPM is <130/80 and mean awake ABPM is <135/95 before diagnosing white coat hypertension. If white coat hypertension is diagnosed, annual BP measurement is recommended to monitor progression.; Serial office measurements over 3-5 visits can be used if ABPM or HBPM is not available.
2018 European Society of Hypertension/European Society of Cardiology Guidelines for the Management of Arterial Hypertension^79^ | Screening programs for HTN are recommended and all adults should have their office BP measured and recorded in their medical file and be aware of their BP.; Rescreen BP every 5 years if BP remains optimal, rescreen every 3 years if BP remains normal, and rescreen at least annually if BP is high-normal. Consider screening more frequently in patients >50 years. | Auscultatory or oscillometric semiautomatic or automatic sphygmomanometers are the preferred method for measure BP in the doctor’s office. BP measurement devices should be validated according to standard protocols. The following techniques should be used: allow patient to sit in a quiet environment for 5 minutes before beginning BP measurements; take at least three BP measurements, in the sitting position, spaced 1–2 min apart, and additional measurements if the first two differ by >10 mm Hg and consider the average of the last two BP readings; use a standard bladder (12–13 cm wide and 35 cm long), but have a larger and a smaller bladder available for large (arm circumference >32 cm) and thin arms, respectively; have the cuff at the heart level, whatever the position of the patient; measure BP in both arms at first visit to detect possible differences. | The diagnosis of hypertension (mean ≥140/90 mm Hg) should be based on repeated office BP measurements on more than one visit, except when HTN is severe, or out-of-office BP measurement with ABPM and/or HBPM provided that these measurements are logistically and economically feasible.; Out-of-office BP is specifically recommended for a number of clinical indications, including identifying white-coast and masked hypertension.; Diagnostic threshold for HBPM is ≥135/85 mm Hg. For diagnostic evaluation BP, HBPM should be measured daily on at least 3 days and preferably on 6-7 consecutive days; in the mornings as well as in the evenings. BP should be measured in a quiet room, with the patient in the seated position, back and arm supported, after 5 min of rest and with two measurements per occasion taken 1–2 min apart. Home BP is the average of these readings.; Diagnostic threshold for daytime or awake ABPM is mean ≥135/85 mm Hg, mean ≥120/70 mm Hg for nighttime or asleep ABPM, or ≥130/80 mm Hg for 24-hr ABPM. 70% usable BP recordings are required for a valid ABPM measurement session.
American Academy of Family Physicians (AAFP), 2015^219^ | Not specified | Screen for high blood pressure in adults aged 18 years or older. No additional details provided, but a link is provided to the USPSTF recommendation with an endorsement. | Obtain measurements outside of the clinical setting for diagnostic confirmation before starting treatment. No additional details provided, but a link is provided to the USPSTF recommendation.
Joint National Committee on Prevention, Detection, Evaluation and Treatment of Blood Pressure (JNC 7),^†^ 2004^2^ | Recheck in 2 years for adults with normal BP; recheck in 1 year for adults with high-normal BP | Measurements should be made by an operator who is trained and regularly retrained in the standardized technique, and the patient must be properly prepared and positioned. Persons should be seated quietly for at least 5 minutes in a chair, with feet on the floor, and arm supported at heart level. Caffeine, exercise, and smoking should be avoided for at least 30 minutes prior to measurement. An appropriately sized cuff (cuff bladder encircling at least 80 percent of the arm) should be used to ensure accuracy. At least two measurements should be made and the average recorded. | Stage 1 hypertension diagnosis (140-159/90-99 mm Hg) should be confirmed within 2 months after initial elevated OBPM; the measurement method for confirmation is not specified; Stage 2 hypertension (≥160/≥100 mm Hg) should be confirmed within 1 month; those with ≥180/110 mm Hg evaluate and treat immediately.; Indications for the use of ABPM are: suspected white-coat hypertension in patients with hypertension and no target organ damage, apparent drug resistance, hypotensive symptoms with antihypertensive medication, episodic hypertension or autonomic dysfunction. The ABPM diagnostic threshold is mean ≥135/85 mm Hg (awake) or mean ≥120/75 mm Hg (sleep).; HBPM can be used prior to consideration of ABPM. For those whose out-of-office BPs are consistently <130/80 mm Hg despite an elevated office BP, and who lack evidence of target organ disease, ABPM or drug therapy can be avoided. A protocol for HBPM is not reported.

* Update currently in progress with expected publication August 2019; the update will include the following systematically reviewed question on confirmation: In adults with suspected primary hypertension, what is the best method of measuring blood pressure (HBPM, ABOM, or OBPM) to establish the diagnosis and predict cardiovascular events?

† The JNC 8 Panel did not address diagnosis of hypertension in its 2014 guidelines. The Supplement to the guidelines includes additional content not supported by a systematic review but that is intended to aid in implementing the main guidelines. In the Supplement the JNC 8 Panel recommends averaging 2-3 measurements at each visit to establish a diagnosis of hypertension. Definitions of hypertension were not addressed but thresholds for pharmacologic treatment were defined. HBPM and ABPM were not addressed^220^

Abbreviations: AAFP = American Academy of Family Physicians; ABPM = ambulatory blood pressure measurement; ACC = American College of Cardiology; ACP = American College of Physicians; AHA = American Heart Association; AOBP = automated office blood pressure; BP = blood pressure; CHEP = Canadian Hypertension Education Program; HBPM = home blood pressure monitoring; JNC = Joint National Committee on Prevention, Detection, Evaluation and Treatment of Blood Pressure; mm Hg = millimeters of mercury; NR = not reported; OBPM = office blood pressure measurement; USPSTF = United States Preventive Services Task Force

Out-of-office methods for confirmation of hypertension include ambulatory BP monitoring (ABPM) and home BP monitoring (HBPM). Kiosk-based blood pressure measurements are another out-of-office measurement modality used for self-directed BP measurements in settings such as pharmacies, although concerns have been raised about the validity of these devices^40^ (Table 5). ABPM is considered the gold standard noninvasive blood pressure measurement, providing the best predictive value for future CVD events.^28,^ ^41^ ABPM devices are small portable machines connected to an upper arm cuff that record BP at regular intervals over 12 to 48 hours while patients go about their normal activities, including sleep. Measurements are typically taken at 20- to 30-minute intervals during the daytime period.^5^ Substantial variation exists in the level of specificity among guidelines for the protocols that should be used for ABPM and HBPM (Table 4). Screening intervals are increasingly addressed by guidelines, with a focus on risk-based screening intervals or rescreening of individuals with white coat hypertension. In addition to formal guidelines, national organizations have published policy and scientific statements regarding blood pressure measurement protocols and techniques.^31,^ ^42^

Table 5 Blood Pressure Measurement Modalities

Method | Brief Description
OBPM | Office based BP measurement (OBPM) can be performed using the manual auscultatory^*^ method or with an oscillometric^†^ sphygmomanometer.
AOBP | Automated office BP (AOBP) is a specific type of OBPM where multiple pre-programmed measurements, usually spaced one minute apart over 4-7 minutes, are taken while the patient is in a quiet room; may be attended or unattended.
HBPM | Home blood pressure measurement (HBPM) is when an individual uses an automated oscillometric device to measure BP while seated and resting at home; measurements are taken at one or more times per day over days to weeks, but protocols vary.
ABPM | Ambulatory blood pressure measurement (ABPM) is the use of a preprogrammed device typically worn by patient for 12 or 24 hours during their normal activities (including sleep) in and outside of the home; automated to take BPs at 20-30 minute intervals.
Kiosk | A kiosk is a station where BP is automatically assessed by a device that is triggered by the individual having their BP measured; kiosks are designed to operate without the assistance of medical staff and are often located in pharmacies or other public or private settings.

* The manual auscultatory method involves a trained observer using a stethoscope to detect Korotkoff sounds, which are made by the turbulent flow of blood past the restricted area created by the inflated cuff. The readings are made using a mercury or aneroid sphygmomanometer at the brachial artery.

† Oscillometric sphygmomanometers use a pressure transducer to assess the oscillations of pressure in a cuff during gradual deflation. The point of maximum oscillation corresponds to the mean intra-arterial pressure. Systolic and diastolic measurements are then calculated based on an empirically derived algorithm.

Some concerns exist about the calibration and validation of measurement devices. Device manufacturers typically recommend regular calibration of oscillometric devices, including ABPM.^31^ However, experts note that calibration rarely occurs; if at all, calibration may occur only at large academic medical centers with access to clinical engineering support.^43,^ ^44^ Standardized protocols are not in place for calibration of HBPM devices once they have left the manufacturer.^31^ In addition, systematic reviews have found that BP devices frequently have not passed validation protocols, or have passed with protocol violations.^45,^ ^46^ The American Medical Association has developed a Validated Device Listing to help patients and providers easily identify validated BP measurement devices (https://www.validatebp.org/).^43^

## Previous USPSTF Recommendation and Current Clinical Practice

### 2015 USPSTF Recommendation

In 2015, the USPSTF recommended screening for high blood pressure in adults age 18 years or older and procurement of measurements outside of the clinical setting for diagnostic confirmation before starting treatment.^1^ This was an A recommendation, and the measurement accuracy and modality components were new to the 2015 consideration of this topic. The USPSTF found that elevated 24-hr ambulatory systolic blood pressure was consistently and significantly associated with stroke and other cardiovascular outcomes, independent of office blood pressure and with greater predictive value. Because of its large evidence base, ABPM was considered the best confirmatory test for hypertension. The USPSTF stated that HBPM may also be a reasonable confirmatory method but had less evidence to support its use.

### Current Clinical Practice in the United States

Blood pressure measurement techniques in current clinical practice vary substantially from guideline-endorsed protocols. According to the 2016 National Ambulatory Medical Care Survey, BP was measured in 65.9 percent of clinic visits by patients age 18 years or older in the United States.^47^ However, these measurements are often not taken in accordance with defined measurement protocols.^48–51^ Several studies have found that when routine office measurements are repeated using recommended protocols, there are significant differences in BP values.^52,^ ^53^ The reasons for not following recommended BP measurement guidelines in the office are likely multifactorial and may include lack of information, training, and time.

Despite national guidelines recommending out-of-office confirmatory methods, survey data suggest that this is not common in current practice, with surveys showing that out-of-office measures are rarely ordered or available to clinicians.^49,^ ^51^ Physicians have described a number of barriers to ABPM, including challenges in accessing testing, costs of testing, concerns about patient willingness to complete ABPM, and concerns about accuracy and benefit of ABPM.^54^ Physician concerns regarding HBPM include: patient compliance with protocols, accuracy of HBPM, out-of-pocket cost, and time to instruct patients on HBPM protocols.^54^

The Centers for Medicare & Medicaid Services (CMS) has covered ABPM since 2001 for patients with suspected white coat hypertension.^55^ Research has shown, however, that utilization of the coverage was exceedingly low, with an estimated 0.1 percent of Medicare beneficiaries having ABPM claims between 2007 and 2010, with some hypothesizing that the reimbursement rate may be too low to encourage its use.^56,^ ^57^ In July 2019, CMS expanded coverage of ABPM to once per year in eligible beneficiaries with suspected masked hypertension, defined as those with average OBPM between 120 mm Hg and 129 mm Hg for SBP or between 75 mm Hg and 79 mm Hg for DBP on two separate office visits, with at least two separate measurements made at each visit, and with at least two measurements taken outside the office that are ≥130/80 mm Hg.^58^ This coverage decision is consistent with ACC/AHA guidelines and the AHA Scientific Statement for screening for masked hypertension.^20,^ ^31^