# Appendix G Ongoing Studies

Appendix G Table 1 Ongoing or Recently Completed Studies

Study reference/ trial identifier; Principal Investigator | Official title | Location | Estimated N | Study objective | Relevant Outcomes | 2021 status (Jan 2021)
NCT03267420; Marcel Ruzicka | Blood Pressure Measurement: Should Technique Define Targets? | Canada | 90 | To compare 4 different methods of measuring blood pressure in the office (casual, resting average of 3 readings with nurse present or absent for resting period, and average of 5 readings) as well as a 24-hour ambulatory measurement. | Difference in avg SBP between BP protocols | Unknown; Est completion date: Jun 2019; no results published
NCT03130257; Beverly Green | Blood Pressure Checks for Diagnosing Hypertension (BP-CHECK) | US | 510 | To compare the accuracy and acceptability (i.e., comfort, convenience) of clinic, home, and kiosk BP testing to 24-hour BP ambulatory monitoring. | Comparative acceptability of clinic, home, kiosk, and 24-hour blood pressure diagnostic testing; Pt reported QoL | Completed; Completion date: Aug 2019; no results published; Protocol (https://pubmed.ncbi.nlm.nih.gov/30634036/) published 2019
NCT03147573; Luis González de Paz | Validity of 1BPM for Diagnosis of Hypertension | Spain | 214 | To compare 1-hour ABPM, OBPM, and HBPM to daytime ABPM for the confirmation of hypertension diagnosis. | Accuracy of confirmation modalities compared to daytime ABPM | Completed; Completion date: Sep 2019; No results published; Protocol (https://pubmed.ncbi.nlm.nih.gov/31133597/) published 2019
NCT03732924; Sheldon Tobe | Zero to Five Automated Oscillometric Office Blood Pressure (AOBP) Measurement | Canada | 600 | To compare the difference between the daytime ABPM and AOBP with zero or five minutes wait time. | Difference in SBP and DBP between groups; Difference in SBP and DBP between AOBP and daytime ABPM | Completed; Completion date: Jul 2020; no results published
NCT03774147; Claire Zabawa | 24-hr Ambulatory Blood Pressure Monitoring in Patients With Blood Pressure Above Thresholds in General Practice (MAPAGE) | France | 1067 | To analyze the feasibility and benefits of ABPM among primary care hypertensive patients in daily practice | Prevalence of WCH | Unknown; Est completion date: Dec 2019
NCT03480217; Ian Kronish | Implementing Hypertension Screening Guidelines in Primary Care | US | 2000 | Use cluster-randomized design among 8 primary care clinics to test the effectiveness of a theory-informed multifaceted implementation strategy designed to increase the uptake of the 2015 United States Preventive Services Task Force (USPSTF) hypertension screening guidelines | Change in ordering of out-of-office blood pressure testing | Recruiting; Est completion date: Apr 2021; Protocol (https://pubmed.ncbi.nlm.nih.gov/32771002/) published 2020
NCT03866226; XiaoHong PAN | The Effect of ABPM on Sleep Disturbance (EMBED) | China | 450 | To examine whether ABPM affects sleep, as well as the relationship and influencing factors of sleep and ABPM results, and screening for people who are susceptible to ABPM testing | Sleep questionnaire score | Active, not recruiting; Est completion date: Dec 2021
NCT03855605; Moo-Yong Rhee | Diagnosis of Hypertension by Home Blood Pressure Monitoring | S Korea | 500 | To validate the diagnostic algorithm of HTN by using 24-hour ambulatory blood pressure and home blood pressure measurement | Validation of the diagnostic algorithm of HTN | Recruiting; Est completion date: Dec 2020
NCT02804074; Gianfranco Parati | MASked-unconTrolled hypERtension Management Based on Office BP or on Out-of-office (Ambulatory) BP Measurement (MASTER) | Italy | 1240 | To investigate whether a management strategy based on out-of-office BP (Ambulatory BP monitoring) versus a management strategy based on office BP measurements is associated with differences in outcome | Percentage of participants w masked HTN; Tx of masked HTN | Recruiting; Est completion date: Jan 2023; Protocol (https://pubmed.ncbi.nlm.nih.gov/30573476/) published 2018
ISRCTN13127656; Colin McAlister | HYVET 2: treatment of white coat hypertension in the very elderly | UK | 100 | To assess the cardiovascular outcomes following treatment of white coat hypertension with established anti-hypertensive drugs versus standard of care in the very elderly - feasibility study | Tx of WCH | Stopped; No longer recruiting; Est completion date: Apr 2021
NCT02142881; Paul E Drawz | Treatment of Masked Hypertension | US | 4 | To evaluate whether antihypertensive treatment can modify BP patterns in patients with masked hypertension | Percentage of participants w masked HTN; Tx of masked HTN | Completed; Completion date: Dec 2017; No results published
NCT02893358; Yan Li | Antihypertensive Treatment in Masked Hypertension for Target Organ Protection (ANTI-MASK) | China | 300 | To estimate the target organ protection after 12 months of antihypertensive treatment in masked hypertension patients with at least one kind of target organ damage | Percentage of participants w masked HTN; Tx of masked HTN | Recruiting; Est completion date: Dec 2021

Abbreviations: ABPM = ambulatory blood pressure monitoring; avg = average; BP = blood pressure; DBP = diastolic blood pressure; Est = estimated; HTN = hypertension; SBP = systolic blood pressure; Tx = treatment; WCH = white coat hypertension