# Appendix F Additional Figures

Appendix F Figure 1 Key Question 2 Exploratory Analysis: Test Accuracy of Office Blood Pressure Monitoring at a Threshold of ≥140/90 mm Hg to Identify Hypertension Detected by 24-hr Ambulatory Blood Pressure Monitoring, by Author

NOTE: I^2^ for sensitivity=98.2%, I^2^ for specificity=96.9%

Appendix F Figure 1 is a forest plot of an exploratory analysis for Key Question 2 that shows the test accuracy of office blood pressure monitoring at a threshold of ≥140/90 mm Hg to identify hypertension detected by 24-hr ambulatory blood pressure monitoring, by author. The overall pooled sensitivity is 0.72 (95% CI, 0.58, 0.84) and the pooled specificity is 0.83 (95% CI, 0.78, 0.88)

Appendix F Figure 2 Key Question 3 Exploratory Analysis: Test Accuracy of Confirmatory Office Blood Pressure Monitoring at a Threshold of ≥140/90 mm Hg to Identify Hypertension Detected by 24-hr Ambulatory Blood Pressure Monitoring, by Author

NOTE: I^2^ for sensitivity=99.6%, I^2^ for specificity=99.4%

Appendix F Figure 2 is a forest plot of an exploratory analysis for Key Question 3 that shows the test accuracy of confirmatory office blood pressure monitoring at a threshold of ≥140/90 mm Hg to identify hypertension detected by 24-hr ambulatory blood pressure monitoring, by author. The overall pooled sensitivity is 0.74 (95% CI, 0.50, 0.89) and the pooled specificity is 0.62 (95% CI, 0.42, 0.79)