# Appendix E Additional Evidence Tables

Appendix E Table 1 Study Characteristics of Included Studies for KQ 1

Appendix E Table 2 Baseline Population Characteristics of Included Studies for KQ 1

Appendix E Table 3 Inclusion and Exclusion Criteria of Included Studies for KQ 2, by Author

Appendix E Table 4 Protocol Variations and Conclusions of Included Studies for KQ2a, by Author

Appendix E Table 5 Inclusion and Exclusion Criteria of Included Studies for KQ 3, by Author

Appendix E Table 6 Protocol Variations and Conclusions of Included Studies for KQ 3a, by Category

Appendix E Table 7 QoL/Psychiatric Distress Results of Included Studies for KQ 4, by Author

Appendix E Table 8 Absenteeism Results of Included Studies for KQ 4, by Author

Appendix E Table 9 Tolerability/Sleep Results of Included Studies for KQ 4, by Author