# Appendix D Excluded Studies

Reasons for Exclusion

Exclusion Code | Definition
E1 | Wrong study aim/relevance
E2 | Wrong setting
E3 | Wrong comparator (for KQ2 and 3, ABPM was not the gold standard; or within-class comparisons such as OMRON device A vs OMRON device B)
E4 | No relevant outcomes
E4a | Not enough data to complete 2x2 table (KQ2) or 1x2 table (KQ3)
E4b | Reporting of concordance (kappa) without sens/spec/PPV/NPV
E4c | Sleep disturbance measure with no comparator not related to the ABPM device
E5 | Population
E5a | >20% of excluded populations and data not stratified
E5b | >20% treated hypertensives
E6 | Wrong intervention (e.g., wrist or finger monitors)
E7 | Wrong study design
E8 | Non-English
E9 | Non-Very High HDI Country
E9a | Conducted in Brazil
E10 | Poor study quality
E11 | Ongoing study, no outcomes published
E11a | Abstract Only
E12 | Unable to locate publication
E13 | IPD-MA or registry where there are overlapping populations already included
E14 | Article retracted

1 Design of the Women’s Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19:61–109. KQ2E1, KQ3E1, KQ4E1.9492970
2 Ambulatory blood pressure monitoring for diagnosing hypertension in patients with elevated office blood pressure. Tecnologica MAP Supplement. 1999:1–3. KQ2E7, KQ3E7, KQ4E7.10848161
3 “Masked” and “white-coat” hypertension could signal more serious complications. Experiencing temporary spikes in blood pressure may put you at greater risk of cardiac events. Heart Advisor. 2009;12(11):6. KQ2E7, KQ3E7, KQ4E7.
4 Measuring blood pressure: two arms are better than one. Johns Hopkins Medical Letter, Health After 50. 2012;24(3):6. PMID: 22649825. KQ2E7, KQ3E7, KQ4E7.22649825
5 Abir-Khalil S, Zaimi S, Tazi MA, . Prevalence and predictors of white-coat hypertension in a large database of ambulatory blood pressure monitoring. Eastern Mediterranean Health Journal. 2009;15(2):400–7. KQ2E9, KQ3E9, KQ4E9.19554987
6 Adiyaman A, Tosun N, Elving LD, . The effect of crossing legs on blood pressure. Blood pressure monitoring. 2007;12(3):189–93. PMID: 17496470. 10.1097/MBP.0b013e3280b083a7 KQ2E5b, KQ3E5b, KQ4E4.17496470
7 Agarwal R, Weir MR. Treated hypertension and the white coat phenomenon: Office readings are inadequate measures of efficacy. Journal of the American Society of Hypertension. 2013;7(3):236–43. 10.1016/j.jash.2013.02.005 KQ2E5, KQ3E5, KQ4E4.23523137
8 Aihara A, Imai Y, Sekino M, . Discrepancy between screening blood pressure and ambulatory blood pressure: a community-based study in Ohasama. Hypertension research. 1998;21(2):127–36. KQ2E4a, KQ3E5, KQ4E4.9661809
9 Akilli H, Kayrak M, Aribas A, . The relationship between exercise capacity and masked hypertension in sedentary patients with diabetes mellitus. Clin Exp Hypertens. 2013;36(1):9–16. 10.3109/10641963.2013.783047 KQ2E9, KQ3E9, KQ4E9.23734826
10 Al-Hashmi K, Al-Busaidi N, Amina B, . White coat hypertension and masked hypertension among omani patients attending a tertiary hospital for ambulatory blood pressure monitoring. Oman Med J. 2015;30(2):90–4. 10.5001/omj.2015.20 KQ2E5b, KQ3E5b, KQ4E4.25960832
11 Al-Husainy S, Farmer J, Gibson JM, . Is measurement of blood pressure worthwhile in the diabetic eye clinic? Eye. 2005;19(3):312–6. KQ2E4a, KQ3E5, KQ4E4.15272291
12 Al-Turki KA, Al-Baghli NA, Al-Ghamdi AJ, . Hypertension in the eastern province of saudi arabia: results of a screening campaign. Journal of Family and Community Medicine. 2008;15(3):95–101. KQ2E3, KQ3E3, KQ4E4.23012174
13 Ali F, Tacey M, Lykopandis N, . Microvascular narrowing and BP monitoring: A single centre observational study. PLoS ONE [Electronic Resource]. 2019;14(3):e0210625. PMID: 30870422. 10.1371/journal.pone.0210625 KQ2E5, KQ3E5b, KQ4E4.30870422
14 Almeida AE, Stein R, Gus M, . Relevance to Home Blood Pressure Monitoring Protocol of Blood Pressure Measurements Taken Before First- Morning Micturition and in the Afternoon. Arq Bras Cardiol. 2014;103(4):338–47. PMID: 25352508. 10.5935/abc.20140139 KQ2E5, KQ3E9a, KQ4E4.25352508
15 Alpert BS. Are kiosk blood pressure readings trustworthy? Blood pressure monitoring. 2012;17(6):257–8. PMID: 23147536. KQ2E7, KQ3E7, KQ4E7.23147536
16 Altintas E, Takoh K, Ohno Y, . Wearable and low-stress ambulatory blood pressure monitoring technology for hypertension diagnosis. Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2015;2015:4962–5. 10.1109/EMBC.2015.7319505 KQ2E4, KQ3E4, KQ4E4.26737405
17 AlWabel AH, Almufadhi MA, Alayed FM, . Assessment of hypertension and its associated risk factors among medical students in Qassim University. Saudi Journal of Kidney Diseases & Transplantation. 2018;29(5):1100–8. PMID: 30381506. 10.4103/1319-2442.243959 KQ2E3, KQ3E5, KQ4E4.30381506
18 Andreadis EA, Agaliotis GD, Angelopoulos ET, . Automated office blood pressure and 24-h ambulatory measurements are equally associated with left ventricular mass index. American journal of hypertension. 2011;24(6):661–6. PMID: 21415839. 10.1038/ajh.2011.38 KQ2E5, KQ3E7c, KQ4E4.21415839
19 Andreadis EA, Angelopoulos ET, Tsakanikas AP, . Automated office versus home measurement of blood pressure in the assessment of morning hypertension. Blood pressure monitoring. 2012;17(1):24–34. KQ2E5, KQ3E4b, KQ4E4.22218221
20 Andreadis EA, Geladari CV, Angelopoulos ET, . Morning Surge and Peak Morning Ambulatory Blood Pressure Versus Automated Office Blood Pressure in Predicting Cardiovascular Disease. High Blood Pressure & Cardiovascular Prevention. 2019;26(3):209–15. PMID: 30989620. 10.1007/s40292-019-00315-7 KQ2E5, KQ3E4a, KQ4E4.30989620
21 Andreadis EA, Geladari CV, Angelopoulos ET, . Attended and Unattended Automated Office Blood Pressure Measurements Have Better Agreement With Ambulatory Monitoring Than Conventional Office Readings. J Am Heart Assoc. 2018;7(8). PMID: 29627767. 10.1161/JAHA.118.008994 KQ2E5, KQ3E4b, KQ4E4.29627767
22 Anstey DE, Booth JN, 3rd, Abdalla M, . Predicted Atherosclerotic Cardiovascular Disease Risk and Masked Hypertension Among Blacks in the Jackson Heart Study. Circ Cardiovasc Qual Outcomes. 2017;10(7). 10.1161/CIRCOUTCOMES.116.003421 KQ2E4a, KQ3E5, KQ4E4.
23 Anstey DE, Colantonio LD, Yano Y, . The importance of using 24-hour and nighttime blood pressure for the identification of white coat hypertension: Data from the Jackson Heart Study. J Clin Hypertens. 2018;06:06. 10.1111/jch.13330 KQ2E4a, KQ3E5, KQ4E4.
24 Anstey DE, Muntner P, Bello NA, . Diagnosing Masked Hypertension Using Ambulatory Blood Pressure Monitoring, Home Blood Pressure Monitoring, or Both? Hypertension. 2018;72(5):1200–7. PMID: 30354812. 10.1161/HYPERTENSIONAHA.118.11319 KQ2E4a, KQ3E5, KQ4E4.30354812
25 Antza C, Doundoulakis I, Akrivos E, . Early Vascular Aging Risk Assessment From Ambulatory Blood Pressure Monitoring: The Early Vascular Aging Ambulatory Score. American journal of hypertension. 2018;31(11):1197–204. PMID: 30239585. 10.1093/ajh/hpy115 KQ2E5, KQ3E5a, KQ4E4.30239585
26 Apostolides AY, Cutter G, Daugherty SA, . Three-year incidence of hypertension in thirteen U.S. communities. On behalf of the Hypertension Detection and Follow-up Program cooperative group. Preventive Medicine. 1982;11(5):487–99. KQ2E1, KQ3E1, KQ4E1.7156059
27 Arima H, Kiyohara Y, Kato I, . Alcohol reduces insulin-hypertension relationship in a general population: the Hisayama study. Journal of Clinical Epidemiology. 2002;55(9):863–9. KQ2E1, KQ3E1, KQ4E1.12393073
28 Armanyous S, Ohashi Y, Lioudis M, . Diagnostic Performance of Blood Pressure Measurement Modalities in Living Kidney Donor Candidates. Clinical Journal of The American Society of Nephrology: CJASN. 2019;14(5):738–46. PMID: 30948455. 10.2215/CJN.02780218 KQ2E5, KQ3E5, KQ4E4.30948455
29 Armstrong D, Matangi M, Brouillard D, . Automated office blood pressure - being alone and not location is what matters most. Blood pressure monitoring. 2015;20(4):204–8. PMID: 26154710. 10.1097/MBP.0000000000000133 KQ2E5, KQ3E5b, KQ4E4.26154710
30 Asayama K, Ohkubo T, Hara A, . Repeated evening home blood pressure measurement improves prognostic significance for stroke: a 12-year follow-up of the Ohasama study. Blood pressure monitoring. 2009;14(3):93–8. KQ2E1, KQ3E1, KQ4E1.19359986
31 Asayama K, Ohkubo T, Kikuya M, . Use of 2003 European Society of Hypertension-European Society of Cardiology guidelines for predicting stroke using self-measured blood pressure at home: the Ohasama study. European Heart Journal. 2005;26(19):2026–31. KQ2E1, KQ3E1, KQ4E1.15917279
32 Asayama K, Ohkubo T, Kikuya M, . Prediction of stroke by home “morning” versus “evening” blood pressure values: the Ohasama study. Hypertension. 2006;48(4):737–43. KQ2E1, KQ3E1, KQ4E1.16952977
33 Asayama K, Thijs L, Li Y, . Setting thresholds to varying blood pressure monitoring intervals differentially affects risk estimates associated with white-coat and masked hypertension in the population. Hypertension. 2014;64(5):935–42. 10.1161/HYPERTENSIONAHA.114.03614 KQ2E13, KQ3E5, KQ4E4.25135185
34 Augustovski FA, Calvo CB, Deprati M, . The deep-breath test as a diagnostic maneuver for white-coat effect in hypertensive patients. Journal of the American Board of Family Practice. 2004;17(3):184–9. KQ2E5b, KQ3E5b, KQ4E4.
35 Baguet JP, Joseph X, Ormezzano O, . Ambulatory blood pressure variation in healthy subjects, hypertensive elderly and type 1 diabetic patients in relation to the sitting or standing position. Blood pressure monitoring. 2001;6(4):191–4. KQ2E3, KQ3E3, KQ4E4.11805467
36 Bakris GL, Smith DH, Giles TD, . Comparative antihypertensive efficacy of angiotensin receptor blocker-based treatment in African-American and white patients. Journal of Clinical Hypertension. 596;7(10):587–95. KQ2E5, KQ3E4a, KQ4E4.
37 Bakx JC, Seidell JC, Deurenberg P, . Development of hypertension in obese subjects seen in general practice. Family Practice. 1987;4(1):11–8. KQ2E1, KQ3E1, KQ4E1.3569720
38 Banegas JR, de la Cruz JJ, Graciani A, . Impact of Ambulatory Blood Pressure Monitoring on Reclassification of Hypertension Prevalence and Control in Older People in Spain. J Clin Hypertens. 2015;17(6):453–61. 10.1111/jch.12525 KQ2E2, KQ3E5, KQ4E4.
39 Banegas JR, Ruilope LM, de la Sierra A, . Relationship between Clinic and Ambulatory Blood-Pressure Measurements and Mortality. N Engl J Med. 2018;378(16):1509–20. PMID: 29669232. 10.1056/NEJMoa1712231 KQ2E5, KQ3E14, KQ4E4.29669232
40 Beltman FW, Heesen WF, Kok RH, . Predictive value of ambulatory blood pressure shortly after withdrawal of antihypertensive drugs in primary care patients. BMJ. 1996;313(7054):404–6. PMID: 8761232. KQ2E5, KQ3E7c, KQ4E4.8761232
41 Ben-Dov IZ, Ben-Arie L, Mekler J, . Normal ambulatory blood pressure: a clinical practice-based comparison of two recently published definitions. Journal of human hypertension. 2005;19(7):565–7. KQ2E3, KQ3E3, KQ4E4.15829998
42 Ben-Dov IZ, Ben-Arie L, Mekler J, . Normal ambulatory blood pressure: a clinical-practice-based analysis of recent American Heart Association recommendations. American Journal of Medicine. 2006;119(1):69–8. KQ2E3, KQ3E3, KQ4E4.
43 Birk JL, Cornelius T, Edmondson D, . Duration of Perseverative Thinking as Related to Perceived Stress and Blood Pressure: An Ambulatory Monitoring Study. Psychosomatic Medicine. 2019;03:03. PMID: 31274822. 10.1097/PSY.0000000000000727 KQ2E1, KQ3E1, KQ4E1.31274822
44 Bjorklund K, Lind L, Lithell H. Twenty-four hour ambulatory blood pressure in a population of elderly men. Journal of Internal Medicine. 2000;248(6):501–10. PMID: 11155143. KQ2E10, KQ3E5, KQ4E4.11155143
45 Bjorklund K, Lind L, Vessby B, . Different metabolic predictors of white-coat and sustained hypertension over a 20-year follow-up period: a population-based study of elderly men. Circulation. 2002;106(1):63–8. KQ2E10, KQ3E5, KQ4E4.12093771
46 Bjorklund K, Lind L, Zethelius B, . Isolated ambulatory hypertension predicts cardiovascular morbidity in elderly men. Circulation. 2003;107(9):1297–302. KQ2E10, KQ3E5, KQ4E4.12628951
47 Blanco F, Gil P, Arco CD, . Association of clinic and ambulatory blood pressure with vascular damage in the elderly: the EPICARDIAN study. Blood pressure monitoring. 2006;11(6):329–35. PMID: 17106317. KQ2E4a, KQ3E5, KQ4E4.17106317
48 Blekkenhorst LC, Lewis JR, Prince RL, . Nitrate-rich vegetables do not lower blood pressure in individuals with mildly elevated blood pressure: a 4-wk randomized controlled crossover trial. Am J Clin Nutr. 2018;107(6):894–908. 10.1093/ajcn/nqy061 KQ2E1, KQ3E1, KQ4E1.29868911
49 Bobrie G, Chatellier G, Genes N, . Cardiovascular prognosis of “masked hypertension” detected by blood pressure self-measurement in elderly treated hypertensive patients. Jama. 2004;291(11):1342–9. KQ2E1, KQ3E1, KQ4E1.15026401
50 Bombelli M, Sega R, Facchetti R, . Prevalence and clinical significance of a greater ambulatory versus office blood pressure (‘reversed white coat’ condition) in a general population. Journal of hypertension. 2005;23(3):513–20. PMID: 15716691. KQ2E4a, KQ3E5, KQ4E4.15716691
51 Booth JN, Anstey DE, Bello NA, . Race and sex differences in asleep blood pressure: The Coronary Artery Risk Development in Young Adults (CARDIA) study. Journal of Clinical Hypertension. 2019;21(2):184–92. PMID: 30719843. 10.1111/jch.13474 KQ1E1, KQ2E4a, KQ3E5, KQ4E4.30719843
52 Booth JN, 3rd, Muntner P, Diaz KM, . Evaluation of Criteria to Detect Masked Hypertension. J Clin Hypertens. 2016;18(11):1086–94. 10.1111/jch.12830 KQ2E7, KQ3E7, KQ4E4.
53 Botomino A, Martina B, Ruf D, . White coat effect and white coat hypertension in community pharmacy practice. Blood pressure monitoring. 2005;10(1):13–8. PMID: 15687869. KQ2E5, KQ3E7c, KQ4E4.15687869
54 Boubouchairopoulou N, Karpettas N, Athanasakis K, . Cost estimation of home blood pressure monitoring versus combined office and ambulatory measurements in hypertension management. Value Health [serial on the Internet]. 2014; 17(7): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01055065/full. KQ2E1, KQ3E1, KQ4E1.
55 Boucher P, Gilbert-Ouimet M, Trudel X, . Masked hypertension and effort-reward imbalance at work among 2369 white-collar workers. Journal of human hypertension. 2017;31(10):620–6. 10.1038/jhh.2017.42 KQ2E2, KQ3E5, KQ4E4.28639611
56 Boyko EJ, Barr EL, Zimmet PZ, . Two-hour glucose predicts the development of hypertension over 5 years: the AusDiab study. Journal of human hypertension. 2008;22(3):168–76. KQ2E1, KQ3E1, KQ4E1.18046430
57 Brantsma AH, Bakker SJ, de ZD, . Urinary albumin excretion as a predictor of the development of hypertension in the general population. Journal of the American Society of Nephrology. 2006;17(2):331–5. KQ2E1, KQ3E1, KQ4E1.16434504
58 Brguljan-Hitij J, Thijs L, Li Y, . Risk stratification by ambulatory blood pressure monitoring across JNC classes of conventional blood pressure. American journal of hypertension. 2014;27(7):956–65. 10.1093/ajh/hpu002 KQ2E4a, KQ3E5, KQ4E4.24572704
59 Bromfield SG, Booth JN, 3rd, Loop MS, . Evaluating different criteria for defining a complete ambulatory blood pressure monitoring recording: data from the Jackson Heart Study. Blood pressure monitoring. 2018;23(2):103–11. 10.1097/MBP.0000000000000309 KQ2E5b, KQ3E5, KQ4E4.29240564
60 Bromfield SG, Shimbo D, Booth JN, 3rd, . Cardiovascular Risk Factors and Masked Hypertension: The Jackson Heart Study. Hypertension. 2016;68(6):1475–82. 10.1161/HYPERTENSIONAHA.116.08308 KQ2E4a, KQ3E5, KQ4E4.27777359
61 Bulpitt CJ, Beckett N, Peters R, . Does white coat hypertension require treatment over age 80?: Results of the hypertension in the very elderly trial ambulatory blood pressure side project. Hypertension. 2013;61(1):89–94. KQ2E5, KQ3E4a, KQ4E4.23172934
62 Cacciolati C, Hanon O, Alperovitch A, . Masked hypertension in the elderly: cross-sectional analysis of a population-based sample. American journal of hypertension. 2011;24(6):674–80. KQ2E1, KQ3E1, KQ4E1.21415840
63 Cacciolati C, Hanon O, Dufouil C, . Categories of hypertension in the elderly and their 1-year evolution. The Three-City Study. Journal of hypertension. 2013;31(4):680–9. KQ2E1, KQ3E1, KQ4E1.23412428
64 Cahan A, Ben-Dov IZ, Mekler J, . The role of blood pressure variability in misdiagnosed clinic hypertension. Hypertension. 2011;34(2):187–92. KQ2E5, KQ3E5b, KQ4E4.
65 Cameron AJ, Welborn TA, Zimmet PZ, . Overweight and obesity in Australia: the 1999-2000 Australian Diabetes, Obesity and Lifestyle Study (AusDiab). Med J Aust. 2003;178(9):427–32. KQ2E1, KQ3E1, KQ4E1.12720507
66 Campbell NR, Myers MG, McKay DW. Is usual measurement of blood pressure meaningful? Blood pressure monitoring. 1999;4(2):71–6. KQ2E5b, KQ3E5b, KQ4E4.10450116
67 Campbell P, Ghuman N, Wakefield D, . Long-term reproducibility of ambulatory blood pressure is superior to office blood pressure in the very elderly. Journal of human hypertension. 2010;24(11):749–54. KQ2E4a, KQ3E5, KQ4E4.20200549
68 Canter DA, Texter MJ, McLain RW. Short report: ambulatory blood pressure monitoring can play an integral role in patient selection, dosage adjustment and efficacy assessment in clinical trials of antihypertensive agents. Journal of hypertension. 1994;12(4):491–4. KQ2E5, KQ3E4a, KQ4E4.8064175
69 Carlson DJ, Dieberg G, McFarlane JR, . Blood pressure measurements in research: suitability of auscultatory, beat-to-beat, and ambulatory blood pressure measurements. Blood pressure monitoring. 2019;24(1):18–23. PMID: 30489333. 10.1097/MBP.0000000000000355 KQ2E4b, KQ3E5, KQ4E4.30489333
70 Carson AP, Lewis CE, Jacobs DR, Jr., . Evaluating the Framingham hypertension risk prediction model in young adults: the Coronary Artery Risk Development in Young Adults (CARDIA) study. Hypertension. 2013;62(6):1015–20. KQ2E1, KQ3E1, KQ4E1.24041951
71 Carugo S, Solari D, Esposito A, . Clinic blood pressure, ambulatory blood pressure and cardiac structural alterations in nonagenarians and in centenarians. Blood Pressure. 2012;21(2):97–103. KQ2E5b, KQ3E5, KQ4E4.22149625
72 Celis H, Staessen JA, Buntix F, . Antihypertensive treatment based on home or office blood pressure measurement: protocol of the randomized controlled THOP trial. Blood pressure monitoring. 1998;3:S29–S35. KQ2E5, KQ3E10, KQ4E4.
73 Celis H, Staessen JA, Thijs L, . Cardiovascular risk in white-coat and sustained hypertensive patients. Blood Press. 2002;11(6):352–6. KQ2E1, KQ3E4a, KQ4E4.12523678
74 Cesar CV, Victoria PR, Rogelio TS. Loaned self-measurement equipment model compared with ambulatory blood pressure monitoring. Blood pressure monitoring. 2003;8(2):63–70. PMID: 12819557. KQ2E9, KQ3E9, KQ4E9.12819557
75 Chan KS, Lai KPL, Chan PF, . Evaluation of the applicability of deep breathing test in the diagnosis of hypertension with white-coat effect in Chinese patients in primary care. Clin. 2019;25:2. PMID: 30774977. 10.1186/s40885-018-0106-4 KQ2E5, KQ3E5b, KQ4E4.30774977
76 Chanudet X, Chau NP, Larroque P. Short-term representatives of daytime and night-time ambulatory blood pressures. Journal of hypertension. 1992;10(6):595–600. KQ2E4a, KQ3E4a, KQ4E4.1320081
77 Chatellier G, Battaglia C, Pagny JY, . Decision to treat mild hypertension after assessment by ambulatory monitoring and World Health Organisation recommendations. BMJ. 1992;305(6861):1062–6. KQ2E1, KQ3E1, KQ4E1.1467686
78 Cheng YB, Thijs L, Zhang ZY, . Outcome-Driven Thresholds for Ambulatory Blood Pressure Based on the New American College of Cardiology/American Heart Association Classification of Hypertension. Hypertension. 2019:Hypertensionaha11913512. PMID: 31378104. 10.1161/hypertensionaha.119.13512 KQ2E13, KQ3E5, KQ4E4.31378104
79 Cheung BM, Ong KL, Tso AW, . C-reactive protein as a predictor of hypertension in the Hong Kong Cardiovascular Risk Factor Prevalence Study (CRISPS) cohort. Journal of human hypertension. 2012;26(2):108–16. KQ2E1, KQ3E1, KQ4E1.21270838
80 Cheung BM, Wat NM, Man YB, . Relationship between the metabolic syndrome and the development of hypertension in the Hong Kong Cardiovascular Risk Factor Prevalence Study-2 (CRISPS2). American journal of hypertension. 2008;21(1):17–22. KQ2E1, KQ3E1, KQ4E1.18091739
81 Choi T, Rhee M, Park H, . Multiple office blood pressure measurement is not inferior to home blood pressure monitoring compared with 24-hour ambulatory blood pressure monitoring: a prospective multicenter study. Eur Heart J [serial on the Internet]. 2015; 36: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01472592/full. KQ2E5, KQ3E11a, KQ4E4.
82 Chonan K, Kikuya M, Araki T, . Device for the self-measurement of blood pressure that can monitor blood pressure during sleep. Blood pressure monitoring. 2001;6(4):203–5. KQ2E5, KQ3E5b, KQ4E5b.11805470
83 Chow WS, Cheung BM, Tso AW, . Hypoadiponectinemia as a predictor for the development of hypertension: a 5-year prospective study. Hypertension. 2007;49(6):1455–61. KQ2E1, KQ3E1, KQ4E1.17452504
84 Chrubasik SA, Chrubasik CA, Piper J, . Impact of risk factors on cardiovascular risk: a perspective on risk estimation in a Swiss population. Swiss Med Wkly. 2015;145:w14180. 10.4414/smw.2015.14180 KQ2E4, KQ3E4, KQ4E4.26375858
85 Chrubasik-Hausmann S, Chrubasik C, Walz B, . Comparisons of home and daytime ambulatory blood pressure measurements. BMC Cardiovasc Disord. 2014;14:94. 10.1186/1471-2261-14-94 KQ2E3, KQ3E4a, KQ4E4.25084732
86 Clark S, Fowlie S, Pannarale G, . Age and blood pressure measurement: experience with the TM2420 ambulatory blood pressure monitor and elderly people. Age Ageing. 1992;21(6):398–403. KQ2E4a, KQ3E4a, KQ4E4.1471576
87 Clement DL, De Buyzere ML, De Bacquer DA, . Prognostic value of ambulatory blood-pressure recordings in patients with treated hypertension. N Engl J Med. 2003;348(24):2407–15. KQ2E1, KQ3E1, KQ4E1.12802026
88 Coll de Tuero G, Llibre JB, Poncelas AR, . Isolated clinical hypertension diagnosis: self-home BP, ambulatory BP monitoring, or both simultaneously? Blood pressure monitoring. 2011;16(1):11–5. KQ2E5, KQ3E4a, KQ4E4.21183853
89 Coll-de-Tuero G, Saez M, Roca-Saumell C, . Evolution of target organ damage by different values of self-blood pressure measurement in untreated hypertensive patients. American journal of hypertension. 2012;25(12):1256–63. KQ2E5, KQ3E4a, KQ4E4.22914254
90 Conen D, Aeschbacher S, Thijs L, . Age-specific differences between conventional and ambulatory daytime blood pressure values. Hypertension. 2014;64(5):1073–9. 10.1161/HYPERTENSIONAHA.114.03957 KQ2E13, KQ3E5, KQ4E4.25185130
91 Conroy RM, Atkins N, Mee F, . Using Hawksley random zero sphygmomanometer as a gold standard may result in misleading conclusions. Blood Pressure. 1994;3(5):283–6. KQ2E3, KQ3E3, KQ4E4.7866591
92 Costa A, Bosone D, Ramusino MC, . Twenty-four-hour blood pressure profile, orthostatic hypotension, and cardiac dysautonomia in elderly type 2 diabetic hypertensive patients. Clinical autonomic research/. 2016;26(6):433–9. KQ2E5, KQ3E4a, KQ4E4.
93 Critselis E, Chrysohoou C, Kollia N, . Stage 1 hypertension, but not elevated blood pressure, predicts 10-year fatal and non-fatal CVD events in healthy adults: the ATTICA Study. Journal of human hypertension. 2019. 10.1038/s41371-019-0169-z KQ2E3, KQ3E5, KQ4E4.
94 Cuspidi C, Meani S, Sala C, . How reliable is isolated clinical hypertension defined by a single 24-h ambulatory blood pressure monitoring? Journal of hypertension. 2007;25(2):315–20. KQ2E5, KQ3E4a, KQ4E4.17211238
95 Cuspidi C, Meani S, Salerno M, . Reproducibility of nocturnal blood pressure fall in early phases of untreated essential hypertension: a prospective observational study. Journal of human hypertension. 2004;18(7):503–9. KQ2E1, KQ3E4a, KQ4E4.14749713
96 Cuspidi C, Parati G. Masked hypertension: an independent predictor of organ damage. Journal of hypertension. 2007;25(2):275–9. PMID: 17211231. 10.1097/HJH.0b013e32801da2d2 KQ2E7, KQ3E7, KQ4E7.17211231
97 Cuspidi C, Sala C, Valerio C, . Nocturnal blood pressure in untreated essential hypertensives. Blood Pressure. 2011;20(6):335–41. KQ2E5, KQ3E4a, KQ4E4.21651423
98 Danninger K, Hafez A, Binder RK, . High prevalence of hypertension and early vascular aging: a screening program in pharmacies in Upper Austria. Journal of human hypertension. 2019;29:29. PMID: 31358883. 10.1038/s41371-019-0222-y KQ2E2, KQ3E5, KQ4E4.31358883
99 de Gaudemaris R, Chau NP, Mallion JM. Home blood pressure: variability, comparison with office readings and proposal for reference values. Groupe de la Mesure, French Society of Hypertension. Journal of hypertension. 1994;12(7):831–8. PMID: 7963513. KQ2E3, KQ3E5, KQ4E4.7963513
100 de la Sierra A, Banegas JR, Vinyoles E, . Prevalence of Masked Hypertension in Untreated and Treated Patients With Office Blood Pressure Below 130/80 mm Hg. Circulation. 2018;137(24):2651–3. PMID: 29712713. 10.1161/CIRCULATIONAHA.118.034619 KQ2E5, KQ3E4a, KQ4E4.29712713
101 de la Sierra A, Banegas JR, Vinyoles E, . Prevalence of Masked Hypertension in Untreated and Treated Patients With Office Blood Pressure Below 130/80 mm Hg. Circulation. 2018;137:2651–3. 10.1161/CIRCULATIONAHA.118.034619 KQ2E5, KQ3E4a, KQ4E4.29712713
102 De Leon-Robert A, Gascon-Canovas JJ, Anton-Botella JJ, . Validity of self blood pressure measurement in the control of the hypertensive patient: factors involved. BMC Cardiovascular Disorders. 2019;19(1):171. PMID: 31315567. 10.1186/s12872-019-1145-9 KQ2E5, KQ3E5, KQ4E4.31315567
103 de lSA, Banegas J, Divison J, . Ambulatory blood pressure in hypertensive patients with inclusion criteria for the SPRINT trial. Journal of the American Society of Hypertension. 2016; 10(12): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01473618/full. KQ2E5a, KQ3E5a, KQ4E4.
104 de Tuero GC, Boreu QF, Rodriguez-Poncelas A, . Assessment of self-monitoring of blood pressure in the diagnosis of isolated clinic hypertension. Blood Pressure. 2006;15(4):227–36. PMID: 17078176. KQ2E3, KQ3E5, KQ4E4.17078176
105 Dell’Oro R, Facchetti R, Bombelli M, ., editors. 24-hour systolic blood pressure load represents an important variable in determining the cardiovascular risk profile of white-coat hypertension. High Blood Press Cardiovasc Prev; 2017; Conference: 34th national congress of the italian society of hypertension, SIIA 2017. Italy. KQ2E11a, KQ3E11a, KQ4E4.
106 Denissen SJ, van der Aalst CM, Vonder M, . Impact of a cardiovascular disease risk screening result on preventive behaviour in asymptomatic participants of the ROBINSCA trial. European journal of preventive cardiology. 2019;26(12):1313–22. PMID: 30966821. 10.1177/2047487319843396 KQ1E4, KQ21, KQ3E1, KQ4E1.30966821
107 Dernellis J, Panaretou M. Aortic stiffness is an independent predictor of progression to hypertension in nonhypertensive subjects. Hypertension. 2005;45(3):426–31. KQ2E1, KQ3E1, KQ4E1.15710784
108 Di Monaco S, Rabbia F, Covella M, . Evaluation of a short home blood pressure measurement in an outpatient population of hypertensives. Clin Exp Hypertens. 2016;38(8):673–9. 10.1080/10641963.2016.1200600 KQ2E5, KQ3E7c, KQ4E4.27936339
109 Divison JA, Sanchis C, Artigao LM, . Home-based self-measurement of blood pressure: a proposal using new reference values (the PURAS study). Blood pressure monitoring. 2004;9(4):211–8. PMID: 1531148. KQ2E3, KQ3E5, KQ4E4.15311148
110 Dolan E, Stanton A, Thijs L, . Superiority of ambulatory over clinic blood pressure measurement in predicting mortality: the Dublin outcome study. Hypertension. 2005;46(1):156–61. KQ2E1, KQ3E1, KQ4E1.15939805
111 Ebbs D. A comparison of selected antihypertensives and the use of conventional vs ambulatory blood pressure in the detection and treatment of hypertension. Cardiology. 2001;96:Suppl-9. KQ2E5, KQ3E4a, KQ4E4.
112 Edick CM, Parnell D, Christensen ML, . Falsely elevated systolic blood pressure with patient-operated blood pressure measuring devices. J Am Pharm Assoc (Wash). 2000;40(5):670–2. PMID: 11029849. KQ2E3, KQ3E5, KQ4E4.11029849
113 Eguchi K, Hoshide S, Ishikawa J, . Cardiovascular prognosis of sustained and white-coat hypertension in patients with type 2 diabetes mellitus. Blood pressure monitoring. 2008;13(1):15–20. 10.1097/MBP.0b013e3282f13f4a KQ2E5, KQ3E4a, KQ4E4.18199919
114 Eguchi K, Pickering TG, Hoshide S, . Ambulatory blood pressure is a better marker than clinic blood pressure in predicting cardiovascular events in patients with/without type 2 diabetes. American journal of hypertension. 2008;21(4):443–50. KQ2E4, KQ3E4a, KQ4E4.18292756
115 Elijovich F, Laffer CL. Bayesian analysis supports use of ambulatory blood pressure monitors for screening. Hypertension. 1992;19:(2 Suppl):II268–II72. KQ2E5, KQ3E5, KQ4E4.1735591
116 Endo Y, Serizawa F, Kato T, . Clinical characteristics of young-onset and medical treatment-requiring hypertension identified by targeted screening in university health check-up. Clinical & Experimental Hypertension (New York). 2011;33(8):552–7. KQ2E3, KQ3E5, KQ4E4.
117 Enstrom IE, Pennert KM. 24 h non-invasive ambulatory blood pressure monitoring: do the number of recordings per hour and/or ways of analyzing day and night matter? Blood pressure monitoring. 2001;6(5):253–6. KQ2E4a, KQ3E4a, KQ4E4.12055420
118 Ernst ME, Bergus GR. Favorable patient acceptance of ambulatory blood pressure monitoring in a primary care setting in the United States: a cross-sectional survey. BMC family practice. 2003;4:15. PMID: 14533981. 10.1186/1471-2296-4-15 KQ2E1, KQ3E1, KQ4E5b.14533981
119 Esme M, Yavuz BB, Yavuz B, . Masked Hypertension is Associated With Cognitive Decline in Geriatric Age-Geriatric MASked Hypertension and Cognition (G-MASH-cog) Study. J Gerontol A Biol Sci Med Sci. 2018;73(2):248–54. 10.1093/gerona/glx150 KQ2E9, KQ3E9, KQ4E9.28958009
120 Espinosa R, Spruill TM, Zawadzki MJ, . Can blood pressure measurements taken in the physician’s office avoid the ‘white coat’ bias? Blood pressure monitoring. 2011;16(5):231–7. KQ2E5, KQ3E4a, KQ4E4.21897208
121 Everson SA, Kaplan GA, Goldberg DE, . Hypertension incidence is predicted by high levels of hopelessness in Finnish men. Hypertension. 2000;35(2):561–7. KQ2E1, KQ3E1, KQ4E1.10679498
122 Fagot-Campagna A, Balkau B, Simon D, . Is insulin an independent risk factor for hypertension? The Paris Prospective Study. Int J Epidemiol. 1997;26(3):542–50. KQ2E1, KQ3E1, KQ4E1.9222779
123 Farhan H, Al-Hasani M, Misbah M, . Comparative study of ambulatory blood pressure monitoring and clinic blood pressure measurement in the risk assessment and management of hypertension. Sultan Qaboos University Medical Journal. 2010;10(3):370–6. KQ2E5, KQ3E5a, KQ4E4.21509258
124 Faria J, Mesquita-Bastos J, Bertoquini S, . Long-term cardiovascular risk of white-coat hypertension with normal night-time blood pressure values. Blood pressure monitoring. 2019;24(2):59–66. PMID: 30856622. 10.1097/MBP.0000000000000364 KQ2E5, KQ3E4a, KQ4E4.30856622
125 Fava C, Burri P, Almgren P, . Heritability of ambulatory and office blood pressure phenotypes in Swedish families. Journal of hypertension. 2004;22(9):1717–21. KQ2E4b, KQ3E5, KQ4E4.15311099
126 Figliuzzi I, Presta V, Miceli F, . 24-Hour ambulatory blood pressure levels and control in a large cohort of adult outpatients with different classes of obesity. Journal of human hypertension. 2019;33(4):298–307. PMID: 30420644. 10.1038/s41371-018-0132-4 KQ2E5, KQ3E4a, KQ4E4.30420644
127 Fitchett G, Powell LH. Daily spiritual experiences, systolic blood pressure, and hypertension among midlife women in SWAN. Ann Behav Med. 2009;37(3):257–67. KQ2E1, KQ3E1, KQ4E1.19662465
128 Fogari R, Derosa G, Zoppi A, . Comparative effect of canrenone or hydrochlorothiazide addition to valsartan/amlodipine combination on urinary albumin excretion in well-controlled type 2 diabetic hypertensive patients with microalbuminuria. Expert Opin Pharmacother. 2014;15(4):453–9. 10.1517/14656566.2014.874415 KQ2E1, KQ3E1, KQ4E4.24410484
129 Formiga F, Ferrer A, Sobrino J, . Ambulatory blood pressure monitoring (ABPM) in nonagenarians. Archives of Gerontology & Geriatrics. 2009;48(3):367–71. KQ2E5b, KQ3E5, KQ4E4.18423650
130 Franklin SS, Thijs L, Hansen TW, . Significance of white-coat hypertension in older persons with isolated systolic hypertension: a meta-analysis using the International Database on Ambulatory Blood Pressure Monitoring in Relation to Cardiovascular Outcomes population. [Review]. Hypertension. 2012;59(3):564–71. KQ2E5, KQ3E5, KQ4E4.22252396
131 Franklin SS, Thijs L, Li Y, . Masked hypertension in diabetes mellitus: treatment implications for clinical practice. Hypertension. 2013;61(5):964–71. KQ2E4a, KQ3E5, KQ4E4.23478096
132 Gaborieau V, Delarche N, Gosse P. Ambulatory blood pressure monitoring versus self-measurement of blood pressure at home: correlation with target organ damage. Journal of hypertension. 2008;26(10):1919–27. KQ2E5, KQ3E5b, KQ4E4.18806615
133 Gasowski J, Li Y, Kuznetsova T, . Is “usual” blood pressure a proxy for 24-h ambulatory blood pressure in predicting cardiovascular outcomes? American journal of hypertension. 2008;21(9):994–1000. KQ2E1, KQ3E1, KQ4E1.18600212
134 Gazzola K, Cammenga M, van der Hoeven NV, . Prevalence and reproducibility of differences between home and ambulatory blood pressure and their relation with hypertensive organ damage. Journal of human hypertension. 2017;31(9):555–60. 10.1038/jhh.2017.27 KQ2E5, KQ3E5b, KQ4E4.28382957
135 Giantin V, Franchin A, Toffanello ED, . Masked and white-coat hypertension in two cohorts of elderly subjects, ambulatory and hospitalized patients. Archives of Gerontology & Geriatrics. 2009;49:Suppl-8. KQ2E10, KQ3E5, KQ4E4.
136 Giubertoni E, Bertelli L, Bartolacelli Y, . Parity as predictor of early hypertension during menopausal transition. Journal of hypertension. 2013;31(3):501–7. KQ2E1, KQ3E1, KQ4E1.23196900
137 Glen S, Elliott H, Curzio J, . White-coat hypertension as a cause of cardiovascular dysfunction. Lancet. 1996;348(654–7). PMID: 8782756. 10.1016/S0140-6736(96)02303-3 KQ2E4a, KQ3E7c, KQ4E4.8782756
138 Godwin M, Birtwhistle R, Delva D, . Manual and automated office measurements in relation to awake ambulatory blood pressure monitoring. Fam Pract. 2011;28(1):110–7. KQ2E5b, KQ3E5b, KQ4E4.20720213
139 Gong S, Liu K, Ye R, . Nocturnal dipping status and the association of morning blood pressure surge with subclinical target organ damage in untreated hypertensives. Journal of Clinical Hypertension. 2019;03:03. PMID: 31376230. 10.1111/jch.13641 KQ2E9, KQ3E9, KQ4E9.31376230
140 Gorostidi M, de la Sierra A, Gonzalez-Albarran O, . Abnormalities in ambulatory blood pressure monitoring in hypertensive patients with diabetes. Hypertension Research - Clinical & Experimental. 2011;34(11):1185–9. 10.1038/hr.2011.100 KQ2E5, KQ3E5b, KQ4E4.
141 Graves JW, Grossardt BR. Discarding the first of three nurse-auscultatory or oscillometric blood pressure measurements does not improve the association of office blood pressure with ABPM. Blood pressure monitoring. 2010;15(3):146–51. KQ2E5, KQ3E4a, KQ4E4.20407368
142 Graves JW, Grossardt BR, Gullerud RE, . The trained observer better predicts daytime ABPM diastolic blood pressure in hypertensive patients than does an automated (Omron) device. Blood pressure monitoring. 2006;11(2):53–8. KQ2E5, KQ3E4b, KQ4E4.16534405
143 Green B, Anderson M, Cook A, ., editors. Blood pressure checks for diagnosing hypertension (bp-check). Hypertension; 2017; Conference: american heart association’s council on hypertension 2017 scientific sessions. United States. KQ2E5, KQ3E11a, KQ4E4.
144 Green BB, Anderson ML, Campbell J, . Blood pressure checks and diagnosing hypertension (BP-CHECK): Design and methods of a randomized controlled diagnostic study comparing clinic, home, kiosk, and 24-hour ambulatory BP monitoring. Contemporary Clinical Trials. 2019;79:1–13. PMID: 30634036. 10.1016/j.cct.2019.01.003 KQ2E5, KQ3E11, KQ4E4.30634036
145 Greiver M, White D, Kaplan DM, . Where should automated blood pressure measurements be taken? Pilot RCT of BpTRU measurements taken in private or nonprivate areas of a primary care office. Blood pressure monitoring. 2012;17(3):137–8. KQ2E3, KQ3E3, KQ4E4.22561736
146 Grin JM, McCabe EJ, White WB. Management of hypertension after ambulatory blood pressure monitoring. Ann Intern Med. 1993;118(11):833–7. KQ2E1, KQ3E4a, KQ4E4.8480956
147 Grossman A, Cohen N, Shemesh J, . Exaggerated blood pressure response to exercise is not associated with masked hypertension in patients with high normal blood pressure levels. J Clin Hypertens. 2014;16(4):277–82. 10.1111/jch.12303 KQ2E5, KQ3E4a, KQ4E4.
148 Guagnano MT, Pace-Palitti V, Murri R, . The prevalence of hypertension in gynaecoid and android obese women. Journal of human hypertension. 1996;10(9):619–24. KQ2E3, KQ3E3, KQ4E4.8953208
149 Gunawan F, Ng HY, Gilfillan C, . Ambulatory blood pressure monitoring in type 2 diabetes mellitus: a cross-sectional study. Current hypertension reviews. 2018;15(2):135–43. PMID: 29875006. 10.2174/1573402114666180607090205 KQ2E5b, KQ3E5, KQ4E4.29875006
150 Guo S, Lin H, Pan S, . The differential diagnostic value of serum homocysteine for white coat hypertension. Oncotarget. 2017;8(60):101271–83. 10.18632/oncotarget.21020 KQ2E9, KQ3E9, KQ4E9.29254163
151 Gustavsen PH, Hoegholm A, Bang LE, . White coat hypertension is a cardiovascular risk factor: a 10-year follow-up study. Journal of human hypertension. 2003;17(12):811–7. KQ2E5, KQ3E4a, KQ4E4.14704724
152 Handler J, Mohan Y, Kanter MH, . Screening for High Blood Pressure in Adults During Ambulatory Nonprimary Care Visits: Opportunities to Improve Hypertension Recognition. J Clin Hypertens. 2015;17(6):431–9. 10.1111/jch.12517 KQ2E3, KQ3E5, KQ4E4.
153 Handler J, Zhao Y, Egan BM. Impact of the number of blood pressure measurements on blood pressure classification in US adults: NHANES 1999-2008. Journal of clinical hypertension (Greenwich, Conn). 2012;14(11):751–9. KQ2E3, KQ3E5, KQ4E4.
154 Hanninen MR, Niiranen TJ, Puukka PJ, . Metabolic risk factors and masked hypertension in the general population: the Finn-Home study. Journal of human hypertension. 2014. PMID: 24384630. KQ2E3, KQ3E5, KQ4E4.24384630
155 Hansen KW, Poulsen PL, Ebbehoj E, . What is hypertension in diabetes? Ambulatory blood pressure in 137 normotensive and normoalbuminuric Type 1 diabetic patients. Diabetic Medicine. 2001;18(5):370–3. PMID: 11472447. KQ2E4a, KQ3E5, KQ4E4.11472447
156 Hansen TW, Jeppesen J, Rasmussen S, . Ambulatory blood pressure and mortality: a population-based study. Hypertension. 2005;45(4):499–504. KQ2E1, KQ3E1, KQ4E1.15753229
157 Hansen TW, Kikuya M, Thijs L, . Prognostic superiority of daytime ambulatory over conventional blood pressure in four populations: a meta-analysis of 7,030 individuals. Journal of hypertension. 2007;25(8):1554–64. KQ2E13, KQ3E5, KQ4E4.17620947
158 Hansen TW, Li Y, Boggia J, . Predictive role of the nighttime blood pressure. Hypertension. 2011;57(1):3–10. PMID: 21079049. 10.1161/hypertensionaha.109.133900 KQ2E4a, KQ3E4a, KQ4E4.21079049
159 Hara A, Tanaka K, Ohkubo T, . Ambulatory versus home versus clinic blood pressure: the association with subclinical cerebrovascular diseases: the Ohasama Study. Hypertension. 2012;59(1):22–8. KQ2E4a, KQ3E5, KQ4E4.22083163
160 Helvaci MR, Kaya H, Duru M, . What is the relationship between white coat hypertension and dyslipidemia? International Heart Journal. 2008;49(1):87–93. KQ2E9, KQ3E9, KQ4E9.18360067
161 Helvaci MR, Kaya H, Yalcin A, . Prevalence of white coat hypertension in underweight and overweight subjects. International Heart Journal. 2007;48(5):605–13. KQ2E9, KQ3E9, KQ4E9.17998770
162 Henskens LH, van Boxtel MP, Kroon AA, . Subjective sleep disturbance increases the nocturnal blood pressure level and attenuates the correlation with target-organ damage. Journal of hypertension. 2011;29(2):242–50. KQ2E5, KQ3E4a, KQ45b.21243737
163 Her AY, Kim YH, Rim SJ, . Home blood pressure is the predictor of subclinical target organ damage like ambulatory blood pressure monitoring in untreated hypertensive patients. Anatolian journal of cardiology. 2014;14(8):711–8. 10.5152/akd.2014.5119 KQ2E5, KQ3E4b, KQ4E4.25188760
164 Hermida RC. Ambulatory blood pressure monitoring in the prediction of cardiovascular events and effects of chronotherapy: rationale and design of the MAPEC study. Chronobiol Int. 2007;24(4):749–75. KQ2E1, KQ3E1, KQ4E1.17701685
165 Hermida RC. Sleep-time ambulatory blood pressure as a prognostic marker of vascular and other risks and therapeutic target for prevention by hypertension chronotherapy: Rationale and design of the Hygia Project. Chronobiol Int. 2016;33(7):906–36. PMID: 27221952. 10.1080/07420528.2016.1181078 KQ1E6, KQ4E6.27221952
166 Hermida RC, Ayala DE, Mojon A, . Sleep-Time Ambulatory BP Is an Independent Prognostic Marker of CKD. J Am Soc Nephrol. 2017;28(9):2802–11. 10.1681/ASN.2016111186 KQ2E1, KQ3E1, KQ4E1.28455314
167 Hermida RC, Ayala DE, Smolensky MH, . Sleep-time blood pressure: Unique sensitive prognostic marker of vascular risk and therapeutic target for prevention. Sleep medicine reviews. 2017;33:17–27. 10.1016/j.smrv.2016.04.001 KQ2E1, KQ3E1, KQ4E1.27316324
168 Hermida RC, Ayala DE, Ýn A, . Decreasing sleep-time blood pressure determined by ambulatory monitoring reduces cardiovascular risk. Journal of the American College of Cardiology. 2011;58(11):1165–73. KQ2E1, KQ3E1, KQ4E1.21884956
169 Hond E, Celis H, Vandenhoven G, . Determinants of white-coat syndrome assessed by ambulatory blood pressure or self-measured home blood pressure. Blood pressure monitoring. 2003;8(1):37–40. KQ2E5, KQ3E10, KQ4E4.12604935
170 Hond ED, Celis H, Fagard R, . Self-measured versus ambulatory blood pressure in the diagnosis of hypertension. Journal of hypertension. 2003;21(4):717–22. KQ2E5, KQ3E10, KQ4E4.12658017
171 Huang J, Wang Y, Liu Z, . Simultaneous validation of the Grandway MD2301 digital automatic blood pressure monitor by the British Hypertension Society and the Association for the Advancement of Medical Instrumentation/the International Organization for Standardization protocols. Blood pressure monitoring. 2017;22(1):44–7. 10.1097/MBP.0000000000000218 KQ2E9, KQ3E9, KQ4E9.27749334
172 Iannucci G, Balsano C, Paroli M, . Office normotensives with a minimal augmentation of intima-media thickness of common carotid arteries: really normotensives? European Review for Medical & Pharmacological Sciences. 2013;17(23):3164–8. KQ2E4a, KQ3E5, KQ4E4.24338457
173 Inden Y, Tsuda M, Hayashi H, . Relationship between Joint National Committee-VI classification of hypertension and ambulatory blood pressure in patients with hypertension diagnosed by casual blood pressure. Clin Cardiol. 1998;21(11):801–6. KQ2E5, KQ3E4a, KQ4E4.9825191
174 Ingelsson E, Bjorklund-Bodegard K, Lind L, . Diurnal blood pressure pattern and risk of congestive heart failure. Jama. 2006;295(24):2859–66. KQ2E1, KQ3E1, KQ4E1.16804152
175 Inoue R, Ohkubo T, Kikuya M, . Predicting stroke using 4 ambulatory blood pressure monitoring-derived blood pressure indices: the Ohasama Study. Hypertension. 2006;48(5):877–82. KQ2E1, KQ3E1, KQ4E1.16982961
176 Inoue T, Iseki K, Iseki C, . Higher heart rate predicts the risk of developing hypertension in a normotensive screened cohort. Circ J. 2007;71(11):1755–60. KQ2E1, KQ3E1, KQ4E1.17965497
177 Ishikawa J, Nasothimiou EG, Karpettas N, . Automatic office blood pressure measured without doctors or nurses present. Blood pressure monitoring. 2012;17(3):96–102. PMID: 22425703. 10.1097/MBP.0b013e328352ade4 KQ2E5, KQ3E7c, KQ4E4.22425703
178 James GD, Marion R, Pickering TG. White-coat hypertension and sex. Blood pressure monitoring. 1998;3(5):281–7. KQ2E5, KQ3E4a, KQ4E4.10212367
179 Juhaeri, Stevens J, Chambless LE, . Associations between weight gain and incident hypertension in a bi-ethnic cohort: the Atherosclerosis Risk in Communities Study. Int J Obes Relat Metab Disord. 2002;26(1):58–64. KQ2E1, KQ3E1, KQ4E1.11791147
180 Jula A, Puukka P, Karanko H. Multiple clinic and home blood pressure measurements versus ambulatory blood pressure monitoring. Hypertension. 1999;34(2):261–6. KQ2E5, KQ3E4a, KQ4E4.10454451
181 Jung DH, Kim JY, Kim JK, . Relative contribution of obesity and serum adiponectin to the development of hypertension. Diabetes Res Clin Pract. 2014;103(1):51–6. KQ2E1, KQ3E1, KQ4E1.24398319
182 Juraschek SP, Ishak A, Mukamal KJ, . Impact of Clinic-Based Blood Pressure Approaches on Blood Pressure Measurement. American journal of hypertension. 2019;27:27. PMID: 31350541. 10.1093/ajh/hpz118 KQ2E5, KQ3E4a, KQ4E4.31350541
183 Kallem RR, Meyers KE, Cucchiara AJ, . Blood pressure variability of two ambulatory blood pressure monitors. Blood pressure monitoring. 2014;19(2):98–102. 10.1097/MBP.0000000000000019 KQ2E1, KQ3E1, KQ4E1.24374722
184 Kamel N, Gursoy A, Koseoglulari O, . Isolated office hypertension: association with target organ damage and cardiovascular risk indices. Journal of the National Medical Association. 2006;98(4):601–6. KQ2E5, KQ3E5, KQ4E4.16623073
185 Kao YT, Huang CC, Leu HB, . Ambulatory pulse pressure as a novel predictor for long-term prognosis in essential hypertensive patients. Journal of human hypertension. 2011;25(7):444–50. KQ2E5, KQ3E5b, KQ4E4.20686500
186 Kario K. Diagnosis of true uncontrolled hypertension using both home and ambulatory blood pressure monitoring. Journal of human hypertension. 2013. KQ2E5, KQ3E10, KQ4E4.
187 Kario K. Global Impact of 2017 American Heart Association/American College of Cardiology Hypertension Guidelines: A Perspective From Japan. Circulation. 2018;137(6):543–5. PMID: 29431656. 10.1161/CIRCULATIONAHA.117.032851 KQ1E7, KQ2E7, KQ3E7, KQ4E7.29431656
188 Kario K, Shimada K, Schwartz JE, . Silent and clinically overt stroke in older Japanese subjects with white-coat and sustained hypertension. Journal of the American College of Cardiology. 2001;38(1):238–45. KQ2E1, KQ3E1, KQ4E1.11451281
189 Karpettas N, Destounis A, Kollias A, . Prediction of treatment-induced changes in target-organ damage using changes in clinic, home and ambulatory blood pressure. Hypertension research. 2014;37(6):543–7. 10.1038/hr.2014.24 KQ2E5, KQ3E4a, KQ4E4.24572912
190 Karwalajtys T, Kaczorowski J, Hutchison B, . Blood pressure variability and prevalence of hypertension using automated readings from multiple visits to a pharmacy-based community-wide programme. Journal of human hypertension. 2009;23(9):585–9. KQ2E4a, KQ3E5b, KQ4E4.19158822
191 Kay LE. Accuracy of blood pressure measurement in the family practice center. The Journal of the American Board of Family Practice. 1998;11(4):252–8. PMID: 9719346. KQ2E3, KQ3E5, KQ4E4.9719346
192 Kenny IE, Saeed S, Gerdts E, . Masked hypertension in obesity: potential predictors and arterial damage. Blood pressure monitoring. 2017;22(1):12–7. 10.1097/MBP.0000000000000220 KQ2E5b, KQ3E5, KQ4E4.27776078
193 Khoury S, Yarows SA, O’Brien TK, . Ambulatory blood pressure monitoring in a nonacademic setting. Effects of age and sex. American journal of hypertension. 1992;5(9):616–23. KQ2E5, KQ3E5b, KQ4E4.1418850
194 Kikuya M, Ohkubo T, Asayama K, . Ambulatory blood pressure and 10-year risk of cardiovascular and noncardiovascular mortality: the Ohasama study. Hypertension. 2005;45(2):240–5. KQ2E1, KQ3E1, KQ4E1.15596571
195 Kim J, Kim E, Yi H, . Short-term incidence rate of hypertension in Korea middle-aged adults. Journal of hypertension. 2006;24(11):2177–82. KQ2E1, KQ3E1, KQ4E1.17053538
196 Kim J, Lee MY, Kim J, . 3c.03: Optimal Duration of Home Blood Pressure Measurements for the Diagnosis of Arterial Hypertension: A Prospective Multicenter Study. Journal of hypertension. 2015;33 Suppl 1:e37. 10.1097/01.hjh.0000467447.76482.cd KQ2E11a, KQ3E11a, KQ4E4.
197 Kim SJ, Lee J, Nam CM, . Progression rate from new-onset pre-hypertension to hypertension in Korean adults. Circ J. 2011;75(1):135–40. KQ2E1, KQ3E1, KQ4E1.21099126
198 Kirkendall WM, Feinleib M, Freis ED, . Recommendations for human blood pressure determination by sphygmomanometers. Subcommittee of the AHA Postgraduate Education Committee. Circulation. 1980;62(5):1146A–55A. KQ2E1, KQ3E1, KQ4E1.
199 Kivimaki M, Batty GD, Singh-Manoux A, . Validating the Framingham Hypertension Risk Score: results from the Whitehall II study. Hypertension. 2009;54(3):496–501. KQ2E1, KQ3E1, KQ4E1.19597041
200 Klarskov P, Bang LE, Schultz-Larsen P, . Intensive versus conventional blood pressure monitoring in a general practice population. The Blood Pressure Reduction in Danish General Practice trial: a randomized controlled parallel group trial. Fam Pract. 2018;35(4):433–9. 10.1093/fampra/cmx106 KQ2E5, KQ3E5b, KQ4E4.29351658
201 Klein R, Klein BE, Moss SE, . The relationship of retinopathy in persons without diabetes to the 15-year incidence of diabetes and hypertension: Beaver Dam Eye Study. Trans Am Ophthalmol Soc. 2006;104:98–107. KQ2E1, KQ3E1, KQ4E1.17471330
202 Kollias A, Andreadis E, Agaliotis G, . The optimal night-time home blood pressure monitoring schedule: agreement with ambulatory blood pressure and association with organ damage. Journal of hypertension. 2018;36(2):243–9. PMID: 28915229. 10.1097/HJH.0000000000001562 KQ2E5, KQ3E4a, KQ4E4.28915229
203 Kotsis V, Stabouli S, Bouldin M, . Impact of obesity on 24-hour ambulatory blood pressure and hypertension. Hypertension. 2005;45(4):602–7. PMID: 15723966. KQ2E4a, KQ3E4a, KQ4E4.15723966
204 Koupil I, Leon DA, Byberg L. Birth weight, hypertension and “white coat” hypertension: size at birth in relation to office and 24-h ambulatory blood pressure. Journal of human hypertension. 2005;19(8):635–42. KQ2E10, KQ3E5, KQ4E4.15944722
205 Krogager C, Laugesen E, Rossen NB, . Evaluation of interarm blood pressure differences using the Microlife WatchBP Office in a clinical setting. Blood pressure monitoring. 2017;22(3):161–5. 10.1097/MBP.0000000000000246 KQ2E5, KQ3E4a, KQ4E4.28234747
206 Kroke A, Fleischhauer W, Mieke S, . Blood pressure measurement in epidemiological studies: a comparative analysis of two methods. Data from the EPIC-Potsdam Study. European Prospective Investigation into Cancer and Nutrition. Journal of hypertension. 1998;16(6):739–46. KQ2E3, KQ3E5, KQ4E4.9663913
207 Kronish IM, Edmondson D, Shimbo D, . A Comparison of the Diagnostic Accuracy of Common Office Blood Pressure Measurement Protocols. American journal of hypertension. 2018;31(7):827–34. PMID: 29897394. 10.1093/ajh/hpy053 KQ2E3, KQ3E5, KQ4E4.29897394
208 Krzesinski P, Gielerak G, Stanczyk A, . The benefit from hemodynamically guided antihypertensive therapy depends on baseline blood pressure. Journal of hypertension [serial on the Internet]. 2015; 33: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01103973/full. KQ2E11a, KQ3E11a, KQ4E4.
209 Krzesinski P, Stanczyk A, Gielerak G, . The diagnostic value of supine blood pressure in hypertension. Arch Med Sci. 2016;12(2):310–8. 10.5114/aoms.2016.59256 KQ2E5b, KQ3E5b, KQ4E4.27186174
210 Kubo T, Fujino Y, Nakamura T, . An industry-based cohort study of the association between weight gain and hypertension risk among rotating shift workers. J Occup Environ Med. 2013;55(9):1041–5. KQ2E1, KQ3E1, KQ4E1.23969502
211 Kuznetsova T, Malyutina S, Pello E, . Ambulatory blood pressure of adults in Novosibirsk, Russia: interim report on a population study. Blood pressure monitoring. 2000;5(5–6):291–6. PMID: 11153053. KQ2E4a, KQ3E5, KQ4E4.11153053
212 Kuznetsova T, Staessen JA, Kawecka-Jaszcz K, . Quality control of the blood pressure phenotype in the European Project on Genes in Hypertension. Blood pressure monitoring. 2002;7(4):215–24. PMID: 12198337. KQ2E4a, KQ3E5, KQ4E4.12198337
213 Kvist TV, Lindholt JS, Rasmussen LM, . The DanCavas Pilot Study of Multifaceted Screening for Subclinical Cardiovascular Disease in Men and Women Aged 65-74 Years. Eur J Vasc Endovasc Surg. 2017;53(1):123–31. 10.1016/j.ejvs.2016.10.010 KQ1E6, KQ4E6.27890524
214 Lakoski SG, Cushman M, Siscovick DS, . The relationship between inflammation, obesity and risk for hypertension in the Multi-Ethnic Study of Atherosclerosis (MESA). Journal of human hypertension. 2011;25(2):73–9. KQ2E1, KQ3E1, KQ4E1.20944659
215 Lamarre-Cliche M, Cheong NN, Larochelle P. Comparative assessment of four blood pressure measurement methods in hypertensives. Canadian Journal of Cardiology. 2011;27(4):455–60. KQ2E5, KQ3E5a, KQ4E4.
216 Landsbergis PA, Travis A, Schnall PL. Working conditions and masked hypertension. High Blood Pressure & Cardiovascular Prevention. 2013;20(2):69–76. KQ2E4a, KQ3E5, KQ4E4.23702576
217 Lang T, De GR, Chatellier G, . Prevalence and therapeutic control of hypertension in 30,000 subjects in the workplace. Hypertension. 2001;38(3):449–54. KQ2E3, KQ3E3, KQ4E4.11566921
218 Lantelme P, Milon H, Vernet M, . Difference between office and ambulatory blood pressure or real white coat effect: does it matter in terms of prognosis? Journal of hypertension. 2000;18(4):383–9. KQ2E5, KQ3E7c, KQ4E4.10779087
219 Larsen TR, Gelaye A, Waanbah B, . Prevalence of masked hypertension in African Americans. J Clin Hypertens. 2014;16(11):801–4. 10.1111/jch.12418 KQ2E4a, KQ3E5, KQ4E4.
220 Lee DH, Ha MH, Kim JR, . Gamma-glutamyltransferase, alcohol, and blood pressure. A four year follow-up study. Ann Epidemiol. 2002;12(2):90–6. KQ2E1, KQ3E1, KQ4E1.11880216
221 Lee DH, Ha MH, Kim JR, . Effects of smoking cessation on changes in blood pressure and incidence of hypertension: a 4-year follow-up study. Hypertension. 2001;37(2):194–8. KQ2E1, KQ3E1, KQ4E1.11230270
222 Lee DH, Ha MH, Kim KY, . Gamma-glutamyltransferase: an effect modifier in the association between age and hypertension in a 4-year follow-up study. Journal of human hypertension. 2004;18(11):803–7. KQ2E1, KQ3E1, KQ4E1.15141269
223 Lee JH, Yang DH, Park HS, . Incidence of hypertension in Korea: 5-year follow-up study. J Korean Med Sci. 2011;26(10):1286–92. KQ2E1, KQ3E1, KQ4E1.22022179
224 Lee JS, Kawakubo K, Kashihara H, . Effect of long-term body weight change on the incidence of hypertension in Japanese men and women. Int J Obes Relat Metab Disord. 2004;28(3):391–5. KQ2E1, KQ3E1, KQ4E1.14724660
225 Leitao CB, Rodrigues TC, Kramer CK, . Which patients with diabetes should undergo ambulatory blood pressure monitoring? Journal of hypertension. 2011;29(2):236–41. 10.1097/HJH.0b013e32834068c3 KQ2E9a, KQ3E9a, KQ4E4.21045725
226 Leitschuh M, Cupples LA, Kannel W, . High-normal blood pressure progression to hypertension in the Framingham Heart Study. Hypertension. 1991;17(1):22–7. KQ2E1, KQ3E1, KQ4E1.1986979
227 Lempiainen P, Vasunta R-L, Bloigu R, . Non-dipping blood pressure pattern and new-onset diabetes in a 21-year follow-up. Blood pressure. 2019. PMID: Pubmed 31092019. 10.1080/08037051.2019.1615369 KQ2E4a, KQ3E5, KQ4E4.31092019
228 Levine DA, Lewis CE, Williams OD, . Geographic and demographic variability in 20-year hypertension incidence: the CARDIA study. Hypertension. 2011;57(1):39–47. KQ2E1, KQ3E1, KQ4E1.21135358
229 Li Y, Zhang L, Wei FF, . Strategies for Classifying Patients Based on Office, Home and Ambulatory Blood Pressure Measurement. Journal of hypertension. 2015;33 Suppl 1:e39. 10.1097/01.hjh.0000467453.47773.9e KQ2E5, KQ3E11a, KQ4E4.
230 Licitra R, Acconcia MC, Puddu PE, . Ambulatory blood pressure monitoring in prehypertensive subjects. Cardiovasc Hematol Disord Drug Targets. 2012;12(1):44–50. KQ2E1, KQ3E1, KQ4E1.22524174
231 Lim YH, Choi SY, Oh KW, . Comparison Between an Automated Device and a Manual Mercury Sphygmomanometer in an Epidemiological Survey of Hypertension Prevalence. American journal of hypertension. 2013. KQ2E3, KQ3E5, KQ4E4.
232 Lindholt JS, Sogaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017;390(10109):2256–65. PMID: 28859943. 10.1016/S0140-6736(17)32250-X KQ1E6, KQ4E6.28859943
233 Little P, Barnett J, Barnsley L, . Comparison of acceptability of and preferences for different methods of measuring blood pressure in primary care. BMJ. 2002;325(7358):258–9. KQ2E1, KQ3E1, KQ4E5b.12153924
234 Liu JE, Roman MJ, Pini R, . Cardiac and arterial target organ damage in adults with elevated ambulatory and normal office blood pressure. Annals of Internal Medicine. 1999;131(8):564–72. KQ2E7, KQ3E7, KQ4E7.10523216
235 Liu Y. Observation on repeatability of grading by casual blood pressure in hypertensives & new proposal. Circ Cardiovasc Qual Outcomes [serial on the Internet]. 2017; 10(Supplement 3) (no pagination): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01469954/full. KQ2E9, KQ3E9, KQ4E9.
236 Mancia G, Bombelli M, Brambilla G, . Long-term prognostic value of white coat hypertension: an insight from diagnostic use of both ambulatory and home blood pressure measurements. Hypertension. 2013;62(1):168–74. PMID: 23716584. KQ2E4a, KQ3E5, KQ4E4.23716584
237 Mancia G, Carugo S, Grassi G, . Prevalence of left ventricular hypertrophy in hypertensive patients without and with blood pressure control: data from the PAMELA population. Pressioni Arteriose Monitorate E Loro Associazioni. Hypertension. 2002;39(3):744–9. KQ2E4a, KQ3E5, KQ4E4.11897756
238 Mancia G, Facchetti R, Parati G, . Effect of long-term antihypertensive treatment on white-coat hypertension. Hypertension. 2014;64(6):1388–98. 10.1161/HYPERTENSIONAHA.114.04278 KQ2E5, KQ3E5, KQ4E4.25245386
239 Mancia G, Ulian L, Parati G, . Increase in blood pressure reproducibility by repeated semi-automatic blood pressure measurements in the clinic environment. Journal of hypertension. 1994;12(4):469–73. KQ2E1, KQ3E1, KQ4E1.8064172
240 Manios E, Michas F, Stamatelopoulos K, . Impact of masking effect on subclinical carotid atherosclerosis in normotensives and untreated masked hypertensive and hypertensive patients. Blood pressure monitoring. 2015;20(2):64–8. 10.1097/MBP.0000000000000093 KQ2E5, KQ3E4a, KQ4E4.25397594
241 Manning G, Rushton L, Millar-Craig MW. Twenty-four hour ambulatory blood pressure: a sample from a normal British population. Journal of human hypertension. 1998;12(2):123–7. KQ2E4a, KQ3E5, KQ4E4c.9504353
242 Manning G, Rushton L, Millar-Craig MW. Clinical implications of white coat hypertension: an ambulatory blood pressure monitoring study. Journal of human hypertension. 1999;13(12):817–22. KQ2E5, KQ3E4a, KQ4E4.10618670
243 Mannucci E, Lambertucci L, Monami M, . Pulse pressure and mortality in hypertensive type 2 diabetic patients. A cohort study. Diabetes/Metabolism Research Reviews. 2006;22(3):172–5. 10.1002/dmrr.598 KQ2E5, KQ3E5b, KQ4E4.
244 Mansoor GA, White WB. Self-measured home blood pressure in predicting ambulatory hypertension. American journal of hypertension. 2004;17(11 Pt 1):1017–22. PMID: 15533727. 10.1016/j.amjhyper.2004.06.015 KQ2E5, KQ3E7c, KQ4E4.15533727
245 Mar J, Pastor R, Abasolo R, . Ambulatory blood pressure monitoring and diagnostic errors in hypertension: a Bayesian approach. Med Decis Making. 1998;18(4):429–35. KQ2E5, KQ3E3, KQ4E4.10372586
246 Maricoto T, Silva EAR, Damiao P, . The OXIMAPA Study: Hypertension Control by ABPM and Association with Sleep Apnea Syndrome by Pulse Oximetry. Acta Med Port. 2017;30(2):93–9. 10.20344/amp.7495 KQ2E5b, KQ3E5b, KQ4E4.28527475
247 Marschang P, Niederwanger A, Gasser RW, . Symptomatic upper extremity deep vein thrombosis as a complication of ambulatory blood pressure monitoring. Thrombosis & Haemostasis. 2008;100(4):711–2. KQ2E1, KQ3E1, KQ4E7.18841298
248 Martinez MA, Garcia-Puig J, Martin JC, . Frequency and determinants of white coat hypertension in mild to moderate hypertension: a primary care-based study. Monitorizacion Ambulatoria de la Presion Arterial (MAPA)-Area 5 Working Group. American journal of hypertension. 1999;12(3):251–9. KQ2E5, KQ3E4a, KQ4E4.10192226
249 Mas-Heredia M, Moles-Moliner E, Gonzalez-de Paz L, . Validity and applicability of a new recording method for hypertension. Rev Esp Cardiol. 2014;67(9):717–23. 10.1016/j.rec.2013.12.017 KQ2E5, KQ3E5a, KQ4E4.25172067
250 Masding MG, Jones JR, Bartley E, . Assessment of blood pressure in patients with Type 2 diabetes: comparison between home blood pressure monitoring, clinic blood pressure measurement and 24-h ambulatory blood pressure monitoring. Diabetic Medicine. 2001;18(6):431–7. PMID: 11472460. KQ2E5b, KQ3E5, KQ4E4.11472460
251 Maselli M, Giantin V, Franchin A, . Detection of blood pressure increments in active elderly individuals: the role of ambulatory blood pressure monitoring. Nutr Metab Cardiovasc Dis. 2014;24(8):914–20. 10.1016/j.numecd.2014.01.003 KQ2E5, KQ3E5, KQ4E4.24548664
252 Matsumoto S, Fukui M, Hamaguchi M, . Clinical characteristics of patients who report incorrect data of home-measured blood pressure. Diabetes Care. 2014;37(2):e24–5. PMID: 103810232. Language: English. Entry Date: 20150116. Revision Date: 20150710. Publication Type: Journal Article. 10.2337/dc13-1821 KQ2E3, KQ3E3, KQ4E4.24459157
253 Matsuo T, Sairenchi T, Suzuki K, . Long-term stable obesity increases risk of hypertension. Int J Obes (Lond). 2011;35(8):1056–62. KQ2E1, KQ3E1, KQ4E1.21042324
254 Mazalovic K, Morlon F, Beis J-N, . Validity of ambulatory blood pressure monitoring in daily primary healthcare practice in France. Blood pressure monitoring. 2018;23(6):288–93. 10.1097/MBP.0000000000000342 KQ2E5, KQ3E4a, KQ4E4.30048256
255 Mazze RS, Simonson GD, Robinson RL, . Characterizing blood pressure control in individuals with Type 2 diabetes: the relationship between clinic and self-monitored blood pressure. Diabetic Medicine. 2003;20(9):752–7. PMID: 12925057. KQ2E3, KQ3E3, KQ4E4.12925057
256 McGowan N, Padfield PL. Self blood pressure monitoring: a worthy substitute for ambulatory blood pressure? Journal of human hypertension. 2010;24(12):801–6. PMID: 20164849. 10.1038/jhh.2010.15 KQ2E5a, KQ3E5, KQ4E5a.20164849
257 McLean DL, McAlister FA, Johnson JA, . A randomized trial of the effect of community pharmacist and nurse care on improving blood pressure management in patients with diabetes mellitus: study of cardiovascular risk intervention by pharmacists-hypertension (SCRIP-HTN). Archives of Internal Medicine. 2008;168:2355–61. KQ2E1, KQ3E1, KQ4E1.19029501
258 McMahon A, McNulty H, Hughes C, ., editors. Investigating the association between the MTHFR C677 T polymorphism and blood pressure as measured by ambulatory blood pressure monitoring. Proc Nutr Soc; 2016; Conference: summer meeting 2016: new technology in nutrition research and practice. Ireland. KQ2E11a, KQ3E11a, KQ4E4.
259 Melgarejo JD, Maestre GE, Thijs L, . Prevalence, Treatment, and Control Rates of Conventional and Ambulatory Hypertension Across 10 Populations in 3 Continents. Hypertension. 2017;70(1):50–8. 10.1161/HYPERTENSIONAHA.117.09188 KQ2E13, KQ3E5, KQ4E4.28483916
260 Mesquita-Bastos J, Bertoquini S, Polonia J. Cardiovascular prognostic value of ambulatory blood pressure monitoring in a Portuguese hypertensive population followed up for 8.2 years. Blood pressure monitoring. 2010;15(5):240–6. KQ2E1, KQ3E1, KQ4E1.20616705
261 Michaud A, Lamarre-Cliche M, Cloutier L. Screening for hypertension: an elevated office blood pressure measurement is valuable, adding an automated one is even better. Blood pressure monitoring. 2019;24(3):123–9. PMID: 30998552. 10.1097/MBP.0000000000000382 KQ2E5, KQ3E7c, KQ4E4.30998552
262 Modesti PA, Pieri F, Cecioni I, . Comparison of ambulatory blood pressure monitoring and conventional office measurement in the workers of a chemical company. International journal of cardiology. 1994;46(2):151–7. KQ2E10, KQ3E5, KQ4E4.7814164
263 Modin D, Biering-Sørensen SR, Mogelvang R, . Prognostic Value of Echocardiography in Hypertensive Versus Nonhypertensive Participants From the General Population. Hypertension (0194911X). 2018;71(4):742–51. 10.1161/HYPERTENSIONAHA.117.10674 KQ2E3, KQ3E5, KQ4E4.
264 Moran A, Palmas W, Pickering TG, . Office and ambulatory blood pressure are independently associated with albuminuria in older subjects with type 2 diabetes. Hypertension. 2006;47(5):955–61. 10.1161/01.HYP.0000216634.73504.7d KQ2E5b, KQ3E5, KQ4E4.16585416
265 Moreira JSR, de Paula TP, Sperb LF, . Association of plasma vitamin D status with lifestyle patterns and ambulatory blood pressure monitoring parameters in patients with type 2 diabetes and hypertension. Diabetes Res Clin Pract. 2018;139:139–46. 10.1016/j.diabres.2018.02.038 KQ2E5, KQ3E5, KQ4E4.29518487
266 Morikawa Y, Nakagawa H, Miura K, . Relationship between shift work and onset of hypertension in a cohort of manual workers. Scand J Work Environ Health. 1999;25(2):100–4. KQ2E1, KQ3E1, KQ4E1.10360464
267 Morrin NM, Stone MR, Henderson KJ. Reproducibility of 24-h ambulatory blood pressure and measures of autonomic function. Blood pressure monitoring. 2017;22(3):169–72. PMID: 28125521. 10.1097/MBP.0000000000000241 KQ2E5, KQ3E5a, KQ4E4.28125521
268 Mortensen RN, Gerds TA, Jeppesen JL, . Office blood pressure or ambulatory blood pressure for the prediction of cardiovascular events. Eur Heart J. 2017;38(44):3296–304. 10.1093/eurheartj/ehx464 KQ2E1, KQ3E1, KQ4E1.29020268
269 Muldoon MF, Nazzaro P, Sutton-Tyrrell K, . White-coat hypertension and carotid artery atherosclerosis: a matching study. Archives of Internal Medicine. 2000;160(10):1507–12. KQ2E4a, KQ3E5, KQ4E4.10826466
270 Muntner P, Woodward M, Mann DM, . Comparison of the Framingham Heart Study hypertension model with blood pressure alone in the prediction of risk of hypertension: the Multi-Ethnic Study of Atherosclerosis. Hypertension. 2010;55(6):1339–45. KQ2E1, KQ3E1, KQ4E1.20439822
271 Musso NR, Vergassola C, Barone C, . Ambulatory blood pressure monitoring: how reproducible is it? American journal of hypertension. 1997;10(8):936–9. PMID: 9270090. KQ2E1, KQ3E1, KQ4E1.9270090
272 Mwasongwe S, Min Y-I, Booth J, . Masked hypertension and kidney function decline: the Jackson Heart Study. Journal of hypertension [serial on the Internet]. 2018; 36(7): Available from:https://www.ncbi.nlm.nih.gov/pmc/articles/PMC5990961/pdf/nihms968864.pdf. KQ2E4a, KQ3E5, KQ4E4.
273 Myers M, Godwin M, Dawes M, . Conventional versus automated measurement of blood pressure in primary care patients with systolic hypertension: randomised parallel design controlled trial. BMJ. 2011;342(7793):372-. KQ2E5, KQ3E5b, KQ4E4.
274 Myers MG. A proposed algorithm for diagnosing hypertension using automated office blood pressure measurement. Journal of hypertension. 2010;28(4):703–8. KQ2E5, KQ3E4a, KQ4E4.20150823
275 Myers MG, Godwin M, Dawes M, . Measurement of blood pressure in the office: recognizing the problem and proposing the solution. Hypertension. 2010;55(2):195–200. PMID: 20038756. 10.1161/HYPERTENSIONAHA.109.141879 KQ2E7, KQ3E7, KQ4E7.20038756
276 Myers MG, Godwin M, Dawes M, . Conventional versus automated measurement of blood pressure in the office (CAMBO) trial. Fam Pract. 2012;29(4):376–82. KQ2E5, KQ3E5b, KQ4E4.22117083
277 Myers MG, Valdivieso M, Chessman M, . Can sphygmomanometers designed for self-measurement of blood pressure in the home be used in office practice? Blood pressure monitoring. 2010;15(6):300–4. PMID: 20975533. 10.1097/MBP.0b013e328340d128 KQ2E5, KQ3E5b, KQ4E4.20975533
278 Myers MG, Valdivieso M, Kiss A. Optimum frequency of office blood pressure measurement using an automated sphygmomanometer. Blood pressure monitoring. 2008;13(6):333–8. KQ2E5, KQ3E4a, KQ4E4.19020423
279 Myers MG, Valdivieso M, Kiss A. Use of automated office blood pressure measurement to reduce the white coat response. Journal of hypertension. 2009;27(2):280–6. KQ2E5b, KQ3E4a, KQ4E1.19155785
280 Nakanishi N, Suzuki K, Tatara K. Clustering of cardiovascular risk factors and risk of development of hypertension in Japanese male office workers. J Cardiovasc Risk. 2003;10(3):213–20. KQ2E1, KQ3E1, KQ4E1.12775955
281 Narita K, Eguchi K, Kario K. Ambulatory blood pressure variability increases over a 19-year follow-up in a clinic on a solitary island. Blood pressure monitoring. 2018;23(6):283–7. PMID: 30048257. 10.1097/MBP.0000000000000343 KQ2E4a, KQ3E5, KQ4E4.30048257
282 Nielsen FS, Gaede P, Vedel P, . White coat hypertension in NIDDM patients with and without incipient and overt diabetic nephropathy. Diabetes Care. 1997;20(5):859–63. PMID: 9135956. KQ2E5, KQ3E4a, KQ4E4.9135956
283 Nielsen PE, Christensen HR, Hilden T. Ambulatory daytime blood pressure in relation to age and gender compared to previous population studies based on office blood pressure. The Danish Study Group on Ambulatory Blood Pressure. Journal of human hypertension. 1996;10:Suppl-8. KQ2E7, KQ3E7, KQ4E7.
284 Niiranen TJ, Asayama K, Thijs L, . Optimal number of days for home blood pressure measurement. American journal of hypertension. 2015;28(5):595–603. 10.1093/ajh/hpu216 KQ2E3, KQ3E5, KQ4E4.25399016
285 Niiranen TJ, Hanninen MR, Johansson J, . Home-measured blood pressure is a stronger predictor of cardiovascular risk than office blood pressure: the Finn-Home study. Hypertension. 2010;55(6):1346–51. KQ2E1, KQ3E1, KQ4E1.20385970
286 Niiranen TJ, Jula AM, Kantola IM, . Comparison of agreement between clinic and home-measured blood pressure in the Finnish population: the Finn-HOME Study. Journal of hypertension. 2006;24(8):1549–55. PMID: 16877957. 10.1097/01.hjh.0000239290.94764.81 KQ2E3, KQ3E5, KQ4E4.16877957
287 Nilsson PM, Engstrom G, Hedblad B. Long-term predictors of increased mortality risk in screened men with new hypertension; the Malmo preventive project. Journal of hypertension. 2008;26(12):2288–94. 10.1097/HJH.0b013e32831313b1 KQ1E6, KQ4E4.19008707
288 Ntineri A, Nasothimiou E, Kollias A, . 3c.05: Diagnostic Agreement of the European Society of Hypertension Home Blood Monitoring Schedule with Ambulatory Blood Pressure Monitoring in Untreated and Treated Subjects. Journal of hypertension. 2015;33 Suppl 1:e38. 10.1097/01.hjh.0000467449.84105.d0 KQ2E11a, KQ3E11a, KQ4E4.
289 Nystrom F, Malmstrom O, Karlberg BE, . Twenty-four hour ambulatory blood pressure in the population. Journal of Internal Medicine. 1996;240(5):279–84. KQ2E4a, KQ3E5, KQ4E4.8946810
290 O’Brien E, Murphy J, Tyndall A, . Twenty-four-hour ambulatory blood pressure in men and women aged 17 to 80 years: the Allied Irish Bank Study. Journal of hypertension. 1991;9(4):355–60. KQ2E4a, KQ3E5, KQ4E4.1646262
291 O’Shea JC, Murphy MB. Ambulatory blood pressure monitoring: which arm? Journal of human hypertension. 2000;14(4):227–30. KQ2E5, KQ3E4a, KQ4E4.10805046
292 Ogedegbe G, Pickering TG, Clemow L, . The misdiagnosis of hypertension: the role of patient anxiety. Arch Intern Med. 2008;168(22):2459–65. KQ2E5, KQ3E5, KQ4E4.19064830
293 Ohkubo T, Asayama K, Kikuya M, . How many times should blood pressure be measured at home for better prediction of stroke risk? Ten-year follow-up results from the Ohasama study. Journal of hypertension. 2004;22(6):1099–104. KQ2E1, KQ3E1, KQ4E1.15167443
294 Ohkubo T, Asayama K, Kikuya M, . Prediction of ischaemic and haemorrhagic stroke by self-measured blood pressure at home: the Ohasama study. Blood pressure monitoring. 2004;9(6):315–20. KQ2E1, KQ3E1, KQ4E1.15564987
295 Ohkubo T, Hozawa A, Nagai K, . Prediction of stroke by ambulatory blood pressure monitoring versus screening blood pressure measurements in a general population: the Ohasama study. Journal of hypertension. 2000;18(7):847–54. KQ2E1, KQ3E1, KQ4E1.10930181
296 Ohkubo T, Imai Y, Tsuji I, . Home blood pressure measurement has a stronger predictive power for mortality than does screening blood pressure measurement: a population-based observation in Ohasama, Japan. Journal of hypertension. 1998;16(7):971–5. KQ2E1, KQ3E1, KQ4E1.9794737
297 Ohkubo T, Imai Y, Tsuji I, . Prediction of mortality by ambulatory blood pressure monitoring versus screening blood pressure measurements: a pilot study in Ohasama. Journal of hypertension. 1997;15(4):357–64. KQ2E1, KQ3E1, KQ4E1.9211170
298 Ohkubo T, Kikuya M, Metoki H, . Prognosis of “masked” hypertension and “white-coat” hypertension detected by 24-h ambulatory blood pressure monitoring 10-year follow-up from the Ohasama study. Journal of the American College of Cardiology. 2005;46(3):508–15. KQ2E1, KQ3E1, KQ4E1.16053966
299 Okubo Y, Sairenchi T, Irie F, . Association of alcohol consumption with incident hypertension among middle-aged and older Japanese population: the Ibarakai prefectural health study (IPHS). Hypertension. 2014;63(1):41–7. KQ2E1, KQ3E1, KQ4E1.24126168
300 Okubo Y, Suwazono Y, Kobayashi E, . An association between smoking habits and blood pressure in normotensive Japanese men: a 5-year follow-up study. Drug Alcohol Depend. 2004;73(2):167–74. KQ2E1, KQ3E1, KQ4E1.14725956
301 Omboni S, Aristizabal D, De la Sierra A, . Hypertension types defined by clinic and ambulatory blood pressure in 14 143 patients referred to hypertension clinics worldwide. Data from the ARTEMIS study. Journal of hypertension. 2016;34(11):2187–98. PMID: 27512964. 10.1097/HJH.0000000000001074 KQ2E5, KQ3E13, KQ4E4.27512964
302 Ormezzano O, Baguet JP, Francois P, . Is there any real target organ damage associated with white-coat normotension? Clinical Autonomic Research. 2004;14(3):160–6. KQ2E4a, KQ3E5, KQ4E4.15241644
303 Ostchega Y, Nwankwo T, Sorlie PD, . Assessing the validity of the Omron HEM907XL oscillometric blood pressure measurement device in a National Survey environment. Journal of clinical hypertension (Greenwich, Conn). 2010;12(1):22–8. KQ2E3, KQ3E5, KQ4E4.
304 Otsuka K, Okajima K, Oinuma S, . Aging and circadian disruption of blood pressure observed using 7-day/24-hour ambulatory blood pressure monitoring. J Am Geriatr Soc. 2014;62(11):2213–5. 10.1111/jgs.13115 KQ2E1, KQ3E1, KQ4E1.25413195
305 Owens P, Lyons S, O’Brien E. Ambulatory blood pressure in the hypertensive population: patterns and prevalence of hypertensive subforms. Journal of hypertension. 1998;16(12:Pt 1):t–43. KQ2E5, KQ3E4a, KQ4E4.
306 Ozdemir FN, Guz G, Sezer S, . Ambulatory blood pressure monitoring in potential renal transplant donors. Nephrol Dial Transplant. 2000;15(7):1038–40. PMID: 10862644. KQ2E9, KQ3E9, KQ4E9.10862644
307 Padwal R, Rashead M, Snider J, . Worksite-based cardiovascular risk screening and management: a feasibility study. Vasc Health Risk Manag. 2017;13:209–13. 10.2147/VHRM.S138800 KQ1E7, KQ4E4.28652760
308 Padwal RS, Townsend RR, Trudeau L, . Comparison of an in-pharmacy automated blood pressure kiosk to daytime ambulatory blood pressure in hypertensive subjects. Journal of the American Society of Hypertension. 2015;9(2):123–9. PMID: 25600420. 10.1016/j.jash.2014.11.004 KQ2E5b, KQ3E5b, KQ4E4.25600420
309 Palatini P, Pessina A, Dal Palu C. The Hypertension and Ambulatory Recording Venetia Study (HARVEST): a trial on the predictive value of ambulatory blood pressure monitoring for the development of fixed hypertension in patients with borderline hypertension. High Blood Press. 1993;2:11–8. KQ2E5, KQ3E10, KQ4E4.
310 Palatini P, Reboldi G, Beilin LJ, . Prognostic Value of Ambulatory Blood Pressure in the Obese: The Ambulatory Blood Pressure-International Study. J Clin Hypertens. 2016;18(2):111–8. 10.1111/jch.12700 KQ2E4b, KQ3E4a, KQ4E4.
311 Palatini P, Reboldi G, Beilin LJ, . Masked tachycardia. A predictor of adverse outcome in hypertension. Journal of hypertension. 2017;35(3):487–92. PMID: 27930441. 10.1097/HJH.0000000000001194 KQ2E1, KQ3E1, KQ4E1.27930441
312 Palatini P, Saladini F, Mos L, . Clinical characteristics and risk of hypertension needing treatment in young patients with systolic hypertension identified with ambulatory monitoring. Journal of hypertension. 2018;36(9):1810–5. PMID: 30005026. 10.1097/hjh.0000000000001754 KQ2E4a, KQ3E5, KQ4E4.30005026
313 Palatini P, Thijs L, Staessen JA, . Predictive value of clinic and ambulatory heart rate for mortality in elderly subjects with systolic hypertension. Archives of Internal Medicine. 2002;162(20):2313–21. KQ2E1, KQ3E1, KQ4E1.12418945
314 Palatini P, Winnicki M, Santonastaso M, . Prevalence and clinical significance of isolated ambulatory hypertension in young subjects screened for stage 1 hypertension. Hypertension. 2004;44(2):170–4. PMID: 15210653. 10.1161/01.HYP.0000135250.57004.19 KQ2E5, KQ3E10, KQ4E4.15210653
315 Pang TC, Brown MA. Accuracy of ambulatory blood pressure monitors in routine clinical practice. American journal of hypertension. 2006;19(8):801–9. PMID: 16876678. KQ2E5, KQ3E4a, KQ4E4.16876678
316 Pannarale G, Bebb G, Clark S, . Bias and variability in blood pressure measurement with ambulatory recorders. Hypertension. 1993;22(4):591–8. KQ2E4, KQ3E5, KQ4E4.8406665
317 Pannarale G, Gaudio C, Mirabelli F, . Ambulatory monitoring predicts development of drug-treated hypertension in subjects with high normal blood pressure. Blood Press. 2004;13(4):247–51. PMID: 15581340. KQ2E5, KQ3E5, KQ4E4.15581340
318 Pannarale G, Moroni C, Acconcia MC, . The natural history of prehypertension. A 20-year follow-up. Eur Rev Med Pharmacol Sci. 2017;21(6):1329–34. KQ2E5, KQ3E4a, KQ4E4.28387894
319 Parati G, Omboni S, Bilo G. Why Is Out-of-Office Blood Pressure Measurement Needed? Home Blood Pressure Measurements Will Increasingly Replace Ambulatory Blood Pressure Monitoring in the Diagnosis and Management of Hypertension. Hypertension. 2009. KQ2E7, KQ3E7, KQ4E7.
320 Parati G, Omboni S, Staessen J, . Limitations of the difference between clinic and daytime blood pressure as a surrogate measure of the ‘white-coat’ effect. Syst-Eur investigators. Journal of hypertension. 1998;16(1):23–9. PMID: 9533413. KQ2E5, KQ3E4a, KQ4E4.9533413
321 Pavlik VN, Hyman DJ, Toronjo C. Comparison of Automated and Mercury Column Blood Pressure Measurements in Health Care Settings. Journal of clinical hypertension (Greenwich, Conn). 2000;2(2):81–6. KQ2E3, KQ3E3, KQ4E4.
322 Pessanha P, Viana M, Ferreira P, . Diagnostic value and cost-benefit analysis of 24 hours ambulatory blood pressure monitoring in primary care in Portugal. BMC Cardiovascular Disorders. 2013;13:57. KQ2E5, KQ3E4a, KQ4E4.23937261
323 Peters GL, Binder SK, Campbell NR. The effect of crossing legs on blood pressure: a randomized single-blind cross-over study. Blood pressure monitoring. 1999;4(2):97–101. KQ2E3, KQ3E5, KQ4E4.10450120
324 Petersen EH, Theilade S, Hansen TW, . Cuff inflations do not affect night-time blood pressure: comparison of 24h ambulatory blood pressure measured by a cuff and a tonometric device in type 2 diabetes. Blood pressure monitoring. 2015;20(6):369–72. 10.1097/MBP.0000000000000140 KQ2E6, KQ3E6, KQ4E4.26154852
325 Piantanida E, Gallo D, Veronesi G, . Masked hypertension in newly diagnosed hypothyroidism: a pilot study. J Endocrinol Invest. 2016;39(10):1131–8. 10.1007/s40618-016-0488-7 KQ2E5, KQ3E5, KQ4E4.27193102
326 Pickering TG. Should doctors still measure blood pressure? Journal of Clinical Hypertension. 2006;8(6):394–6. KQ2E7, KQ3E7, KQ4E7.16760676
327 Pickering TG, Shimbo D, Haas D. Ambulatory blood-pressure monitoring. N Engl J Med. 2006;354(22):2368–74. PMID: 354/22/2368 [pii];10.1056/NEJMra060433 [doi]. KQ2E7, KQ3E7, KQ4E7.16738273
328 Pierdomenico SD, Lapenna D, Bucci A, . Cardiovascular outcome in treated hypertensive patients with responder, masked, false resistant, and true resistant hypertension. American journal of hypertension. 2005;18(11):1422–8. KQ2E1, KQ3E1, KQ4E1.16280275
329 Pierdomenico SD, Mezzetti A, Lapenna D, . ‘White-coat’ hypertension in patients with newly diagnosed hypertension: evaluation of prevalence by ambulatory monitoring and impact on cost of health care. Eur Heart J. 1995;16(5):692–7. KQ2E5, KQ3E4a, KQ4E4.7588903
330 Pincomb GA, Lovallo WR, McKey BS, . Acute blood pressure elevations with caffeine in men with borderline systemic hypertension. Am J Cardiol. 1996;77(4):270–4. KQ2E3, KQ3E5, KQ4E4.8607407
331 Player MS, King DE, Mainous AG, III, . Psychosocial factors and progression from prehypertension to hypertension or coronary heart disease. Ann Fam Med. 2007;5(5):403–11. KQ2E1, KQ3E1, KQ4E1.17893381
332 Polonia JJ, Gama GM, Silva JA, . Sequential follow-up clinic and ambulatory blood pressure evaluation in a low risk population of white-coat hypertensive patients and in normotensives. Blood pressure monitoring. 2005;10(2):57–64. KQ2E7, KQ3E7, KQ4E4.15812251
333 Pugliese DN, Booth JN, 3rd, Deng L, . Sex differences in masked hypertension: the Coronary Artery Risk Development in Young Adults study. Journal of hypertension. 2019;24:24. PMID: 31246891. 10.1097/HJH.0000000000002175 KQ2E4a, KQ3E5, KQ4E4.31246891
334 Punzi HA. Efficacy and safety of olmesartan/amlodipine/hydrochlorothiazide in patients with hypertension not at goal with mono, dual or triple drug therapy: results of the CHAMPiOn study. Ther Adv Cardiovasc Dis. 2014;8(1):12–21. 10.1177/1753944713520062 KQ2E5, KQ3E5, KQ4E4.24492985
335 Rabkin SW, Mathewson FAL, Hsu PH. Relation of body weight to development of ischemic heart disease in a cohort of young north American men after a 26 year observation period: The manitoba study. Am J Cardiol. 1977;39(3):452–8. KQ2E1, KQ3E1, KQ4E1.842466
336 Radi S, Lang T, Lauwers-Cances V, . One-year hypertension incidence and its predictors in a working population: the IHPAF study. Journal of human hypertension. 2004;18(7):487–94. KQ2E3, KQ3E3, KQ4E4.14961044
337 Raptis AE, Spring MW, Viberti G. Comparison of blood pressure measurement methods in adult diabetics. Lancet. 1997;349:175–6. KQ2E3, KQ3E3, KQ4E4.
338 Ravenell J, Shimbo D, Booth Iii JN, . Thresholds for Ambulatory Blood Pressure Among African Americans in the Jackson Heart Study. Circulation. 2017;135(25):2470–80. 10.1161/CIRCULATIONAHA.116.027051 KQ2E4, KQ3E5, KQ4E4.28428231
339 Redmond N, Booth JN, 3rd, Tanner RM, . Prevalence of Masked Hypertension and Its Association With Subclinical Cardiovascular Disease in African Americans: Results From the Jackson Heart Study. J Am Heart Assoc. 2016;5(3):e002284. 10.1161/JAHA.115.002284 KQ2E4a, KQ3E5, KQ4E4.27025968
340 Reino-Gonzalez S, Pita-Fernandez S, Cibiriain-Sola M, . Validity of clinic blood pressure compared to ambulatory monitoring in hypertensive patients in a primary care setting. Blood Press. 2015;24(2):111–8. 10.3109/08037051.2014.992197 KQ2E5b, KQ3E5b, KQ4E4.25588075
341 Rhee MY, Kim SW, Choi EH, . Prevalence of Masked Hypertension: a Population-Based Survey in a Large City by Using 24-Hour Ambulatory Blood Pressure Monitoring. Korean circ. 2016;46(5):681–7. KQ2E4a, KQ3E5, KQ4E4.
342 Rinfret F, Cloutier L, Larochelle P, . Impact of devices and environments on automated office blood pressure measurements. Canadian journal of cardiology. 2017;33(10):S175-. KQ2E3, KQ3E5, KQ4E4.
343 Rizzoni D, Muiesan ML, Montani G, . Relationship between initial cardiovascular structural changes and daytime and nighttime blood pressure monitoring.[Erratum appears in Am J Hypertens 1993 Feb;6(2):177]. American journal of hypertension. 1992;5(3):180–6. KQ2E5, KQ3E4a, KQ4E4.1575945
344 Rollnik JD, Kugler J. Sphygmomanometry induces different blood pressure changes in normotensive and untreated (borderline) hypertensive subjects. Journal of hypertension. 1999;17(2):303–4. KQ2E3, KQ3E3, KQ4E4.10067801
345 Ruxer J, Mozdzan M, Baranski M, . “White coat hypertension” in type 2 diabetic patients. Polskie Archiwum Medycyny Wewnetrznej. 2007;117(10):452–6. KQ2E5, KQ3E4a, KQ4E4.18320786
346 Ryan JM, Howes LG. White coat effect of alcohol. American journal of hypertension. 2000;13(10):1135–8. KQ2E4a, KQ3E5, KQ4E4.11041169
347 Sakuma M, Imai Y, Tsuji I, . Predictive value of home blood pressure measurement in relation to stroke morbidity: a population-based pilot study in Ohasama, Japan. Hypertension research. 1997;20(3):167–74. KQ2E1, KQ3E1, KQ4E1.9328797
348 Salazar MR, Espeche WG, Aizpurua M, . Should the first blood pressure reading be discarded? Journal of human hypertension. 2015;29(6):373–8. 10.1038/jhh.2014.98 KQ2E4b, KQ3E4b, KQ4E4.25339293
349 Sandrim VC, Yugar-Toledo JC, Desta Z, . Endothelial nitric oxide synthase haplotypes are related to blood pressure elevation, but not to resistance to antihypertensive drug therapy. Journal of hypertension. 2006;24(12):2393–7. KQ2E1, KQ3E1, KQ4E1.17082721
350 Satoh H, Saijo Y, Kishi R, . Brachial-ankle pulse wave velocity is an independent predictor of incident hypertension in Japanese normotensive male subjects. Environ Health Prev Med. 2011;16(4):217–23. KQ2E1, KQ3E1, KQ4E1.21431793
351 Schettini C, Bianchi M, Nieto F, . Ambulatory blood pressure: normality and comparison with other measurements. Hypertension Working Group. Hypertension. 1999;34(4:Pt 2):t–25. KQ2E9, KQ3E9, KQ4E9.
352 Schrader J, Lüders S, Züchner C, . Practice vs ambulatory blood pressure measurement under treatment with ramipril (PLUR Study): a randomised, prospective long-term study to evaluate the benefits of ABPM in patients on antihypertensive treatment. Journal of human hypertension. 2000;14:435–40. KQ2E5, KQ3E4a, KQ4E4.10918548
353 Schulz M, Liese AD, Boeing H, . Associations of short-term weight changes and weight cycling with incidence of essential hypertension in the EPIC-Potsdam Study. Journal of human hypertension. 2005;19(1):61–7. KQ2E1, KQ3E1, KQ4E1.15343355
354 Schulze MB, Hoffmann K, Kroke A, . Risk of hypertension among women in the EPIC-Potsdam Study: comparison of relative risk estimates for exploratory and hypothesis-oriented dietary patterns. American journal of epidemiology. 2003;158(4):365–73. KQ2E1, KQ3E1, KQ4E1.12915502
355 Schwan A. Postural effects on diastolic blood pressure are differently recorded by a non-invasive ambulatory blood pressure monitor and a standard auscultatory device. Clinical Physiology. 1993;13:621–9. KQ2E3, KQ3E5, KQ4E4.8119056
356 Schwartz C, Koshiaris C, Clark C, . 1b.10: Does the Right Arm Know What the Left Arm Is Doing? Ethnic Variations in Clinical Interarm Difference and Relationship to White Coat Effects. Journal of hypertension. 2015;33 Suppl 1:e7. 10.1097/01.hjh.0000467372.96193.86 KQ2E1, KQ3E1, KQ4E1.
357 Schwartz CL, Clark C, Koshiaris C, . Interarm Difference in Systolic Blood Pressure in Different Ethnic Groups and Relationship to the “White Coat Effect”: A Cross-Sectional Study. American journal of hypertension. 2017;30(9):884–91. 10.1093/ajh/hpx073 KQ2E4a, KQ3E5, KQ4E4.28475667
358 Schwartz JE, Burg MM, Shimbo D, . Clinic Blood Pressure Underestimates Ambulatory Blood Pressure in an Untreated Employer-Based US Population: Results From the Masked Hypertension Study. Circulation. 2016;134(23):1794–807. PMID: 27920072. 10.1161/circulationaha.116.023404 KQ2E1, KQ3E5, KQ4E4.27920072
359 Scisney-Matlock M, Grand A, Steigerwalt SP, . Reliability and reproducibility of clinic and home blood pressure measurements in hypertensive women according to age and ethnicity. Blood pressure monitoring. 2009;14(2):49–57. KQ2E5, KQ3E5b, KQ4E4.19305185
360 Segura J, Banegas JR, Ruilope LM. Usefulness of ambulatory blood pressure monitoring (ABPM) in daily clinical practice: Data from the Spanish ABPM registry. Clin Exp Pharmacol Physiol. 2014;41(1):30–6. PMID: 23710883. 10.1111/1440-1681.12126 KQ2E7, KQ3E7, KQ4E7.23710883
361 Seo J, Lee CJ, Oh J, . Large discrepancy between unobserved automated office blood pressure and ambulatory blood pressure in a high cardiovascular risk cohort. Journal of hypertension. 2019;37(1):42–9. PMID: 30507862. 10.1097/HJH.0000000000001868 KQ2E5, KQ3E5a, KQ4E4.30507862
362 Seravalle G, Bombelli M, Villa P, ., editors. 24-h systolic blood pressure load represents an important variable in determining the cardiovascular risk of white-coat hypertension. Eur Heart J; 2017; Conference: European Society of Cardiology, ESC Congress 2017. Spain. KQ2E11a, KQ3E5, KQ4E4.
363 Sheppard JP, Martin U, Gill P, . Prospective external validation of the Predicting Out-of-OFfice Blood Pressure (PROOF-BP) strategy for triaging ambulatory monitoring in the diagnosis and management of hypertension: observational cohort study. BMJ. 2018;361:k2478. 10.1136/bmj.k2478 KQ2E6, KQ3E6, KQ4E4.29950396
364 Sheps SG, Bailey KR, Zachariah PK. Short-term (six hour), ambulatory blood pressure monitoring. Journal of human hypertension. 1994;8(12):873–8. KQ2E4, KQ3E5, KQ4E4.7884784
365 Shimbo D, Kuruvilla S, Haas D, . Preventing misdiagnosis of ambulatory hypertension: algorithm using office and home blood pressures. Journal of hypertension. 2009;27(9):1775–83. KQ2E5, KQ3E7c, KQ4E4.19491703
366 Shimbo D, Muntner P. Should Out-of-Office Monitoring Be Performed for Detecting White Coat Hypertension? Ann Intern Med. 2019. PMID: 31181573. 10.7326/m19-1134 KQ1E7, KQ2E7, KQ3E7, KQ4E7.31181573
367 Shimbo D, Muntner P, Mann D, . Endothelial dysfunction and the risk of hypertension: the multi-ethnic study of atherosclerosis. Hypertension. 2010;55(5):1210–6. PMID: 20308612. KQ2E3, KQ3E5, KQ4E4.20308612
368 Shimbo D, Pickering TG, Spruill TM, . Relative utility of home, ambulatory, and office blood pressures in the prediction of end-organ damage. American journal of hypertension. 2007;20(5):476–82. KQ2E5, KQ3E4b, KQ4E4.17485006
369 Shin J, Xu E, Lim YH, . Relationship between nocturnal blood pressure and 24-h urinary sodium excretion in a rural population in Korea. Clin Hypertens. 2014;20:9. 10.1186/2056-5909-1-3 KQ2E1, KQ3E1, KQ4E4.26909196
370 Shook RP, Lee DC, Sui X, . Cardiorespiratory fitness reduces the risk of incident hypertension associated with a parental history of hypertension. Hypertension. 2012;59(6):1220–4. KQ2E1, KQ3E1, KQ4E1.22585947
371 Silveira A, Mesquita A, Maldonado J, . White coat effect in treated and untreated patients with high office blood pressure. Relationship with pulse wave velocity and left ventricular mass index. Revista Portuguesa de Cardiologia. 2002;21(5):517–30. KQ2E4a, KQ3E4a, KQ4E4.12174516
372 Smirnova M, Britov AN, Platonova EM, . 1b.06: Masked Hypertension Prevalence and Its Markers in Organized Cohort. Journal of hypertension. 2015;33 Suppl 1:e6. 10.1097/01.hjh.0000467368.42828.71 KQ2E4a, KQ3E4a, KQ4E4.
373 Sova M, Sovova E, Hobzova M, . The effect of continuous positive airway pressure therapy on the prevalence of masked hypertension in obstructive sleep apnea patients. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2015;159(2):277–82. 10.5507/bp.2014.063 KQ2E5, KQ3E5, KQ4E4.25559094
374 Spruill TM, Shallcross AJ, Ogedegbe G, . Psychosocial Correlates of Nocturnal Blood Pressure Dipping in African Americans: The Jackson Heart Study. American journal of hypertension. 2016;29(8):904–12. 10.1093/ajh/hpw008 KQ2E4a, KQ3E5, KQ4E4.26869251
375 Staessen J, Amery A. APTH-a trial on ambulatory blood pressure monitoring and treatment of hypertension: objectives and protocol. Acta Cardiol. 1993;48(1):25–42. KQ2E5, KQ3E4a, KQ4E4.8383396
376 Staessen JA, Bieniaszewski L, O’Brien ET, . An epidemiological approach to ambulatory blood pressure monitoring:the Belgian Population Study. Blood pressure monitoring. 1996;1(1):13–26. PMID: 10226197. KQ2E4a, KQ3E5, KQ4E4.10226197
377 Staessen JA, Byttebier G, Buntinx F, . Antihypertensive treatment based on conventional or ambulatory blood pressure measurement. A randomized controlled trial. Ambulatory Blood Pressure Monitoring and Treatment of Hypertension Investigators. Jama. 1997;278(13):1065–72. KQ2E5, KQ3E4, KQ4E4.9315764
378 Staessen JA, Celis H, Hond ED, . Comparison of conventional and automated blood pressure measurements: interim analysis of the THOP trial. Treatment of Hypertension According to Home or Office Blood Pressure. Blood pressure monitoring. 2002;7(1):61–2. KQ2E1, KQ3E5b, KQ4E4.12040246
379 Staessen JA, Den HE, Celis H, . Antihypertensive treatment based on blood pressure measurement at home or in the physician’s office: a randomized controlled trial. Jama. 2004;291(8):955–64. KQ2E5, KQ3E10, KQ4E4.14982911
380 Staessen JA, Fagard R, Lijnen P, . Ambulatory blood pressure and blood pressure measured at home: progress report on a population study. Journal of Cardiovascular Pharmacology. 1994;23 Suppl 5:S5–11. KQ2E4b, KQ3E5, KQ4E4.7609507
381 Staessen JA, Fagard R, Thijs L, . Randomised double-blind comparison of placebo and active treatment for older patients with isolated systolic hypertension. The Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. Lancet. 1997;350(9080):757–64. KQ2E1, KQ3E1, KQ4E1.9297994
382 Staessen JA, Hansen TW, ¤ger WH. Added VALUE of an ancillary study on ambulatory blood pressure monitoring. Journal of hypertension. 2007;25(3):513–5. KQ2E7, KQ3E7, KQ4E7.17278965
383 Staessen JA, O’Brien ET, Amery AK, . Ambulatory blood pressure in normotensive and hypertensive subjects: results from an international database. J Hypertens Suppl. 1994;12(7):S1–12. PMID: 7769499. KQ2E4a, KQ3E4a, KQ4E4.7769499
384 Staessen JA, Thijs L, Fagard R, . Predicting cardiovascular risk using conventional vs ambulatory blood pressure in older patients with systolic hypertension. Systolic Hypertension in Europe Trial Investigators. Jama. 1999;282(6):539–46. KQ2E1, KQ3E1, KQ4E1.10450715
385 Staessen JA, Thijs L, O’Brien ET, . Ambulatory pulse pressure as predictor of outcome in older patients with systolic hypertension. American journal of hypertension. 2002;15(10 Pt 1):835–43. KQ2E1, KQ3E1, KQ4E1.12372669
386 Stergiou GS, Asayama K, Thijs L, . Prognosis of white-coat and masked hypertension: International Database of HOme blood pressure in relation to Cardiovascular Outcome. Hypertension. 2014;63(4):675–82. 10.1161/hypertensionaha.113.02741 KQ2E3, KQ3E5, KQ4E4.24420553
387 Strachan MW, Gough K, McKnight JA, . Ambulatory blood pressure monitoring: is it necessary for the routine assessment of hypertension in people with diabetes? Diabetic Medicine. 2002;19(9):787–9. PMID: 12207818. KQ2E5, KQ3E4a, KQ4E4.12207818
388 Suarez C, del AC, Garcia-Polo I. Ambulatory blood pressure monitoring: is the daytime period enough for making clinical decisions? Blood pressure monitoring. 2003;8(6):267–70. KQ2E5, KQ3E5b, KQ4E4.14688558
389 Sung KC, Lim S, Rosenson RS. Hyperinsulinemia and homeostasis model assessment of insulin resistance as predictors of hypertension: a 5-year follow-up study of Korean sample. American journal of hypertension. 2011;24(9):1041–5. KQ2E1, KQ3E1, KQ4E1.21614095
390 Sung KC, Wild SH, Byrne CD. Development of new fatty liver, or resolution of existing fatty liver, over five years of follow-up, and risk of incident hypertension. J Hepatol. 2014. KQ2E1, KQ3E1, KQ4E1.
391 Sung SH, Cheng HM, Wang KL, . White coat hypertension is more risky than prehypertension: important role of arterial wave reflections. Hypertension. 2013;61(6):1346–53. KQ2E4a, KQ3E5, KQ4E4.23608649
392 Suzuki H, Kobayashi K, Okada H. Combination of Echocardiography and Pulse Wave Velocity Provides Clues for the Differentiation between White Coat Hypertension and Hypertension in Postmenopausal Women. Pulse. 2014;1(3–4):131–8. 10.1159/000360977 KQ2E3, KQ3E5, KQ4E4.26587432
393 Svendsen M, Tonstad S, Heggen E, . The effect of kiwifruit consumption on blood pressure in subjects with moderately elevated blood pressure: a randomized, controlled study. Blood Press. 2015;24(1):48–54. 10.3109/08037051.2014.976979 KQ2E5, KQ3E4a, KQ4E4.25483553
394 Tadic M, Bombelli M, Villa P, . 24-hour systolic blood pressure load represents an important variable in determining the cardiovascular RIK profile of white-coat hypertension. Journal of hypertension [serial on the Internet]. 2017; 35: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01407109/full. KQ2E11a, KQ3E5, KQ4E4.
395 Takeno K, Mita T, Nakayama S, . Masked hypertension, endothelial dysfunction, and arterial stiffness in type 2 diabetes mellitus: a pilot study. American journal of hypertension. 2012;25(2):165–70. KQ2E4a, KQ3E5, KQ4E4.22089111
396 Talleruphuus U, Bang LE, Wiinberg N, . Isolated systolic hypertension in an elderly Danish population. Prevalence and daytime ambulatory blood pressure. Blood Press. 2006;15(6):347–53. KQ2E5, KQ3E4a, KQ4E4.17472025
397 Tanabe P, Persell SD, Adams JG, . Increased blood pressure in the emergency department: pain, anxiety, or undiagnosed hypertension? Ann Emerg Med. 2008;51(3):221–9. KQ2E2, KQ3E2, KQ4E4.18207606
398 Taner A, Unlu A, Kayrak M, . The value of serum asymmetric dimethylarginine levels for the determination of masked hypertension in patients with diabetes mellitus. Atherosclerosis. 2013;228(2):432–7. 10.1016/j.atherosclerosis.2013.02.024 KQ2E9, KQ3E9, KQ4E9.23540293
399 Tanner RM, Shimbo D, Seals SR, . White-Coat Effect Among Older Adults: Data From the Jackson Heart Study. J Clin Hypertens. 2016;18(2):139–45. 10.1111/jch.12644 KQ2E4a, KQ3E5, KQ4E4.
400 Theilade S, Lajer M, Joergensen C, . Discrepancy between tonometric ambulatory and cuff-based office blood pressure measurements in patients with type 1 diabetes. Journal of Clinical Hypertension. 2012;14(10):686–93. KQ2E3, KQ3E5, KQ4E4.23031146
401 Thijs L, Hansen TW, Kikuya M, . The International Database of Ambulatory blood pressure in relation to Cardiovascular Outcome (IDACO): protocol and research perspectives. Blood pressure monitoring. 2007;12(4):255–62. KQ2E13, KQ3E5, KQ4E4.17760218
402 Thijs L, Staessen J, Fagard R, . Number of measurements required for the analysis of diurnal blood pressure profile. Journal of human hypertension. 1994;8(4):239–44. KQ2E5, KQ3E5, KQ4E4.8021903
403 Thijs L, Staessen JA, Celis H, . The international database of self-recorded blood pressures in normotensive and untreated hypertensive subjects. Blood pressure monitoring. 1999;4(2):77–86. PMID: 10450117. KQ2E3, KQ3E5, KQ4E4.10450117
404 Thomas O, Shipman KE, Day K, . Prevalence and determinants of white coat effect in a large UK hypertension clinic population. Journal of human hypertension. 2016;30(6):386–91. 10.1038/jhh.2015.95 KQ2E5, KQ3E5b, KQ4E4.26377355
405 Thomopoulos C, Papadopoulos DP, Papazachou O, . Free leptin is associated with masked hypertension in nonobese subjects: a cross-sectional study. Hypertension. 2009;53(6):965–72. KQ2E1, KQ3E1, KQ4E1.19398660
406 Tientcheu D, Ayers C, Das SR, . Target Organ Complications and Cardiovascular Events Associated With Masked Hypertension and White-Coat Hypertension: Analysis From the Dallas Heart Study. Journal of the American College of Cardiology. 2015;66(20):2159–69. 10.1016/j.jacc.2015.09.007 KQ2E3, KQ3E3, KQ4E4.26564592
407 Ting-Tse L, Jyh-Ming Juang J, Jen-Kuang L, . Comparison of Home and Ambulatory Blood Pressure Measurements in Association With Preclinical Hypertensive Cardiovascular Damage. Journal of Cardiovascular Nursing. 2019;34(2):106–14. 10.1097/JCN.0000000000000515 KQ2E5, KQ3E5b, KQ4E4.
408 Tomiyama H, Hashimoto H, Hirayama Y, . Synergistic acceleration of arterial stiffening in the presence of raised blood pressure and raised plasma glucose. Hypertension. 2006;47(2):180–8. KQ2E1, KQ3E1, KQ4E1.16380535
409 Tomiyama H, Koji Y, Yambe M, . Elevated C-reactive protein augments increased arterial stiffness in subjects with the metabolic syndrome. Hypertension. 2005;45(5):997–1003. KQ2E1, KQ3E1, KQ4E1.15837828
410 Torres G, Sanchez-de-la-Torre M, Martinez-Alonso M, . Use of Ambulatory Blood Pressure Monitoring for the Screening of Obstructive Sleep Apnea. J Clin Hypertens. 2015;17(10):802–9. 10.1111/jch.12619 KQ2E5, KQ3E4a, KQ4E4.
411 Toyama H, Hasegawa Y, Ejima Y, . Characteristics of young-onset white coat hypertension identified by targeted screening for hypertension at a university health check-up. Hypertension research. 2008;31(6):1063–8. KQ2E3, KQ3E3, KQ4E4.18716352
412 Tozawa M, Iseki K, Iseki C, . Impact of multiple risk factor clustering on the elevation of blood pressure. Hypertension research. 2002;25(6):811–6. KQ2E1, KQ3E1, KQ4E1.12484502
413 Tozawa M, Oshiro S, Iseki C, . Multiple risk factor clustering of hypertension in a screened cohort. Journal of hypertension. 2000;18(10):1379–85. KQ2E1, KQ3E1, KQ4E1.11057424
414 Trudel X, Brisson C, Larocque B, . Masked hypertension: different blood pressure measurement methodology and risk factors in a working population. Journal of hypertension. 2009;27(8):1560–7. PMID: 19444141. KQ2E2, KQ3E5, KQ4E4.19444141
415 Trudel X, Brisson C, Milot A. Job strain and masked hypertension. Psychosom Med. 2010;72(8):786–93. PMID: 20639388. 10.1097/PSY.0b013e3181eaf327 KQ2E2, KQ3E5, KQ4E4.20639388
416 Trudel X, Milot A, Brisson C. Persistence and progression of masked hypertension: a 5-year prospective study. International Journal of Hypertension. 2013;2013:836387. KQ2E2, KQ3E5, KQ4E4.24455208
417 Tsivgoulis G, Pikilidou M, Katsanos AH, . Association of Ambulatory Blood Pressure Monitoring parameters with the Framingham Stroke Risk Profile. J Neurol Sci. 2017;380:106–11. 10.1016/j.jns.2017.07.007 KQ2E5a, KQ3E5b, KQ4E4.28870547
418 Tsuji I, Imai Y, Nagai K, . Proposal of reference values for home blood pressure measurement: prognostic criteria based on a prospective observation of the general population in Ohasama, Japan. American journal of hypertension. 1997;10(4 Pt 1):409–18. KQ2E1, KQ3E1, KQ4E1.9128207
419 Ugajin T, Hozawa A, Ohkubo T, . White-coat hypertension as a risk factor for the development of home hypertension: the Ohasama study. Arch Intern Med. 2005;165(13):1541–6. PMID: 16009871. KQ2E3, KQ3E5, KQ4E4.16009871
420 Umemoto S, Kawano R, Kawamura A, . Effects of Japan diet-based antihypertensive diet on blood pressure and its variability in subjects with untreated normal high blood pressure and stage I hypertension: a randomized controlled trial. Circ Cardiovasc Genet [serial on the Internet]. 2017; 136(Supplement 1) (no pagination): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01440989/full. KQ2E3, KQ3E3, KQ4E4.
421 Uzu T, Nakao K, Kume S, . High sodium intake is associated with masked hypertension in Japanese patients with type 2 diabetes and treated hypertension. American journal of hypertension. 2012;25(11):1170–4. KQ2E5b, KQ3E5, KQ4E4.22810841
422 van der Steen MS, Lenders JW, Thien T. Side effects of ambulatory blood pressure monitoring. Blood pressure monitoring. 2005;10(3):151–5. KQ2E1, KQ3E1, KQ4E5a.15923817
423 Vasan RS, Larson MG, Leip EP, . Assessment of frequency of progression to hypertension in non-hypertensive participants in the Framingham Heart Study: a cohort study. Lancet. 2001;358(9294):1682–6. KQ2E1, KQ3E1, KQ4E1.11728544
424 Veerabhadrappa P, Diaz KM, Feairheller DL, . Endothelial-dependent flow-mediated dilation in African Americans with masked-hypertension. American journal of hypertension. 2011;24(10):1102–7. KQ2E4a, KQ3E4a, KQ4E4.21677701
425 Veerman DP, van Montfrans GA. Nurse-measured or ambulatory blood pressure in routine hypertension care. Journal of hypertension. 1993;11(3):287–92. KQ2E5, KQ3E5b, KQ4E4.8387086
426 Verberk WJ, Kroon AA, Thien T, . Prevalence of the white-coat effect at multiple visits before and during treatment. Journal of hypertension. 2006;24(12):2357–63. PMID: 17082716. 10.1097/01.hjh.0000251899.47626.4f KQ2E5, KQ3E4a, KQ4E4.17082716
427 Verdecchia P, Angeli F, Mazzotta G, . Home Blood Pressure Measurements Will Not Replace 24-Hour Ambulatory Blood Pressure Monitoring. Hypertension. 2009. KQ2E7, KQ3E7, KQ4E7.
428 Verdecchia P, Angeli F, Reboldi G. Masked and White-Coat Hypertension: Moving to African Americans. Journal of the American College of Cardiology. 2015;66:2170–2. 10.1016/j.jacc.2015.09.008 KQ2E7, KQ3E7, KQ4E4.26564593
429 Verdecchia P, Palatini P, Schillaci G, . Independent predictors of isolated clinic (‘white-coat’) hypertension. Journal of hypertension. 2001;19(6):1015–20. KQ2E5, KQ3E4a, KQ4E4.11403348
430 Verdecchia P, Porcellati C, Schillaci G, . Ambulatory blood pressure. An independent predictor of prognosis in essential hypertension. Hypertension. 1994;24(6):793–801. KQ2E5, KQ3E5, KQ4E4.7995639
431 Verdecchia P, Schillaci G, Boldrini F, . Variability between current definitions of ‘normal’ ambulatory blood pressure. Implications in the assessment of white coat hypertension. Hypertension. 1992;20(4):555–62. KQ2E5, KQ3E5, KQ4E4.1398890
432 Verdecchia P, Schillaci G, Borgioni C, . White-coat hypertension. Lancet. 1996;348(9039):1444–5. KQ2E7, KQ3E7, KQ4E7.
433 Verdecchia P, Schillaci G, Borgioni C, . White coat hypertension and white coat effect. Similarities and differences. American journal of hypertension. 1995;8(8):790–8. KQ2E5, KQ3E5, KQ4E4.7576395
434 Verdecchia P, Schillaci G, Reboldi G, . Different prognostic impact of 24-hour mean blood pressure and pulse pressure on stroke and coronary artery disease in essential hypertension. Circulation. 2001;103(21):2579–84. KQ2E1, KQ3E1, KQ4E1.11382727
435 Viera AJ, Lin FC, Tuttle LA, . Levels of office blood pressure and their operating characteristics for detecting masked hypertension based on ambulatory blood pressure monitoring. American journal of hypertension. 2015;28(1):42–9. 10.1093/ajh/hpu099 KQ2E4a, KQ3E5, KQ4E4.24898379
436 Vinyoles E, Felip A, Pujol E, . Clinical characteristics of isolated clinic hypertension. Journal of hypertension. 2008;26(3):438–45. PMID: 18300853. 10.1097/HJH.0b013e3282f3150b KQ2E5, KQ3E4a, KQ4E4.18300853
437 Vinyoles E, Rodriguez-Blanco T, de la Sierra A, . Isolated clinic hypertension: diagnostic criteria based on 24-h blood pressure definition. Journal of hypertension. 2010;28(12):2407–13. KQ2E5, KQ3E3, KQ4E4.20852448
438 Vischer AS, Mayr M, Socrates T, . Impact of Single-Occasion American vs. Canadian Office Blood Pressure Measurement Recommendations on Blood Pressure Classification. American journal of hypertension. 2019;32(2):143–5. PMID: 30371728. 10.1093/ajh/hpy159 KQ2E3, KQ3E3, KQ4E4.30371728
439 Volzke H, Fung G, Ittermann T, . A new, accurate predictive model for incident hypertension. Journal of hypertension. 2013;31(11):2142–50. KQ2E1, KQ3E1, KQ4E1.24077244
440 Vrijkotte TG, van Doornen LJ, de Geus EJ. Effects of work stress on ambulatory blood pressure, heart rate, and heart rate variability. Hypertension. 2000;35(4):880–6. KQ2E5, KQ3E5, KQ4E4.10775555
441 Wang L, Forman J, Gold D, . Self-reported blood pressure is comparable to measured blood pressure in a study of general population participants. Cad Saude Publica [serial on the Internet]. 2017; 135(no pagination): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01417350/full. KQ2E11a, KQ3E5, KQ4E4.
442 White WB, Jalil F, Wakefield DB, . Relationships among clinic, home, and ambulatory blood pressures with small vessel disease of the brain and functional status in older people with hypertension. American Heart Journal. 2018;205:21–30. PMID: 30145340. 10.1016/j.ahj.2018.08.002 KQ2E5, KQ3E4a, KQ4E4.30145340
443 Wiinberg N, Hoegholm A, Christensen HR, . 24-h ambulatory blood pressure in 352 normal Danish subjects, related to age and gender. American journal of hypertension. 1995;8(10:Pt 1):t–86. 10.1016/0895-7061(95)00216-2 KQ2E4a, KQ3E5, KQ4E4.
444 Wijkman M, ¤nne T, Grodzinsky E, . Ambulatory systolic blood pressure predicts left ventricular mass in type 2 diabetes, independent of central systolic blood pressure. Blood pressure monitoring. 2012;17(4):139–44. 10.1097/MBP.0b013e328355fdfb KQ2E5b, KQ3E5, KQ4E4.22735793
445 Wijkman M, Lanne T, Engvall J, . Masked nocturnal hypertension-a novel marker of risk in type 2 diabetes. Diabetologia. 2009;52(7):1258–64. KQ2E4a, KQ3E5b, KQ4E4.19396423
446 Wing LM, Brown MA, Beilin LJ, . ‘Reverse white-coat hypertension’ in older hypertensives. Journal of hypertension. 2002;20:639–44. KQ2E5, KQ3E4a, KQ4E4.11910298
447 Wing LMH, Chowdhury EK, Reid CM, . Night-time ambulatory blood pressure is the best pretreatment blood pressure predictor of 11-year mortality in treated older hypertensives. Blood pressure monitoring. 2018. PMID: 29864033. 10.1097/mbp.0000000000000331 KQ2E4a, KQ3E4a, KQ4E4.29864033
448 Wing LMH, Chowdhury EK, Reid CM, . Night-time ambulatory blood pressure is the best pretreatment blood pressure predictor of 11-year mortality in treated older hypertensives. Blood pressure monitoring. 2018;23(5):237–43. PMID: 29864033. 10.1097/MBP.0000000000000331 KQ2E5, KQ3E4a, KQ4E4.29864033
449 Wittenberg C, Erman A, Sulkes J, . Which cuff size is preferable for blood pressure monitoring in most hypertensive patients? Journal of human hypertension. 1994;8(11):819–22. KQ2E5, KQ3E5b, KQ4E4.7853324
450 Wolak T, Wilk L, Paran E, . Is it possible to shorten ambulatory blood pressure monitoring? Journal of clinical hypertension (Greenwich, Conn). 2013;15(8):570–4. KQ2E5, KQ3E5b, KQ4E4.
451 Woodiwiss AJ, Molebatsi N, Maseko MJ, . Nurse-recorded auscultatory blood pressure at a single visit predicts target organ changes as well as ambulatory blood pressure. Journal of hypertension. 2009;27(2):287–97. KQ2E9, KQ3E9, KQ4E9.19155786
452 Wuerzner G, Bochud M, Zweiacker C, . Step count is associated with lower nighttime systolic blood pressure and increased dipping. American journal of hypertension. 2013;26(4):527–34. KQ2E5b, KQ3E5b, KQ4E4.23467208
453 Wuopio J, Ostgren CJ, Lanne T, . The association between circulating endostatin and a disturbed circadian blood pressure pattern in patients with type 2 diabetes. Blood Pressure. 2018;27(4):215–21. PMID: 29488402. 10.1080/08037051.2018.1444941 KQ2E4a, KQ3E5, KQ4E4.29488402
454 Yamada Y, Ishizaki M, Kido T, . Alcohol, high blood pressure, and serum gamma-glutamyl transpeptidase level. Hypertension. 1991;18(6):819–26. KQ2E1, KQ3E1, KQ4E1.1683858
455 Yamasue K, Hayashi T, Ohshige K, . Masked hypertension in elderly managerial employees and retirees. Clin Exp Hypertens. 2008;30(3):203–11. PMID: 18425700. KQ2E10, KQ3E5, KQ4E4.18425700
456 Yambe M, Tomiyama H, Yamada J, . Arterial stiffness and progression to hypertension in Japanese male subjects with high normal blood pressure. Journal of hypertension. 2007;25(1):87–93. KQ2E1, KQ3E1, KQ4E1.17143178
457 Yang Y, Xu JZ, Wang Y, . Ambulatory versus clinic blood pressure in predicting overall subclinical target organ damage progression in essential hypertensive patients: a 3-year follow-up study. Blood pressure monitoring. 2016;21(6):319–26. PMID: 27579902 10.1097/MBP.0000000000000209 KQ2E9, KQ3E9, KQ4E9.27579902
458 Yasui D, Asayama K, Takada N, . Evaluating home blood pressure in treated hypertensives in comparison with the referential value of casual screening of blood pressure: the Ohasama study. Blood pressure monitoring. 2012;17(3):89–95. PMID: 22425704. KQ2E3, KQ3E5, KQ4E4.22425704
459 Zambrana RE, Lopez L, Dinwiddie GY, . Prevalence and Incident Prehypertension and Hypertension in Postmenopausal Hispanic Women: Results from the Women’s Health Initiative. American journal of hypertension. 2014;27(3):372–81. KQ2E1, KQ3E1, KQ4E1.24480867
460 Zawadzka A, Bird R, Casadei B, . Audit of ambulatory blood pressure monitoring in the diagnosis and management of hypertension in practice. Journal of human hypertension. 1998;12(4):249–52. KQ2E5, KQ3E4a, KQ4E4.9607694
461 Zhang L, Li Y, Wei FF, . Strategies for classifying patients based on office, home, and ambulatory blood pressure measurement. Hypertension. 2015;65(6):1258–65. 10.1161/HYPERTENSIONAHA.114.05038 KQ2E9, KQ3E9, KQ4E9.25870194
462 Zhou J, Liu C, Shan P, . Prevalence and distinguishing features of masked hypertension in type 2 diabetic patients. Journal of Diabetes & its Complications. 2013;27(1):82–6. 10.1016/j.jdiacomp.2012.07.003 KQ2E9, KQ3E9, KQ4E9.22906551
463 Zoccali C, Mallamaci F. The overdriven glomerulus as a cardiovascular risk factor. Kidney Int. 2018;93(1):13–5. 10.1016/j.kint.2017.08.035 KQ2E1, KQ3E1, KQ4E1.29291815