# Appendix C Included Studies

Ancillary articles indented under primary article

## Key Question 1

- Kaczorowski J, Chambers LW, Dolovich L, . Improving cardiovascular health at population level: 39 community cluster randomised trial of Cardiovascular Health Awareness Program (CHAP). BMJ. 2011;342:d442. PMID: 21300712. 10.1136/bmj.d442 21300712
  - Kaczorowski J, Chambers LW, Karwalajtys T, . Cardiovascular Health Awareness Program (CHAP): a community cluster-randomised trial among elderly Canadians. Prev Med. 2008;46(6):537–44. PMID: 18372036. 10.1016/j.ypmed.2008.02.005 18372036
  - Karwalajtys T, Kaczorowski J, Chambers LW, . Community mobilization, participation, and blood pressure status in a Cardiovascular Health Awareness Program in Ontario. Am J Health Promot. 2013;27(4):252–61. PMID: 23448415. 10.4278/ajhp.101221-QUAL-408 23448415
  - Ye C, Foster G, Kaczorowski J, . The impact of a cardiovascular health awareness program (CHAP) on reducing blood pressure: a prospective cohort study. BMC Public Health. 2013;13:1230. PMID: 24369050. 10.1186/1471-2458-13-1230 24369050

## Key Question 2

- Abdalla M, Goldsmith J, Muntner P, . Is Isolated Nocturnal Hypertension A Reproducible Phenotype? Am J Hypertens. 2016;29(1):33–8. 10.1093/ajh/hpv058 25904648
- Fagard RH, van den Broeke C, de Cort P. Prognostic significance of blood pressure measured in the office, at home and during ambulatory monitoring in older patients in general practice. Journal of human hypertension. 2005;19(10):801–7. PMID: 15959536. 10.1038/sj.jhh.1001903 15959536
- Gill P, Haque MS, Martin U, . Measurement of blood pressure for the diagnosis and management of hypertension in different ethnic groups: one size fits all. BMC Cardiovasc Disord. 2017;17(1):55. PMID: 28178928. 10.1186/s12872-017-0491-8 28178928
  - Martin U, Haque MS, Wood S, . Ethnicity and differences between clinic and ambulatory blood pressure measurements. American journal of hypertension. 2015;28(6):729–38. PMID: 25398890. 10.1093/ajh/hpu211 25398890
  - Wood S, Martin U, Gill P, . Blood pressure in different ethnic groups (BP-Eth): a mixed methods study. BMJ Open. 2012;2(6):2012. PMID: 23129572. 10.1136/bmjopen-2012-001598 23129572
- Gosse P, Dauphinot V, Roche F, . Prevalence of clinical and ambulatory hypertension in a population of 65-year-olds: the PROOF study. Journal of clinical hypertension (Greenwich, Conn). 2010;12(3):160–5. PMID: 20433528. 10.1111/j.1751-7176.2009.00235.x 20433528
- Gourlay SG, McNeil JJ, Marriner T, . Discordance of mercury sphygmomanometer and ambulatory blood pressure measurements for the detection of untreated hypertension in a population study. Journal of human hypertension. 1993;7(5):467–72. PMID: 8263887.8263887
- Hanninen MR, Niiranen TJ, Puukka PJ, . Comparison of home and ambulatory blood pressure measurement in the diagnosis of masked hypertension. Journal of hypertension. 2010;28(4):709–14. PMID: 20061982. 10.1097/HJH.0b013e3283369faa 20061982
- Hansen TW, Jeppesen J, Rasmussen S, . Ambulatory blood pressure monitoring and risk of cardiovascular disease: a population based study. American journal of hypertension. 2006;19(3):243–50. PMID: 16500508. 10.1016/j.amjhyper.2005.09.018 16500508
  - Sehestedt T, Jeppesen J, Hansen TW, . Can ambulatory blood pressure measurements substitute assessment of subclinical cardiovascular damage? Journal of hypertension. 2012;30(3):513–21. PMID: 22241138. 10.1097/HJH.0b013e32834f6f60 22241138
- Ishikawa J, Hoshide S, Eguchi K, . Masked hypertension defined by ambulatory blood pressure monitoring is associated with an increased serum glucose level and urinary albumin-creatinine ratio. Journal of clinical hypertension (Greenwich, Conn). 2010;12(8):578–87. PMID: 20695934. 10.1111/j.1751-7176.2010.00286.x 20695934
  - Hoshide S, Ishikawa J, Eguchi K, . Masked nocturnal hypertension and target organ damage in hypertensives with well-controlled self-measured home blood pressure. Hypertension research. 2007;30(2):143–9. PMID: 17460384. 10.1291/hypres.30.143 17460384
- Kanno A, Metoki H, Kikuya M, . Usefulness of assessing masked and white-coat hypertension by ambulatory blood pressure monitoring for determining prevalent risk of chronic kidney disease: the Ohasama study. Hypertension research. 2010;33(11):1192–8. PMID: 20703228. 10.1038/hr.2010.139 20703228
  - Hozawa A, Ohkubo T, Kikuya M, . Blood pressure control assessed by home, ambulatory and conventional blood pressure measurements in the Japanese general population: the Ohasama study. Hypertension research. 2002;25(1):57–63. PMID: 11924727. 10.1291/hypres.25.57 11924727
  - Imai Y, Tsuji I, Nagai K, . Ambulatory blood pressure monitoring in evaluating the prevalence of hypertension in adults in Ohasama, a rural Japanese community. Hypertension research. 1996;19(3):207–12. PMID: 8891750. 10.1291/hypres.19.207 8891750
- Larkin KT, Schauss SL, Elnicki DM. Isolated clinic hypertension and normotension: false positives and false negatives in the assessment of hypertension. Blood pressure monitoring. 1998;3:247–54.
- Lyamina NP, Smith ML, Lyamina SV, . Pressor response to 30-s breathhold: a predictor of masked hypertension. Blood Press. 2012;21(6):372–6. PMID: 22725829. 10.3109/08037051.2012.694213 22725829
- Mancia G, Facchetti R, Bombelli M, . Long-term risk of mortality associated with selective and combined elevation in office, home, and ambulatory blood pressure. Hypertension. 2006;47(5):846–53. PMID: 16567588. 10.1161/01.HYP.0000215363.69793.bb 16567588
  - Cuspidi C, Facchetti R, Bombelli M, . Risk of new-onset metabolic syndrome associated with white-coat and masked hypertension: data from a general population. Journal of hypertension. 2018;36(9):1833–9. PMID: 29965885. 10.1097/hjh.0000000000001767 29965885
  - Mancia G, Sega R, Bravi C, . Ambulatory blood pressure normality: results from the PAMELA study. Journal of hypertension. 1995;13(12 Pt 1):1377–90. PMID: 8866899.8866899
- O’Flynn AM, Curtin RJ, Perry IJ, . Hypertension Prevalence, Awareness, Treatment, and Control: Should 24-Hour Ambulatory Blood Pressure Monitoring be the Tool of Choice? J Clin Hypertens. 2016;18(7):697–702. PMID: 26611695. 10.1111/jch.12737 26611695
- Poudel B, Booth JN, 3rd, Sakhuja S, . Prevalence of ambulatory blood pressure phenotypes using the 2017 American College of Cardiology/American Heart Association blood pressure guideline thresholds: data from the Coronary Artery Risk Development in Young Adults study. J Hypertens. 2019;37(7):1401–10. PMID: 31145711. 10.1097/HJH.0000000000002055 31145711
  - Muntner P, Lewis CE, Diaz KM, . Racial differences in abnormal ambulatory blood pressure monitoring measures: Results from the Coronary Artery Risk Development in Young Adults (CARDIA) study. American journal of hypertension. 2015;28(5):640–8. PMID: 25376639. 10.1093/ajh/hpu193 25376639
- Scuteri A, Morrell CH, Orru M, . Gender specific profiles of white coat and masked hypertension impacts on arterial structure and function in the SardiNIA study. International journal of cardiology. 2016;217:92–8. PMID: 27179214. 10.1016/j.ijcard.2016.04.172 27179214
  - Scuteri A, Najjar SS, Orru M, . Age- and gender-specific awareness, treatment, and control of cardiovascular risk factors and subclinical vascular lesions in a founder population: the SardiNIA Study. Nutr Metab Cardiovasc Dis. 2009;19(8):532–41. PMID: 19321325. 10.1016/j.numecd.2008.11.004 19321325
  - Terracciano A, Scuteri A, Strait J, . Are personality traits associated with white-coat and masked hypertension? Journal of hypertension. 2014;32(10):1987–92; discussion 92. PMID: 25186529. 10.1097/HJH.0000000000000289 25186529
- Selenta C, Hogan BE, Linden W. How often do office blood pressure measurements fail to identify true hypertension? An exploration of white-coat normotension. Arch Fam Med. 2000;9(6):533–40. PMID: 10862216. 10.1001/archfami.9.6.533 10862216
- Shimbo D, Newman JD, Schwartz JE. Masked hypertension and prehypertension: diagnostic overlap and interrelationships with left ventricular mass: the Masked Hypertension Study. American journal of hypertension. 2012;25(6):664–71. PMID: 22378035. 10.1038/ajh.2012.15 22378035
  - Oe Y, Shimbo D, Ishikawa J, . Alterations in diastolic function in masked hypertension: findings from the masked hypertension study. American journal of hypertension. 2013;26(6):808–15. PMID: 23446956. 10.1093/ajh/hpt021 23446956
- Thomas SJ, Booth JN, 3rd, Bromfield SG, . Clinic and ambulatory blood pressure in a population-based sample of African Americans: the Jackson Heart Study. Journal of the American Society of Hypertension. 2017;11(4):204–12.e5. PMID: 28285829. 10.1016/j.jash.2017.02.001 28285829
  - Diaz KM, Veerabhadrappa P, Brown MD, . Prevalence, Determinants, and Clinical Significance of Masked Hypertension in a Population-Based Sample of African Americans: The Jackson Heart Study. American journal of hypertension. 2015;28(7):900–8. PMID: 25499058. 10.1093/ajh/hpu241 25499058
  - McMullan CJ, Hickson DA, Taylor HA, . Prospective analysis of the association of ambulatory blood pressure characteristics with incident chronic kidney disease. Journal of hypertension. 2015;33(9):1939–46; discussion 46. PMID: 26066645. 10.1097/HJH.0000000000000638 26066645
- Wei FF, Zhang ZY, Thijs L, . Conventional and Ambulatory Blood Pressure as Predictors of Retinal Arteriolar Narrowing. Hypertension. 2016;68(2):511–20. PMID: 27324224. 10.1161/HYPERTENSIONAHA.116.07523 27324224
- Wojciechowska W, Stolarz-Skrzypek K, Olszanecka A, . Subclinical arterial and cardiac damage in white-coat and masked hypertension. Blood Press. 2016;25(4):249–56. PMID: 26953075. 10.3109/08037051.2016.1150563 26953075

## Key Question 3

- Bayo J, Cos FX, Roca C, . Home blood pressure self-monitoring: diagnostic performance in white-coat hypertension. Blood pressure monitoring. 2006;11(2):47–52. PMID: 16534404. 10.1097/01.mbp.0000200479.19046.94 16534404
- de la Sierra A, Vinyoles E, Banegas JR, . Prevalence and clinical characteristics of white-coat hypertension based on different definition criteria in untreated and treated patients. Journal of hypertension. 2017;35(12):2388–94. PMID: 28723880. 10.1097/HJH.0000000000001493 28723880
  - de la Sierra A, Vinyoles E, Banegas JR, . Short-Term and Long-Term Reproducibility of Hypertension Phenotypes Obtained by Office and Ambulatory Blood Pressure Measurements. J Clin Hypertens. 2016;18(9):927–33. PMID: 26890293. 10.1111/jch.12792 26890293
- Ernst ME, Sezate GS, Lin W, . Indication-specific 6-h systolic blood pressure thresholds can approximate 24-h determination of blood pressure control. Journal of human hypertension. 2011;25(4):250–5. PMID: 20574446. 10.1038/jhh.2010.66 20574446
  - Ernst ME, Weber CA, Dawson JD, . How well does a shortened time interval characterize results of a full ambulatory blood pressure monitoring session? Journal of clinical hypertension (Greenwich, Conn). 2008;10(6):431–5. PMID: 18550932. 10.1111/j.1751-7176.2008.07784.x 18550932
- Fogari R, Corradi L, Zoppi A, . Repeated office blood pressure controls reduce the prevalence of white-coat hypertension and detect a group of white-coat normotensive patients. Blood pressure monitoring. 1996;1(1):51–4. PMID: 10226202.10226202
- Gerc V, Favrat B, Brunner HR, . Is nurse-measured blood pressure a valid substitute for ambulatory blood pressure monitoring? Blood pressure monitoring. 2000;5(4):203–9. PMID: 11035861. 10.1097/00126097-200008000-00002 11035861
- Hoegholm A, Kristensen KS, Madsen NH, . White coat hypertension diagnosed by 24-h ambulatory monitoring. Examination of 159 newly diagnosed hypertensive patients. American journal of hypertension. 1992;5(2):64–70. PMID: 1550667. 10.1093/ajh/5.2.64 1550667
  - Hoegholm A, Kristensen KS, Madsen NH, . The frequency of white coat hypertension among patients with newly diagnosed hypertension. Cardiovasc Rev Rep. 1994;15:55–61.
- Husain A, Lin FC, Tuttle LA, . The Reproducibility of Racial Differences in Ambulatory Blood Pressure Phenotypes and Measurements. American journal of hypertension. 2017;30(10):961–7. PMID: 28531258. 10.1093/ajh/hpx079 28531258
  - Viera AJ, Lin FC, Tuttle LA, . Reproducibility of masked hypertension among adults 30 years or older. Blood pressure monitoring. 2014;19(4):208–15. PMID: 24842491. 10.1097/MBP.0000000000000054 24842491
- Kim S, Park JJ, Lee SA, . Diagnostic accuracy of manual office blood pressure measurement in ambulatory hypertensive patients in Korea. The Korean journal of internal medicine. 2018;33(1):113–20. PMID: 28602060. 10.3904/kjim.2016.161 28602060
- Kotsis V, Stabouli S, Toumanidis S, . Target organ damage in “white coat hypertension” and “masked hypertension”. American journal of hypertension. 2008;21(4):393–9. PMID: 18292757. 10.1038/ajh.2008.15 18292757
  - Zakopoulos NA, Kotsis VT, Pitiriga V, . White-coat effect in normotension and hypertension. Blood pressure monitoring. 2002;7(5):271–6. PMID: 12409886. 10.1097/00126097-200210000-00004 12409886
- Manios ED, Koroboki EA, Tsivgoulis GK, . Factors influencing white-coat effect. American journal of hypertension. 2008;21(2):153–8. PMID: 18174883. 10.1038/ajh.2007.43 18174883
- Nasothimiou EG, Tzamouranis D, Rarra V, . Diagnostic accuracy of home vs. ambulatory blood pressure monitoring in untreated and treated hypertension. Hypertension research. 2012;35(7):750–5. PMID: 22357523. 10.1038/hr.2012.19 22357523
  - Stergiou GS, Salgami EV, Tzamouranis DG, . Masked hypertension assessed by ambulatory blood pressure versus home blood pressure monitoring: is it the same phenomenon? American journal of hypertension. 2005;18(6):772–8. PMID: 15925734. 10.1016/j.amjhyper.2005.01.003 15925734
  - Stergiou GS, Skeva II, Baibas NM, . Diagnosis of hypertension using home or ambulatory blood pressure monitoring: comparison with the conventional strategy based on repeated clinic blood pressure measurements. Journal of hypertension. 2000;18(12):1745–51. PMID: 11132597. 10.1097/00004872-200018120-00007 11132597
- Nunan D, Thompson M, Heneghan CJ, . Accuracy of self-monitored blood pressure for diagnosing hypertension in primary care. Journal of hypertension. 2015;33(4):755–62; discussion 62. PMID: 25915880. 10.1097/HJH.0000000000000489 25915880
- Park JS, Rhee MY, Namgung J, . Comparison of Optimal Diagnostic Thresholds of Hypertension With Home Blood Pressure Monitoring and 24-Hour Ambulatory Blood Pressure Monitoring. American journal of hypertension. 2017;30(12):1170–6. PMID: 28992112. 10.1093/ajh/hpx115 28992112
  - Rhee MY, Kim JY, Kim JH, . Optimal schedule of home blood-pressure measurements for the diagnosis of hypertension. Hypertens Res. 2018. PMID: 29977083. 10.1038/s41440-018-0069-6 29977083
- Salazar MR, Espeche WG, Stavile RN, . Could self-measured office blood pressure be a hypertension screening tool for limited-resources settings? Journal of human hypertension. 2018;32(6):415–22. PMID: 29713048. 10.1038/s41371-018-0057-y 29713048
- Shin J, Park SH, Kim JH, . Discordance between ambulatory versus clinic blood pressure according to global cardiovascular risk group. The Korean journal of internal medicine. 2015;30(5):610–9. PMID: 26354055. 10.3904/kjim.2015.30.5.610 26354055
- Tocci G, Presta V, Figliuzzi I, . Prevalence and clinical outcomes of white-coat and masked hypertension: Analysis of a large ambulatory blood pressure database. J Clin Hypertens. 2018;20(2):297–305. PMID: 29370477. 10.1111/jch.13181 29370477
  - Presta V, Figliuzzi I, D’Agostino M, . Nocturnal blood pressure patterns and cardiovascular outcomes in patients with masked hypertension. J Clin Hypertens. 2018. PMID: 30058135. 10.1111/jch.13361 30058135
- Ungar A, Pepe G, Monami M, . Isolated ambulatory hypertension is common in outpatients referred to a hypertension centre. Journal of human hypertension. 2004;18(12):897–903. PMID: 15241442. 10.1038/sj.jhh.1001756 15241442
- Zabludowski JR, Rosenfeld JB. Evaluation of clinic blood pressure measurements: assessment by daytime ambulatory blood pressure monitoring. Isr J Med Sci. 1992;28(6):345–8. PMID: 1607269.1607269

## Key Question 4

- Ameling EH, de Korte DF, Man it, V. Impact of diagnosis and treatment of hypertension on quality of life: a double-blind, randomized, placebo-controlled, cross-over study of betaxolol. J Cardiovasc Pharmacol. 1991;18(5):752–60. PMID: 1723773. 10.1097/00005344-199111000-00014 1723773
- Haynes RB, Sackett DL, Taylor DW, . Increased absenteeism from work after detection and labeling of hypertensive patients. N Engl J Med. 1978;299(14):741–4. PMID: 692548. 10.1056/NEJM197810052991403 692548
  - Taylor DW, Haynes RB, Sackett DL, . Longterm follow-up of absenteeism among working men following the detection and treatment of their hypertension. Clin Invest Med. 1981;4(3–4):173–7. PMID: 7337988.7337988
- Kuwajima I, Nishinaga M, Kanamaru A. The accuracy and clinical performance of a new compact ambulatory blood pressure monitoring device, the ES-H531. American journal of hypertension. 1998;11(11:Pt 1):t–33. PMID: 9832176. 10.1016/s0895-7061(98)00155-1 9832176
- Mann AH. The psychological effect of a screening programme and clinical trial for hypertension upon the participants. Psychol Med. 1977;7(3):431–8. PMID: 905459.905459
  - [No author listed]. Randomised controlled trial of treatment for mild hypertension: design and pilot trial. Report of Medical Research Council Working Party on Mild to Moderate Hypertension. Br Med J. 1977;1(6074):1437–40. PMID: 324577. 10.1136/bmj.1.6074.1437 324577
- Manning G, Rushton L, Donnelly R, . Variability of diurnal changes in ambulatory blood pressure and nocturnal dipping status in untreated hypertensive and normotensive subjects. American journal of hypertension. 2000;13(9):1035–8. PMID: 10981556. 10.1016/s0895-7061(00)00261-2 10981556
  - Manning G, Vijan SG, Millar-Craig MW. Does perception of sleep quality affect diurnal variation of blood pressure and heart rate during 24Hr blood pressure monitoring? Clin Sci. 1992;83:(Suppl 27):22P.
- Nasothimiou EG, Karpettas N, Dafni MG, . Patients’ preference for ambulatory versus home blood pressure monitoring. Journal of human hypertension. 2013;28(4):224–9. PMID: 24152822. 10.1038/jhh.2013.104 24152822
- Rudd P, Price MG, Graham LE, . Consequences of worksite hypertension screening. Changes in absenteeism. Hypertension. 1987;10(4):425–36. PMID: 3653971. 10.1161/01.hyp.10.4.425 3653971
- Sherwood A, Hill LK, Blumenthal JA, . The Effects of Ambulatory Blood Pressure Monitoring on Sleep Quality in Men and Women With Hypertension: Dipper vs. Nondipper and Race Differences. Am J Hypertens. 2019;32(1):54–60. PMID: 30204833. 10.1093/ajh/hpy138 30204833
- Spruill TM, Feltheimer SD, Harlapur M, . Are there consequences of labeling patients with prehypertension? An experimental study of effects on blood pressure and quality of life. J Psychosom Res. 2013;74(5):433–8. PMID: 23597332. 10.1016/j.jpsychores.2013.01.009 23597332
- Tompson AC, Ward AM, McManus RJ, . Acceptability and psychological impact of out-of-office monitoring to diagnose hypertension: an evaluation of survey data from primary care patients. Br J Gen Pract. 2019;69(683):e389–e97. PMID: 30910876. 10.3399/bjgp19X702221 30910876
- Verdecchia P, Angeli F, Borgioni C, . Ambulatory blood pressure and cardiovascular outcome in relation to perceived sleep deprivation. Hypertension. 2007;49(4):777–83. PMID: 17261645. 10.1161/01.HYP.0000258215.26755.20 17261645
- Viera AJ, Lingley K, Esserman D. Effects of labeling patients as prehypertensive. J Am Board Fam Med. 2010;23(5):571–83. PMID: 20823351. 10.3122/jabfm.2010.05.100047 20823351
- Viera AJ, Lingley K, Hinderliter AL. Tolerability of the Oscar 2 ambulatory blood pressure monitor among research participants: a cross-sectional repeated measures study. BMC Med Res Methodol. 2011;11:59. PMID: 21524301. 10.1186/1471-2288-11-59 21524301